# Characteristics and Outcomes of Studies of Early Intensive Behavioral and Developmental Interventions

Table F-1 Characteristics and outcomes of early intensive behavioral and developmental intervention studies

## References

1 Peters-Scheffer N, Didden R, Mulders M, et al. Effectiveness of low intensity behavioral treatment for children with autism spectrum disorder and intellectual disability. Research in Autism Spectrum Disorders. 2013;7(9):1012-25.
2 Peters-Scheffer N, Didden R, Mulders M, et al. Low intensity behavioral treatment supplementing preschool services for young children with autism spectrum disorders and severe to mild intellectual disability. Res Dev Disabil. Nov-Dec. 2010;31(6):1678-84. [pmid: 20627451].
3 Itzchak EB, Zachor DA. Who Benefits from Early Intervention in Autism Spectrum Disorders?. Research in Autism Spectrum Disorders. 2011;5(1):345-50.
4 Zachor DA, Itzchak EB. Treatment Approach, Autism Severity and Intervention Outcomes in Young Children. Research in Autism Spectrum Disorders. 2010;4(3):425-32. [other: EJ878590].
5 Strain PS, Bovey EH. Randomized, Controlled Trial of the Leap Model of Early Intervention for Young Children with Autism Spectrum Disorders. Topics in Early Childhood Special Education. 2011;31(3):133-54.
6 Eldevik S, Hastings RP, Jahr E, et al. Outcomes of behavioral intervention for children with autism in mainstream pre-school settings. J Autism Dev Disord. Feb. 2012;42(2):210-20. [pmid: 21472360].
7 Eikeseth S, Klintwall L, Jahr E, et al. Outcome for Children with Autism Receiving Early and Intensive Behavioral Intervention in Mainstream Preschool and Kindergarten Settings. Research in Autism Spectrum Disorders. 2012;6(2):829-35.
8 Flanagan HE, Perry A, Freeman NL. Effectiveness of large-scale community-based intensive Behavioral Intervention: A waitlist comparison study exploring outcomes and predictors. Research in Autism Spectrum Disorders. 2012;6(2):673-82.
9 Freeman N, Perry A. Outcomes of intensive behavioural intervention in the Toronto Preschool Autism Service. Journal on Developmental Disabilities. 2010;16(2):17-32.
10 Shine R, Perry A. The relationship between parental stress and intervention outcome of children with autism. Journal on Developmental Disabilities. 2010;16(2):64-6.
11 Perry A, Cummings A, Geier JD, et al. Predictors of Outcome for Children Receiving Intensive Behavioral Intervention in a Large, Community-Based Program. Research in Autism Spectrum Disorders. 2011;5(1):592-603.
12 Perry A, Blacklock K, Dunn Geier J. The relative importance of age and IQ as predictors of outcomes in Intensive Behavioral Intervention. Research in Autism Spectrum Disorders. 2013;7(9):1142-50.
13 Perry A, Cummings A, Geier JD, et al. Effectiveness of Intensive Behavioral Intervention in a Large, Community-Based Program. Research in Autism Spectrum Disorders. Oct. 2008;2(4):621-42.
14 Boyd BA, Hume K, McBee MT, et al. Comparative Efficacy of LEAP TEACCH Non-Model-Specific Special Education Programs for Preschoolers with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jun. 28. [pmid: 23812661].
15 Kovshoff H, Hastings RP, Remington B. Two-year outcomes for children with autism after the cessation of early intensive behavioral intervention. Behav Modif. Sep. 2011;35(5):427-50. [pmid: 21586502].
16 Remington B, Hastings RP, Kovshoff H, et al. Early intensive behavioral intervention: outcomes for children with autism and their parents after two years. Am J Ment Retard. Nov. 2007;112(6):418-38. [pmid: 17963434].
17 Schreibman L, Stahmer AC. A Randomized Trial Comparison of the Effects of Verbal and Pictorial Naturalistic Communication Strategies on Spoken Language for Young Children with Autism. J Autism Dev Disord. 2013. Nov. 23. [pmid: 24272416].
18 Strauss K, Vicari S, Valeri G, et al. Parent inclusion in Early Intensive Behavioral Intervention: the influence of parental stress, parent treatment fidelity and parent-mediated generalization of behavior targets on child outcomes. Res Dev Disabil. Mar-Apr. 2012;33(2):688-703. [pmid: 22188793].
19 Fava L, Strauss K, Valeri G, et al. The Effectiveness of a Cross-Setting Complementary Staff- and Parent-Mediated Early Intensive Behavioral Intervention for Young Children with ASD. Research in Autism Spectrum Disorders. 2011;5(4):1479-92.
20 Landa RJ, Holman KC, O'Neill AH, et al. Intervention targeting development of socially synchronous engagement in toddlers with autism spectrum disorder: a randomized controlled trial. J Child Psychol Psychiatry. Jan. 2011;52(1):13-21. [pmid: 21126245].
21 Landa RJ, Kalb LG. Long-term outcomes of toddlers with autism spectrum disorders exposed to short-term intervention. Pediatrics. Nov. Suppl 2. 2012;130:S186-90. [pmid: 23118250].
22 Dawson G, Jones EJ, Merkle K, et al. Early behavioral intervention is associated with normalized brain activity in young children with autism. J Am Acad Child Adolesc Psychiatry. Nov. 2012;51(11):1150-9. [pmid: 23101741].
23 Dawson G, Rogers S, Munson J, et al. Randomized Controlled Trial of an Intervention for Toddlers With Autism: The Early Start Denver Model. Pediatrics. 2010. January. 2010.
24 Roberts J, Williams K, Carter M, et al. A Randomised Controlled Trial of Two Early Intervention Programs for Young Children with Autism: Centre-Based with Parent Program and Home-Based. Research in Autism Spectrum Disorders. 2011;5(4):1553-66.
25 Aldred C, Green J, Adams C. A new social communication intervention for children with autism: pilot randomised controlled treatment study suggesting effectiveness. J Child Psychol Psychiatry. Nov. 2004;45(8):1420-30. [pmid: 15482502].
26 Aldred C, Green J, Emsley R, et al. Mediation of treatment effect in a communication intervention for pre-school children with autism. Journal of Autism and Developmental Disorders. 2012;42(3):447-54. [pmid: 21512834].
27 Keen D, Couzens D, Muspratt S, et al. The effects of a parent-focused intervention for children with a recent diagnosis of autism spectrum disorder on parenting stress and competence. Research in Autism Spectrum Disorders. 2010;4(2):229-41.
28 Casenhiser DM, Shanker SG, Stieben J. Learning through interaction in children with autism: preliminary data from asocial-communication-based intervention. Autism. Mar. 2013;17(2):220-41. [pmid: 21949005].
29 Rogers SJ, Estes A, Lord C, et al. Effects of a brief Early Start Denver Model (ESDM)–based parent intervention on toddlers at risk for autism spectrum disorders: A randomized controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(10):1052-65. [pmid: 23021480].
30 Estes A, Vismara L, Mercado C, et al. The Impact of Parent-Delivered Intervention on Parents of Very Young Children with Autism. J Autism Dev Disord. 2013. Jul. 10. [pmid: 23838727].
31 Pajareya K, Nopmaneejumruslers K. A pilot randomized controlled trial of DIR/Floortime parent training intervention for pre-school children with autistic spectrum disorders. Autism. Sep. 2011;15(5):563-77. [pmid: 21690083].
32 Carter AS, Messinger DS, Stone WL, et al. A randomized controlled trial of Hanen's ‘More Than Words’ in toddlers with early autism symptoms. J Child Psychol Psychiatry. Jul. 2011;52(7):741-52. [pmid: 21418212].
33 Oosterling I, Visser J, Swinkels S, et al. Randomized controlled trial of the focus parent training for toddlers with autism: 1-year outcome. J Autism Dev Disord. Dec. 2010;40(12):1447-58. [pmid: 20440639].
34 Reed P, Osborne L. Impact of Severity of Autism and Intervention Time-Input on Child Outcomes: Comparison across Several Early Interventions. British Journal of Special Education. 2012;39(3):130-6.
35 Reed P, Osborne LA, Makrygianni M, et al. Evaluation of the Barnet Early Autism Model (BEAM) Teaching Intervention Programme in a “Real World” Setting. Research in Autism Spectrum Disorders. June. 2013. 2013;7(6):631-8.
36 Wong VCN, Kwan QK. Randomized controlled trial for early intervention for autism: A pilot study of the Autism 1-2-3 project. Journal of Autism and Developmental Disorders. 2010;40(6):677-88. [pmid: 20020319].
37 McConkey R, Truesdale-Kennedy M, Crawford H, et al. Preschoolers with Autism Spectrum Disorders: Evaluating the Impact of a Home-Based Intervention to Promote Their Communication. Early Child Development and Care. 2010;180(3):299-315.