# Excluded Studies

Exclusion reasons
X-1 Participants not in target age range
X-2 Not original research
X-3 Study size (N<10)
X-4 Does not address Key Questions
X-5 Does not address behavioral intervention for children with ASD 0-12 years of age
X-6 Article not obtainable

1 Brasic JR, Gianutsos JG. Neuromotor Assessment and Autistic Disorder. 2000:287-98. X-4.
2 Carr D, Felce D. Application of Stimulus Equivalence to Language Intervention for Individuals with Severe Linguistic Disabilities. 2000:181-205. X-4.
3 Carr JE, Nicolson AC, Higbee TS. Evaluation of a brief multiple-stimulus preference assessment in a naturalistic context. Journal of Applied Behavior Analysis. 2000;33(3):353-7. X-3, X-5. [pmid: 11051581].
4 Chez MG, Buchanan CP. Reply to B. Rimland's “Comments on ‘Secretin and Autism: A Two-Part Clinical Investigation’”. Journal of Autism and Developmental Disorders. 2000;30(2):97-8. X-5.
5 Ernst M. Commentary: Considerations on the Characterization and Treatment of Self-Injurious Behavior. Journal of Autism and Developmental Disorders. 2000;30(5):447-50. X-2, X-5. [pmid: 11098882].
6 Feinberg E, Vacca J. The Drama and Trauma of Creating Policies on Autism: Critical Issues To Consider in the New Millennium. Focus on Autism and Other Developmental Disabilities. 2000;15(3):130-7. X-5.
7 Geckeler AS, Libby ME, Graff RB, et al. Effects of reinforcer choice measured in single-operant and concurrent-schedule procedures. Journal of Applied Behavior Analysis. 2000;33(3):347-51. X-3, X-5. [pmid: 11051580].
8 Goldstein H. Commentary: Interventions To Facilitate Auditory, Visual, and Motor Integration: “Show Me the Data”. Journal of Autism and Developmental Disorders. 2000;30(5):423-5. X-2, X-5. [pmid: 11098878].
9 Gringras P. Practical Paediatric Psychopharmacological Prescribing in Autism: The Potential and the Pitfalls. 2000:229-47. X-4.
10 Horská A, Naidu S, Herskovits EH, et al. Quantitative 1H MR spectroscopic imaging in early Rett syndrome. Neurology. 2000;54(3):715-22. X-5. [pmid: 10680809].
11 Johnston MV. Commentary: Potential Neurobiologic Mechanisms through Which Metabolic Disorders Could Relate to Autism. Journal of Autism and Developmental Disorders. 2000;30(5):471-3. X-2, X-5. [pmid: 11098886].
12 Kaiser AP, Hancock TB, Nietfeld JP. The Effects of Parent-Implemented Enhanced Milieu Teaching on the Social Communication of Children Who Have Autism. Early Education and Development. 2000;11(4):423-46. X-3.
13 Kennedy CH, Meyer KA, Knowles T, et al. Analyzing the multiple functions of stereotypical behavior for students with autism: Implications for assessment and treatment. Journal of Applied Behavior Analysis. 2000;33(4):559-71. X-5. [pmid: 11214031].
14 Kerr KP, Mulhern F, McDowell C. Applied Behaviour Analysis. It Works, It's Positive; Now What's the Problem?. Early Child Development and Care. 2000;163:125-31. X-6.
15 Maag JW, Katsiyannis A. Recent Legal and Policy Developments in Special Education. NASSP Bulletin. 2000;84(613):1-8. X-5.
16 Mallory BL, Erickson K. “Play and Imagination in Children with Autism,” by Pamela J. Wolfberg. Book Review. Early Childhood Research Quarterly. 2000;15(4):583-6. X-5.
17 Miller N, Neuringer A. Reinforcing variability in adolescents with autism. Journal of Applied Behavior Analysis. 2000;33(2):151-65. X-5. [pmid: 10885524].
18 Moore D, Taylor J. Interactive Multimedia Systems for Students with Autism. Journal of Educational Media. 2000;25(3):169-77. X-1, X-2, X-3, X-4.
19 Nind M, Powell S. Intensive Interaction and Autism: Some Theoretical Concerns. Children & Society. 2000;14(2):98-109. X-5.
20 Pomeranz K. Siegel's defense: More inaccuracies. Journal of Autism and Developmental Disorders. 2000;30(4):363. X-2, X-5. [pmid: 11039863].
21 Rimland B. Comments on “Secretin and Autism: A Two-Part Clinical Investigation”. Chez MG, et al. Journal of Autism and Developmental Disorders. 2000. 2000;30(2):95. X-1, X-2, X-3, X-4, X-5. [pmid: 10832773].
22 Sallows G. Educational Interventions for Children with Autism in the UK. Early Child Development and Care. 2000;163:25-47. X-6.
23 Tantam D. Psychological Disorder in Adolescents and Adults with Asperger Syndrome. Autism: The International Journal of Research and Practice. 2000;4(1):47-62. X-5.
24 Tsai L. Children with Autism Spectrum Disorder: Medicine Today and in the New Millennium. Focus on Autism and Other Developmental Disabilities. 2000;15(3):138-45. X-2, X-5.
25 Wray JA, Yoon JH, Vollmer T, et al. Pilot study of the behavioral effects of flumazenil in two children with autism. Journal of Autism and Developmental Disorders. 2000;30(6):619-20. X-3. [pmid: 11261474].
26 Yell ML, Drasgow E. Litigating a Free Appropriate Public Education: The Lovaas Hearings and Cases. 2000:205-14. X-4.
27 Charman T, Baron-Cohen S, Baird G, et al. Commentary: The Modified Checklist for Autism in Toddlers. Journal of Autism and Developmental Disorders. 2001;31(2):145-8. X-5. [pmid: 11450813].
28 Chen NC, Bedair HS, McKay B, et al. Clozapine in the treatment of aggression in an adolescent with autistic disorder. Journal of Clinical Psychiatry. 2001;62(6):479-80. X-5. [pmid: 11465533].
29 Clifford P, Friesen S, Jardine DW. Whatever Happens to Him Happens to Us: Reading Coyote Reading the World. Journal of Educational Thought/Revue de la Pensee Educative. 2001;35(1):9-26. X-5.
30 Dempsey I, Foreman P. A Review of Educational Approaches for Individuals with Autism. 2001:103-16. X-4.
31 Dunlap G, Kern L, Worcester J. ABA and Academic Instruction. Focus on Autism and Other Developmental Disabilities. 2001;16(2):129-36. X-1, X-2, X-3, X-4.
32 Dunlap G, Newton SJ, Fox L, et al. Family Involvement in Functional Assessment and Positive Behavior Support. 2001:215-21. X-4.
33 Durand MV, Merges E. Functional Communication Training: A Contemporary Behavior Analytic Intervention for Problem Behaviors. 2001:110-9. X-4.
34 Earles-Vollrath TL. Book Review: Teaching Kids and Adults with Autism: Building the Framework for Lifetime Learning. Focus on Autism and Other Developmental Disabilities. 2001;16(1):64. X-5.
35 Gobbi G, Pulvirenti L. Long-term treatment with clozapine in an adult with autistic disorder accompanied by aggressive behavior. Journal of Psychiatry & Neuroscience. 2001;26(4):340-1. X-5. [pmid: 11590976].
36 Gorbachevskaya N, Bashina V, Gratchev V, et al. Cerebrolysin therapy in Rett syndrome: Clinical and EEG mapping study. Brain & Development. 2001;23(Suppl1):S90-S3. X-5. [pmid: 11738849].
37 Johnston SS, O'Neill RE. Searching for Effectiveness and Efficiency in Conducting Functional Assessments: A Review and Proposed Process for Teachers and Other Practitioners. 2001:205-14. X-4.
38 Koegel LK, Koegel RL, Frea WD, et al. Identifying early intervention targets for children with autism in inclusive school settings. Behavior Modification. 2001;25(5):745-61. X-3, X-5. [pmid: 11573338].
39 Kohler FW, Anthony LJ, Steighner SA, et al. Teaching Social Interaction Skills in the Integrated Preschool: An Examination of Naturalistic Tactics. Topics in Early Childhood Special Education. 2001;21(2):93-103. X-3.
40 Koning C, Magill-Evans J. Validation of the Child and Adolescent Social Perception Measure. Occupational Therapy Journal of Research. 2001;21(1):49-67. X-5.
41 Mueller MM, Wilczynski SM, Moore JW, et al. Antecedent manipulations in a tangible condition: Effects of stimulus preference on aggression. Journal of Applied Behavior Analysis. 2001;34(2):237-40. X-3, X-5. [pmid: 11421319].
42 Ogletree BT, Oren T. Application of ABA Principles to General Communication Instruction. 2001:102-9. X-2, X-4.
43 Roane HS, Piazza CC, Sgro GM, et al. Analysis of aberrant behaviour associated with Rett syndrome. Disability and Rehabilitation: An International, Multidisciplinary Journal. 2001;23(3-4):139-48. X-5.
44 Robins DL, Fein D, Barton ML, et al. The Modified Checklist for Autism in Toddlers: An initial study investigating the early detection of autism and pervasive developmental disorders. Journal of Autism and Developmental Disorders. 2001;31(2):131-44. X-5. [pmid: 11450812].
45 Robins DL, Fein D, Barton ML, et al. Reply to Charman et al.'s Commentary on the Modified Checklist for Autism in Toddlers. Journal of Autism and Developmental Disorders. 2001. 2001;31(2):149-51. X-5.
46 Rogers EL. Functional Behavioral Assessment and Children with Autism: Working as a Team. Focus on Autism and Other Developmental Disabilities. 2001;16(4):228-31. X-1, X-2, X-3, X-4.
47 Rogers MF, Myles BS. Using Social Stories and Comic Strip Conversations To Interpret Social Situations for an Adolescent with Asperger Syndrome. 2001:310-3. X-4.
48 Roseman B, Schneider E, Crimmins D, et al. What to measure in autism drug trials. Journal of Autism and Developmental Disorders. 2001;31(3):361-2. X-5. [pmid: 11518490].
49 Rosinski D. The Miraculous and the Mundane. Focus on Autism and Other Developmental Disabilities. 2001;16(1):12-6. X-5.
50 Safran SP. Asperger Syndrome: The Emerging Challenge to Special Education. 2001:151-60. X-4.
51 Schneiter R, Devine MA. Reduction of Self-Injurious Behaviors of an Individual with Autism: Use of a Leisure Communication Book. Therapeutic Recreation Journal. 2001;35(3):207-19. X-5.
52 Schwartz IS, Boulware G-L, McBride BJ, et al. Functional Assessment Strategies for Young Children with Autism. Focus on Autism and Other Developmental Disabilities. 2001;16(4):222-7. X-1, X-2, X-3, X-4.
53 Simpson RL. ABA and Students with Autism Spectrum Disorders: Issues and Considerations for Effective Practice. Focus on Autism and Other Developmental Disabilities. 2001. 2001;16(2):68-71. X-5.
54 Starr EM, Foy JB, Cramer KM. Parental Perceptions of the Education of Children with Pervasive Developmental Disorders. Education and Training in Mental Retardation and Developmental Disabilities. 2001;36(1):55-68. X-5.
55 Symons FJ, Clark RD, Roberts JP, et al. Classroom Behavior of Elementary School-Age Boys with Fragile X Syndrome. Journal of Special Education. 2001;34(4):194-202. X-5.
56 Yasuhara A, Sugiyama Y. Music therapy for children with Rett syndrome. Brain & Development. 2001;23(Suppl1):S82-S4. X-5. [pmid: 11738847].
57 Beatson JE, Prelock PA. The Vermont Rural Autism Project: Sharing experiences, shifting attitudes. Focus on Autism and Other Developmental Disabilities. 2002;17(1):48-54. X-3, X-4, X-5.
58 Bibby P, Eikeseth S, Martin NT, et al. “Progress and outcomes for children with autism receiving parent-managed intensive interventions”: Erratum. Research in Developmental Disabilities. 2002;23(1):79-104. X-5.
59 Carr JE, Dozier CL, Patel MR, et al. Treatment of Automatically Reinforced Object Mouthing with Noncontingent Reinforcement and Response Blocking: Experimental Analysis and Social Validation. Research in Developmental Disabilities. 2002;23(1):37-44. X-3. [pmid: 12071394].
60 Davis BJ, Smith T, Donahoe P. Evaluating supervisors in the UCLA treatment model for children with autism: Validation of an assessment procedure. Behavior Therapy. 2002;33(4):601-14. X-4, X-5.
61 Dunn W, Saiter J, Rinner L. Asperger Syndrome and Sensory Processing: A Conceptual Model and Guidance for Intervention Planning. 2002:172-85. X-4.
62 Fiumara A, Polizzi A, Mazzei R, et al. Rett syndrome phenotype following infantile acute encephalopathy. Journal of Child Neurology. 2002;17(9):700-2. X-5. [pmid: 12503649].
63 Freeden I. A troll in the consulting room. British Journal of Psychotherapy. 2002;19(2):189-202. X-5.
64 Garfinkle AN, Schwartz IS. Peer imitation: Increasing social interactions in children with autism and other developmental disabilities in inclusive preschool classrooms. Topics in Early Childhood Special Education. 2002;22(1):26-38. X-3.
65 Goldstein H. Communication Intervention for Children with Autism: A Review of Treatment Efficacy. 2002:373-96. X-4.
66 Hagiwara T. Academic Assessment of Children and Youth with Asperger Syndrome, Pervasive Developmental Disorders-Not Otherwise Specified, and High-Functioning Autism. 2002. X-3, X-4.
67 Jensen VK, Sinclair LV. Treatment of Autism in Young Children: Behavioral Intervention and Applied Behavior Analysis. Infants and Young Children. 2002;14(4):42-52. X-2, X-5.
68 Kerr KP, Campbell A, McGrory S. The Saplings Model of Education: Case Studies in Autism. Journal of Precision Teaching & Celeration. 2002;18(2):49-60. X-5.
69 Lee R, McComas JJ, Jawor J. The effects of differential and lag reinforcement schedules on varied verbal responding by individuals with autism. Journal of Applied Behavior Analysis. 2002;35(4):391-402. X-3. [pmid: 12555910].
70 Levy SE, Hyman SL. Alternative/Complementary Approaches to Treatment of Children with Autism Spectrum Disorders. 2002:33-42. X-2, X-3, X-4.
71 Madsen KM, Hviid A, Vestergaard M, et al. A population-based study of measles, mumps, and rubella vaccination and autism. The New England Journal of Medicine. 2002;347(19):1477-82. X-5. [pmid: 12421889].
72 Mandlawitz MR. The Impact of the Legal System on Educational Programming for Young Children with Autism Spectrum Disorder. 2002:495-508. X-4.
73 McConnell SR. Interventions To Facilitate Social Interaction for Young Children with Autism: Review of Available Research and Recommendations for Educational Intervention and Future Research. 2002:351-72. X-4.
74 McElwee J, Munson S. Attaining Fluency by a Youngster with Autism for a Beginning Listener Skill. Journal of Precision Teaching & Celeration. 2002;18(1):30-2. X-3, X-5.
75 Niederhofer H, Staffen W, Mair A. Lofexidine in hyperactive impulsive children with autistic disordery. Journal of the American Academy of Child & Adolescent Psychiatr. 2002;41(12):1396-7. X-5.
76 Osterling JA, Dawson G, Munson JA. Early recognition of 1-year-old infants with autism spectrum disorder versus mental retardation. Development and Psychopathology. 2002;14(2):239-51. X-5. [pmid: 12030690].
77 Ruble LA, Dalrymple NJ. COMPASS: A Parent-Teacher Collaborative Model for Students with Autism. Focus on Autism and Other Developmental Disabilities. 2002;17(2):76-83. X-2, X-3, X-5.
78 Schall C. A. Consumer's Guide to Monitoring Psychotropic Medication for Individuals with Autism Spectrum Disorders. 2002:229-35. X-4.
79 Research into Early Intervention for Children with Autism and Related Disorders: Methodological and Design Issues: Report on a Workshop Funded by the Wellcome Trust, Institute of Child Health, London, UK,November 2001. 2003:217-25. X-4.
80 Able-Boone H, Crais ER, Downing K. Preparation of Early Intervention Practitioners for Working with Young Children with Low Incidence Disabilities. Teacher Education and Special Education. 2003;26(1):79-82. X-5.
81 Antshel KM, Remer R. Social Skills Training in Children With Attention Deficit Hyperactivity Disorder: A Randomized-Controlled Clinical Trial. J Clin Child Adolesc Psychol. 2003;32(1):152-65. X-5. [pmid: 12573940].
82 Bruns DA, Gallagher EA. Having Their Piece of the PIIE: Promoting the Communicative Behaviors of Young Children with Autism/PDD. 2003:20-7. X-3, X-4.
83 Campbell JM. Efficacy of Behavioral Interventions for Reducing Problem Behavior in Persons with Autism: A Quantitative Synthesis of Single-Subject Research. Research in Developmental Disabilities. 2003. 2003;24(2):120-38. X-1. [pmid: 12623082].
84 Connor M. Monitoring and Reviewing Early Behavioural Intervention in Autism (Lovaas). Routledge. 325 Chestnut Street Suite 800,Philadelphia, PA 19106. 2003:21-33. X-4.
85 Craven-Thuss B, Nicolson R. Amoxapine treatment of interfering behaviors in autistic disorder. Journal of the American Academy of Child & Adolescent Psychiatry. 2003;42(5):515-6. X-3. [pmid: 12707553].
86 Dahle KB. Services To Young Children with Autism in the General Classroom. 2003:65-70. X-4.
87 Dahle KB. The Clinical and Educational Systems: Differences and Similarities. 2003:238-46. X-4.
88 Diehl SF. Epilogue: Autism Spectrum Disorder: The Context of Speech-Language Pathologist Intervention. Language, Speech, and Hearing Services in Schools. 2003;34(3):253-4. X-5.
89 Diehl SF. The SLP's Role in Collaborative Assessment and Intervention for Children with ASD. 2003:95-115. X-4.
90 Gale S, Ozonoff S, Lainhart J. Brief Report: Pitocin Induction in Autistic and Nonautistic Individuals. Journal of Autism and Developmental Disorders. 2003;33(2):205-8. X-5. [pmid: 12757361].
91 Glaeser BC, Pierson MR, Fritschmann N. Comic Strip Conversation: A Positive Behavioral Support Strategy. 2003:14-9. X-3.
92 Goforth HW, Rao M. Improvement in behaviour and attention in an autistic patient treated with ziprasidone. Australian and New Zealand Journal of Psychiatry. 2003;37(6):775-6. X-3. [pmid: 14636398].
93 Hess K. Keep the Change: A Hard-Earned Success. Young Children. 2003;58(4):30-2. X-3, X-5.
94 Hviid A, Stellfeld M, Wohlfahrt J, et al. Association Between Thimerosal-Containing Vaccine and Autism. JAMA: Journal of the American Medical Association. 2003;290(13):1763-6. X-5.
95 Kerr AM, Webb P, Prescott RJ, et al. Results of Surgery for Scoliosis in Rett Syndrome. Journal of Child Neurology. 2003;18(10):703-8. X-5. [pmid: 14649553].
96 Koppenhaver DA, Erickson KA. Natural emergent literacy supports for preschoolers with Autism and severe communication impairments. Topics in Language Disorders. 2003;23(4):283-92. X-3.
97 Mahoney G, Perales F. Using Relationship-Focused Intervention To Enhance the Social-Emotional Functioning of Young Children with Autism Spectrum Disorders. Topics in Early Childhood Special Education. 2003. 2003;23(2):77-89. X-5.
98 McCabe H. The Beginnings of Inclusion in the People's Republic of China. Research and Practice for Persons with Severe Disabilities. 2003. 2003;28(1):16-22. X-5.
99 Moore V, Goodson S. How well does early diagnosis of autism stand the test of time? Follow-up study of children assessed for autism at age 2 and development of an early diagnostic service. Autism. 2003;7(1):47-63. X-5. [pmid: 12638764].
100 Nasuno M, Takeuchi K, J-i Yamamoto. Feasibility of Parents of Children with Autism Using an Applied Behavior Analytic Early Treatment Program: A Preliminary Study in Malaysia. Japanese Journal of Special Education. 2003;40(6):723-32. X-1, X-3, X-4.
101 Nelson C, Huefner DS. Young Children with Autism: Judicial Responses to the Lovaas and Discrete Trial Training Debates. 2003:1-19. X-4.
102 Niederhofer H, Staffen W, Mair A. Immunoglobulins as an alternative strategy of psychopharmacological treatment of children with autistic disorder. Neuropsychopharmacology. 2003;28(5):1014-5. X-5. [pmid: 12700706].
103 Odom SL, Brown WH, Frey T, et al. Evidence-Based Practices for Young Children with Autism: Contributions for Single-Subject Design Research. 2003:166-75. X-2, X-3.
104 Oh HM, Oh JM, Choi SC, et al. An efficient method for the rapid establishment of Epstein-Barr virus immortalization of human B lymphocytes. Cell Prolif. Aug. 2003;36(4):191-7. X-5. [pmid: 12950388].
105 Osborne J. Art and the Child with Autism: Therapy or Education?. 2003:411-23. X-4.
106 Polirstok SR, Dana L, Buono S, et al. Improving functional communication skills in adolescents and young adults with severe autism using gentle teaching and positive approaches. Topics in Language Disorders. 2003;23(2):146-53. X-5.
107 Polirstok SR, Lesser DR. Useful Online Information, Resources, and Interventions for Speech Language Pathologists and Teachers of Students with Autistic Spectrum Disorders. Topics in Language Disorders. 2003;23(2):166-7. X-5.
108 Prizant BM, Wetherby AM, Rubin E, et al. The SCERTS Model: A Transactional, Family-Centered Approach to Enhancing Communication and Socioemotional Abilities of Children with Autism Spectrum Disorder. Infants and Young Children. 2003;16(4):296-316. X-1, X-2, X-3, X-4.
109 Roane HS, Fisher WW, McDonough EM. Progressing from programmatic to discovery research: A case example with the overjustification effect. Journal of Applied Behavior Analysis. 2003;36(1):35-46. X-5. [pmid: 12723865].
110 Rogers-Adkinson DL, Ochoa TA, Delgado B. Developing Cross-Cultural Competence: Serving Families of Children with Significant Developmental Needs. 2003:4-8. X-4.
111 Safran SP, Safran JS, Ellis K. Intervention ABCs for Children with Asperger Syndrome. 2003:154-65. X-4.
112 Tissot C, Evans R. Visual Teaching Strategies for Children with Autism. Early Child Development and Care. 2003;173(4):425-33. X-1, X-2, X-3, X-4.
113 Webster A, Feiler A, Webster V. Early Intensive Family Intervention and Evidence of Effectiveness: Lessons from the South West Autism Programme. 2003:383-98. X-4.
114 Woods JJ, Wetherby AM. Early Identification of and Intervention for Infants and Toddlers Who Are at Risk for Autism Spectrum Disorder. 2003:180-93. X-2, X-3, X-4.
115 Zionts LT, Zionts P, Harrison S, et al. Urban African American Families' Perceptions of Cultural Sensitivity within the Special Education System. Focus on Autism and Other Developmental Disabilities. 2003;18(1):41-50. X-5.
116 Barnes-Holmes Y, Barnes-Holmes D, McHugh L. Teaching Derived Relational Responding to Young Children. Journal of Early and Intensive Behavior Intervention. 2004;1(1):3-12. X-1, X-2, X-3, X-4.
117 Bodfish JW. Treating the Core Features of Autism: Are We There yet?. Mental Retardation and Developmental Disabilities Research Reviews. 2004;10(4):318-26. X-1, X-2, X-3, X-4. [pmid: 15666340].
118 Bölte S, Bosch G. Bosch's Cases: A 40 years Follow-up of Patients with Infantile Autism and Asperger Syndrome. German Journal of Psychiatry. 2004;7(1):10-3. X-5.
119 Bruinsma Y, Koegel RL, Koegel LK. Joint Attention and Children with Autism: A Review of the Literature. Wiley-Blackwell. 111 River Street, Hoboken, NJ 07030-5774. 2004:169-75. X-4.
120 Bryson SE, Landry R, Czapinski P, et al. Autistic Spectrum Disorders: Causal Mechanisms and Recent Findings on Attention and Emotion. International Journal of Special Education. 2004;19(1):14-22. X-5.
121 Carpenter B, Addenbrooke M, Attfield E, et al. Celebrating Families: An Inclusive Model of Family-Centred Training. British Journal of Special Education. 2004;31(2):75-80. X-5.
122 Chen W, Landau S, Sham P, et al. No evidence for links between autism, MMR and measles virus. Psychological Medicine. 2004;34(3):543-53. X-5. [pmid: 15259839].
123 Dong WK, Greenough WT. Plasticity of Nonneuronal Brain Tissue: Roles in Developmental Disorders. Mental Retardation and Developmental Disabilities Research Reviews. 2004;10(2):85-90. X-5. [pmid: 15362161].
124 Drash PW, Tudor RM. An Analysis of Autism as a Contingency-Shaped Disorder of Verbal Behavior. Analysis of Verbal Behavior. 2004;20:5-23. X-5. [pmid: 22477283].
125 Drash PW, Tudor RM. Is Autism a Preventable Disorder of Verbal Behavior? A Response to Five Commentaries. Analysis of Verbal Behavior. 2004. 2004;20:55-62. X-5. [pmid: 22477289].
126 Goldsmith TR, LeBlanc LA. Use of Technology in Interventions for Children with Autism. Journal of Early and Intensive Behavior Intervention. 2004;1(2):166-78. X-1, X-2, X-3, X-4.
127 Goyal M, O'Riordan MA, Wiznitzer M. Effect of Topiramate on Seizures and Respiratory Dysrhythmia in Rett Syndrome. Journal of Child Neurology. 2004;19(8):588-91. X-5. [pmid: 15605467].
128 Haines J, Camarata S. Examination of Candidate Genes in Language Disorder: A Model of Genetic Association for Treatment Studies. Mental Retardation and Developmental Disabilities Research Reviews. 2004;10(3):208-17. X-5. [pmid: 15611983].
129 Himle MB, Miltenberger RG, Flessner C, et al. Teaching safety skills to children to prevent gun play. Journal of Applied Behavior Analysis. 2004;37(1):1-9. X-3, X-5. [pmid: 15154211].
130 Hixson MD. Autism as a Contingency-Shaped Disorder of Verbal Behavior: Evidence Obtained and Evidence Needed. Analysis of Verbal Behavior. 2004;20:49-53. X-2, X-5. [pmid: 22477288].
131 Houzel D. The Psychoanalysis of Infantile Autism. Journal of Child Psychotherapy. 2004. 2004;30(2):225-37. X-3, X-5.
132 Icasiano F, Hewson P, Machet P, et al. Childhood autism spectrum disorder in the Barwon region: A community based study. Journal of Paediatrics and Child Health. 2004;40(12):696-701. X-5. [pmid: 15569287].
133 Kaidar M, Zalsman G. Olanzapine for Childhood Disintegrative Disorder. Israel Journal of Psychiatry and Related Sciences. 2004;41(1):71-2. X-1, X-2, X-3, X-4. [pmid: 15160660].
134 Kwon H. Tardive dyskinesia in an autistic patient treated with risperidone. The American Journal of Psychiatry. 2004;161(4):757-8. X-5. [pmid: 15056529].
135 Malow BA. Sleep Disorders, Epilepsy, and Autism. Mental Retardation and Developmental Disabilities Research Reviews. 2004;10(2):122-5. X-2, X-5. [pmid: 15362168].
136 Noland RM, Gabriels RL. Screening and Identifying Children with Autism Spectrum Disorders in the Public School System: The Development of a Model Process. Journal of Autism and Developmental Disorders. 2004;34(3):265-77. X-5. [pmid: 15264495].
137 Nuzzolo-Gomez R, Greer DR. Emergence of Untaught Mands or Tacts of Novel Adjective-Object Pairs as a Function of Instructional History. Analysis of Verbal Behavior. 2004;20:63-76. X-3. [pmid: 22477290].
138 Reading R. Review of Age at first measles-mumps-rubella vaccination in children with autism and school-matched control subjects: A population-based study in metropolitan Atlanta. Child: Care, Health and Development. 2004;30(4):398-9. X-5.
139 Renna R. Autism spectrum disorders Learning to Listen as We Shape Behaviors Blending Choice Theory with Applied Behavioral Analysis. International Journal of Reality Therapy. 2004;23(2):17-22. X-2, X-5.
140 Schwartz IS, Sandall SR, McBride BJ, et al. Project DATA (Developmentally Appropriate Treatment for Autism): An Inclusive School-Based Approach to Educating Young Children with Autism. Topics in Early Childhood Special Education. 2004;24(3):156-68. X-5.
141 Smeeth L, Cook C, Fombonne E, et al. MMR vaccination and pervasive developmental disorders: A case-control study. The Lancet. 2004;364(9438):963-9. X-5.
142 Smith C, Goddard S, Fluck M. A Scheme to Promote Social Attention and Functional Language in Young Children with Communication Difficulties and Autistic Spectrum Disorder. Educational Psychology in Practice. 2004;20(4):319-33. X-3, X-4.
143 Smith DL, Gillon GT. Autistic Spectrum Disorder: Caseload Characteristics, and Interventions Implemented by Speech-Language TherapistsKairaranga. Kairaranga. 2004;5(2):46-54. X-1, X-2, X-3, X-4.
144 Sulzbacher S, Mas J, Larson EH, et al. Pediatric Tele-Health Consultation to Rural Schools and Clinics in the Pacific Northwest. Journal of Special Education Technology. 2004;19(1):35-42. X-5.
145 Summers AJ, Houlding MC, Reitzel MJA. Behaviour Management Services for Children with Autism-PDD: Program Description and Patterns of Referral. Focus on Autism and Other Developmental Disabilities. 2004;19(2):95-101. X-4.
146 Taylor BA, Hughes CE, Richard E, et al. Teaching Teenagers with Autism to Seek Assistance when Lost. Journal of Applied Behavior Analysis. 2004;37(1):79-82. X-5. [pmid: 15154218].
147 Tharp BR. Epileptic Encephalopathies and Their Relationship to Developmental Disorders: Do Spikes Cause Autism?. Mental Retardation and Developmental Disabilities Research Reviews. 2004;10(2):132-4. X-2, X-5. [pmid: 15362170].
148 Tuchman R. AEDS and Psychotropic Drugs in Children with Autism and Epilepsy. Mental Retardation and Developmental Disabilities Research Reviews. May. 2004. 2004;10(2):135-8. X-5. [pmid: 15362171].
149 Waltz M, Shattock P. Autistic disorder in nineteenth-century London. Autism. 2004;8(1):7-20. X-3, X-5. [pmid: 15070544].
150 Woo EJ, Ball R, Bostrom A, et al. Vaccine Risk Perception Among Reporters of Autism After Vaccination: Vaccine Adverse Event Reporting System 1990-2001. American Journal of Public Health. 2004;94(6):990-55. X-5. [pmid: 15249304].
151 Yang P, Tsai J-H. Occurrence of Priapism with Risperidone-Paroxetine Combination in an Autistic Child. Journal of Child and Adolescent Psychopharmacology. 2004;14(3):342-3. X-5. [pmid: 15650488].
152 Carr JE, Firth AM. The Verbal Behavior Approach to Early and Intensive Behavioral Intervention for Autism: A Call for Additional Empirical Support. Journal of Early and Intensive Behavior Intervention. 2005;2(1):18-27. X-2, X-5.
153 Clark E, Zhou Z. Autism in China: From Acupuncture to Applied Behavior Analysis. Psychology in the Schools. 2005;42(3):285-95. X-5.
154 Cohen MJ. The effect of increasing the rate of clerical skill performance on challenging behavior. Journal of Precision Teaching & Celeration. 2005;21(1):2-12. X-5.
155 Corbett BA, Abdullah M. Video Modeling: Why Does It Work for Children with Autism?. Journal of Early and Intensive Behavior Intervention. 2005;2(1):2-8. X-2, X-5.
156 DeRosier ME, Marcus SR. Building friendships and combating bullying: effectiveness of S.S.GRIN at one-year follow-up. J Clin Child Adolesc Psychol. Mar. 2005;34(1):140-50. X-5. [pmid: 15677288].
157 Doughty SS, Poe SG, Anderson CM. Effects of Punishment and Response-Independent Attention on Severe Problem Behavior and Appropriate Toy Play. Journal of Early and Intensive Behavior Intervention. 2005;2(2):91-8. X-3.
158 Dumont-Mathieu T, Fein D. Screening for Autism in Young Children: The Modified Checklist for Autism in Toddlers (M-Chat) and Other Measures. Mental Retardation and Developmental Disabilities Research Reviews. 2005;11(3):253-62. X-5. [pmid: 16161090].
159 Easterbrooks RS, Handley MC. Behavior Change in a Student with a Dual Diagnosis of Deafness and Pervasive Development Disorder: A Case Study. American Annals of the Deaf. 2005;150(5):401-7. X-3, X-5. [pmid: 16610472].
160 Elefant C, Wigram T. Learning ability in children with Rett syndrome. Brain & Development. 2005;27(Suppl1):S97-S101. X-5. [pmid: 16182495].
161 Ferraioli S, Hughes C, Smith T. A Model for Problem Solving in Discrete Trial Training for Children with Autism. Journal of Early and Intensive Behavior Intervention. 2005;2(4):224-46. X-2, X-5.
162 Galinat K, Barcalow K, Krivda B. Caring for Children with Autism in the School Setting. Journal of School Nursing. 2005;21(4):208-17. X-5. [pmid: 16048365].
163 Groden J, Goodwin MS, Baron MG, et al. Assessing Cardiovascular Responses to Stressors in Individuals With Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 2005;20(4):244-52. X-5.
164 Handleman JS, Harris SL. Douglass Developmental Disabilities Center: An ABA Program for Children and Adults with Autism Spectrum Disorders. International Journal of Behavioral Consultation and Therapy. 2005;1(4):301-11. X-2, X-3, X-4.
165 Hay I, Winn S. Students with Asperger's Syndrome in an Inclusive Secondary School Environment: Teachers', Parents', and Students' Perspectives. Australasian Journal of Special Education. 2005;29(2):140-54. X-3, X-4.
166 Kraemer B, Delsignore A, Gundelfinger R, et al. Comorbidity of Asperger syndrome and gender identity disorder. European Child & Adolescent Psychiatry. 2005;14(5):292-6. X-5. [pmid: 15981142].
167 Leblanc L, Richardson W, McIntosh J. The Use of Applied Behavioral Analysis in Teaching Children with Autism. International Journal of Special Education. 2005;20(1):13-34. X-3.
168 Lerman DC, Parten M, Addison LR, et al. A Methodology for Assessing the Functions of Emerging Speech in Children with Developmental Disabilities. Journal of Applied Behavior Analysis. 2005;38(3):303-16. X-5. [pmid: 16270841].
169 McInnes LA, González PJ, Manghi ER, et al. A genetic study of autism in Costa Rica: Multiple variables affecting IQ scores observed in a preliminary sample of autistic cases. BMC Psychiatry. 2005. X-5.
170 Mukaddes NM, Topcu Z. Letter to the editors. Autism. 2005;9(2):213-5. X-5. [pmid: 15857863].
171 Noto LA. A Case Study of the Ann Sullivan Center in Lima, Peru. International Journal of Special Education. 2005;20(2):47-57. X-2, X-3, X-4.
172 Rapp JT, Rapp J. Stereotypy II: A Review of Neurobiological Interpretations and Suggestions for an Integration with Behavioral Methods. Elsevier Customer Service Department. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2005:548-64. X-4.
173 Romanczyk RG, White S, Gillis JM. Social Skills versus Skilled Social Behavior: A Problematic Distinction in Autism Spectrum Disorders. Journal of Early and Intensive Behavior Intervention. 2005;2(3):177-93. X-1, X-2, X-3, X-4.
174 Ronald A, Happé F, Plomin R. The genetic relationship between individual differences in social and nonsocial behaviours characteristic of autism. Developmental Science. 2005;8(5):444-58. X-5. [pmid: 16048517].
175 Stephens CE. Overcoming Challenges and Identifying a Consensus about Autism Intervention Programming. International Journal of Special Education. 2005. 2005;20(1):35-49. X-5.
176 Trepagnier CY, Sebrechts MM, Finkelmeyer A, et al. Virtual environments to address autistic social deficits. Annual Review of CyberTherapy and Telemedicine. 2005;3:101-7. X-1, X-2, X-3, X-4.
177 Tucci V, Hursh D, Laitinen R, et al. Competent Learner Model for Individuals With Autism/PDD. Exceptionality. 2005;13(1):55-63. X-5.
178 Weinberg M. Creation of a Commission for Accreditation of Programs and Services Using Applied Behavior Analysis for Treatment Purposes. International Journal of Behavioral Consultation and Therapy. 2005;1(4):338-40. X-5.
179 Williams G, Perez-Gonzalez LA, Queiroz ABM. Using a Combined Blocking Procedure to Teach Color Discrimination to a Child with Autism. Journal of Applied Behavior Analysis. 2005;38(4):555-8. X-3. [pmid: 16463537].
180 Ali S, Frederickson N. Investigating the Evidence Base of Social Stories. Educational Psychology in Practice. 2006;22(4):355-77. X-1, X-2, X-3, X-4.
181 Banerjee M. Autism & communication—A psycho-bio-social approach. Indian Journal of Community Psychology. 2006;2(2):1-15. X-6.
182 Baranek GT, David FJ, Poe MD, et al. Sensory Experiences Questionnaire: discriminating sensory features in young children with autism, developmental delays, and typical development. Journal of Child Psychology and Psychiatry. 2006;47(6):591-601. X-5. [pmid: 16712636].
183 Barretto A, Wacker DP, Harding J, et al. Using Telemedicine to Conduct Behavioral Assessments. Journal of Applied Behavior Analysis. 2006;39(3):333-40. X-5. [pmid: 17020213].
184 Brock SE. An Examination of the Changing Rates of Autism in Special Education. California School Psychologist. 2006;11:31-40. X-5.
185 Caldwell P. Speaking the Other's Language: Imitation as a Gateway to Relationship. Infant and Child Development. 2006;15(3):275-82. X-5.
186 Carlson JS, Brinkman T, Majewicz-Hefley A. Medication Treatment Outcomes for School-Aged Children Diagnosed with Autism. California School Psychologist. 2006;11:21-30. X-1, X-2, X-3, X-4.
187 Eaves LC, Wingert H, Ho HH. Screening for autism: Agreement with diagnosis. Autism. 2006;10(3):229-42. X-5. [pmid: 16682396].
188 Fish WW. Perceptions of Parents of Students with Autism towards the IEP Meeting: A Case Study of One Family Support Group Chapter. Education. 2006;127(1):56-68. X-5.
189 Huang AX, Wheeler JJ. Effective Interventions for Individuals with High-Functional Autism. International Journal of Special Education. 2006. 2006;21(3):165-75. X-5.
190 Humphrey N, Parkinson G. Research on Interventions for Children and Young People on the Autistic Spectrum: A Critical Perspective. Journal of Research in Special Educational Needs. 2006;6(2):76-86. X-2, X-5.
191 Jones P, West E, Stevens D. Nurturing Moments of Transformation in Teachers--Comparative Perspectives on the Challenges of Professional Development. British Journal of Special Education. 2006;33(2):82-90. X-5.
192 Landa R, Garrett-Mayer E. Development in Infants with Autism Spectrum Disorders: A Prospective Study. Journal of Child Psychology and Psychiatry. 2006;47(6):629-38. X-5. [pmid: 16712640].
193 Lerman DC, Addison LR, Kodak T. A Preliminary Analysis of Self-Control with Aversive Events: The Effects of Task Magnitude and Delay on the Choices of Children with Autism. Journal of Applied Behavior Analysis. 2006;39(2):227-32. X-3. [pmid: 16813043].
194 Margetts JK, Le Couteur A, Croom S. Families in a state of flux: The experience of grandparents in autism spectrum disorder. Child: Care, Health and Development. 2006;32(5):565-74. X-5.
195 Meadan H, Halle JW, Watkins RV, et al. Examining Communication Repairs of 2 Young Children with Autism Spectrum Disorder: The Influence of the Environment. American Journal of Speech-Language Pathology. 2006;15(1):57-71. X-3, X-5. [pmid: 16533093].
196 Miller CA. Developmental Relationships between Language and Theory of Mind. American Journal of Speech-Language Pathology. 2006;15(2):142-54. X-2, X-5. [pmid: 16782686].
197 Molloy CA, Morrow AL, Meinzen-Derr J, et al. Elevated cytokine levels in children with autism spectrum disorder. Journal of Neuroimmunology. 2006;172(1-2):198-205. X-5. [pmid: 16360218].
198 Munir S, Scholwinski E, Lasser J. The Use of Psychodrama Techniques for Students with Asperger's Disorder. Journal of School Counseling. 2006;4(2):1-38. X-1, X-2, X-3, X-4.
199 Nation K, Clarke P, Wright B, et al. Patterns of Reading Ability in Children with Autism Spectrum Disorder. Journal of Autism and Developmental Disorders. 2006;36(7):911-9. X-5. [pmid: 16897396].
200 Niehus R, Lord C. Early Medical History of Children with Autism Spectrum Disorders. Journal of Developmental and Behavioral Pediatrics. 2006;27(Suppl2):S120-S7. X-5. [pmid: 16685178].
201 Ouellette-Kuntz H, Coo H, Yu TC, et al. Prevalence of Pervasive Developmental Disorders in Two Canadian Provinces. Journal of Policy and Practice in Intellectual Disabilities. 2006;3(3):164-72. X-5.
202 Pistoljevic N, Greer DR. The Effects of Daily Intensive Tact Instruction on Preschool Students' Emission of Pure Tacts and Mands in Non-Instructional Setting. Journal of Early and Intensive Behavior Intervention. 2006;3(1):103-20. X-3.
203 Richler J, Luyster R, Risi S, et al. Is There a ‘Regressive Phenotype’ of Autism Spectrum Disorder Associated with the Measles-Mumps-Rubella Vaccine? A CPEA Study. Journal of Autism and Developmental Disorders. 2006;36(3):299-316. X-5. [pmid: 16729252].
204 Smeets EEJ, Julu POO, van Waardenburg D, et al. Management of a severe forceful breather with Rett Syndrome using carbogen. Brain & Development. 2006;28(10):625-32. X-5. [pmid: 16765005].
205 Stahmer AC, Schreibman L, Powell NP. Social Validation of Symbolic Play Training for Children with Autism. Journal of Early and Intensive Behavior Intervention. 2006;3(2):196-210. X-3.
206 Stichter JP, Brown T, Clarent R, et al. Addressing the Challenges: Developing a Programmatic Framework for the Systematic Integration of Evidence-Based Practices for Young Children with Autism Spectrum Disorder. Beyond Behavior. 2006;16(1):18-32. X-2, X-5.
207 Stuart SK, Flis LD, Rinaldi C. Connecting with Families: Parents Speak up about Preschool Services for Their Children with Autism Spectrum Disorders. TEACHING Exceptional Children. 2006;39(1):46-51. X-4, X-5.
208 Tang J-C, Wu L-T, Chiang C-H. An Investigation of Variables Relevant to the Stereotyped Behavior in Students with Developmental Disabilities in Taiwan. Journal of the International Association of Special Education. 2006;7(1):28-35. X-5.
209 Tiger JH, Hanley GP, Hernandez E. An Evaluation of the Value of Choice with Preschool Children. Journal of Applied Behavior Analysis. 2006;39(1):1-16. X-3, X-5. [pmid: 16602381].
210 Tissot C, Evans R. Securing Provision for Children with Autistic Spectrum Disorders: The Views of Parents. Research Article. Perspectives in Education. March. 2006. 2006;24(1):73-86. X-5.
211 Tofil NM, Buckmaster MA, Winkler MK, et al. Deep Sedation with Propofol in Patients with Rett Syndrome. Journal of Child Neurology. 2006;21(3):210-3. X-5. [pmid: 16901422].
212 Wood JJ, Piacentini JC, Southam-Gerow M, et al. Family cognitive behavioral therapy for child anxiety disorders. J Am Acad Child Adolesc Psychiatry. Mar. 2006;45(3):314-21. X-5. [pmid: 16540816].
213 Alpern CS, Zager D. Addressing Communication Needs of Young Adults with Autism in a College-Based Inclusion Program. Division on Developmental Disabilities, Council for Exceptional Children. DDD, P.O. Box 3512, Fayetteville, AR 72702. 2007:428-36. X-4.
214 Anderson DK, Lord C, Risi S, et al. Patterns of growth in verbal abilities among children with autism spectrum disorder. J Consult Clin Psychol. Aug. 2007;75(4):594-604. X-5. [pmid: 17663613].
215 Banda DR, Matuszny RM, Turkan S. Video Modeling Strategies to Enhance Appropriate Behaviors in Children with Autism Spectrum Disorders. TEACHING Exceptional Children. 2007;39(6):47-52. X-1, X-2, X-3, X-4.
216 Beresford B, Tozer R, Rabiee P, et al. Desired Outcomes for Children and Adolescents with Autistic Spectrum Disorders. Children & Society. 2007;21(1):4-16. X-5.
217 Bergström-Isacsson M, Julu POO, Witt-Engerström I. Autonomic responses to music and vibroacoustic therapy in Rett syndrome: A controlled within-subject study. Nordic Journal of Music Therapy. 2007;16(1):42-59. X-5.
218 Biederman BG, Freedman B. Modeling Skills, Signs and Lettering for Children with Down Syndrome, Autism and Other Severe Developmental Delays by Video Instruction in Classroom Setting. Journal of Early and Intensive Behavior Intervention. 2007;4(4):736-43. X-1, X-2, X-3, X-4.
219 Conroy MA, Asmus JM, Boyd BA, et al. Antecedent Classroom Factors and Disruptive Behaviors of Children with Autism Spectrum Disorders. Journal of Early Intervention. 2007;30(1):19-35. X-3, X-5.
220 Denning CB. Social Skills Interventions for Students with Asperger Syndrome and High-Functioning Autism: Research Findings and Implications for Teachers. Beyond Behavior. 2007;16(3):16-23. X-2, X-5.
221 Fabrizio MA, Schirmer K, King A, et al. Precision Teaching a Foundational Motor Skill to a Child with Autism. Journal of Precision Teaching and Celeration. 2007;23:16-8. X-3, X-4.
222 Fisher WW, Kodak T, Moore JW. Embedding an Identity-Matching Task within a Prompting Hierarchy to Facilitate Acquisition of Conditional Discriminations in Children with Autism. Journal of Applied Behavior Analysis. 2007;40(3):489-99. X-3. [pmid: 17970262].
223 Fortunato JA, Sigafoos J, Morsillo-Searls LM. A Communication Plan for Autism and its Applied Behavior Analysis Treatment: A Framing Strategy. Child and Youth Care Forum. 2007;36(2-3):87-97. X-2, X-4, X-5.
224 Foxx RM, Meindl J. The long term successful treatment of the aggressive/destructive behaviors of a preadolescent with autism. Behavioral Interventions. 2007;22(1):83-97. X-5.
225 Goodman G, Williams CM. Interventions for Increasing the Academic Engagement of Students with Autism Spectrum Disorders in Inclusive Classrooms. TEACHING Exceptional Children. 2007;39(6):53-61. X-1, X-2, X-3, X-4.
226 Grey IM, Bruton C, Honan R, et al. Co-Operative Learning for Children with an Autistic Spectrum Disorder (ASD) in Mainstream and Special Class Settings: An Exploratory Study. Educational Psychology in Practice. 2007;23(4):317-27. X-3.
227 Halle J, Meadan H. A protocol for assessing early communication of young children with autism and other developmental disabilities. Topics in Early Childhood Special Education. 2007;27(1):49-61. X-3, X-5.
228 Hilton C, Graver K, LaVesser P. Relationship between social competence and sensory processing in children with high functioning autism spectrum disorders. Research in Autism Spectrum Disorders. 2007;1(2):164-73. X-5.
229 Kelley ME, Shillingsburg AM, Castro JM, et al. Assessment of the Functions of Vocal Behavior in Children with Developmental Disabilities: A Replication. Journal of Applied Behavior Analysis. 2007;40(3):571-6. X-5. [pmid: 17970272].
230 Landa R. Early Communication Development and Intervention for Children with Autism. Mental Retardation and Developmental Disabilities Research Reviews. 2007;13(1):16-25. X-2, X-5. [pmid: 17326115].
231 Lee L-C, David AB, Rusyniak J, et al. Performance of the Social Communication Questionnaire in children receiving preschool special education services. Research in Autism Spectrum Disorders. 2007;1(2):126-38. X-5.
232 Luyster R, Qiu S, Lopez K, et al. Predicting outcomes of children referred for autism using the MacArthur--Bates Communicative Development Inventory. Journal of Speech, Language, and Hearing Research. 2007;50(3):667-81. X-5.
233 Matson JL, Matson ML, Rivet TT. Social-Skills Treatments for Children with Autism Spectrum Disorders: An Overview. SAGE Publications. 2455 Teller Road, Thousand Oaks, CA 91320. 2007:682-707. X-1, X-2, X-3, X-4.
234 McClellan J, Sikich L, Findling RL, et al. Treatment of Early-Onset Schizophrenia Spectrum Disorders (TEOSS): Rationale, Design, and Methods. Journal of the American Academy of Child & Adolescent Psychiatry. 2007;46(8):969-78. X-5. [pmid: 17667476].
235 Medhurst B, Beresford J. “THOMAS” Training: An Early Years Intervention for Children with an Autistic Spectrum Disorder (ASD). Educational Psychology in Practice. 2007;23(1):1-17. X-1, X-3, X-4.
236 Newman L. Secondary School Experiences of Students with Autism. Facts from NLTS2. NCSER 2007-3005. 2007:1-16. X-5.
237 Niederhofer H. Glutamate antagonists seem to be slightly effective in psychopharmacologic treatment of autism. Journal of Clinical Psychopharmacology. 2007;27(3):317-8. X-3. [pmid: 17502791].
238 Nikopoulos CK, Keenan M. Using video modeling to teach complex social sequences to children with autism. J Autism Dev Disord. Apr. 2007;37(4):678-93. X-3. [pmid: 16897375].
239 Petursdottir A-L, McComas J, McMaster K, et al. The Effects of Scripted Peer Tutoring and Programming Common Stimuli on Social Interactions of a Student with Autism Spectrum Disorder. Journal of Applied Behavior Analysis. 2007;40(2):353-7. X-3. [pmid: 17624077].
240 Ross-Swain D. The Effects of Auditory Stimulation on Auditory Processing Disorder: A Summary of the Findings. International Journal of Listening. 2007;21(2):140-55. X-1, X-3, X-4.
241 Shattuck PT, Grosse SD. Issues Related to the Diagnosis and Treatment of Autism Spectrum Disorders. Mental Retardation and Developmental Disabilities Research Reviews. 2007;13(2):129-35. X-5. [pmid: 17563895].
242 Simpson CG, Spencer VG, Button R, et al. Using Guided Reading with Students with Autism Spectrum Disorders. TEACHING Exceptional Children Plus. 2007;4(1):1-9. X-2, X-3, X-4.
243 Stahmer AC, Mandell DS. State infant/toddler program policies for eligibility and services provision for young children with autism. Administration and Policy in Mental Health and Mental Health Services Research. 2007;34(1):29-37. X-4. [pmid: 16758329].
244 Stichter JP, Crider G, Moody M, et al. Developing an Outcome-Based Curricular Framework for Employing Evidence-Based Practices in Autism. Beyond Behavior. 2007;16(2):3-17. X-3, X-4.
245 Tomchek SD, Dunn W. Sensory processing in children with and without autism: A comparative study using the Short Sensory Profile. American Journal of Occupational Therapy. 2007;61(2):190-200. X-5. [pmid: 17436841].
246 van Ijzendoorn MH, Rutgers AH, Bakermans-Kranenburg MJ, et al. Parental sensitivity and attachment in children with autism spectrum disorder: Comparison with children with mental retardation, with language delays, and with typical development. Child Development. 2007;78(2):597-608. X-5. [pmid: 17381792].
247 Walpole CW, Roscoe EM, Dube WV. Use of a Differential Observing Response to Expand Restricted Stimulus Control. Journal of Applied Behavior Analysis. 2007;40(4):707-12. X-3. [pmid: 18189104].
248 Webb SJ, Nalty T, Munson J, et al. Rate of head circumference growth as a function of autism diagnosis and history of autistic regression. Journal of Child Neurology. 2007;22(10):1182-90. X-5. [pmid: 17940244].
249 Woo EJ, Ball R, Landa R, et al. Developmental regression and autism reported to the Vaccine Adverse Event Reporting System. Autism. 2007;11(4):301-10. X-5. [pmid: 17656395].
250 Zambolin K, Fabrizio M, Ferris K, et al. Tracking Teachers' Behavior to Concurrently Decrease Punishment Use with and Problem Behavior in a Child with Autism while Decreasing the Child's Frequency of Negative Statements. Journal of Precision Teaching and Celeration. 2007;23:27-9. X-3.
251 Barcia G, Posar A, Santucci M, et al. Autism and coeliac disease. Journal of Autism and Developmental Disorders. 2008;38(2):407-8. X-2, X-5. [pmid: 17985220].
252 Bauminger N, Solomon M, Aviezer A, et al. Children with autism and their friends: A multidimensional study of friendship in high-functioning autism spectrum disorder. Journal of Abnormal Child Psychology. 2008;36(2):135-50. X-5. [pmid: 18172754].
253 Bevan-Brown J, Carroll-Lind J, Kearney A, et al. Making Assumptions vs. Building Relationships: Lessons from a Participatory Action Research Project to Identify Effective Practices for Learners with Autism Spectrum Disorder. Kairaranga. 2008;9:22-31. X-3, X-5.
254 Bloh C. Assessing Transfer of Stimulus Control Procedures across Learners with Autism. Analysis of Verbal Behavior. 2008;24:87-101. X-3. [pmid: 22477406].
255 Boyd BA, Conroy MA, Asmus JM, et al. Descriptive Analysis of Classroom Setting Events on the Social Behaviors of Children with Autism Spectrum Disorder. Education and Training in Developmental Disabilities. 2008;43(2):186-97. X-3, X-5.
256 Bradley LA, Krakowski B, Thiessen A. With Little Research out There It's a Matter of Learning What Works in Teaching Students with Deafness and Autism. Odyssey: New Directions in Deaf Education. 2008;9(1):16-8. X-2, X-5.
257 Cahill SM. Teaching Organizational Skills through Self-Regulated Learning Strategies. TEACHING Exceptional Children Plus. 2008;5(1):1-9. X-5.
258 Cain J. Teaming from Three Perspectives: Interviews with Participatory Action Research Participants. Kairaranga. 2008;9:43-5. X-3, X-5.
259 Dahlgren S, Sandberg AD. Referential communication in children with autism spectrum disorder. Autism. 2008;12(4):335-48. X-5. [pmid: 18579643].
260 Dawson G. Early behavioral intervention, brain plasticity, and the prevention of autism spectrum disorder. Dev Psychopathol. Summer. 2008;20(3):775-803. X-5. [pmid: 18606031].
261 Delano ME, Stone L. Extending the Use of Social Stories to Young Children with Emotional and Behavioral Disabilities. Beyond Behavior. 2008;18(1):2-8. X-1, X-3, X-4.
262 DeVincent C, Gadow KD, Strong G, et al. Screening for autism spectrum disorder with the Early Childhood Inventory-4. Journal of Developmental and Behavioral Pediatrics. 2008;29(1):1-10. X-5. [pmid: 18300725].
263 Dodd S, Hupp SDA, Jewell JD, et al. Using parents and siblings during a social story intervention for two children diagnosed with PDD-NOS. Journal of Developmental and Physical Disabilities. 2008;20(3):217-29. X-3.
264 Fitzgerald PB, Herring S, Hoy K, et al. A study of the effectiveness of bilateral transcranial magnetic stimulation in the treatment of the negative symptoms of schizophrenia. Brain Stimul. Jan. 2008;1(1):27-32. X-5. [pmid: 20633367].
265 Gita S, Bognar J, Kalbli K, et al. Comparative Study on Inclusive and Special Education Curricula in Hungary. Physical Education and Sport. 2008;52:16-22. X-1, X-3, X-4.
266 Hartwig Moorhead HJ, Green J, McQuistion RR, et al. Wellness Interventions for School Counselors: A Case-Study in Treating Asperger's Disorder. Journal of School Counseling. 2008;6(1):1-33. X-5.
267 Hasselbusch A, Penman M. Working Together: An Occupational Therapy Perspective on Collaborative Consultation. Kairaranga. 2008;9(1):24-31. X-1, X-3, X-4.
268 Hergüner S, Mukaddes NM. Risperidone-induced double incontinence. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2008;32(4):1085-6. X-3. [pmid: 18387724].
269 Hines E, Simonsen B. The Effects of Picture Icons on Behavior for a Young Student with Autism. Beyond Behavior. 2008;18(1):9-17. X-3.
270 Jurecka A, Tylki-Szymanska A, Zikanova M, et al. D-ribose therapy in four Polish patients with adenylosuccinate lyase deficiency: absence of positive effect. J Inherit Metab Dis. Dec. 2008;31(Suppl 2):S329-32. X-5. [pmid: 18649008].
271 Kelly A. What Works for One: Practice Considerations for Supporting a Child or Young Person with Autism Spectrum Disorder, Drawn from Participatory Action Research. Kairaranga. 2008;9:54-60. X-1, X-3, X-4.
272 Kuhn LR, Bodkin AE, Devlin SD, et al. Using Pivotal Response Training with Peers in Special Education to Facilitate Play in Two Children with Autism. Education and Training in Developmental Disabilities. 2008;43(1):37-45. X-3.
273 Lattimore LP, Parsons MB, Reid DH. Simulation training of community job skills for adults with autism: A further analysis. Behavior Analysis in Practice. 2008;1(1):24-9. X-5. [pmid: 22477676].
274 Lerman DC, Sansbury T, Hovanetz A, et al. Using behavior analysis to examine the outcomes of unproven therapies: An evaluation of hyperbaric oxygen therapy for children with autism. Behavior Analysis in Practice. 2008;1(2):50-8. X-3. [pmid: 22477688].
275 Lindsey-Glenn PF, Gentry JE. Improving Vocabulary Skills through Assistive Technology: Rick's Story. TEACHING Exceptional Children Plus. 2008;5(2):1-11. X-3.
276 Loiacono V, Allen B. Are Special Education Teachers Prepared to Teach the Increasing Number of Students Diagnosed with Autism?. International Journal of Special Education. 2008;23(2):120-7. X-4, X-5.
277 Loth E, Gómez JC, Happé F. Detecting changes in naturalistic scenes: Contextual inconsistency does not influence spontaneous attention in high-functioning people with autism spectrum disorder. Autism Research. 2008;1(3):179-88. X-5. [pmid: 19360664].
278 Matson JL, Ancona MN, Wilkins J. Sleep Disturbances in Adults with Autism Spectrum Disorders and Severe Intellectual Impairments. Journal of Mental Health Research in Intellectual Disabilities. 2008;1(3):129-39. X-5.
279 Matson JL, Gonzalez ML, Rivet TT. Reliability of the Autism Spectrum Disorder-Behavior Problems for Children (ASD-BPC). Research in Autism Spectrum Disorders. 2008;2(4):696-706. X-4, X-5.
280 Medhurst B, Clay D. The Thomas Outreach Project (TOP): An Early Years Intervention for Children with an Autistic Spectrum Disorder (ASD). Educational Psychology in Practice. 2008;24(1):69-78. X-1, X-2, X-3, X-4.
281 Morgan L, Wetherby AM, Barber A. Repetitive and stereotyped movements in children with autism spectrum disorders late in the second year of life. Journal of Child Psychology and Psychiatry. 2008;49(8):826-37. X-5. [pmid: 18503532].
282 Najdowski AC, Wallace MD, Penrod B, et al. Caregiver-Conducted Experimental Functional Analyses of Inappropriate Mealtime Behavior. Journal of Applied Behavior Analysis. 2008;41(3):459-65. X-3, X-4. [pmid: 18816987].
283 Ozonoff S, Macari S, Young GS, et al. Atypical object exploration at 12 months of age is associated with autism in a prospective sample. Autism. 2008;12(5):457-72. X-5. [pmid: 18805942].
284 Petursdottir AI, Carr JE, Lechago SA, et al. An Evaluation of Intraverbal Training and Listener Training for Teaching Categorization Skills. Journal of Applied Behavior Analysis. 2008;41(1):53-68. X-1, X-3, X-4. [pmid: 18468279].
285 Reichle J, Dropik PL, Alden-Anderson E, et al. Teaching a Young Child with Autism to Request Assistance Conditionally: A Preliminary Study. American Journal of Speech-Language Pathology. 2008;17(3):231-40. X-3. [pmid: 18663108].
286 Robertson MA, Sigalet DL, Holst JJ, et al. Intestinal Permeability and Glucagon-like peptide-2 in Children with Autism: A Controlled Pilot Study. Journal of Autism and Developmental Disorders. 2008;38(6):1066-71. X-5. [pmid: 18311517].
287 Russell AJ, Mataix-Cols D, Anson MAW, et al. Psychological treatment for obsessive-compulsive disorder in people with autism spectrum disorders—A pilot study. Psychotherapy and Psychosomatics. 2008;78(1):59-61. X-5. [pmid: 19018159].
288 Salter G, Seigal A, Claxton M, et al. Can autistic children read the mind of an animated triangle?. Autism. 2008;12(4):349-71. X-4, X-5. [pmid: 18579644].
289 Schechter R, Grether JK. Continuing increases in autism reported to California's developmental services system: Mercury in retrograde. Archives of General Psychiatry. 2008;65(1):19-24. X-5. [pmid: 18180424].
290 Silverman MJ. Nonverbal Communication, Music Therapy, and Autism: A Review of Literature and Case Example. Journal of Creativity in Mental Health. 2008;3(1):3-19. X-2, X-5.
291 Simpson RL. Children and Youth with Autism Spectrum Disorders: The Search for Effective Methods. Focus on Exceptional Children. March. 2008. 2008;40(7):1. X-5.
292 Skokauskas N, Moran T. Role of CAMHS in assessing children with suspected autism-spectrum disorder in Ireland. Psychiatric Bulletin. 2008;32(10):394. X-5.
293 Smith L. Ethical Principles in Practice: Evidence from Participatory Action Research. Kairaranga. 2008;9:16-21. X-5.
294 Stock RA, Schulze KA, Mirenda P. A Comparison of Stimulus-Stimulus Pairing, Standard Echoic Training, and Control Procedures on the Vocal Behavior of Children with Autism. Analysis of Verbal Behavior. 2008;24:123-33. X-3. [pmid: 22477408].
295 Szymanski C, Brice PJ. When Autism and Deafness Coexist in Children: What We Know Now. Odyssey: New Directions in Deaf Education. 2008;9(1):10-5. X-5.
296 Vedora J, Ross R, Kelm K. Feeding Frenzy: Using Picture Schedules to Reduce Mealtime Struggles. TEACHING Exceptional Children Plus. 2008;4(6):1-11. X-3.
297 Weiss MJ, Fabrizio M, Bamond M. Skill Maintenance and Frequency Building: Archival Data from Individuals with Autism Spectrum Disorders. Journal of Precision Teaching and Celeration. 2008;24:28-37. X-1, X-3, X-4.
298 Williams KE, Hendy H, Knecht S. Parent feeding practices and child variables associated with childhood feeding problems. Journal of Developmental and Physical Disabilities. 2008;20(3):231-42. X-5.
299 Yeh-Kennedy M. Brady, Our Firstborn Son, Has Autism. Odyssey: New Directions in Deaf Education. 2008;9(1):26-30. X-5.
300 Young HA, Geier DA, Geier MR. Thimerosal exposure in infants and neurodevelopmental disorders: An assessment of computerized medical records in the Vaccine Safety Datalink. Journal of the Neurological Sciences. 2008;271(1-2):110-8. X-5. [pmid: 18482737].
301 Ager S, Downs J, Fyfe S, et al. Parental experiences of scoliosis management in Rett syndrome. Disability and Rehabilitation: An International, Multidisciplinary Journal. 2009;31(23):1917-24. X-5.
302 Alwell M, Cobb B. Social and Communicative Interventions and Transition Outcomes for Youth with Disabilities: A Systematic Review. Career Development for Exceptional Individuals. 2009;32(2):94-107. X-1, X-3, X-4.
303 Amend ER, Schuler P, Beaver-Gavin K, et al. A Unique Challenge: Sorting out the Differences between Giftedness and Asperger's Disorder. Gifted Child Today. 2009;32(4):57-63. X-5.
304 Ames CS, Jarrold C. Identifying symbolic relationships in autism spectrum disorders: a deficit in the identification of temporal co-occurrence?. J Autism Dev Disord. Dec. 2009;39(12):1723-34. X-5. [pmid: 19593646].
305 Asaro K, Saddler B. Effects of Planning Instruction on a Young Writer with Asperger Syndrome. Intervention in School and Clinic. 2009;44(5):268-75. X-3.
306 Atladóttir HÓ, Pedersen MG, Thorsen P, et al. Association of family history of autoimmune diseases and autism spectrum disorders. Pediatrics. 2009;124(2):687-94. X-5. [pmid: 19581261].
307 Bellini S, Benner L, Peters-Myszak J. A Systematic Approach to Teaching Social Skills to Children with Autism Spectrum Disorders: A Guide for Practitioners. Beyond Behavior. 2009;19(1):26-39. X-1, X-2, X-3, X-4.
308 Benavides CA, Poulson CL. Task Interspersal and Performance of Matching Tasks by Preschoolers with Autism. Research in Autism Spectrum Disorders. 2009;3(3):619-29. X-3.
309 Boulet SL, Boyle CA, Schieve LA. Health care use and health and functional impact of developmental disabilities among US children, 1997-2005. Arch Pediatr Adolesc Med. Jan. 2009;163(1):19-26. X-5. [pmid: 19124699].
310 Campbell DB, Buie TM, Winter H, et al. Distinct genetic risk based on association of MET in families with co-occurring autism and gastrointestinal conditions. Pediatrics. 2009;123(3):1018-24. X-5. [pmid: 19255034].
311 Carter SL. Recent Trends in Conducting School-Based Experimental Functional Analyses. International Journal of Behavioral Consultation and Therapy. 2009;5(2):185-91. X-2.
312 Chan AL, Wang MT, Su CY, et al. Risk of digoxin intoxication caused by clarithromycin-digoxin interactions in heart failure patients: a population-based study. Eur J Clin Pharmacol. Dec. 2009;65(12):1237-43. X-5. [pmid: 19655133].
313 Chappell N, Graff RB, Libby ME, et al. Further Evaluation of the Effects of Motivating Operations on Preference Assessment Outcomes. Research in Autism Spectrum Disorders. 2009;3(3):660-9. X-3.
314 Daniel KL, Prue C, Taylor MK, et al. ‘Learn the signs. Act early’: A campaign to help every child reach his or her full potential. Public Health. 2009;123(Suppl 1):e11-e6. X-1, X-3, X-4. [pmid: 19767041].
315 Darrow A-A. Adapting for Students with Autism. General Music Today. 2009;22(2):24-6. X-5.
316 DeLeon IG, Frank MA, Gregory MK, et al. On the Correspondence between Preference Assessment Outcomes and Progressive-Ratio Schedule Assessments of Stimulus Value. Journal of Applied Behavior Analysis. 2009;42(3):729-33. X-5. [pmid: 20190936].
317 Delgado CE. Fourth Grade Outcomes of Children with a Preschool History of Developmental Disability. Education and Training in Developmental Disabilities. 2009;44(4):573-9. X-5.
318 Dorminy KP, Luscre D, Gast DL. Teaching organizational skills to children with high functioning autism and Asperger's syndrome. Education and Training in Developmental Disabilities. 2009;44(4):538-50. X-3.
319 Eikeseth S, Hayward DW. The Discrimination of Object Names and Object Sounds in Children with Autism: A Procedure for Teaching Verbal Comprehension. Journal of Applied Behavior Analysis. 2009;42(4):807-12. X-3, X-5. [pmid: 20514186].
320 Foto Özdemir D, Ilgın Karabacak N, Akkaş BE, et al. Differences in cerebral blood flow following risperidone treatment in children with autistic disorder. Türk Psikiyatri Dergisi. 2009;20(4):1-9. X-6. [pmid: 19306120].
321 Fox RA, Holtz CA, Moist AM. A community-based accommodation program for adults with autism and mental retardation. Education and Training in Developmental Disabilities. 2009;44(1):118-26. X-5.
322 François D, Powell S, Dautenhahn K. A long-term study of children with autism playing with a robotic pet: Taking inspirations from non-directive play therapy to encourage children's proactivity and initiative-taking. Interaction Studies: Social Behaviour and Communication in Biological and Artificial Systems. 2009;10(3):324-73. X-3.
323 Geller E, Foley GM. Expanding the “Ports of Entry” for Speech-Language Pathologists: A Relational and Reflective Model for Clinical Practice. American Journal of Speech-Language Pathology. 2009;18(1):4-21. X-5. [pmid: 18845696].
324 Gerhard T, Chavez B, Olfson M, et al. National patterns in the outpatient pharmacological management of children and adolescents with autism spectrum disorder. Journal of Clinical Psychopharmacology. 2009;29(3):307-10. X-4. [pmid: 19440093].
325 Glaze DG, Percy AK, Motil KJ, et al. A study of the treatment of Rett syndrome with folate and betaine. Journal of Child Neurology. 2009;24(5):551-6. X-5. [pmid: 19225139].
326 Goin-Kochel RP, Mackintosh VH, Myers BJ. Parental reports on the efficacy of treatments and therapies for their children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2009;3(2):528-37. X-4.
327 Granpeesheh D, Dixon DR, Tarbox J, et al. The Effects of Age and Treatment Intensity on Behavioral Intervention Outcomes for Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2009;3(4):1014-22. X-5.
328 Gregory MK, DeLeon IG, Richman DM. The Influence of Matching and Motor-Imitation Abilities on Rapid Acquisition of Manual Signs and Exchange-Based Communicative Responses. Journal of Applied Behavior Analysis. 2009;42(2):399-404. X-3. [pmid: 19949531].
329 Grenwelge CH. Test Review: Woodcock, R. W., Schrank, F. A., Mather, N., & McGrew, K. S. 2007). “Woodcock-Johnson III Tests of Achievement, Form C/Brief Battery.” Rolling Meadows, IL: Riverside. Journal of Psychoeducational Assessment. 2009;27(4):345-50. X-5.
330 Griffith PS, Powlett CL, Griffith AD, et al. An exploratory analysis of the epidemiology and surgical management of perforated diverticular disease over a two-year period at a referral centre in the Caribbean. West Indian Med J. Dec. 2009;58(6):561-5. X-1, X-3, X-4, X-5. [pmid: 20583683].
331 Gustafsson C, Ojehagen A, Hansson L, et al. Effects of Psychosocial Interventions for People with Intellectual Disabilities and Mental Health Problems: A Survey of Systematic Reviews. SAGE Publications. 2455 Teller Road, Thousand Oaks, CA 91320. 2009:281-90. X-4.
332 Gutierrez A, Hale MN, O'Brien HA, et al. Evaluating the Effectiveness of Two Commonly Used Discrete Trial Procedures for Teaching Receptive Discrimination to Young Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2009;3(3):630-8. X-3.
333 Hallahan B, Daly EM, McAlonan G, et al. Brain morphometry volume in autistic spectrum disorder: A magnetic resonance imaging study of adults. Psychological Medicine. 2009;39(2):337-46. X-5. [pmid: 18775096].
334 Hammerschlag CA. Autistic rider. Caring. Aug. 2009;28(8):62. X-5. [pmid: 19772030].
335 Hartley SL, Sikora DM. Sex Differences in Autism Spectrum Disorder: An Examination of Developmental Functioning, Autistic Symptoms, and Coexisting Behavior Problems in Toddlers. Journal of Autism and Developmental Disorders. 2009;39(12):1715-22. X-5. [pmid: 19582563].
336 Hayward DW, Gale CM, Eikeseth S. Intensive Behavioural Intervention for Young Children with Autism: A Research-Based Service Model. Research in Autism Spectrum Disorders. 2009;3(3):571-80. X-5.
337 Herscovitch B, Roscoe EM, Libby ME, et al. A Procedure for Identifying Precursors to Problem Behavior. Journal of Applied Behavior Analysis. 2009;42(3):697-702. X-5. [pmid: 20190931].
338 Jeste SS, Nelson CA. Event Related Potentials in the Understanding of Autism Spectrum Disorders: An Analytical Review. Springer. 233 Spring Street, New York, NY 10013. 2009:495-510. X-4.
339 Keen D. Engagement of Children with Autism in Learning. Australasian Journal of Special Education. October. 2009. 2009;33(2):130-40. X-5.
340 Kishida Y, Kemp C. The engagement and interaction of children with autism spectrum disorder in segregated and inclusive early childhood center-based settings. Topics in Early Childhood Special Education. 2009;29(2):105-18. X-4.
341 Kodak T, Clements A. Acquisition of Mands and Tacts with Concurrent Echoic Training. Journal of Applied Behavior Analysis. 2009;42(4):839-43. X-3. [pmid: 20514191].
342 Kozima H, Michalowski MP, Nakagawa C. Keepon: A playful robot for research, therapy, and entertainment. International Journal of Social Robotics. 2009;1(1):3-18. X-3, X-4.
343 Kroeger AK, Sorensen-Burnworth R. Toilet Training Individuals with Autism and Other Developmental Disabilities: A Critical Review. 2009;3:607-18. X-5.
344 Kurt O, Parsons C. Improving Classroom Learning: The Effectiveness of Time Delay within the TEACCH Approach. International Journal of Special Education. 2009;24(3):173-85. X-3.
345 Lancioni GE, Singh NN, O'Reilly MF, et al. Microswitch- and VOCA-Assisted Programs for Two Post-Coma Persons with Minimally Conscious State and Pervasive Motor Disabilities. Research in Developmental Disabilities: A Multidisciplinary Journal. 2009;30(6):1459-67. X-5.
346 Lang R, Machalicek W, O'Reilly M, et al. Review of Interventions to Increase Functional and Symbolic Play in Children with Autism. Education and Training in Developmental Disabilities. 2009;44(4):481-92. X-1, X-2, X-3, X-4.
347 Lattimore LP, Parsons MB, Reid DH. Rapid training of a community job skill to nonvocal adults with autism: An extension of intensive teaching. Behavior Analysis in Practice. 2009;2(1):34-42. X-5. [pmid: 22477694].
348 Levingston HB, Neef NA, Cihon TM. The Effects of Teaching Precurrent Behaviors on Children's Solution of Multiplication and Division Word Problems. Journal of Applied Behavior Analysis. 2009;42(2):361-7. X-3, X-5. [pmid: 19949525].
349 Lunsky Y, Gracey C, Bradley E. Adults with autism spectrum disorders using psychiatric hospitals in Ontario: Clinical profile and service needs. Research in Autism Spectrum Disorders. 2009;3(4):1006-13. X-5.
350 MacDonald R, Sacramone S, Mansfield R, et al. Using Video Modeling to Teach Reciprocal Pretend Play to Children with Autism. Journal of Applied Behavior Analysis. 2009;42(1):43-55. X-3. [pmid: 19721729].
351 Machalicek W, O'Reilly M, Chan JM, et al. Using Videoconferencing to Conduct Functional Analysis of Challenging Behavior and Develop Classroom Behavioral Support Plans for Students with Autism. Education and Training in Developmental Disabilities. 2009;44(2):207-17. X-3.
352 Mancil RG. Milieu Therapy as a Communication Intervention: A Review of the Literature Related to Children with Autism Spectrum Disorder. Division on Developmental Disabilities, Council for Exceptional Children. DDD, P.O. Box 3512, Fayetteville, AR 72702. 2009:105-17. X-4.
353 Martin N. Art Therapy and Autism: Overview and Recommendations. Art Therapy: Journal of the American Art Therapy Association. 2009. 2009;26(4):187-90. X-5.
354 Matson JL, Fodstad JC. The Treatment of Food Selectivity and Other Feeding Problems in Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2009;3(2):455-61. X-1, X-2, X-3, X-4.
355 Matson JL, Fodstad JC, Dempsey T. The Relationship of Children's Feeding Problems to Core Symptoms of Autism and PDD-NOS. Research in Autism Spectrum Disorders. 2009;3(3):759-66. X-5.
356 Matson JL, Fodstad JC, Mahan S, et al. Cutoffs, Norms, and Patterns of Comorbid Difficulties in Children with an ASD on the Baby and Infant Screen for Children with aUtIsm Traits (BISCUIT-Part 2). Research in Autism Spectrum Disorders. 2009;3(4):977-88. X-5.
357 McGarrell M, Healy O, Leader G, et al. Six reports of children with autism spectrum disorder following intensive behavioral intervention using the preschool inventory of repertoires for kindergarten (PIRK®). Research in Autism Spectrum Disorders. 2009;3(3):767-82. X-3.
358 McGarrell M, Healy O, Leader G, et al. Six Reports of Children with Autism Spectrum Disorder Following Intensive Behavioral Intervention Using the Preschool Inventory of Repertoires for Kindergarten (PIRK[R]). Research in Autism Spectrum Disorders. 2009;3(3):767-82. X-3.
359 Meadan H, Ostrosky MM, Zaghlawan HY, et al. Promoting the Social and Communicative Behavior of Young Children with Autism Spectrum Disorders: A Review of Parent-Implemented Intervention Studies. SAGE Publications and Hammill Institute on Disabilities. 2455 Teller Road, Thousand Oaks, CA 91320. 2009:90-104. X-1, X-2, X-3, X-4.
360 Moore TR. A brief report on the effects of a self-management treatment package on stereotypic behavior. Research in Autism Spectrum Disorders. 2009;3(3):695-701. X-5.
361 Morris EK. A Case Study in the Misrepresentation of Applied Behavior Analysis in Autism: The Gernsbacher Lectures. Behavior Analyst. 2009;32(1):205-40. X-5. [pmid: 22478522].
362 Noggle CA, Dean RS. Atypical and Typical Antipsychotics in the Schools. Psychology in the Schools. 2009;46(9):869-84. X-1, X-2, X-3, X-4.
363 Oblak A, Gibbs TT, Blatt GJ. Decreased GABAA receptors and benzodiazepine binding sites in the anterior cingulate cortex in autism. Autism Research. 2009;2(4):205-19. X-5. [pmid: 19650112].
364 O'Connor E. The Use of Social Story DVDs to Reduce Anxiety Levels: A Case Study of a Child with Autism and Learning Disabilities. Support for Learning. 2009;24(3):133-6. X-3.
365 O'Reilly M, Lang R, Davis T, et al. A Systematic Examination of Different Parameters of Presession Exposure to Tangible Stimuli that Maintain Problem Behavior. Journal of Applied Behavior Analysis. 2009;42(4):773-83. X-3, X-5. [pmid: 22102760].
366 Orvalho V, Miranda J, Sousa AA. Facial synthesys of 3D avatars for therapeutic applications. Annual Review of CyberTherapy and Telemedicine. 2009;7:96-8. X-1, X-3.
367 Ozonoff S, Young GS, Steinfeld MB, et al. How early do parent concerns predict later autism diagnosis?. Journal of Developmental and Behavioral Pediatrics. 2009;30(5):367-75. X-5. [pmid: 19827218].
368 Pence ST, Roscoe EM, Bourret JC, et al. Relative Contributions of Three Descriptive Methods: Implications for Behavioral Assessment. Journal of Applied Behavior Analysis. 2009;42(2):425-46. X-5. [pmid: 19949536].
369 Pennington RC. Exploring New Waters: Writing Instruction for Students with Autism Spectrum Disorders. Beyond Behavior. 2009;19(1):17-25. X-5.
370 Planty M, Hussar W, Snyder T, et al. The Condition of Education 2009: Indicator 9--Children and Youth With Disabilities. NCES 2009-081. National Center for Education Statistics. P.O. Box 1398, Jessup, MD 20794-1398. 2009:5. X-4.
371 Reeb RN, Folger SF, Oneal BJ. Behavioral Summarized Evaluation: An assessment tool to enhance multidisciplinary and parent-professional collaborations in assessing symptoms of autism. Children's Health Care. 2009;38(4):301-20. X-5.
372 Remington A, Swettenham J, Campbell R, et al. Selective attention and perceptual load in autism spectrum disorder. Psychological Science. 2009;20(11):1388-93. X-5. [pmid: 19843262].
373 Rojahn J, Matson JL, Mahan S, et al. Cutoffs, Norms, and Patterns of Problem Behaviors in Children with an ASD on the Baby and Infant Screen for Children with aUtIsm Traits (BISCUIT-Part 3). Research in Autism Spectrum Disorders. 2009;3(4):989-98. X-5.
374 Roscoe EM, Rooker GW, Pence ST, et al. Assessing the Utility of a Demand Assessment for Functional Analysis. Journal of Applied Behavior Analysis. 2009;42(4):819-25. X-5. [pmid: 20514188].
375 Ruef MB, Nefdt N, Openden D, et al. Learn by Doing: A Collaborative Model for Training Teacher-Candidate Students in Autism. Education and Training in Developmental Disabilities. 2009;44(3):343-55. X-1, X-3, X-4.
376 Schneider A, Hagerman JR, Hessl D. Fragile X Syndrome--From Genes to Cognition. Developmental Disabilities Research Reviews. 2009;15(4):333-42. X-5. [pmid: 20014363].
377 Schumann CM, Barnes CC, Lord C, et al. Amygdala enlargement in toddlers with autism related to severity of social and communication impairments. Biological Psychiatry. 2009;66(10):942-9. X-5. [pmid: 19726029].
378 Sharp WG, Jaquess DL. Bite size and texture assessments to prescribe treatment for severe food selectivity in autism. Behavioral Interventions. 2009;24(3):157-70. X-3.
379 Shih A, Rosanoff M, Wallace S, et al. Autism Speaks Global Autism Public Health Initiative: Bridging gaps in autism awareness, research, and services around the world. Beijing Da Xue Xue Bao. Aug. 18. 2009;41(4):389-91. X-5. [pmid: 19845067].
380 Shillingsburg AM, Kelley ME, Roane HS, et al. Evaluation and Training of Yes-No Responding across Verbal Operants. Journal of Applied Behavior Analysis. 2009;42(2):209-23. X-3. [pmid: 19949510].
381 Shumway S, Wetherby AM. Communicative acts of children with autism spectrum disorders in the second year of life. Journal of Speech, Language, and Hearing Research. 2009;52(5):1139-56. X-5.
382 Sutherland S, Stroot SA. Brad's story: Exploration of an inclusive adventure education experience. Therapeutic Recreation Journal. 2009;43(3):27-39. X-5.
383 Sy JR, Borrero JC. Parametric Analysis of Presession Exposure to Edible and Nonedible Stimuli. Journal of Applied Behavior Analysis. 2009;42(4):833-7. X-5. [pmid: 20514190].
384 Tarbox J, Madrid W, Aguilar B, et al. Use of chaining to increase complexity of echoics in children with autism. J Appl Behav Anal. Winter. 2009;42(4):901-6. X-3. [pmid: 20514201].
385 Temudo T, Rios M, Prior C, et al. Evaluation of CSF neurotransmitters and folate in 25 patients with Rett disorder and effects of treatment. Brain & Development. 2009;31(1):46-51. X-5. [pmid: 18572337].
386 Thomson K, Martin GL, Arnal L, et al. Instructing Individuals to Deliver Discrete-Trials Teaching to Children with Autism Spectrum Disorders: A Review. Research in Autism Spectrum Disorders. 2009;3(3):590-606. X-5.
387 Tincani M, Travers J, Boutot A. Race, Culture, and Autism Spectrum Disorder: Understanding the Role of Diversity in Successful Educational Interventions. Research and Practice for Persons with Severe Disabilities (RPSD). 2009;34(3):1-10. X-1, X-2, X-3, X-4.
388 Van Rie GL, Heflin LJ. The effect of sensory activities on correct responding for children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2009;3(3):783-96. X-3.
389 Vilardaga R. A Relational Frame Theory Account of Empathy. International Journal of Behavioral Consultation and Therapy. 2009;5(2):178-84. X-5.
390 Wang P, Spillane A. Evidence-Based Social Skills Interventions for Children with Autism: A Meta-Analysis. Education and Training in Developmental Disabilities. 2009;44(3):318-42. X-5.
391 Webb SJ, Jones EJ. Early Identification of Autism: Early Characteristics, Onset of Symptoms, and Diagnostic Stability. Infants and Young Children. 2009;22(2):100-18. X-5.
392 Weeden M, Ehrhardt K, Poling A. Conspicuous by Their Absence: Studies Comparing and Combining Risperidone and Applied Behavior Analysis to Reduce Challenging Behavior in Children with Autism. Research in Autism Spectrum Disorders. 2009;3(4):905-12. X-5.
393 Weiss MJ, DelPizzo-Cheng E, LaRue RH, et al. ABA and PBS: The Dangers in Creating Artificial Dichotomies in Behavioral Intervention. Behavior Analyst Today. 2009;10(3):1-12. X-5.
394 Whitby PJ, Mancil RG. Academic Achievement Profiles of Children with High Functioning Autism and Asperger Syndrome: A Review of the Literature. Division on Developmental Disabilities, Council for Exceptional Children. DDD, P.O. Box 3512, Fayetteville, AR 72702. 2009:551-60. X-2, X-4.
395 Whitby PJ, Travers JC, Harnik J. Academic Achievement and Strategy Instruction to Support the Learning of Children with High-Functioning Autism. Beyond Behavior. 2009;19(1):3-9. X-2, X-5.
396 Whittingham K, Sofronoff K, Sheffield J, et al. Behavioural Family Intervention with Parents of Children with ASD: What Do They Find Useful in the Parenting Program Stepping Stones Triple P?. Research in Autism Spectrum Disorders. 2009. 2009;3(3):702-13. X-5.
397 Wilder DA, Register M, Register S, et al. Functional Analysis and Treatment of Rumination Using Fixed-Time Delivery of a Flavor Spray. Journal of Applied Behavior Analysis. 2009;42(4):877-82. X-5. [pmid: 20514197].
398 Wolfe PS, Condo B, Hardaway E. Sociosexuality Education for Persons with Autism Spectrum Disorders Using Principles of Applied Behavior Analysis. TEACHING Exceptional Children. 2009;42(1):50-61. X-1, X-2, X-3, X-4.
399 Wood JJ, McLeod BD, Piacentini JC, et al. One-year follow-up of family versus child CBT for anxiety disorders: Exploring the roles of child age and parental intrusiveness. Child Psychiatry Hum Dev. Jun. 2009;40(2):301-16. X-5. [pmid: 19165592].
400 Young A, Ruble L, McGrew J. Public vs. private insurance: Cost, use, accessibility, and outcomes of services for children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2009;3(4):1023-33. X-4, X-5.
401 Massachusetts & New Hampshire. Insurance; autism spectrum disorders. Ment Phys Disabil Law Rep. Sep-Oct. 2010;34(5):812. X-5. [pmid: 21197720].
402 Autism spectrum disorders. Diagnosis and management involve time and patience. Harv Ment Health Lett. Sep. 2010;27(3):4-5. X-5. [pmid: 20941863].
403 Autism spectrum disorders and the gut. Consensus recommendations for evaluation and treatment. Harv Ment Health Lett. Apr. 2010;26(10):4. X-5. [pmid: 20499455].
404 Effectiveness of Group Cognitive-Behavioural Treatment for Men with Intellectual Disabilities at Risk of Sexual Offending. Journal of Applied Research in Intellectual Disabilities. November. 2010;23(6):537-51. X-5.
405 Questions on Verbal Behavior and Its Application to Individuals with Autism: An Interview with the Experts. Behavior Analyst Today. 2010. 2010;11(3):186-205. X-5.
406 Adamo SM. On Not Being Able to Enter Noah's Ark. Journal of Child Psychotherapy. 2010;36(1):48-60. X-5.
407 Adnani N. Design and clinical implementation of a TG-106 compliant linear accelerator data management system and MU calculator. J Appl Clin Med Phys. 2010;11(3):3212. X-5. [pmid: 20717087].
408 Agam Y, Joseph RM, Barton JJ, et al. Reduced cognitive control of response inhibition by the anterior cingulate cortex in autism spectrum disorders. Neuroimage. Aug. 1. 2010;52(1):336-47. X-5. [pmid: 20394829].
409 Agyapong V, Migone M, Crosson C, et al. Recognition and management of Asperger's syndrome: Perceptions of primary school teachers. Irish Journal of Psychological Medicine. 2010;27(1):6-10. X-5.
410 Akshoomoff N, Stahmer AC, Corsello C, et al. What Happens Next? Follow-Up from the Children's Toddler School Program. Journal of Positive Behavior Interventions. 2010;12(4):245-53. X-5. [pmid: 21113315].
411 Alexander RT, Green FN, O'Mahony B, et al. Personality disorders in offenders with intellectual disability: a comparison of clinical, forensic and outcome variables and implications for service provision. J Intellect Disabil Res. Jul. 2010;54(7):650-8. X-5. [pmid: 20136682].
412 Allen KD, Wallace DP, Greene DJ, et al. Community-based vocational instruction using videotaped modeling for young adults with Autism Spectrum Disorders performing in air-inflated mascots. Focus on Autism and Other Developmental Disabilities. 2010;25(3):186-92. X-5.
413 Allen KD, Wallace DP, Renes D, et al. Use of video modeling to teach vocational skills to adolescents and young adults with autism spectrum disorders. Education & Treatment of Children. 2010;33(3):339-49. X-5.
414 Al-Shammari Z, Daniel C, Faulkner P, et al. Improving Inappropriate Social Behavior of Autistic Students Using the LISTEN Intervention Strategy. Journal of Instructional Psychology. 2010;37(4):286-94. X-1, X-3, X-4.
415 Alvarez A. Levels of analytic work and levels of pathology: the work of calibration. Int J Psychoanal. Aug. 2010;91(4):859-78. X-2, X-5. [pmid: 20840643].
416 Aman MG, Kasper W, Manos G, et al. Line-item analysis of the Aberrant Behavior Checklist: results from two studies of aripiprazole in the treatment of irritability associated with autistic disorder. J Child Adolesc Psychopharmacol. Oct. 2010;20(5):415-22. X-5. [pmid: 20973712].
417 Arieff Z, Kaur M, Gameeldien H, et al. 5-HTTLPR polymorphism: analysis in South African autistic individuals. Hum Biol. Jun. 2010;82(3):291-300. X-5. [pmid: 20649385].
418 Asberg J, Sandberg AD. Discourse Comprehension Intervention for High-Functioning Students with Autism Spectrum Disorders: Preliminary Findings from a School-Based Study. Journal of Research in Special Educational Needs. 2010;10(2):91-8. X-1, X-3, X-4.
419 Athens ES, Vollmer TR. An investigation of differential reinforcement of alternative behavior without extinction. J Appl Behav Anal. Winter. 2010;43(4):569-89. X-3. [pmid: 21541145].
420 Atladottir HO, Thorsen P, Ostergaard L, et al. Maternal infection requiring hospitalization during pregnancy and autism spectrum disorders. J Autism Dev Disord. Dec. 2010;40(12):1423-30. X-5. [pmid: 20414802].
421 Axe JB, Sainato DM. Matrix Training of Preliteracy Skills with Preschoolers with Autism. Journal of Applied Behavior Analysis. 2010;43(4):635-52. X-3. [pmid: 21541149].
422 Bagatell N, Mirigliani G, Patterson C, et al. Effectiveness of therapy ball chairs on classroom participation in children with autism spectrum disorders. Am J Occup Ther. Nov-Dec. 2010;64(6):895-903. X-3. [pmid: 21218680].
423 Baharav E, Reiser C. Using telepractice in parent training in early autism. Telemed J E Health. Jul-Aug. 2010;16(6):727-31. X-3. [pmid: 20583950].
424 Baker JK, Haltigan JD, Brewster R, et al. Non-expert ratings of infant and parent emotion: Concordance with expert coding and relevance to early autism risk. International Journal of Behavioral Development. 2010;34(1):88-95. X-5. [pmid: 20436947].
425 Baker N. Exploring the mental health nurse practitioner scope of practice in youth early psychosis: an anecdotal account. Contemp Nurse. Feb-Mar. 2010;34(2):211-20. X-5. [pmid: 20509805].
426 Banda DR, Copple KS, Koul RK, et al. Video modelling interventions to teach spontaneous requesting using AAC devices to individuals with autism: a preliminary investigation. Disabil Rehabil. 2010;32(16):1364-72. X-1, X-3, X-4. [pmid: 20465397].
427 Banda DR, Hart SL, Liu-Gitz L. Impact of Training Peers and Children with Autism on Social Skills during Center Time Activities in Inclusive Classrooms. Research in Autism Spectrum Disorders. 2010;4(4):619-25. X-3.
428 Bansal M, Chan J, Leano R, et al. Effects of perhexiline on myocardial deformation in patients with ischaemic left ventricular dysfunction. Int J Cardiol. Mar. 4. 2010;139(2):107-12. X-5. [pmid: 19840889].
429 Barba L. A one-stop shop for autism services. Behav Healthc. Jun. 28. 2010;30(6):30-1. X-1, X-2, X-3, X-4. [pmid: 20666201].
430 Baruth JM, Casanova MF, El-Baz A, et al. Low-frequency repetitive transcranial magnetic stimulation modulates evoked-gamma frequency oscillations in autism spectrum disorder. Journal of Neurotherapy. 2010;14(3):179-94. X-1, X-3, X-4. [pmid: 21116441].
431 Bellini S, McConnell LL. Strength-Based Educational Programming for Students with Autism Spectrum Disorders: A Case for Video Self-Modeling. Preventing School Failure. 2010;54(4):220-7. X-1, X-2, X-3, X-4.
432 Belotto KC, Raposo NR, Ferreira AS, et al. Relative bioavailability of two oral formulations of risperidone 2 mg: A single-dose, randomized-sequence, open-label, two-period crossover comparison in healthy Brazilian volunteers. Clin Ther. Nov. 2010;32(12):2106-15. X-5. [pmid: 21118746].
433 Ben Said M, Robel L, Vion E, et al. TEDIS: an information system dedicated to patients with pervasive developmental disorders. Stud Health Technol Inform. 2010;160(Pt 1):198-202. X-4, X-5. [pmid: 20841677].
434 Bennett K, Brady MP, Scott J, et al. The Effects of Covert Audio Coaching on the Job Performance of Supported Employees. Focus on Autism and Other Developmental Disabilities. 2010;25(3):173-85. X-5.
435 Berry-Kravis E, Raspa M, Loggin-Hester L, et al. Seizures in fragile X syndrome: characteristics and comorbid diagnoses. Am J Intellect Dev Disabil. Nov. 2010;115(6):461-72. X-5. [pmid: 20945999].
436 Bertoglio K, Jill James S, Deprey L, et al. Pilot study of the effect of methyl B12 treatment on behavioral and biomarker measures in children with autism. J Altern Complement Med. May. 2010;16(5):555-60. X-5. [pmid: 20804367].
437 Bevan-Brown J. Messages from Parents of Children with Autism Spectrum Disorder (ASD). Kairaranga. 2010;11(2):16-22. X-5.
438 Bhatara A, Quintin EM, Levy B, et al. Perception of emotion in musical performance in adolescents with autism spectrum disorders. Autism Res. Oct. 2010;3(5):214-25. X-5. [pmid: 20717952].
439 Biggs MJG, Simpson C, Gaus MD. Using a Team Approach to Address Bullying of Students with Asperger's Syndrome in Activity-Based Settings. Children & Schools. 2010;32(3):135-42. X-1, X-2, X-3, X-4.
440 Bishop DV. Which neurodevelopmental disorders get researched and why?. PLoS One. 2010;5(11):e15112. X-5. [pmid: 21152085].
441 Blacklock K, Perry A. Testing the application of benchmarks for children in Ontario's IBI program: Six case studies. Journal on Developmental Disabilities. 2010;16(2):33-43. X-3.
442 Blake KE. Spectrum disorders: a new generation of complex patients. Pa Nurse. Dec. 2010;65(4):9-11. 5. X-5. [pmid: 21329281].
443 Blardi P, de Lalla A, Ceccatelli L, et al. Variations of plasma leptin and adiponectin levels in autistic patients. Neurosci Lett. Jul. 19. 2010;479(1):54-7. X-5. [pmid: 20478355].
444 Bonell S, McCarthy J. A case study of a young man with intellectual disability, mitochondrial disorder, epilepsy, autism and psychosis: How did we decide which psychotropic drug to use?. Advances in Mental Health and Intellectual Disabilities. 2010;4(3):45-8. X-5.
445 Bonggat PW, Hall LJ. Evaluation of the Effects of Sensory Integration-Based Intervention by a Preschool Special Education Teacher. Education and Training in Autism and Developmental Disabilities. 2010;45(2):294-302. X-3.
446 Bonnel A, McAdams S, Smith B, et al. Enhanced pure-tone pitch discrimination among persons with autism but not Asperger syndrome. Neuropsychologia. Jul. 2010;48(9):2465-75. X-5. [pmid: 20433857].
447 Boyd BA, Shaw E. Autism in the Classroom: A Group of Students Changing in Population and Presentation. Preventing School Failure. 2010;54(4):211-9. X-5.
448 Brambring M, Asbrock D. Validity of false belief tasks in blind children. J Autism Dev Disord. Dec. 2010;40(12):1471-84. X-5. [pmid: 20379770].
449 Brock M, Hatton D. Distinguishing Features of Autism in Boys with Fragile X Syndrome. Journal of Intellectual Disability Research. 2010;54(10):894-905. X-5. [pmid: 20704635].
450 Bronnick KS, Nordby H, Larsen JP, et al. Disturbance of automatic auditory change detection in dementia associated with Parkinson's disease: A mismatch negativity study. Neurobiol Aging. Jan. 2010;31(1):104-13. 18395939. X-5. [pmid: 18395939].
451 Brookman-Frazee LI, Taylor R, Garland AF. Characterizing community-based mental health services for children with autism spectrum disorders and disruptive behavior problems. J Autism Dev Disord. Oct. 2010;40(10):1188-201. X-5. [pmid: 20204690].
452 Budzińska A, Wójcik M. Teaching verbal behaviors to a four-year-old autistic boy using techniques of applied behavior analysis. Acta Neuropsychologica. 2010;8(2):181-5. X-3.
453 Burke RV, Andersen MN, Bowen SL, et al. Evaluation of two instruction methods to increase employment options for young adults with autism spectrum disorders. Res Dev Disabil. Nov-Dec. 2010;31(6):1223-33. X-5. [pmid: 20800988].
454 Caballero A, Connell JE. Evaluation of the Effects of Social Cue Cards for Preschool Age Children with Autism Spectrum Disorders (ASD). Journal of Behavior Assessment and Intervention in Children. 2010;1(1):25-42. X-3.
455 Caglayan AO. Genetic Causes of Syndromic and Non-Syndromic Autism. Wiley-Blackwell. 350 Main Street, Malden, MA 02148. 2010:130-8. X-4.
456 Canevini MP, De Sarro G, Galimberti CA, et al. Relationship between adverse effects of antiepileptic drugs, number of coprescribed drugs, and drug load in a large cohort of consecutive patients with drug-refractory epilepsy. Epilepsia. May. 2010;51(5):797-804. X-5. [pmid: 20545754].
457 Capp PL, de Faria ME, Siqueira SR, et al. Special care dentistry: Midazolam conscious sedation for patients with neurological diseases. Eur J Paediatr Dent. Dec. 2010;11(4):162-4. X-5. [pmid: 21250764].
458 Carbone VJ, Sweeney-Kerwin EJ, Attanasio V, et al. Increasing the Vocal Responses of Children with Autism and Developmental Disabilities Using Manual Sign Mand Training and Prompt Delay. Journal of Applied Behavior Analysis. 2010;43(4):705-9. X-3. [pmid: 21541153].
459 Carter EW, Sisco LG, Chung Y-C, et al. Peer Interactions of Students with Intellectual Disabilities and/or Autism: A Map of the Intervention Literature. Research and Practice for Persons with Severe Disabilities (RPSD). 2010;35(3):1-17. X-2, X-5.
460 Casella SE, Wilder DA, Neidert P, et al. The Effects of Response Effort on Safe Performance by Therapists at an Autism Treatment Facility. Journal of Applied Behavior Analysis. 2010;43(4):729-34. X-1, X-3, X-4. [pmid: 21541157].
461 Catlett C. Resources within “Reason”. Young Exceptional Children. 2010;13(3):41-2. X-5.
462 Cesaroni A, Nardi PV. Plasma disc decompression for contained cervical disc herniation: a randomized, controlled trial. Eur Spine J. Mar. 2010;19(3):477-86. X-5. [pmid: 19902277].
463 Charania SM, LeBlanc LA, Sabanathan N, et al. Teaching effective hand raising to children with autism during group instruction. J Appl Behav Anal. Fall. 2010;43(3):493-7. X-3. [pmid: 21358908].
464 Charman T. Developmental approaches to understanding and treating autism. Folia Phoniatr Logop. 2010;62(4):166-77. X-5. [pmid: 20460929].
465 M-c Cheung, Chan AS, Sze SL, et al. Verbal Memory Deficits in Relation to Organization Strategy in High- and Low-Functioning Autistic Children. Research in Autism Spectrum Disorders. 2010;4(4):764-71. X-5.
466 Chi RP, Fregni F, Snyder AW. Visual memory improved by non-invasive brain stimulation. Brain Res. Sep. 24. 2010;1353:168-75. X-5. [pmid: 20682299].
467 Chisholm K, Gibbons A, Psarros C, et al. Longitudinal outcomes of early implantation in children with auditory neuropathy spectrum disorder (ANSD). Cochlear Implants Int. Jun. 2010;11(Suppl 1):169-75. X-5. [pmid: 21756606].
468 Chong IM, Carr JE. Failure to demonstrate the differential outcomes effect in children with autism. Behavioral Interventions. 2010;25(4):339-48. X-3.
469 Chow JC, Grigorov GN. Dosimetry of a small air cavity for clinical electron beams: A Monte Carlo study. Med Dosim. Summer. 2010;35(2):92-100. X-5. [pmid: 19931020].
470 Christon LM, Mackintosh VH, Myers BJ. Use of complementary and alternative medicine (CAM) treatments by parents of children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2010;4(2):249-59. X-4.
471 Coakley T. State Guidance Documents for Young Children with Autism Spectrum Disorders: Content and Comparison. Infants and Young Children. 2010;23(2):145-64. X-5.
472 Conroy MA. Seeing the Forest among the Trees: When Data Do Not Speak Loud Enough. Journal of Early Intervention. 2010;32(2):99-104. X-5.
473 Coolican J, Smith IM, Bryson SE. Brief parent training in pivotal response treatment for preschoolers with autism. J Child Psychol Psychiatry. Dec. 2010;51(12):1321-30. X-3. [pmid: 21073457].
474 Correa de Sa DD, Hodge DO, Slusser JP, et al. Progression of preclinical diastolic dysfunction to the development of symptoms. Heart. Apr. 2010;96(7):528-32. X-5. [pmid: 20350989].
475 Cuvo AJ, Godard A, Huckfeldt R, et al. Training children with autism spectrum disorders to be compliant with an oral assessment. Research in Autism Spectrum Disorders. 2010;4(4):681-96. X-3, X-4.
476 Cuvo AJ, Reagan AL, Ackerlund J, et al. Training Children with Autism Spectrum Disorders to Be Compliant with a Physical Exam. Research in Autism Spectrum Disorders. 2010;4(2):168-85. X-1, X-3, X-4.
477 da Rosa LA, Cardoso SC, Campos LT, et al. Percentage depth dose evaluation in heterogeneous media using thermoluminescent dosimetry. J Appl Clin Med Phys. 2010;11(1):2947. X-5. [pmid: 20160687].
478 Darrou C, Pry R, Pernon E, et al. Outcome of young children with autism: Does the amount of intervention influence developmental trajectories?. Autism. 2010;14(6):663-77. X-5. [pmid: 21149421].
479 Davis CJ, Brock MD, McNulty K, et al. Efficiency of forced choice preference assessment: Comparing multiple presentation techniques. The Behavior Analyst Today. 2010;10(3-4):440-55. X-5.
480 Davis TE, Fodstad JC, Jenkins WS, et al. Anxiety and avoidance in infants and toddlers with autism spectrum disorders: Evidence for differing symptom severity and presentation. Research in Autism Spectrum Disorders. 2010;4(2):305-13. X-5.
481 De Schipper JC, Schuengel C. Attachment behaviour towards support staff in young people with intellectual disabilities: associations with challenging behaviour. J Intellect Disabil Res. Jul. 2010;54(7):584-96. X-5. [pmid: 20492348].
482 Deitchman C, Reeve SA, Reeve KF, et al. Incorporating video feedback into self-management training to promote generalization of social initiations by children with autism. Education & Treatment of Children. 2010;33(3):475-88. X-3.
483 Dejong M. Some reflections on the use of psychiatric diagnosis in the looked after or “in care” child population. Clin Child Psychol Psychiatry. Oct. 2010;15(4):589-99. X-5. [pmid: 20923905].
484 Delfs CH, Campbell JM. A Quantitative Synthesis of Developmental Disability Research: The Impact of Functional Assessment Methodology on Treatment Effectiveness. Behavior Analyst Today. 2010;11(1):4-19. X-1, X-3, X-4.
485 Depositario-Cabacar DFT, Zelleke T-G. Treatment of Epilepsy in Children with Developmental Disabilities. Developmental Disabilities Research Reviews. 2010;16(3):239-47. X-1, X-2, X-3, X-4. [pmid: 20981762].
486 Dichter GS, Benning SD, Holtzclaw TN, et al. Affective modulation of the startle eyeblink and postauricular reflexes in autism spectrum disorder. J Autism Dev Disord. Jul. 2010;40(7):858-69. X-5. [pmid: 20049632].
487 Dickstein DP. In this issue/abstract thinking: the new normal. J Am Acad Child Adolesc Psychiatry. Nov. 2010;49(11):1087-8. X-5. [pmid: 20970695].
488 Dillenburger K, Keenan M, Doherty A, et al. Living with Children Diagnosed with Autistic Spectrum Disorder: Parental and Professional Views. British Journal of Special Education. March. 2010. 2010;37(1):13-23. X-5.
489 Donaldson JB, Zager D. Mathematics Interventions for Students with High Functioning Autism/Asperger's Syndrome. Council for Exceptional Children. 1110 North Glebe Road Suite 300, Arlington, VA 22201. 2010:40-6. X-4.
490 Dowd AM, Rinehart NJ, McGinley J. Motor Function in Children with Autism: Why Is This Relevant to Psychologists?. Clinical Psychologist. 2010;14(3):90-6. X-5.
491 Downs RC, Downs A. Practices in Early Intervention for Children with Autism: A Comparison with the National Research Council Recommended Practices. Education and Training in Autism and Developmental Disabilities. 2010;45(1):150-9. X-5.
492 Draga RO, Grimbergen MC, Kok ET, et al. Photodynamic diagnosis (5-aminolevulinic acid) of transitional cell carcinoma after bacillus Calmette-Guerin immunotherapy and mitomycin C intravesical therapy. Eur Urol. Apr. 2010;57(4):655-60. X-5. [pmid: 19819064].
493 Dujardin K, Dubois B, Tison F, et al. Parkinson's disease dementia can be easily detected in routine clinical practice. Mov Disord. Dec. 15. 2010;25(16):2769-76. X-5. [pmid: 20925065].
494 Dunst CJ, Trivette CM, Masiello T. Influence of the interests of children with autism on everyday learning opportunities. Psychol Rep. Aug. 2010;107(1):281-8. X-5. [pmid: 20923073].
495 Eklund M, Ostman M. Belonging and doing: important factors for satisfaction with sexual relations as perceived by people with persistent mental illness. Int J Soc Psychiatry. Jul. 2010;56(4):336-47. X-5. [pmid: 19617283].
496 Eldevik S, Hastings RP, Hughes JC, et al. Using participant data to extend the evidence base for intensive behavioral intervention for children with autism. American Journal on Intellectual and Developmental Disabilities. 2010;115(5):381-405. X-5. [pmid: 20687823].
497 Eldib AA, ElGohary MI, Fan J, et al. Dosimetric characteristics of an electron multileaf collimator for modulated electron radiation therapy. J Appl Clin Med Phys. 2010;11(2):2913. X-5. [pmid: 20592689].
498 Erickson CA, Mullett JE, McDougle CJ. Brief Report: Acamprosate in Fragile X Syndrome. Journal of Autism and Developmental Disorders. November. 2010. 2010;40(11):1412-6. X-5. [pmid: 20213249].
499 Esch JW, Esch BE, McCart JD, et al. An Assessment of Self-Echoic Behavior in Young Children. Analysis of Verbal Behavior. 2010;26:3-13. X-5. [pmid: 22477458].
500 Falcomata TS, Roane HS, Feeney BJ, et al. Assessment and treatment of elopement maintained by access to stereotypy. J Appl Behav Anal. Fall. 2010;43(3):513-7. X-3. [pmid: 21358912].
501 Farr W, Yuill N, Raffle H. Social benefits of a tangible user interface for children with Autistic Spectrum Conditions. Autism. May. 2010;14(3):237-52. X-3. [pmid: 20484323].
502 Fernandes FD, Santos TH, Amato CA, et al. Computerized resources in language therapy with children of the autistic spectrum. Pro Fono. Oct-Dec. 2010;22(4):415-20. X-5. [pmid: 21271092].
503 Fernell E, Barnevik-Olsson M, Bågenholm G, et al. Serum levels of 25-hydroxyvitamin D in mothers of Swedish and of Somali origin who have children with and without autism. Acta Paediatrica. 2010;99(5):743-7. X-5. [pmid: 20219032].
504 Finnigan E, Starr E. Increasing Social Responsiveness in a Child with Autism: A Comparison of Music and Non-Music Interventions. Autism: The International Journal of Research and Practice. 2010;14(4):321-48. X-3. [pmid: 20591958].
505 Fischer JL, Howard JS, Sparkman CR, et al. Establishing generalized syntactical responding in young children with autism. Research in Autism Spectrum Disorders. 2010;4(1):76-88. X-3.
506 Flood WA, Lynn C, Mortensen J, et al. Behavioral assessment of an elimination diet to treat purported food sensitivity and problem behaviors in autism: A clinical case report. the Behavior Therapist. 2010;33(6):116-9. X-5.
507 Forsyth R, McNally R, James P, et al. Variation at local government level in the support for families of severely disabled children and the factors that affect it. Dev Med Child Neurol. Nov. 2010;52(11):e259-66. X-5. [pmid: 21175456].
508 Frazier TW, Youngstrom EA, Haycook T, et al. Effectiveness of medication combined with intensive behavioral intervention for reducing aggression in youth with autism spectrum disorder. J Child Adolesc Psychopharmacol. Jun. 2010;20(3):167-77. X-1, X-3. [pmid: 20578929].
509 Frazier TW, Youngstrom EA, Sinclair L, et al. Autism spectrum disorders as a qualitatively distinct category from typical behavior in a large, clinically ascertained sample. Assessment. 2010;17(3):308-20. X-5. [pmid: 20040725].
510 Friman PC. Come on in, the Water Is Fine: Achieving Mainstream Relevance through Integration with Primary Medical Care. Behavior Analyst. 2010;33(1):19-36. X-5. [pmid: 22479124].
511 Furniss GJ. Reflections on the Historical Narrative of Jessica Park, an Artist with Autism. Art Therapy: Journal of the American Art Therapy Association. 2010;27(4):190-4. X-5.
512 Gage NA, Lewis TJ. Structural Analysis in the Classroom. Beyond Behavior. 2010;19(3):3-11. X-1, X-2, X-3, X-4.
513 Gaita L, Manzi B, Sacco R, et al. Decreased serum arylesterase activity in autism spectrum disorders. Psychiatry Research. 2010;180(2-3):105-13. X-5. [pmid: 20488557].
514 Gallagher CM, Goodman MS. Hepatitis B vaccination of male neonates and autism diagnosis, NHIS 1997-2002. J Toxicol Environ Health A. 2010;73(24):1665-77. X-5. [pmid: 21058170].
515 Ganz JB, Flores MM. Implementing Visual Cues for Young Children with Autism Spectrum Disorders and Their Classmates. Young Children. May. 2010. 2010;65(3):78-83. X-5.
516 Ganz JB, Lashley E, Rispoli MJ. Non-responsiveness to intervention: children with autism spectrum disorders who do not rapidly respond to communication interventions. Dev Neurorehabil. 2010;13(6):399-407. X-3. [pmid: 21034281].
517 Garcia-Villamisar DA, Dattilo J. Effects of a leisure programme on quality of life and stress of individuals with ASD. J Intellect Disabil Res. Jul. 2010;54(7):611-9. X-5. [pmid: 20500784].
518 Gau SS-F, Chou M-C, Lee J-C, et al. Behavioral problems and parenting style among Taiwanese children with autism and their siblings. Psychiatry and Clinical Neurosciences. 2010;64(1):70-8. X-5. [pmid: 19968831].
519 Gerritsen J. The Effect of Tomatis Therapy on Children with Autism: Eleven Case Studies. International Journal of Listening. 2010;24(1):50-68. X-1, X-2, X-3, X-4.
520 Ghanizadeh A. Methionine sulfoximine may improve inflammation in autism, a novel hypothesized treatment for autism. Arch Med Res. Nov. 2010;41(8):651-2. X-1, X-2, X-3, X-4. [pmid: 21199736].
521 Gjaerum RG, Ineland J, Sauer L. The story about theater organizations, the public's approval, and the actors' identity formation in Nordic disability theater. J Soc Work Disabil Rehabil. 2010;9(4):254-73. X-4, X-5. [pmid: 21104515].
522 Granpeesheh D, Tarbox J, Dixon DR, et al. Evaluation of an eLearning tool for training behavioral therapists in academic knowledge of applied behavior analysis. Research in Autism Spectrum Disorders. 2010;4(1):11-7. X-5.
523 Granpeesheh D, Tarbox J, Dixon DR, et al. Randomized trial of hyperbaric oxygen therapy for children with autism. Research in Autism Spectrum Disorders. 2010;4(2):268-75. X-5.
524 Green SA, Ben-Sasson A. Anxiety Disorders and Sensory Over-Responsivity in Children with Autism Spectrum Disorders: Is There a Causal Relationship?. Journal of Autism and Developmental Disorders. 2010;40(12):1495-504. X-5. [pmid: 20383658].
525 Greher GR, Hillier A, Dougherty M, et al. SoundScape: An Interdisciplinary Music Intervention for Adolescents and Young Adults on the Autism Spectrum. International Journal of Education & the Arts. 2010;11(9):1-28. X-5.
526 Grey I, Bradley S, McClean B. Patterns of autism diagnostic assessment in Ireland. The Irish Journal of Psychology. 2010;31(1-4):27-42. X-5.
527 Grey I, Lynn E, McClean B. Parents of children with autism: Experiences of education service provision in the Republic of Ireland. The Irish Journal of Psychology. 2010;31(1-4):111-24. X-4.
528 Groskreutz NC, Karsina A, Miguel CF, et al. Using Complex Auditory-Visual Samples to Produce Emergent Relations in Children with Autism. Journal of Applied Behavior Analysis. 2010;43(1):131-6. X-3, X-5. [pmid: 20808504].
529 Guldberg K. Educating Children on the Autism Spectrum: Preconditions for Inclusion and Notions of “Best Autism Practice” in the Early Years. British Journal of Special Education. 2010;37(4):168-74. X-5.
530 Gunby KV, Carr JE, LeBlanc LA. Teaching Abduction-Prevention Skills to Children with Autism. Journal of Applied Behavior Analysis. 2010;43(1):107-12. X-3. [pmid: 20808500].
531 Gunnar MR. A Commentary on “Deprivation-Specific Psychological Patterns: Effects of Institutional Deprivation”. Monographs of the Society for Research in Child Development. 2010;75(1):232-47. X-5. [pmid: 20500642].
532 Gupta S. Antibodies: basic mechanisms and emerging concepts. J Clin Immunol. May. 2010;30(Suppl 1):S1-3. X-5. [pmid: 20387105].
533 Gutman SA, Raphael EI, Ceder LM, et al. The effect of a motor-based, social skills intervention for adolescents with high-functioning autism: Two single-subject design cases. Occupational Therapy International. 2010;17(4):188-97. X-5. [pmid: 20672254].
534 Haley JL, Heick PF, Luiselli JK. Use of an Antecedent Intervention to Decrease Vocal Stereotypy of a Student with Autism in the General Education Classroom. Child & Family Behavior Therapy. 2010;32(4):311-21. X-3.
535 Halko MA, Eldaief MC, Horvath JC, et al. Combining transcranial magnetic stimulation and FMRI to examine the default mode network. J Vis Exp. 2010(46). X-3, X-4, X-5. [pmid: 21248684].
536 Hamad CD, Serna RW, Morrison L, et al. Extending the Reach of Early Intervention Training for Practitioners: A Preliminary Investigation of an Online Curriculum for Teaching Behavioral Intervention Knowledge in Autism to Families and Service Providers. Infants and Young Children. 2010;23(3):195-208. X-5. [pmid: 23504540].
537 Hammond D, Gast DL. Descriptive Analysis of Single Subject Research Designs: 1983-2007. Education and Training in Autism and Developmental Disabilities. 2010;45(2):187-202. X-5.
538 Harish T, Gangadharan S, Bhaumik S, et al. Adults with Asperger syndrome at a Neuropsychiatric Centre in India. British Journal of Developmental Disabilities. 2010;56(111, Pt2):159-65. X-5.
539 Hayashi N, Shibamoto Y, Obata Y, et al. Megavoltage photon beam attenuation by carbon fiber couch tops and its prediction using correction factors. J Radiat Res. 2010;51(4):455-63. X-5. [pmid: 20508376].
540 Hedley D, Young R, Angelica M, et al. Cross-cultural evaluation of the Autism Detection in Early Childhood (ADEC) in Mexico. Autism. 2010;14(2):93-112. X-5. [pmid: 20395280].
541 Heinicke MR, Carr JE, LeBlanc LA, et al. On the Use of Fluency Training in the Behavioral Treatment of Autism: A Commentary. Behavior Analyst. 2010;33(2):223-9. X-2, X-5. [pmid: 22532717].
542 Hellings JA, Cardona AM, Schroeder SR. Long-term safety and adverse events of risperidone in children, adolescents, and adults with pervasive developmental disorders. Journal of Mental Health Research in Intellectual Disabilities. 2010;3(3):132-44. X-1.
543 Henning OJ, Nakken KO. Psychiatric comorbidity and use of psychotropic drugs in epilepsy patients. Acta Neurol Scand Suppl. 2010(190):18-22. X-5. [pmid: 20586730].
544 Hess J, Matson J, Neal D, et al. A Comparison of Psychotropic Drug Side Effect Profiles in Adults Diagnosed with Intellectual Disabilities and Autism Spectrum Disorders. Journal of Mental Health Research in Intellectual Disabilities. 2010;3(2):85-96. X-5.
545 Hintzen A, Delespaul P, van Os J, et al. Social needs in daily life in adults with Pervasive Developmental Disorders. Psychiatry Res. Aug. 30. 2010;179(1):75-80. X-5. [pmid: 20638732].
546 Hobson RP. Explaining autism: Ten reasons to focus on the developing self. Autism. Sep. 2010;14(5):391-407. X-5. [pmid: 20926456].
547 Hoekstra PJ, Troost PW, Lahuis BE, et al. Risperidone-induced weight gain in referred children with autism spectrum disorders is associated with a common polymorphism in the 5-hydroxytryptamine 2C receptor gene. J Child Adolesc Psychopharmacol. Dec. 2010;20(6):473-7. X-5. [pmid: 21186965].
548 Hoglund Carlsson L, Gillberg C, Lannero E, et al. Autism: screening toddlers with CHAT in a child health care programme did not improve early identification. Acta Paediatr. Dec. 2010;99(12):1897-9. X-5. [pmid: 20670307].
549 Holifield C, Goodman J, Hazelkorn M, et al. Using Self-Monitoring to Increase Attending to Task and Academic Accuracy in Children with Autism. Focus on Autism and Other Developmental Disabilities. 2010;25(4):230-8. X-3.
550 Holland CD. Autism, insurance, and the idea: providing a comprehensive legal framework. Cornell Law Rev. Sep. 2010;95(6):1253-82. X-5. [pmid: 20939148].
551 Hollenweger J. MHADIE's matrix to analyse the functioning of education systems. Disabil Rehabil. 2010;32(Suppl 1):S116-24. X-5. [pmid: 20874661].
552 Hui KK, Marina O, Liu J, et al. Acupuncture, the limbic system, and the anticorrelated networks of the brain. Auton Neurosci. Oct. 28. 2010;157(1-2):81-90. X-5. [pmid: 20494627].
553 Humphrey N, Symes W. Responses to Bullying and Use of Social Support among Pupils with Autism Spectrum Disorders (ASDs) in Mainstream Schools: A Qualitative Study. Journal of Research in Special Educational Needs. 2010;10(2):82-90. X-3, X-4.
554 Hutman T, Rozga A, DeLaurentis AD, et al. Response to Distress in Infants at Risk for Autism: A Prospective Longitudinal Study. Journal of Child Psychology and Psychiatry. 2010;51(9):1010-20. X-5. [pmid: 20546081].
555 Iarocci G, Rombough A, Yager J, et al. Visual influences on speech perception in children with autism. Autism. Jul. 2010;14(4):305-20. X-4. [pmid: 20591957].
556 Ingersoll B, Lalonde K. The impact of object and gesture imitation training on language use in children with autism spectrum disorder. J Speech Lang Hear Res. Aug. 2010;53(4):1040-51. X-3. [pmid: 20631228].
557 Jackett JM. Transition and beyond for individuals with autism spectrum disorders (ASD): a New Jersey case study of the adult service sector, its inherent shortcomings, and hope for the future. Seton Hall Law Rev. 2010;40(4):1733-74. X-5. [pmid: 21280391].
558 James WH. Behavioural and biological determinants of human sex ratio at birth. J Biosoc Sci. Sep. 2010;42(5):587-99. X-5. [pmid: 20519063].
559 Janusis GM, Weyandt LL. An exploratory study of substance use and misuse among college students with and without ADHD and other disabilities. J Atten Disord. Nov. 2010;14(3):205-15. X-5. [pmid: 20479474].
560 Jeanson B, Thiessen C, Thomson K, et al. Field testing of the discrete-trials teaching evaluation form. Research in Autism Spectrum Disorders. 2010;4(4):718-23. X-5.
561 Jegatheesan B, Fowler S, Miller PJ. From symptom recognition to services: How South Asian Muslim immigrant families navigate autism. Disability & Society. 2010;25(7):797-811. X-3, X-4.
562 Jones AP, Frederickson N. Multi-informant predictors of social inclusion for students with Autism spectrum disorders attending mainstream school. Journal of Autism and Developmental Disorders. 2010;40(9):1094-103. X-5. [pmid: 20148296].
563 Jones K, Howley M. An investigation into an interaction programme for children on the autism spectrum: Outcomes for children, perceptions of schools and a model for training. Journal of Research in Special Educational Needs. 2010;10(2):115-23. X-3, X-4.
564 Joshi G, Petty C, Wozniak J, et al. The heavy burden of psychiatric comorbidity in youth with autism spectrum disorders: a large comparative study of a psychiatrically referred population. J Autism Dev Disord. Nov. 2010;40(11):1361-70. X-5. [pmid: 20309621].
565 Kagohara DM, van der Meer L, Achmadi D, et al. Behavioral intervention promotes successful use of an iPod-based communication device by an adolescent with autism. Clinical Case Studies. 2010;9(5):328-38. X-5.
566 Kalyva E. Teachers Perspectives of the Sexuality of Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2010;4(3):433-7. X-5.
567 Kane M, Connell JE, Pellecchia M. A Quantitative Analysis of Language Interventions for Children with Autism. Behavior Analyst Today. 2010;11(2):128-44. X-5.
568 Kang S, Lang RB, O'Reilly MF, et al. Problem Behavior during Preference Assessments: An Empirical Analysis and Practical Recommendations. Journal of Applied Behavior Analysis. 2010;43(1):137-41. X-3, X-5. [pmid: 20808505].
569 Kao HSR. Calligraphy therapy: A complementary approach to psychotherapy. Asia Pacific Journal of Counselling and Psychotherapy. 2010;1(1):55-66. X-1, X-2, X-3, X-4.
570 Karanth P, Shaista S, Srikanth N. Efficacy of communication DEALL--an indigenous early intervention program for children with autism spectrum disorders. Indian J Pediatr. Sep. 2010;77(9):957-62. X-5. [pmid: 20821283].
571 Karkhaneh M, Clark B, Ospina MB, et al. Social Stories(TM) to improve social skills in children with Autism spectrum disorder. A systematic review. Autism. 2010;14(6):641-62. X-5. [pmid: 20923896].
572 Katagiri M, Inada N, Kamio Y. Mirroring Effect in 2- and 3-Year-Olds with Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2010;4(3):474-8. X-5.
573 Kawanabe T, Yoritaka A, Shimura H, et al. Successful treatment with Yokukansan for behavioral and psychological symptoms of Parkinsonian dementia. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 17. 2010;34(2):284-7. X-5. [pmid: 19948198].
574 Keenan M, Dillenburger K, Doherty A, et al. The Experiences of Parents during Diagnosis and Forward Planning for Children with Autism Spectrum Disorder. Journal of Applied Research in Intellectual Disabilities. 2010;23(4):390-7. X-5.
575 Kelley E, Naigles L, Fein D. An In-Depth Examination of Optimal Outcome Children with a History of Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2010;4(3):526-38. X-5.
576 Kenworthy L, Case L, Harms MB, et al. Adaptive Behavior Ratings Correlate with Symptomatology and IQ among Individuals with High-Functioning Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2010;40(4):416-23. X-5. [pmid: 19949846].
577 Kerns KA, MacSween J, Vander Wekken S, et al. Investigating the efficacy of an attention training programme in children with foetal alcohol spectrum disorder. Developmental Neurorehabilitation. 2010;13(6):413-22. X-5. [pmid: 21034284].
578 Kim JE, Lyoo IK, Estes AM, et al. Laterobasal amygdalar enlargement in 6- to 7-year-old children with autism spectrum disorder. Archives of General Psychiatry. 2010;67(11):1187-97. X-5. [pmid: 21041620].
579 Koegel LK, Singh AK, Koegel RL. Improving motivation for academics in children with autism. J Autism Dev Disord. Sep. 2010;40(9):1057-66. X-3. [pmid: 20221791].
580 M-s Koh, Shin S, Yeo M-H. The Learning Program for the Development of Autistic Children (LPDAC): Parents' Perspectives on the Treatment Outcomes. Journal of the International Association of Special Education. 2010;11(1):92-100. X-4.
581 Konstantareas M, Rios A, Ramnarace C. Intensive Behavioural Intervention (IBI) training: Cooperation and its relationship to language and social competence in children with Autism Spectrum Disorder (ASD). Journal on Developmental Disabilities. 2010;16(2):67-8. X-5.
582 Koshelev M, Lohrenz T, Vannucci M, et al. Biosensor approach to psychopathology classification. PLoS Comput Biol. 2010;6(10):e1000966. X-5. [pmid: 20975934].
583 Kramberger MG, Stukovnik V, Cus A, et al. Parkinson's disease dementia: clinical correlates of brain spect perfusion and treatment. Psychiatr Danub. Sep. 2010;22(3):446-9. X-5. [pmid: 20856190].
584 Krause M, Vainio L, Zwetchkenbaum S, et al. Dental education about patients with special needs: a survey of U.S. and Canadian dental schools. J Dent Educ. Nov. 2010;74(11):1179-89. X-5. [pmid: 21045222].
585 Kroeger K, Sorensen R. A Parent Training Model for Toilet Training Children with Autism. Journal of Intellectual Disability Research. 2010;54(6):556-67. X-3. [pmid: 20576064].
586 Kuhlthau K, Orlich F, Hall TA, et al. Health-Related Quality of Life in children with autism spectrum disorders: results from the autism treatment network. J Autism Dev Disord. Jun. 2010;40(6):721-9. X-5. [pmid: 20033762].
587 Kuhn G, Kourkoulou A, Leekam SR. How magic changes our expectations about autism. Psychol Sci. Oct. 2010;21(10):1487-93. X-5. [pmid: 20855904].
588 Kumsta R, Kreppner J, Rutter M, et al. Deprivation-Specific Psychological Patterns. Monographs of the Society for Research in Child Development. 2010;75(1):48-78. X-5. [pmid: 20500633].
589 Kutup A, Vashist Y, Kaifi JT, et al. For which type of chronic pancreatitis is the “Hamburg procedure” indicated?. J Hepatobiliary Pancreat Sci. Nov. 2010;17(6):758-62. X-5. [pmid: 19779663].
590 LaCava PG, Rankin A, Mahlios E, et al. A single case design evaluation of a software and tutor intervention addressing emotion recognition and social interaction in four boys with ASD. Autism. May. 2010;14(3):161-78. X-3. [pmid: 20488823].
591 Lake JK, Cardy S, Humphreys KR. Brief report: Animacy and word order in individuals with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2010;40(9):1161-4. X-5. [pmid: 20195740].
592 Lal R. Effect of Alternative and Augmentative Communication on Language and Social Behavior of Children with Autism. Educational Research and Reviews. 2010;5(3):119-25. X-3.
593 Lam SF, Wong BP, Leung D, et al. How parents perceive and feel about participation in community activities. The comparison between parents of preschoolers with and without Autism Spectrum Disorders. Autism. Jul. 2010;14(4):359-77. X-5. [pmid: 20591960].
594 Lang R, Davis T, O'Reilly M, et al. Functional Analysis and Treatment of Elopement across Two School Settings. Journal of Applied Behavior Analysis. 2010;43(1):113-8. X-3. [pmid: 20808501].
595 Lang R, Koegel LK, Ashbaugh K, et al. Physical Exercise and Individuals with Autism Spectrum Disorders: A Systematic Review. Research in Autism Spectrum Disorders. 2010;4(4):565-76. X-1, X-3, X-4.
596 Lang R, O'Reilly M, Sigafoos J, et al. The effects of an abolishing operation intervention component on play skills, challenging behavior, and stereotypy. Behavior Modification. 2010;34(4):267-89. X-3. [pmid: 20562321].
597 Lang R, O'Reilly MF, Sigafoos J, et al. Review of Teacher Involvement in the Applied Intervention Research for Children with Autism Spectrum Disorders. Education and Training in Autism and Developmental Disabilities. 2010;45(2):268-83. X-2, X-5.
598 Lanner T, Nichols B, Field S, et al. The clinical utility of two reinforcement preference assessment techniques: A comparison of duration of assessment and identification of functional reinforcers. The Behavior Analyst Today. 2010;10(3-4):456-66. X-1, X-3.
599 Larsson V, Aarsland D, Ballard C, et al. The effect of memantine on sleep behaviour in dementia with Lewy bodies and Parkinson's disease dementia. Int J Geriatr Psychiatry. Oct. 2010;25(10):1030-8. X-5. [pmid: 20872929].
600 Lazoff T, Zhong L, Piperni T, et al. Prevalence of pervasive developmental disorders among children at the English Montreal School Board. The Canadian Journal of Psychiatry / La Revue canadienne de psychiatrie. 2010;55(11):715-20. X-5.
601 Leaf JB, Sheldon JB, Sherman JA. Comparison of Simultaneous Prompting and No-No Prompting in Two-Choice Discrimination Learning with Children with Autism. Journal of Applied Behavior Analysis. 2010;43(2):215-28. X-3. [pmid: 21119896].
602 Lechago SA, Carr JE, Grow LL, et al. Mands for Information Generalize across Establishing Operations. Journal of Applied Behavior Analysis. 2010;43(3):381-95. X-3. [pmid: 21358900].
603 Lee CY, Kim KH, Kim YH. The efficacy of photodynamic diagnosis in defining the lateral border between a tumor and a tumor-free area during Mohs micrographic surgery. Dermatol Surg. Nov. 2010;36(11):1704-10. X-5. [pmid: 20840493].
604 Legge DB, DeBar RM, Alber-Morgan SR. The Effects of Self-Monitoring with a MotivAider[R] on the On-Task Behavior of Fifth and Sixth Graders with Autism and Other Disabilities. Journal of Behavior Assessment and Intervention in Children. 2010;1(1):43-52. X-3.
605 Lemonnier E, Ben-Ari Y. The diuretic bumetanide decreases autistic behaviour in five infants treated during 3 months with no side effects. Acta Paediatr. Dec. 2010;99(12):1885-8. X-3, X-5. [pmid: 20608900].
606 Lionello-DeNolf KM, Dube WV, McIlvane WJ. Evaluation of Resistance to Change under Different Disrupter Conditions in Children with Autism and Severe Intellectual Disability. Journal of the Experimental Analysis of Behavior. 2010;93(3):369-83. X-3. [pmid: 21119851].
607 Livanis A, Mouzakitis A. The Treatment Validity of Autism Screening Instruments. Assessment for Effective Intervention. 2010;35(4):206-17. X-5.
608 Locke J, Ishijima EH, Kasari C, et al. Loneliness, Friendship Quality and the Social Networks of Adolescents with High-Functioning Autism in an Inclusive School Setting. Journal of Research in Special Educational Needs. 2010;10(2):74-81. X-5.
609 Loiacono V, Valenti V. General Education Teachers Need to Be Prepared to Co-Teach the Increasing Number of Children with Autism in Inclusive Settings. International Journal of Special Education. 2010;25(3):24-32. X-5.
610 Lomas JE, Fisher WW, Kelley ME. The effects of variable-time delivery of food items and praise on problem behavior reinforced by escape. J Appl Behav Anal. Fall. 2010;43(3):425-35. X-3. [pmid: 21358903].
611 Lund C, Oosthuizen P, Flisher AJ, et al. Care among people with schizophrenia spectrum disorders in South Africa. Psychiatric Services. 2010;61(3):235-40. X-5. [pmid: 20194399].
612 Lynch E. Making sense of autism. Nurs Stand. Sep. 15-21. 2010;25(2):18-9. X-5. [pmid: 20949817].
613 Machalicek W, O'Reilly MF, Rispoli M, et al. Training Teachers to Assess the Challenging Behaviors of Students with Autism Using Video Tele-Conferencing. Education and Training in Autism and Developmental Disabilities. 2010;45(2):203-15. X-5.
614 Maenner MJ, Durkin MS. Trends in the prevalence of autism on the basis of special education data. Pediatrics. Nov. 2010;126(5):e1018-25. X-5. [pmid: 20974790].
615 Mahoney JF. Interrater agreement on the Nordoff-Robbins Evaluation Scale I: Client-therapist relationship in musical activity. Music and Medicine. 2010;2(1):23-8. X-5.
616 Majewska MD, Urbanowicz E, Rok-Bujko P, et al. Age-dependent lower or higher levels of hair mercury in autistic children than in healthy controls. Acta Neurobiol Exp (Wars). 2010;70(2):196-208. X-5. [pmid: 20628443].
617 Makrygianni MK, Reed P. A Meta-Analytic Review of the Effectiveness of Behavioural Early Intervention Programs for Children with Autistic Spectrum Disorders. 2010;4:577-93. X-5.
618 Makrygianni MK, Reed P. Factors Impacting on the Outcomes of Greek Intervention Programmes for Children with Autistic Spectrum Disorders. Research in Autism Spectrum Disorders. 2010. 2010;4(4):697-708. X-5.
619 Mancil RG, Boman M. Functional Communication Training in the Classroom: A Guide for Success. Preventing School Failure. 2010;54(4):238-46. X-1, X-2, X-3, X-4.
620 Mandell DS, Morales KH, Xie M, et al. Age of diagnosis among Medicaid-enrolled children with autism, 2001-2004. Psychiatr Serv. Aug. 2010;61(8):822-9. X-5. [pmid: 20675842].
621 Mandell DS, Morales KH, Xie M, et al. County-Level Variation in the Prevalence of Medicaid-Enrolled Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2010;40(10):1241-6. X-5. [pmid: 20195736].
622 Manente CJ, Maraventano JC, LaRue RH, et al. Effective Behavioral Intervention for Adults on the Autism Spectrum: Best Practices in Functional Assessment and Treatment Development. Behavior Analyst Today. 2010;11(1):36-48. X-5.
623 Marchetto MC, Carromeu C, Acab A, et al. A model for neural development and treatment of Rett syndrome using human induced pluripotent stem cells. Cell. Nov. 12. 2010;143(4):527-39. X-5. [pmid: 21074045].
624 Marcus A, Sinnott B, Bradley S, et al. Treatment of idiopathic toe-walking in children with autism using GaitSpot Auditory Speakers and simplified habit reversal. Research in Autism Spectrum Disorders. 2010;4(2):260-7. X-3.
625 Marder K. Cognitive impairment and dementia in Parkinson's disease. Mov Disord. 2010;25(Suppl 1):S110-6. X-5. [pmid: 20187235].
626 Martens BK, Gertz LE, de Lacy Werder CS, et al. Agreement between descriptive and experimental analyses of behavior under naturalistic test conditions. Journal of Behavioral Education. 2010;19(3):205-21. X-3, X-5.
627 Matson JL, Fodstad JC, Mahan S, et al. Cut-offs, norms and patterns of problem behaviours in children with developmental disabilities on the Baby and Infant Screen for Children with aUtIsm Traits (BISCUIT-Part 3). Developmental Neurorehabilitation. 2010;13(1):3-9. X-5. [pmid: 20067340].
628 Matson JL, Hess JA, Boisjoli JA. Comorbid psychopathology in infants and toddlers with autism and pervasive developmental disorders-not otherwise specified (PDD-NOS). Research in Autism Spectrum Disorders. 2010;4(2):300-1. X-5.
629 Matson JL, Mahan S, Kozlowski AM, et al. Developmental milestones in toddlers with autistic disorder, pervasive developmental disorder—not otherwise specified and atypical development. Developmental Neurorehabilitation. 2010;13(4):239-47. X-5. [pmid: 20629590].
630 Matson JL, Mahan S, Sipes M, et al. Effects of Symptoms of Comorbid Psychopathology on Challenging Behaviors among Atypically Developing Infants and Toddlers as Assessed with the Baby and Infant Screen for Children with Autism Traits (BISCUIT). Journal of Mental Health Research in Intellectual Disabilities. 2010;3(3):164-76. X-5.
631 Matson JL, Neal D. Differentiating Communication Disorders and Autism in Children. Research in Autism Spectrum Disorders. 2010;4(4):626-32. X-5.
632 Matsuo M, Maeda T, Sasaki K, et al. Frequent association of autism spectrum disorder in patients with childhood onset epilepsy. Brain Dev. Oct. 2010;32(9):759-63. X-5. [pmid: 20542395].
633 Matsushita H, Sonoyama S. Teaching ball-throwing skills to a boy with Asperger's disorder: A case study. Japanese Journal of Special Education. 2010;47(6):495-508. X-3.
634 Mayoral M, Merchán-Naranjo J, Rapado M, et al. Neurological soft signs in juvenile patients with Asperger syndrome, early-onset psychosis, and healthy controls. Early Intervention in Psychiatry. 2010;4(4):283-90. X-5. [pmid: 20977684].
635 Mayton MR, Wheeler JJ, Menendez AL, et al. An analysis of evidence-based practices in the education and treatment of learners with autism spectrum disorders. Education and Training in Autism and Developmental Disabilities. 2010;45(4):539-51. X-1, X-3, X-4.
636 Mazurik-Charles R, Stefanou C. Using Paraprofessionals to Teach Social Skills to Children with Autism Spectrum Disorders in the General Education Classroom. Journal of Instructional Psychology. 2010;37(2):161-9. X-3.
637 McCoy KM, Mathur RS, Czoka A. Guidelines for Creating a Transition Routine: Changing from One Room to Another. Beyond Behavior. 2010;19(3):22-9. X-3.
638 McDuffie A, Yoder P. Types of parent verbal responsiveness that predict language in young children with autism spectrum disorder. J Speech Lang Hear Res. Aug. 2010;53(4):1026-39. X-5. [pmid: 20605942].
639 McGinnis MA, Houchins-Juarez N, McDaniel JL, et al. Abolishing and Establishing Operation Analyses of Social Attention as Positive Reinforcement for Problem Behavior. Journal of Applied Behavior Analysis. 2010;43(1):119-23. X-3, X-5. [pmid: 20808502].
640 McGuinness TM, Lewis S. Update on autism and vaccines. J Psychosoc Nurs Ment Health Serv. Jun. 2010;48(6):15-8. X-5. [pmid: 20506968].
641 Meguid NA, Hashish AF, Anwar M, et al. Reduced serum levels of 25-hydroxy and 1,25-dihydroxy vitamin D in Egyptian children with autism. The Journal of Alternative and Complementary Medicine. 2010;16(6):641-5. X-5. [pmid: 20569030].
642 Milo J-S, Mace CF, Nevin JA. The Effects of Constant versus Varied Reinforcers on Preference and Resistance to Change. Journal of the Experimental Analysis of Behavior. 2010;93(3):385-94. X-3. [pmid: 21119852].
643 Mitchel K, Regehr K, Reaume J, et al. Group social skills training for adolescents with Asperger Syndrome or high functioning autism. Journal on Developmental Disabilities. 2010;16(2):52-63. X-5.
644 Miyahara M, Ruffman T, Fujita C, et al. How Well Can Young People with Asperger's Disorder Recognize Threat and Learn about Affect in Faces?: A Pilot Study. Research in Autism Spectrum Disorders. 2010;4(2):242-8. X-5.
645 Molinari JA. Vaccination: science versus perception. Dent Today. Dec. 2010;29(12):84. 6. X-5. [pmid: 21229925].
646 Molloy CA, Kalkwart HJ, Manning-Courtney P, et al. Plasma 25(OH)D concentration in children with autism spectrum disorder. Developmental Medicine & Child Neurology. 2010;52(10):969-71. X-4. [pmid: 20497452].
647 Montgomery JM, McCrimmon AW, Schwean VL, et al. Emotional Intelligence in Asperger Syndrome: Implications of Dissonance between Intellect and Affect. Education and Training in Autism and Developmental Disabilities. 2010;45(4):566-82. X-5.
648 Moores-Abdool W. d Students with Autism and Access to General Curriculum: What Is Being Provided?. Issues in Teacher Education. 2010;19(2):153-69. X-5.
649 Moree BN, Davis TE. Cognitive-Behavioral Therapy for Anxiety in Children Diagnosed with Autism Spectrum Disorders: Modification Trends. Research in Autism Spectrum Disorders. 2010;4(3):346-54. X-1, X-2, X-3, X-4.
650 Morrison A, Bickerstaff D, Taylor BJ. Referrals to a learning disability social work team 1996 to 2005. British Journal of Learning Disabilities. 2010;38(3):168-74. X-5.
651 Morse TE. Comprehensive Special Education Programming for Students with Autism Spectrum Disorder in the United States. International Journal of Educational Reform. 2010. 2010;19(1):2-13. X-2, X-5.
652 Mostert MP. Facilitated Communication and Its Legitimacy--Twenty-First Century Developments. Exceptionality. 2010. 2010;18(1):31-41. X-5.
653 Mothander PR, Moe RG. Self-reported depressive symptoms and parental stress in mothers and fathers who bring their infants to an infant mental health clinic. Nord J Psychiatry. Oct. 2010;64(5):310-6. X-5. [pmid: 20184497].
654 Murphy C, Barnes-Holmes D. Establishing five derived mands in three adolescent boys with autism. J Appl Behav Anal. Fall. 2010;43(3):537-41. X-5. [pmid: 21358916].
655 Murphy D. Extreme violence in a man with an autistic spectrum disorder: Assessment and treatment within high-security psychiatric care. Journal of Forensic Psychiatry & Psychology. 2010;21(3):462-77. X-5.
656 Napolitano DA, Smith T, Zarcone JR, et al. Increasing Response Diversity in Children with Autism. Journal of Applied Behavior Analysis. 2010;43(2):265-71. X-3, X-5. [pmid: 21119899].
657 Neitzel J. Positive Behavior Supports for Children and Youth with Autism Spectrum Disorders. Preventing School Failure. 2010;54(4):247-55. X-1, X-2, X-3, X-4.
658 Nepo KG. The Use of Technology to Improve Staff Performance. International Journal of Behavioral Consultation and Therapy. 2010;6(2):134-41. X-5.
659 Neumann N, Dubischar-Krivec AM, Braun C, et al. The mind of the mnemonists: An MEG and neuropsychological study of autistic memory savants. Behavioural Brain Research. 2010;215(1):114-21. X-3, X-5. [pmid: 20637245].
660 Nevelsky A, Bernstein Z, Bar-Deroma R, et al. Design and dosimetry characteristics of a commercial applicator system for intra-operative electron beam therapy utilizing ELEKTA Precise accelerator. J Appl Clin Med Phys. 2010;11(4):3244. X-5. [pmid: 21081880].
661 Nigro-Bruzzi D, Sturmey P. The effects of behavioral skills training on mand training by staff and unprompted vocal mands by children. J Appl Behav Anal. Winter. 2010;43(4):757-61. X-3. [pmid: 21541162].
662 Noterdaeme M, Hutzelmeyer-Nickels A. Early symptoms and recognition of pervasive developmental disorders in Germany. Autism. Nov. 2010;14(6):575-88. X-5. [pmid: 20923894].
663 Oberman LM, Horvath JC, Pascual-Leone A. TMS: using the theta-burst protocol to explore mechanism of plasticity in individuals with Fragile X syndrome and autism. J Vis Exp. 2010(46). X-5. [pmid: 21248685].
664 O'Connor AB, Healy O. Long-Term Post-Intensive Behavioral Intervention Outcomes for Five Children with Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2010;4(4):594-604. X-3.
665 Odom SL, Boyd BA, Hall LJ, et al. Evaluation of Comprehensive Treatment Models for Individuals with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2010;40(4):425-36. X-5. [pmid: 19633939].
666 Odom SL, Collet-Klingenberg L, Rogers SJ, et al. Evidence-Based Practices in Interventions for Children and Youth with Autism Spectrum Disorders. Preventing School Failure. 2010;54(4):275-82. X-1, X-3 ,X-4.
667 O'Hearn K, Schroer E, Minshew N, et al. Lack of Developmental Improvement on a Face Memory Task during Adolescence in Autism. Neuropsychologia. 2010;48(13):3955-60. X-3, X-4. [pmid: 20813119].
668 Ohtake Y, Wehmeyer M, Uchida N, et al. Enabling a Prelinguistic Communicator with Autism to Use Picture Card as a Strategy for Repairing Listener Misunderstandings: A Case Study. Education and Training in Autism and Developmental Disabilities. 2010;45(3):410-21. X-3.
669 Oi M. Do Japanese children with high-functioning autism spectrum disorder respond differently to Wh-questions and Yes/No-questions?. Clinical Linguistics & Phonetics. 2010;24(9):691-705. X-5. [pmid: 20707655].
670 Okada S, Ohtake Y, Yanagihara M. Improving the Manners of a Student with Autism: The Effects of Manipulating Perspective Holders in Social Stories[TM]--A Pilot Study. International Journal of Disability, Development and Education. June. 2010. 2010;57(2):207-19. X-3.
671 Olatunji BO, Cisler JM, Deacon BJ. Efficacy of cognitive behavioral therapy for anxiety disorders: a review of meta-analytic findings. Psychiatr Clin North Am. Sep. 2010;33(3):557-77. X-5. [pmid: 20599133].
672 Olin AR, Reichle J, Johnson L, et al. Examining dynamic visual scene displays: implications for arranging and teaching symbol selection. Am J Speech Lang Pathol. Nov. 2010;19(4):284-97. X-1, X-3, X-4. [pmid: 20581110].
673 Olin JT, Aarsland D, Meng X. Rivastigmine in the treatment of dementia associated with Parkinson's disease: effects on activities of daily living. Dement Geriatr Cogn Disord. 2010;29(6):510-5. X-5. [pmid: 20523050].
674 Palmen A, Didden R, Korzilius H. Effectiveness of behavioral skills training on staff performance in a job training setting for high-functioning adolescents with autism spectrum disorders. Research in Autism Spectrum Disorders. 2010;4(4):731-40. X-5.
675 Pang Y. Facilitating Family Involvement in Early Intervention to Preschool Transition. School Community Journal. 2010;20(2):183-98. X-5.
676 Paribello C, Tao L, Folino A, et al. Open-label add-on treatment trial of minocycline in fragile X syndrome. BMC Neurol. 2010;10:91. X-5. [pmid: 20937127].
677 Parmanto B, Saptono A, Pramana G, et al. VISYTER: versatile and integrated system for telerehabilitation. Telemed J E Health. Nov. 2010;16(9):939-44. X-5. [pmid: 21034239].
678 Parris A. Implementing interventions for an individual with complex needs through a co-ordinated approach. Advances in Mental Health and Intellectual Disabilities. 2010;4(2):33-7. X-5.
679 Paynter J, Peterson C. Language and ToM development in autism versus Asperger syndrome: Contrasting influences of syntactic versus lexical/semantic maturity. Research in Autism Spectrum Disorders. 7//. 2010;4(3):377-85. X-4.
680 Pedrosa E, Shah A, Tenore C, et al. beta-catenin promoter ChIP-chip reveals potential schizophrenia and bipolar disorder gene network. J Neurogenet. Dec. 2010;24(4):182-93. X-5. [pmid: 20615089].
681 Pelletier K, McNamara B, Braga-Kenyon P, et al. Effect of video self-monitoring on procedural integrity. Behavioral Interventions. 2010;25(4):261-74. X-5.
682 Philippe P, Scholl JM, Jacques J. Comorbidity in autism spectrum. Psychiatr Danub. Nov. 2010;22(Suppl 1):S158-60. X-5. [pmid: 21057429].
683 Pichler J, Horn V, Macdonald S, et al. Review of the diagnoses predisposing infants to intestinal failure on hospitalized parenteral nutrition. Transplant Proc. Jan-Feb. 2010;42(1):22-3. 20172273. X-5. [pmid: 20172273].
684 Pinborough-Zimmerman J, Bilder D, Satterfield R, et al. The impact of surveillance method and record source on autism prevalence: Collaboration with Utah maternal and child health programs. Maternal and Child Health Journal. 2010;14(3):392-400. X-5. [pmid: 19475366].
685 Plavnick JB, Ferreri SJ, Maupin AN. The effects of self-monitoring on the procedural integrity of a behavioral intervention for young children with developmental disabilities. Journal of Applied Behavior Analysis. 2010;43(2):315-20. X-3, X-5. [pmid: 21119907].
686 Ploog BO. Stimulus Overselectivity Four Decades Later: A Review of the Literature and Its Implications for Current Research in Autism Spectrum Disorder. Springer. 233 Spring Street, New York, NY 10013. 2010:1332-49. X-4.
687 Polatajko HJ. The CO-OP Twist. Physical & Occupational Therapy in Pediatrics. 2010;30(4):277-9. X-2, X-3, X-5. [pmid: 20809779].
688 Poling A. Looking to the Future: Will Behavior Analysis Survive and Prosper?. Behavior Analyst. 2010;33(1):7-17. X-5. [pmid: 22479123].
689 Pongpech S, Aurboonyawat T, Visudibhan A, et al. Endovascular management in children with vein of Galen aneurysmal malformation. Minim Invasive Neurosurg. Aug. 2010;53(4):169-74. X-5. [pmid: 21132608].
690 Preece D, Jordan R. Obtaining the views of children and young people with autism spectrum disorders about their experience of daily life and social care support. British Journal of Learning Disabilities. 2010;38(1):10-20. X-5.
691 Price CS, Thompson WW, Goodson B, et al. Prenatal and infant exposure to thimerosal from vaccines and immunoglobulins and risk of autism. Pediatrics. 2010;126(4):656-64. X-5. [pmid: 20837594].
692 Prichard EA, Palucka A, Reid M, et al. Review of admissions of individuals with autism spectrum disorders to a specialized Dual Diagnosis Program. Journal on Developmental Disabilities. 2010;16(1):76-84. X-5.
693 Procyshyn RM, Honer WG, Wu TK, et al. Persistent antipsychotic polypharmacy and excessive dosing in the community psychiatric treatment setting: a review of medication profiles in 435 Canadian outpatients. J Clin Psychiatry. May. 2010;71(5):566-73. X-5. [pmid: 20361903].
694 Punt M, DEJ M, DEG E, et al. Minor neurological dysfunction in children with dyslexia. Dev Med Child Neurol. Dec. 2010;52(12):1127-32. X-5. [pmid: 20518800].
695 Rakap S. Impacts of Learning Styles and Computer Skills on Adult Students' Learning Online. Turkish Online Journal of Educational Technology - TOJET. 2010;9(2):108-15. X-5.
696 Randi J, Newman T, Grigorenko EL. Teaching Children with Autism to Read for Meaning: Challenges and Possibilities. Springer. 233 Spring Street, New York, NY 10013. 2010:890-902. X-1, X-2, X-3, X-4.
697 Rao S, Salmon G. Autism spectrum disorders. Br J Hosp Med (Lond). Dec. 2010;71(12):699-703. X-5. [pmid: 21135768].
698 Read N, Schofield A. Autism: are mental health services failing children and parents?. J Fam Health Care. 2010;20(4):120-4. X-5. [pmid: 21053660].
699 Reed DD, Luiselli JK, Morizio LC, et al. Sequential Modification and the Identification of Instructional Components Occasioning Self-Injurious Behavior. Child & Family Behavior Therapy. 2010;32(1):1-16. X-3.
700 Reichle J, Johnson L, Monn E, et al. Task Engagement and Escape Maintained Challenging Behavior: Differential Effects of General and Explicit Cues when Implementing a Signaled Delay in the Delivery of Reinforcement. Journal of Autism and Developmental Disorders. 2010;40(6):709-20. X-3, X-5. [pmid: 20162345].
701 Reid DH, Parsons MB, Lattimore LP. Designing and evaluating assessment-based interventions to reduce stereotypy among adults with autism in a community job. Behavior Analysis in Practice. 2010;3(2):27-36. X-5. [pmid: 22532891].
702 Rezaei V, Mohammadi MR, Ghanizadeh A, et al. Double-blind, placebo-controlled trial of risperidone plus topiramate in children with autistic disorder. Prog Neuropsychopharmacol Biol Psychiatry. Oct. 1. 2010;34(7):1269-72. X-5. [pmid: 20637249].
703 Robb AS. Managing Irritability and Aggression in Autism Spectrum Disorders in Children and Adolescents. Developmental Disabilities Research Reviews. 2010;16(3):258-64. X-1, X-2, X-3, X-4. [pmid: 20981764].
704 Roberts D, Pickering N. Parent training programme for autism spectrum disorders: an evaluation. Community Pract. Oct. 2010;83(10):27-30. X-3. [pmid: 21049753].
705 Rodger S, Ashburner J, Cartmill L, et al. Helping children with autism spectrum disorders and their families: are we losing our occupation-centred focus?. Aust Occup Ther J. Aug. 2010;57(4):276-80. X-1, X-2, X-3, X-4. [pmid: 20854603].
706 Rodger S, Vishram A. Mastering social and organization goals: strategy use by two children with Asperger syndrome during cognitive orientation to daily occupational performance. Phys Occup Ther Pediatr. Nov. 2010;30(4):264-76. X-3. [pmid: 20822395].
707 Rosenthal E, Brennan L, Xie S, et al. Association between cognition and function in patients with Parkinson disease with and without dementia. Mov Disord. Jul. 15. 2010;25(9):1170-6. X-5. [pmid: 20310053].
708 Rosset DB, Santos A, Da Fonseca D, et al. Do children perceive features of real and cartoon faces in the same way? Evidence from typical development and autism. Journal of Clinical and Experimental Neuropsychology. 2010;32(2):212-8. X-1, X-4. [pmid: 19562609].
709 Roth MP, Williams KE, Paul CM. Treating food and liquid refusal in an adolescent with Asperger's disorder. Clinical Case Studies. 2010;9(4):260-72. X-5.
710 Rotheram-Fuller E, Kasari C, Chamberlain B, et al. Social Involvement of Children with Autism Spectrum Disorders in Elementary School Classrooms. Journal of Child Psychology and Psychiatry. 2010;51(11):1227-34. X-5. [pmid: 20673234].
711 Rowles BM, Findling RL. Review of Pharmacotherapy Options for the Treatment of Attention-Deficit/Hyperactivity Disorder (ADHD) and ADHD-Like Symptoms in Children and Adolescents with Developmental Disorders. Developmental Disabilities Research Reviews. 2010;16(3):273-82. X-2, X-5. [pmid: 20981766].
712 Ruble LA, Dalrymple NJ, McGrew JH. The Effects of Consultation on Individualized Education Program Outcomes for Young Children with Autism: The Collaborative Model for Promoting Competence and Success. Journal of Early Intervention. 2010;32(4):286-301. X-4. [pmid: 21691449].
713 Russell G, Ford T, Steer C, et al. Identification of Children with the Same Level of Impairment as Children on the Autistic Spectrum, and Analysis of Their Service Use. Journal of Child Psychology and Psychiatry. 2010;51(6):643-51. X-5. [pmid: 20345841].
714 Russo N, Foxe JJ, Brandwein AB, et al. Multisensory processing in children with autism: high-density electrical mapping of auditory-somatosensory integration. Autism Res. Oct. 2010;3(5):253-67. X-5. [pmid: 20730775].
715 Russo NM, Hornickel J, Nicol T, et al. Biological changes in auditory function following training in children with autism spectrum disorders. Behav Brain Funct. 2010;6:60. X-3, X-5. [pmid: 20950487].
716 Rutter M, Sonuga-Barke EJ, Castle J. Investigating the Impact of Early Institutional Deprivation on Development: Background and Research Strategy of the English and Romanian Adoptees (ERA) Study. Monographs of the Society for Research in Child Development. 2010;75(1):1-20. X-2, X-5. [pmid: 20500631].
717 Salamanca AA. Psychotherapy treatment program in a group of adults with high-functioning autism spectrum disorder. Actas Esp Psiquiatr. Mar-Apr. 2010;38(2):94-100. X-5. [pmid: 20976638].
718 Sawyer MG, Bittman M, La Greca AM, et al. Time demands of caring for children with autism: what are the implications for maternal mental health?. J Autism Dev Disord. May. 2010;40(5):620-8. X-5. [pmid: 19949845].
719 Scheeren AM, Begeer S, Banerjee R, et al. Can you tell me something about yourself?: Self-presentation in children and adolescents with high functioning autism spectrum disorder in hypothetical and real life situations. Autism. Sep. 2010;14(5):457-73. X-3, X-4. [pmid: 20841344].
720 Schmitt FA, Aarsland D, Bronnick KS, et al. Evaluating rivastigmine in mild-to-moderate Parkinson's disease dementia using ADAS-cog items. Am J Alzheimers Dis Other Demen. Aug. 2010;25(5):407-13. X-5. [pmid: 20392860].
721 Schmitt FA, Farlow MR, Meng X, et al. Efficacy of rivastigmine on executive function in patients with Parkinson's disease dementia. CNS Neurosci Ther. Dec. 2010;16(6):330-6. X-5. [pmid: 20950329].
722 Schneider N, Goldstein H. Using Social Stories and Visual Schedules to Improve Socially Appropriate Behaviors in Children with Autism. Journal of Positive Behavior Interventions. 2010;12(3):149-60. X-3.
723 Schultz ST. Can autism be triggered by acetaminophen activation of the endocannabinoid system?. Acta Neurobiol Exp (Wars). 2010;70(2):227-31. X-5. [pmid: 20628445].
724 Schwichtenberg AJ, Young GS, Sigman M, et al. Can family affectedness inform infant sibling outcomes of autism spectrum disorders?. Journal of Child Psychology and Psychiatry. 2010;51(9):1021-30. X-5. [pmid: 20546079].
725 Self TL, Coufal K, Parham DF. Allied healthcare providers' role in screening for autism spectrum disorder. Journal of Allied Health. 2010;39(3, Pt1):165-74. X-5. [pmid: 21174021].
726 Self TL, Hale LS, Crumrine D. Pharmacotherapy and children with autism spectrum disorder: a tutorial for speech-language pathologists. Lang Speech Hear Serv Sch. Jul. 2010;41(3):367-75. X-5. [pmid: 20543026].
727 Senju A, Southgate V, Miura Y, et al. Absence of spontaneous action anticipation by false belief attribution in children with autism spectrum disorder. Development and Psychopathology. 2010;22(2):353-60. X-4. [pmid: 20423546].
728 Sheng L, Ding X, Ferguson M, et al. Prenatal polycyclic aromatic hydrocarbon exposure leads to behavioral deficits and downregulation of receptor tyrosine kinase, MET. Toxicol Sci. Dec. 2010;118(2):625-34. X-5. [pmid: 20889680].
729 Shireman TI, Reichard A, Nazir N, et al. Quality of diabetes care for adults with developmental disabilities. Disabil Health J. Jul. 2010;3(3):179-85. X-5. [pmid: 21122783].
730 Shute N. Desperate for an autism cure. Sci Am. Oct. 2010;303(4):80-5. X-5. [pmid: 20923134].
731 Shyu YI, Tsai JL, Tsai WC. Explaining and selecting treatments for autism: parental explanatory models in Taiwan. J Autism Dev Disord. Nov. 2010;40(11):1323-31. X-5. [pmid: 20224997].
732 Sidener TM, Carr JE, Karsten AM, et al. Evaluation of Single and Mixed Verbal Operant Arrangements for Teaching Mands and Tacts. Analysis of Verbal Behavior. 2010;26:15-30. X-3. [pmid: 22477459].
733 Simpson CG, Gaus MD, Biggs MJG, et al. Physical Education and Implications for Students with Asperger's Syndrome. TEACHING Exceptional Children. 2010;42(6):48-56. X-5.
734 Smith IM, Koegel RL, Koegel LK, et al. Effectiveness of a novel community-based early intervention model for children with autistic spectrum disorder. Am J Intellect Dev Disabil. Nov. 2010;115(6):504-23. X-5. [pmid: 20946003].
735 Smith JJ. How to Fix an Az-Burger. Reclaiming Children and Youth. 2010;19(1):7-11. X-5.
736 Somani BK, Moseley H, Eljamel MS, et al. Photodynamic diagnosis (PDD) for upper urinary tract transitional cell carcinoma (UT-TCC): evolution of a new technique. Photodiagnosis Photodyn Ther. Mar. 2010;7(1):39-43. X-5. [pmid: 20230992].
737 South M, Larson MJ, Krauskopf E, et al. Error processing in high-functioning autism spectrum disorders. Biological Psychology. 2010;85(2):242-51. X-5. [pmid: 20654684].
738 Sperry L, Neitzel J, Engelhardt-Wells K. Peer-Mediated Instruction and Intervention Strategies for Students with Autism Spectrum Disorders. Preventing School Failure. 2010;54(4):256-64. X-1, X-2, X-3, X-4.
739 St Pourcain B, Wang K, Glessner JT, et al. Association between a high-risk autism locus on 5p14 and social communication spectrum phenotypes in the general population. Am J Psychiatry. Nov. 2010;167(11):1364-72. X-5. [pmid: 20634369].
740 Stahmer AC, Suhrheinrich J, Reed S, et al. Pivotal Response Teaching in the Classroom Setting. Preventing School Failure. 2010;54(4):265-74. X-1, X-2, X-3, X-4.
741 Stanislaus P, Zaak D, Stadler T, et al. Photodynamic diagnosis in patients with T1G3 bladder cancer: influence on recurrence rate. World J Urol. Aug. 2010;28(4):407-11. X-5. [pmid: 20582546].
742 Steward R. On the record: Robyn Steward. Interview by Alita Howe. Ment Health Today. 2010 Dec-2011 Jan. 38. X-5. [pmid: 21235057].
743 Stichter JP, Herzog MJ, Visovsky K, et al. Social competence intervention for youth with Asperger Syndrome and high-functioning autism: an initial investigation. J Autism Dev Disord. Sep. 2010;40(9):1067-79. X-1, X-3. [pmid: 20162344].
744 Strata F, Stoianov IP, de Villers-Sidani E, et al. Perinatal asphyxia affects rat auditory processing: implications for auditory perceptual impairments in neurodevelopmental disorders. PLoS One. 2010;5(12):e15326. X-5. [pmid: 21203459].
745 Su H, Dickstein-Fischer L, Harrington K, et al. Cable-driven elastic parallel humanoid head with face tracking for Autism Spectrum Disorder interventions. Conf Proc IEEE Eng Med Biol Soc. 2010;2010:467-70. X-5. [pmid: 21095653].
746 Sun F, Anderson R, Aguilar G. Stratum corneum permeation and percutaneous drug delivery of hydrophilic molecules enhanced by cryopneumatic and photopneumatic technologies. J Drugs Dermatol. Dec. 2010;9(12):1528-30. X-5. [pmid: 21120262].
747 Sy JR, Borrero JC, Borrero CS. Characterizing Response-Reinforcer Relations in the Natural Environment: Exploratory Matching Analyses. Psychological Record. 2010;60(4):609-26. X-3, X-5.
748 Tanaka JW, Wolf JM, Klaiman C, et al. Using computerized games to teach face recognition skills to children with autism spectrum disorder: the Let's Face It! program. J Child Psychol Psychiatry. Aug. 2010;51(8):944-52. X-1, X-3, X-4. [pmid: 20646129].
749 Tarbox J, Schiff A, Najdowski AC. Parent-implemented procedural modification of escape extinction in the treatment of food selectivity in a young child with autism. Education & Treatment of Children. 2010;33(2):223-34. X-3.
750 Tarbox J, Wilke AE, Findel-Pyles RS, et al. A comparison of electronic to traditional pen-and-paper data collection in discrete trial training for children with autism. Research in Autism Spectrum Disorders. 2010;4(1):65-75. X-3, X-4.
751 Taylor N, Isaac C, Milne E. A comparison of the development of audiovisual integration in children with autism spectrum disorders and typically developing children. J Autism Dev Disord. Nov. 2010;40(11):1403-11. X-5. [pmid: 20354776].
752 Thomas BR, Lafasakis M, Sturmey P. The effects of prompting, fading, and differential reinforcement on vocal mands in non-verbal preschool children with autism spectrum disorders. Behavioral Interventions. 2010;25(2):157-68. X-3, X-4.
753 Tiger JH, Toussaint KA, Roath CT. An Evaluation of the Value of Choice-Making Opportunities in Single-Operant Arrangements: Simple Fixed- and Progressive-Ratio Schedules. Journal of Applied Behavior Analysis. 2010;43(3):519-24. X-3, X-5. [pmid: 21358913].
754 Twarek M, Cihon T, Eshleman J. The effects of fluent levels of big 6 + 6 skill elements on functional motor skills with children with autism. Behavioral Interventions. 2010;25(4):275-93. X-3.
755 Uekusa M, Omura K, Nakajima Y, et al. Uptake and kinetics of 5-aminolevulinic acid in oral squamous cell carcinoma. Int J Oral Maxillofac Surg. Aug. 2010;39(8):802-5. X-5. [pmid: 20409686].
756 Ulke-Kurkcuoglu B, Kircaali-Iftar G. A comparison of the effects of providing activity and material choice to children with autism spectrum disorders. J Appl Behav Anal. Winter. 2010;43(4):717-21. X-3, X-5. [pmid: 21541155].
757 Valdovinos MG, Bailey L, Taylor SL. Examining risperidone use in those diagnosed with autism 1 year after FDA approval. Journal of Clinical Psychiatry. 2010;71(5):651-2. X-1, X-3, X-4. [pmid: 20492856].
758 Valenti M, Cerbo R, Masedu F, et al. Intensive intervention for children and adolescents with autism in a community setting in Italy: A single-group longitudinal study. Child and Adolescent Psychiatry and Mental Health. 2010;4. X-5.
759 Van Santen JP, Prud'hommeaux ET, Black LM, et al. Computational prosodic markers for autism. Autism. May. 2010;14(3):215-36. X-4. [pmid: 20591942].
760 Viau R, Arsenault-Lapierre G, Fecteau S, et al. Effect of service dogs on salivary cortisol secretion in autistic children. Psychoneuroendocrinology. Sep. 2010;35(8):1187-93. X-4. [pmid: 20189722].
761 Virues-Ortega J. Applied behavior analytic intervention for autism in early childhood: meta-analysis, meta-regression and dose-response meta-analysis of multiple outcomes. Clin Psychol Rev. Jun. 2010;30(4):387-99. X-5. [pmid: 20223569].
762 Vladescu JC, Kodak T. A Review of Recent Studies on Differential Reinforcement during Skill Acquisition in Early Intervention. Journal of Applied Behavior Analysis. 2010;43(2):351-5. X-5. [pmid: 21119913].
763 Volden J, Phillips L. Measuring pragmatic language in speakers with autism spectrum disorders: Comparing the children's communication checklist--2 and the test of pragmatic language. Am J Speech Lang Pathol. Aug. 2010;19(3):204-12. X-5. [pmid: 20220047].
764 Von Benzon N. Moving on from Ramps? The Utility of the Social Model of Disability for Facilitating Experiences of Nature for Disabled Children. Disability & Society. 2010;25(5):617-26. X-5.
765 Wachtel LE, Griffin MM, Dhossche DM, et al. Brief Report: Electroconvulsive Therapy for Malignant Catatonia in an Autistic Adolescent. Autism: The International Journal of Research and Practice. 2010;14(4):349-58. X-5. [pmid: 20591959].
766 Walberg JL, Craig-Unkefer LA. An Examination of the Effects of a Social Communication Intervention on the Play Behaviors of Children with Autism Spectrum Disorder. Education and Training in Autism and Developmental Disabilities. 2010;45(1):69-80. X-3.
767 Wallace GL, Dankner N, Kenworthy L, et al. Age-related temporal and parietal cortical thinning in autism spectrum disorders. Brain. Dec. 2010;133(Pt 12):3745-54. X-5. [pmid: 20926367].
768 Wallace KS, Rogers SJ. Intervening in Infancy: Implications for Autism Spectrum Disorders. 2010;51:1300-20. X-1, X-3, X-4.
769 Wallace S, Parsons S, Westbury A, et al. Sense of presence and atypical social judgments in immersive virtual environments. Responses of adolescents with Autism Spectrum Disorders. Autism. May. 2010;14(3):199-213. X-5. [pmid: 20484000].
770 Wang KK, Zhu TC. Modeling scatter-to-primary dose ratio for megavoltage photon beams. Med Phys. Oct. 2010;37(10):5270-8. X-5. [pmid: 21089761].
771 Watson LR, Baranek GT, Roberts JE, et al. Behavioral and physiological responses to child-directed speech as predictors of communication outcomes in children with autism spectrum disorders. J Speech Lang Hear Res. Aug. 2010;53(4):1052-64. X-4. [pmid: 20631229].
772 Wehmeyer ML, Shogren KA, Zager D, et al. Research-Based Principles and Practices for Educating Students with Autism: Self-Determination and Social Interactions. Education and Training in Autism and Developmental Disabilities. 2010;45(4):475-86. X-5.
773 Weil TN, Inglehart MR. Dental education and dentists' attitudes and behavior concerning patients with autism. J Dent Educ. Dec. 2010;74(12):1294-307. X-5. [pmid: 21123497].
774 Weiss JA, Lunsky Y. Group cognitive behaviour therapy for adults with Asperger syndrome and anxiety or mood disorder: A case series. Clinical Psychology & Psychotherapy. 2010;17(5):438-46. X-5. [pmid: 20827741].
775 Weiss MJ, Pearson N, Foley K, et al. The Importance of Fluency Outcomes in Learners with Autism. Behavior Analyst Today. 2010;11(4):245-52. X-1, X-2, X-3, X-4.
776 Weissman AS, Bates ME. Increased Clinical and Neurocognitive Impairment in Children with Autism Spectrum Disorders and Comorbid Bipolar Disorder. Research in Autism Spectrum Disorders. 2010;4(4):670-80. X-5.
777 Wheeler CA, Hatton D, Holloway TV, et al. Maternal Responses to Child Frustration and Requests for Help in Dyads with Fragile X Syndrome. Journal of Intellectual Disability Research. 2010;54(6):501-15. X-5. [pmid: 20426796].
778 White SE, Weiss JA. Services for adults and adolescents with ASD in Ontario—Parent and professional perspectives. Journal on Developmental Disabilities. 2010;16(1):34-9. X-5.
779 White SW, Koenig K, Scahill L. Group Social Skills Instruction for Adolescents with High-Functioning Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 2010;25(4):209-19. X-1.
780 Wichnick AM, Vener SM, Keating C, et al. The effect of a script-fading procedure on unscripted social initiations and novel utterances among young children with autism. Research in Autism Spectrum Disorders. 2010;4(1):51-64. X-3.
781 Wichnick AM, Vener SM, Pyrtek M, et al. The effect of a script-fading procedure on responses to peer initiations among young children with autism. Research in Autism Spectrum Disorders. 2010;4(2):290-9. X-3.
782 Wilder DA, Allison J, Nicholson K, et al. Further evaluation of antecedent interventions on compliance: the effects of rationales to increase compliance among preschoolers. J Appl Behav Anal. Winter. 2010;43(4):601-13. X-3. [pmid: 21541147].
783 Wilkinson LA. School-Age Children with Autism Spectrum Disorders: Screening and Identification. European Journal of Special Needs Education. August. 2010. 2010;25(3):211-23. X-5.
784 Wilkinson LA. Facilitating the Identification of Autism Spectrum Disorders in School-Age Children. Remedial and Special Education. 2010. 2010;31(5):350-7. X-5.
785 Wise MD, Little AA, Holliman JB, et al. Can state early intervention programs meet the increased demand of children suspected of having autism spectrum disorders?. J Dev Behav Pediatr. Jul-Aug. 2010;31(6):469-76. X-5. [pmid: 20585267].
786 Wong VC, Chen WX. Randomized controlled trial of electro-acupuncture for autism spectrum disorder. Altern Med Rev. Jul. 2010;15(2):136-46. X-1. [pmid: 20806998].
787 Wong VC, Sun JG. Randomized controlled trial of acupuncture versus sham acupuncture in autism spectrum disorder. J Altern Complement Med. May. 2010;16(5):545-53. X-5. [pmid: 20804366].
788 Woodbury-Smith M, Clare I, Holland AJ, et al. Circumscribed interests and ‘offenders’ with autism spectrum disorders: A case-control study. Journal of Forensic Psychiatry & Psychology. 2010;21(3):366-77. X-5.
789 Wu Y-P, Mirenda P, Wang H-P, et al. Assessment and Treatment of Stereotypic Vocalizations in a Taiwanese Adolescent with Autism: A Case Study. International Journal of Special Education. 2010;25(3):160-7. X-5.
790 Xu X, Yang H, Lin YF, et al. Neuronal Abelson helper integration site-1 (Ahi1) deficiency in mice alters TrkB signaling with a depressive phenotype. Proc Natl Acad Sci U S A. Nov. 2. 2010;107(44):19126-31. X-5. [pmid: 20956301].
791 Yang P, Lung F-W, Jong Y-J, et al. Stability and change of cognitive attributes in children with uneven/delayed cognitive development from preschool through childhood. Research in Developmental Disabilities. 2010;31(4):895-902. X-5. [pmid: 20346615].
792 Yanos PT, Lysaker PH, Roe D. Internalized stigma as a barrier to improvement in vocational functioning among people with schizophrenia-spectrum disorders. Psychiatry Research. 2010;178(1):211-3. X-5. [pmid: 20417973].
793 Yilmaz I, Konukman F, Birkan B, et al. Effects of Constant Time Delay Procedure on the Halliwick's Method of Swimming Rotation Skills for Children with Autism. Education and Training in Autism and Developmental Disabilities. 2010;45(1):124-35. X-3, X-5.
794 Yokotani K. Educational level signals unobserved abilities of people with high functioning autism spectrum disorders. Psychol Rep. Aug. 2010;107(1):227-35. X-5. [pmid: 20923067].
795 Zaidman-Zait A, Mirenda P, Zumbo BD, et al. An item response theory analysis of the Parenting Stress Index-Short Form with parents of children with autism spectrum disorders. J Child Psychol Psychiatry. Nov. 2010;51(11):1269-77. X-5. [pmid: 20546082].
796 Autism spectrum disorders revisited. Several recent studies raise new questions about cause and prevention. Harv Ment Health Lett. Oct. 2011;28(4):1-3. X-5. [pmid: 22125823].
797 No “magic pill” for autism spectrum disorders. Although medication prescriptions are common, there is little evidence they do any good. Harv Ment Health Lett. Aug. 2011;28(2):4. X-5. [pmid: 21980632].
798 Fear and its consequences. Sci Am. Feb. 2011;304(2):14. X-5. [pmid: 21319529].
799 Adamek L, Nichols S, Tetenbaum SP, et al. Individual Temperament and Problem Behavior in Children with Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 2011;26(3):173-83. X-5.
800 Adams JB, Audhya T, McDonough-Means S, et al. Effect of a vitamin/mineral supplement on children and adults with autism. BMC Pediatr. 2011;11:111. X-1. [pmid: 22151477].
801 Adams JB, Johansen LJ, Powell LD, et al. Gastrointestinal flora and gastrointestinal status in children with autism--comparisons to typical children and correlation with autism severity. BMC Gastroenterol. 2011;11:22. X-5. [pmid: 21410934].
802 Ahrens EN, Lerman DC, Kodak T, et al. Further evaluation of response interruption and redirection as treatment for stereotypy. J Appl Behav Anal. Spring. 2011;44(1):95-108. X-3. [pmid: 21541130].
803 Akmanoglu N, Tekin-Iftar E. Teaching children with autism how to respond to the lures of strangers. Autism. Mar. 2011;15(2):205-22. X-3. [pmid: 21339247].
804 Al Abdulmohsen T, Kruger TH. The contribution of muscular and auditory pathologies to the symptomatology of autism. Med Hypotheses. Dec. 2011;77(6):1038-47. X-5. [pmid: 21925796].
805 Al-Farsi YM, Al-Sharbati MM, Waly MI, et al. Malnutrition among Preschool-Aged Autistic Children in Oman. Research in Autism Spectrum Disorders. 2011;5(4):1549-52. X-5.
806 Aljunied M, Frederickson N. Cognitive Indicators of Different Levels of Special Educational Support Needs in Autism. Research in Autism Spectrum Disorders. 2011;5(1):368-76. X-5.
807 Alkonyi B, Chugani HT, Karia S, et al. Clinical outcomes in bilateral Sturge-Weber syndrome. Pediatr Neurol. Jun. 2011;44(6):443-9. X-5. [pmid: 21555056].
808 Allen K. Managing Prader-Willi syndrome in families: an embodied exploration. Soc Sci Med. Feb. 2011;72(4):460-8. X-5. [pmid: 21216515].
809 Al-Yafee YA, Al-Ayadhi LY, Haq SH, et al. Novel metabolic biomarkers related to sulfur-dependent detoxification pathways in autistic patients of Saudi Arabia. BMC Neurology. 2011. X-5.
810 Amirabdollahian F, Robins B, Dautenhahn K, et al. Investigating tactile event recognition in child-robot interaction for use in autism therapy. Conf Proc IEEE Eng Med Biol Soc. 2011;2011:5347-51. X-3, X-4. [pmid: 22255546].
811 Anastasiou D, Kauffman JM. A Social Constructionist Approach to Disability: Implications for Special Education. Exceptional Children. 2011;77(3):367-84. X-5.
812 Anderberg D, Chevalier A, Wadsworth J. Anatomy of a health scare: education, income and the MMR controversy in the UK. J Health Econ. May. 2011;30(3):515-30. 21439663. X-5. [pmid: 21439663].
813 Anderson J, Le DD. Abatement of intractable vocal stereotypy using an overcorrection procedure. Behavioral Interventions. 2011;26(2):134-46. X-3.
814 Angell ME, Nicholson JK, Watts EH, et al. Using a Multicomponent Adapted Power Card Strategy to Decrease Latency during Interactivity Transitions for Three Children with Developmental Disabilities. Focus on Autism and Other Developmental Disabilities. 2011;26(4):206-17. X-3.
815 Antshel KM, Polacek C, McMahon M, et al. Comorbid ADHD and anxiety affect social skills group intervention treatment efficacy in children with autism spectrum disorders. J Dev Behav Pediatr. Jul-Aug. 2011;32(6):439-46. X-5. [pmid: 21654508].
816 Arron K, Oliver C, Moss J, et al. The Prevalence and Phenomenology of Self-Injurious and Aggressive Behaviour in Genetic Syndromes. Journal of Intellectual Disability Research. 2011;55(2):109-20. X-5. [pmid: 20977515].
817 Assouline SG, Whiteman CS. Twice-Exceptionality: Implications for School Psychologists in the Post-IDEA 2004 Era. Journal of Applied School Psychology. 2011;27(4):380-402. X-5.
818 Aubry JF, Bouchard H, Bessieres I, et al. Validation of an electron Monte Carlo dose calculation algorithm in the presence of heterogeneities using EGSnrc and radiochromic film measurements. J Appl Clin Med Phys. 2011;12(4):3392. X-5. [pmid: 22088999].
819 Avidan MS, Smith JR, Skrupky LP, et al. The occurrence of antibodies to heparin-platelet factor 4 in cardiac and thoracic surgical patients receiving desirudin or heparin for postoperative venous thrombosis prophylaxis. Thromb Res. Dec. 2011;128(6):524-9. X-5. [pmid: 21794899].
820 Ayres KM, Douglas KH, Lowrey AK, et al. I Can Identify Saturn but I Can't Brush My Teeth: What Happens when the Curricular Focus for Students with Severe Disabilities Shifts. Education and Training in Autism and Developmental Disabilities. 2011;46(1):11-21. X-5.
821 Baandrup L, Fagerlund B, Jennum P, et al. Prolonged-release melatonin versus placebo for benzodiazepine discontinuation in patients with schizophrenia: a randomized clinical trial - the SMART trial protocol. BMC Psychiatry. 2011;11:160. X-5. [pmid: 21975110].
822 Bagshaw M. Anaesthesia and the autistic child. J Perioper Pract. Sep. 2011;21(9):313-7. X-5. [pmid: 22474776].
823 Bailey RL, Angell ME, Stoner JB. Improving Literacy Skills in Students with Complex Communication Needs Who Use Augmentative/Alternative Communication Systems. Education and Training in Autism and Developmental Disabilities. 2011;46(3):352-68. X-1, X-3, X-4.
824 Bakare MO, Igwe MN, Odinka PC, et al. Neuropsychiatric diagnosis and psychotropic medication prescription patterns in a mental hospital-based child and adolescent psychiatric service in Nigeria. J Health Care Poor Underserved. Aug. 2011;22(3):751-5. X-5. [pmid: 21841276].
825 Baltruschat L, Hasselhorn M, Tarbox J, et al. Addressing Working Memory in Children with Autism through Behavioral Intervention. Research in Autism Spectrum Disorders. 2011;5(1):267-76. X-3.
826 Baltruschat L, Hasselhorn M, Tarbox J, et al. Further Analysis of the Effects of Positive Reinforcement on Working Memory in Children with Autism. Research in Autism Spectrum Disorders. 2011. 2011;5(2):855-63. X-3.
827 Bancroft SL, Weiss JS, Libby ME, et al. A comparison of procedural variations in teaching behavior chains: manual guidance, trainer completion, and no completion of untrained steps. J Appl Behav Anal. Fall. 2011;44(3):559-69. X-3. [pmid: 21941385].
828 Barbaro J, Ridgway L, Dissanayake C. Developmental surveillance of infants and toddlers by maternal and child health nurses in an Australian community-based setting: promoting the early identification of autism spectrum disorders. J Pediatr Nurs. Aug. 2011;26(4):334-47. 21726784. X-5. [pmid: 21726784].
829 Barnhill GP, Polloway EA, Sumutka BM. A Survey of Personnel Preparation Practices in Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 2011;26(2):75-86. X-5.
830 Bartlett SM, Rapp JT, Krueger TK, et al. The use of response cost to treat spitting by a child with autism. Behavioral Interventions. 2011;26(1):76-83. X-3.
831 Beherec L, Lambrey S, Quilici G, et al. Retrospective review of clozapine in the treatment of patients with autism spectrum disorder and severe disruptive behaviors. J Clin Psychopharmacol. Jun. 2011;31(3):341-4. X-1, X-3. [pmid: 21508854].
832 Belleudi V, Fusco D, Kirchmayer U, et al. Definition of patients treated with evidence based drugs in absence of prescribed daily doses: the example of acute myocardial infarction. Pharmacoepidemiol Drug Saf. Feb. 2011;20(2):169-76. X-5. [pmid: 21254288].
833 Ben Said M, Robel L, Vion E, et al. Implementation and experimentation of TEDIS: an information system dedicated to patients with pervasive developmental disorders. Stud Health Technol Inform. 2011;169:270-4. X-4, X-5. [pmid: 21893755].
834 Bendixen RM, Elder JH, Donaldson S, et al. Effects of a father-based in-home intervention on perceived stress and family dynamics in parents of children with autism. Am J Occup Ther. Nov-Dec. 2011;65(6):679-87. X-5. [pmid: 22214112].
835 Bennett K, Reichow B, Wolery M. Effects of Structured Teaching on the Behavior of Young Children with Disabilities. Focus on Autism and Other Developmental Disabilities. 2011;26(3):143-52. X-3, X-5.
836 Bent S, Bertoglio K, Ashwood P, et al. A pilot randomized controlled trial of omega-3 fatty acids for autism spectrum disorder. J Autism Dev Disord. May. 2011;41(5):545-54. X-5. [pmid: 20683766].
837 Berger BE, Navar-Boggan AM, Omer SB. Congenital rubella syndrome and autism spectrum disorder prevented by rubella vaccination--United States, 2001-2010. BMC Public Health. 2011;11:340. X-5. [pmid: 21592401].
838 Bergstrom R, Tarbox J, Gutshall KA. Behavioral intervention for domestic pet mistreatment in a young child with autism. Research in Autism Spectrum Disorders. 2011;5(1):218-21. X-3.
839 Bernardi L, Tuzzi A. Analyzing written communication in AAC contexts: a statistical perspective. Augment Altern Commun. Sep. 2011;27(3):183-94. 22008031. X-3, X-5. [pmid: 22008031].
840 Bernhardt EB, Walsh KH, Posey DJ, et al. Memantine for comorbid obsessive-compulsive disorder and Asperger disorder suggests a link in glutamatergic dysregulation. Journal of Clinical Psychopharmacology. 2011;31(5):673-5. X-5. [pmid: 21881459].
841 Betz AM, Higbee TS, Kelley KN, et al. Increasing Response Variability of Mand Frames with Script Training and Extinction. Journal of Applied Behavior Analysis. 2011;44(2):357-62. X-3. [pmid: 21709793].
842 Beversdorf DQ, Saklayen S, Higgins KF, et al. Effect of propranolol on word fluency in autism. Cogn Behav Neurol. Mar. 2011;24(1):11-7. X-5. [pmid: 21487259].
843 Bhandari A, Sandlow JI, Brannigan RE. Risks to offspring associated with advanced paternal age. J Androl. Mar-Apr. 2011;32(2):121-2. X-5. [pmid: 20467047].
844 Bhat AN, Landa RJ, Galloway JC. Current perspectives on motor functioning in infants, children, and adults with autism spectrum disorders. Phys Ther. Jul. 2011;91(7):1116-29. X-5. [pmid: 21546566].
845 Birkan B, Krantz PJ, McClannahan LE. Teaching children with autism spectrum disorders to cooperate with injections. Research in Autism Spectrum Disorders. 2011;5(2):941-8. X-3.
846 Bishop DV, Jacobs PA, Lachlan K, et al. Autism, language and communication in children with sex chromosome trisomies. Arch Dis Child. Oct. 2011;96(10):954-9. X-5. [pmid: 20656736].
847 Blair K-SC, Lee I-S, Cho S-J, et al. Positive behavior support through family–school collaboration for young children with autism. Topics in Early Childhood Special Education. 2011;31(1):22-36. X-3.
848 Bloom SE, Iwata BA, Fritz JN, et al. Classroom Application of a Trial-Based Functional Analysis. Journal of Applied Behavior Analysis. 2011;44(1):19-31. X-5. [pmid: 21541140].
849 Boccanfuso L, O'Kane JM. CHARLIE : An adaptive robot design with hand and face tracking for use in autism therapy. International Journal of Social Robotics. 2011;3(4):337-47. X-3, X-5.
850 Bolton PF, Carcani-Rathwell I, Hutton J, et al. Epilepsy in autism: features and correlates. Br J Psychiatry. Apr. 2011;198(4):289-94. X-5. [pmid: 21972278].
851 Bowker A, D'Angelo NM, Hicks R, et al. Treatments for autism: parental choices and perceptions of change. J Autism Dev Disord. Oct. 2011;41(10):1373-82. X-4, X-5. [pmid: 21161676].
852 Boyd BA, McDonough SG, Rupp B, et al. Effects of a family-implemented treatment on the repetitive behaviors of children with autism. J Autism Dev Disord. Oct. 2011;41(10):1330-41. X-3. [pmid: 21161576].
853 Bragesjo F, Hallberg M. Dilemmas of a vitalizing vaccine market: lessons from the MMR vaccine/autism debate. Sci Context. Mar. 2011;24(1):107-25. X-5. [pmid: 21560548].
854 Brookman-Frazee L, LaRosa A, Nyp SS, et al. Journal article reviews. Journal of Developmental and Behavioral Pediatrics. 2011;32(3):268. X-5.
855 Brosnan J, Healy O. A Review of Behavioral Interventions for the Treatment of Aggression in Individuals with Developmental Disabilities. 2011;32:437-46. X-5.
856 Brown T. Right treatment, right patient?. Am J Nurs. Jun. 2011;111(6):72. X-5. [pmid: 21613926].
857 Bruder MB. A Well Walked Path to Program Efficacy: The Details Tell the Story. Topics in Early Childhood Special Education. 2011;31(3):158-61. X-1, X-2, X-3, X-4, X-5.
858 Bruns DA, Thompson S. Time to Eat: Improving Mealtimes of Young Children with Autism. Young Exceptional Children. 2011;14(4):3-18. X-2, X-5.
859 Buckley AW, Sassower K, Rodriguez AJ, et al. An open label trial of donepezil for enhancement of rapid eye movement sleep in young children with autism spectrum disorders. J Child Adolesc Psychopharmacol. Aug. 2011;21(4):353-7. X-3. [pmid: 21851192].
860 Budd KS, Hella B, Bae H, et al. Delivering Parent-Child Interaction Therapy in an Urban Community Clinic. Cognitive and Behavioral Practice. 2011;18(4):502-14. X-3.
861 Buggey T, Hoomes G. Using Video Self-Modeling with Preschoolers with Autism Spectrum Disorder: Seeing Can Be Believing. Young Exceptional Children. 2011;14(3):2-12. X-1, X-2, X-3, X-4.
862 Buggey T, Hoomes G, Sherberger ME, et al. Facilitating Social Initiations of Preschoolers with Autism Spectrum Disorders Using Video Self-Modeling. Focus on Autism and Other Developmental Disabilities. 2011;26(1):25-36. X-3.
863 Burket JA, Herndon AL, Winebarger EE, et al. Complex effects of mGluR5 antagonism on sociability and stereotypic behaviors in mice: possible implications for the pharmacotherapy of autism spectrum disorders. Brain Res Bull. Oct. 10. 2011;86(3-4):152-8. X-5. [pmid: 21840381].
864 Busse TR, Downey J. Selective Mutism: A Three-Tiered Approach to Prevention and Intervention. Contemporary School Psychology. 2011;15:53-63. X-5.
865 Calarge CA, Miller del D. Predictors of risperidone and 9-hydroxyrisperidone serum concentration in children and adolescents. J Child Adolesc Psychopharmacol. Apr. 2011;21(2):163-9. X-4. [pmid: 21486167].
866 Call NA, Pabico RS, Findley AJ, et al. Differential reinforcement with and without blocking as treatment for elopement. J Appl Behav Anal. Winter. 2011;44(4):903-7. X-3, X-4. [pmid: 22219538].
867 Campbell A, Tincani M. The Power Card Strategy: Strength-Based Intervention to Increase Direction Following of Children with Autism Spectrum Disorder. Journal of Positive Behavior Interventions. 2011;13(4):240-9. X-3.
868 Cappadocia CM, Weiss JA. Review of Social Skills Training Groups for Youth with Asperger Syndrome and High Functioning Autism. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2011:70-8. X-1, X-2, X-3, X-4.
869 Cardon TA, Wilcox MJ. Promoting imitation in young children with autism: a comparison of reciprocal imitation training and video modeling. J Autism Dev Disord. May. 2011;41(5):654-66. X-3. [pmid: 20697791].
870 Cardon TA, Wilcox MJ, Campbell PH. Caregiver perspectives about assistive technology use with their young children with autism spectrum disorders. Infants & Young Children. 2011;24(2):153-73. X-4.
871 Carlson E, Jenkins F, Bitterman A, et al. A Longitudinal View of the Receptive Vocabulary and Math Achievement of Young Children with Disabilities. NCSER 2011-3006. National Center for Special Education Research. 400 Maryland Avenue SW, Washington, DC 20202. 2011:1-105. X-4.
872 Carroll RA, Rapp JT, Rieck TM, et al. The effects of noncontingent reinforcement with alternative oral stimulation in the treatment of rumination. Journal on Developmental Disabilities. 2011;17(1):72-6. X-3.
873 Carter M, Roberts J, Williams K, et al. Interventions Used with an Australian Sample of Preschool Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2011;5(3):1033-41. X-5.
874 Cassella MD, Sidener TM, Sidener DW, et al. Response interruption and redirection for vocal stereotypy in children with autism: a systematic replication. J Appl Behav Anal. Spring. 2011;44(1):169-73. X-3. [pmid: 21541114].
875 Cezar GG. Profile of Gabriela G. Cezar. Interview by Kristie Nybo. Biotechniques. May. 2011;50(5):281. X-5. [pmid: 21548887].
876 Chan JM, O'Reilly MF, Lang RB, et al. Evaluation of a Social Stories[TM] Intervention Implemented by Pre-Service Teachers for Students with Autism in General Education Settings. Research in Autism Spectrum Disorders. 2011;5(2):715-21. X-3.
877 Charles J, Harrison C, Britt H. Autism spectrum disorders. Aust Fam Physician. Sep. 2011;40(9):665. X-4, X-5. [pmid: 21894271].
878 Charles J, Harrison CM, Britt H. Management of children's psychological problems in general practice 1970-1971, 1990-1991 and 2008-2009. Aust N Z J Psychiatry. Nov. 2011;45(11):976-84. X-5. [pmid: 22017686].
879 Charlot L, Abend S, Ravin P, et al. Non-psychiatric health problems among psychiatric inpatients with intellectual disabilities. J Intellect Disabil Res. Feb. 2011;55(2):199-209. 20546095. X-5. [pmid: 20546095].
880 Charman T. Commentary: Glass Half Full or Half Empty? Testing Social Communication Interventions for Young Children with Autism--Reflections on Landa, Holman, O'Neill, and Stuart (2011). Journal of Child Psychology and Psychiatry. January. 2011. 2011;52(1):22-3. X-2, X-5. [pmid: 21143228].
881 Charnsil C. Efficacy of atomoxetine in children with severe autistic disorders and symptoms of ADHD: an open-label study. J Atten Disord. Nov. 2011;15(8):684-9. X-1, X-3. [pmid: 20686100].
882 Chase CA. An Intergenerational E-Mail Pal Project on Attitudes of College Students toward Older Adults. Educational Gerontology. 2011;37(1):27-37. X-5.
883 Chevallier C, Noveck I, Happe F, et al. What's in a voice? Prosody as a test case for the Theory of Mind account of autism. Neuropsychologia. Feb. 2011;49(3):507-17. X-5. [pmid: 21134386].
884 Chiang IT, Chen M-L. Embracing Complexity: Using Technology to Develop a Life-Long Learning Model for Non-Working Time in the Interdependent Homes for Adults with Autism Spectrum Disorders. Turkish Online Journal of Educational Technology - TOJET. 2011;10(4):174-80. X-5.
885 Chien IC, Lin CH, Chou YJ, et al. Prevalence and incidence of autism spectrum disorders among national health insurance enrollees in Taiwan from 1996 to 2005. J Child Neurol. Jul. 2011;26(7):830-4. X-5. [pmid: 21460178].
886 Childress DC. Play Behaviors of Parents and Their Young Children with Disabilities. Topics in Early Childhood Special Education. 2011;31(2):112-20. X-5.
887 Cho W, Kielar KN, Mok E, et al. Multisource modeling of flattening filter free (FFF) beam and the optimization of model parameters. Med Phys. Apr. 2011;38(4):1931-42. X-5. [pmid: 21626926].
888 Choi YB, Li HL, Kassabov SR, et al. Neurexin-neuroligin transsynaptic interaction mediates learning-related synaptic remodeling and long-term facilitation in aplysia. Neuron. May. 12. 2011;70(3):468-81. X-5. [pmid: 21555073].
889 Chung SY, Yoon HJ. A framework for treatment of autism using affective computing. Stud Health Technol Inform. 2011;163:132-4. X-5. [pmid: 21335775].
890 Chung TK, Lynch ER, Fiser CJ, et al. Psychiatric comorbidity and treatment response in patients with tuberous sclerosis complex. Ann Clin Psychiatry. Nov. 2011;23(4):263-9. X-5. [pmid: 22073383].
891 Cihak DF. Comparing Pictorial and Video Modeling Activity Schedules during Transitions for Students with Autism Spectrum DisordersResearch in Autism Spectrum Disorders. 2011;5(1):433-41. X-3, X-5.
892 Cimera RE, Burgess S. Do adults with autism benefit monetarily from working in their communities?. Journal of Vocational Rehabilitation. 2011;34(3):173-80. X-5.
893 Cleary MJ. Developments in Neurofeedback: Should Health Educators Be Paying Attention?. Health Educator. 2011;43(2):21-6. X-5.
894 Collins A, Dworkin RJ. Pilot study of the effectiveness of weighted vests. Am J Occup Ther. Nov-Dec. 2011;65(6):688-94. X-1, X-3, X-4. [pmid: 22214113].
895 Corbett BA, Gunther JR, Comins D, et al. Brief report: theatre as therapy for children with autism spectrum disorder. J Autism Dev Disord. Apr. 2011;41(4):505-11. X-3. [pmid: 20640592].
896 Coulter ME, Miller DT, Harris DJ, et al. Chromosomal microarray testing influences medical management. Genet Med. Sep. 2011;13(9):770-6. X-5. [pmid: 21716121].
897 Coupienne I, Bontems S, Dewaele M, et al. NF-kappaB inhibition improves the sensitivity of human glioblastoma cells to 5-aminolevulinic acid-based photodynamic therapy. Biochem Pharmacol. Mar. 1. 2011;81(5):606-16. X-5. [pmid: 21182827].
898 Crighton P. Vaccines need a shot in the arm. Aust Nurs J. May. 2011;18(10):40-1. X-5. [pmid: 21667703].
899 Croen LA, Grether JK, Yoshida CK, et al. Antidepressant use during pregnancy and childhood autism spectrum disorders. Arch Gen Psychiatry. Nov. 2011;68(11):1104-12. X-5. [pmid: 21727247].
900 Curran MP. Aripiprazole in the treatment of irritability associated with autistic disorder in paediatric patients. CNS Drugs. 2011;25(9):801-2. X-1, X-2, X-3, X-4. [pmid: 21870890].
901 Cusmai R, Moavero R, Bombardieri R, et al. Long-term neurological outcome in children with early-onset epilepsy associated with tuberous sclerosis. Epilepsy Behav. Dec. 2011;22(4):735-9. X-5. [pmid: 22142783].
902 Daley MF, Glanz JM. Straight talk about vaccination. Sci Am. Sep. 2011;305(3):32. 4. X-5. [pmid: 21870438].
903 Danzer E, Gerdes M, Bebbington MW, et al. Preschool neurobehavioral outcome following fetal myelomeningocele surgery. Fetal Diagn Ther. 2011;30(3):174-9. X-5. [pmid: 21912086].
904 Dardennes RM, Al Anbar NN, Prado-Netto A, et al. Treating the cause of illness rather than the symptoms: parental causal beliefs and treatment choices in autism spectrum disorder. Res Dev Disabil. May-Jun. 2011;32(3):1137-46. X-5. [pmid: 21316189].
905 Darretxe L, Sepulveda L. Educational Strategies to Address the Educational Needs of Students with Asperger Syndrome in the Mainstream Classroom. Electronic Journal of Research in Educational Psychology. 2011;9(2):869-92. X-5.
906 David N, T RS, Vogeley K, et al. Impairments in multisensory processing are not universal to the autism spectrum: no evidence for crossmodal priming deficits in Asperger syndrome. Autism Res. Oct. 2011;4(5):383-8. X-5. [pmid: 21882310].
907 Davidovitch M, Golan D, Vardi O, et al. Israeli children with autism spectrum disorder are not macrocephalic. Journal of Child Neurology. 2011;26(5):580-5. X-5. [pmid: 21464237].
908 Davis TN, Durand S, Chan JM. The Effects of a Brushing Procedure on Stereotypical Behavior. Research in Autism Spectrum Disorders. 2011;5(3):1053-8. X-3.
909 Davit CJ, Hundley RJ, Bacic JD, et al. A pilot study to improve venipuncture compliance in children and adolescents with autism spectrum disorders. J Dev Behav Pediatr. Sep. 2011;32(7):521-5. X-4. [pmid: 21694630].
910 Dawson G, Burner K. Behavioral interventions in children and adolescents with autism spectrum disorder: a review of recent findings. Curr Opin Pediatr. Dec. 2011;23(6):616-20. X-2, X-5. [pmid: 22037220].
911 De Leo G, Gonzales CH, Battagiri P, et al. A smart-phone application and a companion website for the improvement of the communication skills of children with autism: clinical rationale, technical development and preliminary results. J Med Syst. Aug. 2011;35(4):703-11. X-3, X-4. [pmid: 20703781].
912 Delong G. A positive association found between autism prevalence and childhood vaccination uptake across the U.S. population. J Toxicol Environ Health A. 2011;74(14):903-16. X-5. [pmid: 21623535].
913 Demb H, Valicenti-McDermott M, Navarro A, et al. The effect of long-term use of risperidone on body weight of children with an autism spectrum disorder. Journal of Clinical Psychopharmacology. 2011;31(5):669-70. X-5. [pmid: 21881456].
914 Devlin S, Healy O, Leader G, et al. Comparison of behavioral intervention and sensory-integration therapy in the treatment of challenging behavior. J Autism Dev Disord. Oct. 2011;41(10):1303-20. X-3. [pmid: 21161577].
915 Dickstein-Fischer L, Alexander E, Yan X, et al. An affordable compact humanoid robot for Autism Spectrum Disorder interventions in children. Conf Proc IEEE Eng Med Biol Soc. 2011;2011:5319-22. X-5. [pmid: 22255539].
916 DiGennaro Reed FD, Hyman SR, Hirst JM. Applications of Technology to Teach Social Skills to Children with Autism. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2011:1003-10. X-3, X-4.
917 DiGennaro Reed FD, Reed DD, Baez CN, et al. A Parametric Analysis of Errors of Commission during Discrete-Trial Training. Journal of Applied Behavior Analysis. 2011;44(3):611-5. X-3, X-5. [pmid: 21941391].
918 Dillenburger K. The Emperor's New Clothes: Eclecticism in Autism Treatment. Research in Autism Spectrum Disorders. 2011;5(3):1119-28. X-5.
919 Dingfelder HE, Mandell DS. Bridging the research-to-practice gap in autism intervention: an application of diffusion of innovation theory. J Autism Dev Disord. May. 2011;41(5):597-609. X-5. [pmid: 20717714].
920 Dionne M, Martini R. Floor time play with a child with autism: A single-subject study. Canadian Journal of Occupational Therapy/ Revue Canadienne D'Ergothérapie. 2011;78(3):196-203. X-3.
921 Dittlinger LH, Lerman DC. Further Analysis of Picture Interference when Teaching Word Recognition to Children with Autism. Journal of Applied Behavior Analysis. 2011;44(2):341-9. X-3, X-5. [pmid: 21709789].
922 Dixon DR, Tarbox J, Najdowski AC, et al. A Comprehensive Evaluation of Language for Early Behavioral Intervention Programs: The Reliability of the SKILLS Language Index. Research in Autism Spectrum Disorders. 2011;5(1):506-11. X-5.
923 Dixon M, Baker JC, Sadowski KA. Applying Skinner's Analysis of Verbal Behavior to Persons with Dementia. Behavior Therapy. 2011;42(1):120-6. X-5. [pmid: 21292058].
924 Dodd JL, Ocampo A, Kennedy KS. Perspective Taking through Narratives: An Intervention for Students with ASD. Communication Disorders Quarterly. 2011;33(1):23-33. X-5.
925 Donaldson JM, Vollmer TR. An Evaluation and Comparison of Time-Out Procedures with and without Release Contingencies. Journal of Applied Behavior Analysis. 2011;44(4):693-705. X-3. [pmid: 22219523].
926 Donaldson SO, Elder JH, Self EH, et al. Fathers' perceptions of their roles during in-home training for children with autism. J Child Adolesc Psychiatr Nurs. Nov. 2011;24(4):200-7. X-5. [pmid: 22044567].
927 Donoghue K, Stallard P, Kucia J. The clinical practice of Cognitive Behavioural Therapy for children and young people with a diagnosis of Asperger's Syndrome. Clin Child Psychol Psychiatry. Jan. 2011;16(1):89-102. X-5. [pmid: 20516059].
928 Dotto-Fojut KM, Reeve KF, Townsend DB, et al. Teaching adolescents with autism to describe a problem and request assistance during simulated vocational tasks. Research in Autism Spectrum Disorders. 2011;5(2):826-33. X-5.
929 Doty KJ. Student perceptions of progress in a postsecondary residential program for adults with learning disabilities. J Soc Work Disabil Rehabil. 2011;10(3):150-65. X-5. [pmid: 21827300].
930 Doughty AH, Hopkins MN. Reducing Stimulus Overselectivity through an Increased Observing-Response Requirement. Journal of Applied Behavior Analysis. 2011;44(3):653-7. X-5. [pmid: 21941399].
931 Doyen C, Mighiu D, Kaye K, et al. Melatonin in children with autistic spectrum disorders: Recent and practical data. European Child & Adolescent Psychiatry. 2011;20(5):231-9. X-2, X-5. [pmid: 21359552].
932 Doyle T, Arnedillo-Sanchez I. Using Multimedia to Reveal the Hidden Code of Everyday Behaviour to Children with Autistic Spectrum Disorders (ASDs). Computers & Education. 2011;56(2):357-69. X-4.
933 Dozier CL, Iwata BA, Worsdell AS. Assessment and Treatment of Foot-Shoe Fetish Displayed by a Man with Autism. Journal of Applied Behavior Analysis. 2011;44(1):133-7. X-5. [pmid: 21541112].
934 Duffy C, Healy O. Spontaneous Communication in Autism Spectrum Disorder: A Review of Topographies and Interventions. Research in Autism Spectrum Disorders. 2011;5(3):977-83. X-2, X-5.
935 Duke TS. Lesbian, Gay, Bisexual, and Transgender Youth with Disabilities: A Meta-Synthesis. Routledge. 325 Chestnut Street Suite 800, Philadelphia, PA 19106. 2011:1-52. X-4.
936 Dunst CJ, Trivette CM, Masiello T. Exploratory investigation of the effects of interest-based learning on the development of young children with autism. Autism. May. 2011;15(3):295-305. 21430019. X-5. [pmid: 21430019].
937 C Edrisinha, MF O'Reilly, HY Choi, et al. “Say Cheese”: teaching photography skills to adults with developmental disabilities. Res Dev Disabil. Mar-Apr. 2011;32(2):636-42. X-5. [pmid: 21227636].
938 Ekas NV, Whitman TL. Adaptation to daily stress among mothers of children with an autism spectrum disorder: the role of daily positive affect. J Autism Dev Disord. Sep. 2011;41(9):1202-13. X-5. [pmid: 21125322].
939 Elson N. Which Way Next? What Is the Real Choice for Students Leaving a Special School?. Support for Learning. 2011;26(4):152-9. X-5.
940 Enticott PG, Kennedy HA, Zangen A, et al. Deep repetitive transcranial magnetic stimulation associated with improved social functioning in a young woman with an autism spectrum disorder. The Journal of ECT. 2011;27(1):41-3. X-3, X-5. [pmid: 20966773].
941 Erdmann J. Broad collaborations bring new energy to autism therapeutics. Chem Biol. Feb. 25. 2011;18(2):142-3. X-5. [pmid: 21338911].
942 Erginousakis D, Filippiadis DK, Malagari A, et al. Comparative prospective randomized study comparing conservative treatment and percutaneous disk decompression for treatment of intervertebral disk herniation. Radiology. Aug. 2011;260(2):487-93. X-5. [pmid: 21613439].
943 Erickson CA, Early M, Stigler KA, et al. An open-label naturalistic pilot study of acamprosate in youth with autistic disorder. J Child Adolesc Psychopharmacol. Dec. 2011;21(6):565-9. X-3. [pmid: 22136091].
944 Erickson CA, Stigler KA, Wink LK, et al. A prospective open-label study of aripiprazole in fragile X syndrome. Psychopharmacology (Berl). Jul. 2011;216(1):85-90. X-5. [pmid: 21318565].
945 Erickson CA, Weng N, Weiler IJ, et al. Open-label riluzole in fragile X syndrome. Brain Res. Mar. 22. 2011;1380:264-70. X-5. [pmid: 21059347].
946 Eskow K, Pineles L, Summers JA. Exploring the effect of autism waiver services on family outcomes. Journal of Policy and Practice in Intellectual Disabilities. 2011;8(1):28-35. X-5.
947 Estes A, Rivera V, Bryan M, et al. Discrepancies between Academic Achievement and Intellectual Ability in Higher-Functioning School-Aged Children with Autism Spectrum Disorder. Journal of Autism and Developmental Disorders. 2011;41(8):1044-52. X-5. [pmid: 21042871].
948 Fallon MA, Zhang J, Kim E-J. Using Course Assessments to Train Teachers in Functional Behavior Assessment and Behavioral Intervention Plan Techniques. Journal of the International Association of Special Education. 2011;12(1):50-8. X-5.
949 Fava L, Strauss K. Cross-setting complementary staff- and parent-mediated Early Intensive Behavioral Intervention for young children with autism: A research-based comprehensive approach. Research in Autism Spectrum Disorders. 2011;5(1):512-22. X-1, X-2, X-3, X-4.
950 Fecteau S, Agosta S, Oberman L, et al. Brain stimulation over Broca's area differentially modulates naming skills in neurotypical adults and individuals with Asperger's syndrome. Eur J Neurosci. Jul. 2011;34(1):158-64. X-5. [pmid: 21676037].
951 Fernandes FD, Amato CA, Balestro JI, et al. Orientation to mothers of children of the autistic spectrum about language and communication. J Soc Bras Fonoaudiol. Mar. 2011;23(1):1-7. X-5. [pmid: 21552725].
952 Fernell E, Hedvall A, Westerlund J, et al. Early intervention in 208 Swedish preschoolers with autism spectrum disorder. A prospective naturalistic study. Res Dev Disabil. Nov-Dec. 2011;32(6):2092-101. X-5. [pmid: 21985993].
953 Ferraioli SJ, Harris SL. Teaching joint attention to children with autism through a sibling‐mediated behavioral intervention. Behavioral Interventions. 2011;26(4):261-81. X-3.
954 Finegold SM. State of the art; microbiology in health and disease. Intestinal bacterial flora in autism. Anaerobe. Dec. 2011;17(6):367-8. X-5. [pmid: 21524713].
955 Fitzpatrick M. Warehousing. Br J Gen Pract. Jul. 2011;61(588):466. X-5. [pmid: 21722473].
956 Flippin M, Crais ER. The Need for More Effective Father Involvement in Early Autism Intervention: A Systematic Review and Recommendations. Journal of Early Intervention. 2011;33(1):24-50. X-1, X-3, X-4.
957 Flippin M, Watson LR. Relationships between the Responsiveness of Fathers and Mothers and the Object Play Skills of Children with Autism Spectrum Disorders. Journal of Early Intervention. 2011;33(3):220-34. X-5.
958 Fong SS, Lee VY, Chan NN, et al. Motor ability and weight status are determinants of out-of-school activity participation for children with developmental coordination disorder. Res Dev Disabil. Nov-Dec. 2011;32(6):2614-23. X-5. [pmid: 21767931].
959 Fountain C, King MD, Bearman PS. Age of diagnosis for autism: Individual and community factors across 10 birth cohorts. Journal of Epidemiology and Community Health. 2011;65(6):503-10. X-5. [pmid: 20974836].
960 Fragala-Pinkham MA, Haley SM, O'Neil ME. Group swimming and aquatic exercise programme for children with autism spectrum disorders: a pilot study. Dev Neurorehabil. 2011;14(4):230-41. X-4. [pmid: 21732807].
961 Frankel FD, Gorospe CM, Chang Y-C, et al. Mothers' Reports of Play Dates and Observation of School Playground Behavior of Children Having High-Functioning Autism Spectrum Disorders. Journal of Child Psychology and Psychiatry. 2011;52(5):571-9. X-4. [pmid: 20860756].
962 Fraser R, Angus B, Cotton S, et al. Prevalence of autism spectrum conditions in a youth mental health service. Australian and New Zealand Journal of Psychiatry. 2011;45(5):426. X-5. [pmid: 21391745].
963 Frazier TW, Shattuck PT, Narendorf SC, et al. Prevalence and correlates of psychotropic medication use in adolescents with an autism spectrum disorder with and without caregiver-reported attention-deficit/hyperactivity disorder. J Child Adolesc Psychopharmacol. Dec. 2011;21(6):571-9. X-5. [pmid: 22166171].
964 Freilinger M, Dunkler D, Lanator I, et al. Effects of creatine supplementation in Rett syndrome: A randomized, placebo-controlled trial. Journal of Developmental and Behavioral Pediatrics. 2011;32(6):454-60. X-5. [pmid: 21654506].
965 Froehlich W. Making a case to continue considering treatment with selective serotonin reuptake inhibitors for children with autism spectrum disorders. Curr Psychiatry Rep. Jun. 2011;13(3):170-3. X-1, X-2, X-3, X-4. [pmid: 21404127].
966 Frye RE, Sreenivasula S, Adams JB. Traditional and non-traditional treatments for autism spectrum disorder with seizures: an on-line survey. BMC Pediatr. 2011;11:37. X-5. [pmid: 21592359].
967 Fukuhara H, Inoue K, Satake H, et al. Photodynamic diagnosis of positive margin during radical prostatectomy: preliminary experience with 5-aminolevulinic acid. Int J Urol. Aug. 2011;18(8):585-91. X-5. [pmid: 21658132].
968 Gadberry AL. A survey of the use of aided augmentative and alternative communication during music therapy sessions with persons with autism spectrum disorders. J Music Ther. Spring. 2011;48(1):74-89. X-5. [pmid: 21866714].
969 Gale CM, Eikeseth S, Rudrud E. Functional assessment and behavioural intervention for eating difficulties in children with autism: a study conducted in the natural environment using parents and ABA tutors as therapists. J Autism Dev Disord. Oct. 2011;41(10):1383-96. X-3. [pmid: 21181250].
970 Galletly SA, Knight BA. Differential Disadvantage of Anglophone Weak Readers Due to English Orthographic Complexity and Cognitive Processing Weakness. Australasian Journal of Special Education. 2011;35(1):72-96. X-5.
971 Gallup GG Jr, Hobbs DR. Evolutionary medicine: bottle feeding, birth spacing, and autism. Med Hypotheses. Sep. 2011;77(3):345-6. X-5. [pmid: 21641730].
972 Ganz JB, Earles-Vollrath TL, Cook KE. Video Modeling: A Visually Based Intervention for Children with Autism Spectrum Disorder. TEACHING Exceptional Children. 2011;43(6):8-19. X-1, X-2, X-3, X-4.
973 Ganz JB, Earles-Vollrath TL, Mason RA, et al. An Aggregate Study of Single-Case Research Involving Aided AAC: Participant Characteristics of Individuals with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2011;5(4):1500-9. X-5.
974 Ganz JB, Flores MM, Lashley EE. Effects of a Treatment Package on Imitated and Spontaneous Verbal Requests in Children with Autism. Education and Training in Autism and Developmental Disabilities. 2011;46(4):596-606. X-3.
975 Garcia-Villamisar D, Dattilo J. Social and Clinical Effects of a Leisure Program on Adults with Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2011;5(1):246-53. X-5.
976 Gargaro BA, Rinehart NJ, Bradshaw JL, et al. Autism and ADHD: how far have we come in the comorbidity debate?. Neurosci Biobehav Rev. Apr. 2011;35(5):1081-8. X-5. [pmid: 21093480].
977 Gaspar de Alba MJ, Bodfish JW. Addressing Parental Concerns at the Initial Diagnosis of an Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2011;5(1):633-9. X-5.
978 Gattino GS, dos Santos Riesgo R, Longo D, et al. Effects of relational music therapy on communication of children with autism: A randomized controlled study. Nordisk tidskrift for musikkterapi - Nordic Journal of Music Therapy. 2011;20(2):142-54. X-5.
979 Geier DA, Kern JK, Davis G, et al. A prospective double-blind, randomized clinical trial of levocarnitine to treat autism spectrum disorders. Med Sci Monit. Jun. 2011;17(6):PI15-23. X-5. [pmid: 21629200].
980 Gerber F, Bessero S, Robbiani B, et al. Comparing residential programmes for adults with autism spectrum disorders and intellectual disability: outcomes of challenging behaviour and quality of life. J Intellect Disabil Res. Sep. 2011;55(9):918-32. X-5. [pmid: 21806693].
981 Ghanizadeh A. Targeting of glycine site on NMDA receptor as a possible new strategy for autism treatment. Neurochem Res. May. 2011;36(5):922-3. X-5. [pmid: 21210221].
982 Ghanizadeh A. Can ziconotide as a N-type voltage-sensitive calcium channel blocker open a new mode for treatment of autism? A hypothesis. Neurosciences (Riyadh). Jan. 2011;16(1):83. X-5. [pmid: 21206454].
983 Ghoneim OM, Ibrahim DA, El-Deeb IM, et al. A novel potential therapeutic avenue for autism: design, synthesis and pharmacophore generation of SSRIs with dual action. Bioorg Med Chem Lett. Nov. 15. 2011;21(22):6714-23. X-5. [pmid: 21982496].
984 Gibbs V, Toth-Cohen S. Family-centered occupational therapy and telerehabilitation for children with autism spectrum disorders. Occupational Therapy In Health Care. 2011;25(4):298-314. X-3. [pmid: 23899082].
985 Gillesen JC, Barakova EI, Huskens BE, et al. From training to robot behavior: towards custom scenarios for robotics in training programs for ASD. IEEE Int Conf Rehabil Robot. 2011;2011:5975381. X-5. [pmid: 22275585].
986 Glaser SE, Shaw SR. Emotion Regulation and Development in Children with Autism and 22q13 Deletion Syndrome: Evidence for Group Differences. Research in Autism Spectrum Disorders. 2011;5(2):926-34. X-5.
987 Goldman LE, Chu PW, Osmond D, et al. The accuracy of present-on-admission reporting in administrative data. Health Serv Res. Dec. 2011;46(6pt1):1946-62. X-1, X-3, X-4, X-5. [pmid: 22092023].
988 Golubchik P, Sever J, Weizman A. Low-dose quetiapine for adolescents with autistic spectrum disorder and aggressive behavior: open-label trial. Clin Neuropharmacol. Nov-Dec. 2011;34(6):216-9. X-5. [pmid: 21996644].
989 Gomot M, Blanc R, Clery H, et al. Candidate electrophysiological endophenotypes of hyper-reactivity to change in autism. J Autism Dev Disord. Jun. 2011;41(6):705-14. X-5. [pmid: 20827502].
990 Gonzalez A, Stombaugh J, Lozupone C, et al. The mind-body-microbial continuum. Dialogues Clin Neurosci. 2011;13(1):55-62. 21485746. X-5. [pmid: 21485746].
991 Gooding LF. The effect of a music therapy social skills training program on improving social competence in children and adolescents with social skills deficits. J Music Ther. Winter. 2011;48(4):440-62. X-5. [pmid: 22506299].
992 Goodman G, Athey-Lloyd L. Interaction structures between a child and two therapists in the psychodynamic treatment of a child with Asperger's disorder. Journal of Child Psychotherapy. 2011;37(3):311-26. X-3, X-5.
993 Gordon K, Pasco G, McElduff F, et al. A communication-based intervention for nonverbal children with autism: what changes? Who benefits?. J Consult Clin Psychol. Aug. 2011;79(4):447-57. X-5. [pmid: 21787048].
994 Gould E, Dixon DR, Najdowski AC, et al. A Review of Assessments for Determining the Content of Early Intensive Behavioral Intervention Programs for Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2011;5(3):990-1002. X-5.
995 Gray K, Jenkins AC, Heberlein AS, et al. Distortions of mind perception in psychopathology. Proc Natl Acad Sci U S A. Jan. 11. 2011;108(2):477-9. X-5. [pmid: 21187372].
996 Greer DR, Pistoljevic N, Cahill C, et al. Effects of Conditioning Voices as Reinforcers for Listener Responses on Rate of Learning, Awareness, and Preferences for Listening to Stories in Preschoolers with Autism. Analysis of Verbal Behavior. 2011;27:103-24. X-3. [pmid: 22532758].
997 Griffin MM. Promoting IEP Participation: Effects of Interventions, Considerations for CLD Students. Career Development for Exceptional Individuals. 2011;34(3):153-64. X-5.
998 Griffith GM, Hastings RP, Oliver C, et al. Psychological well-being in parents of children with Angelman, Cornelia de Lange and Cri du Chat syndromes. J Intellect Disabil Res. Apr. 2011;55(4):397-410. X-5. [pmid: 21323782].
999 Grimmsmann T, Himmel W. Discrepancies between prescribed and defined daily doses: a matter of patients or drug classes?. Eur J Clin Pharmacol. Aug. 2011;67(8):847-54. X-1, X-3, X-4, X-5. [pmid: 21544512].
1000 Groskreutz MP, Groskreutz NC, Higbee TS. Response Competition and Stimulus Preference in the Treatment of Automatically Reinforced Behavior: A Comparison. Journal of Applied Behavior Analysis. 2011;44(1):211-5. X-3. [pmid: 21541129].
1001 Groskreutz NC, Groskreutz MP, Higbee TS. Effects of varied levels of treatment integrity on appropriate toy manipulation in children with autism. Research in Autism Spectrum Disorders. 2011;5(4):1358-69. X-3.
1002 Grow LL, Carr JE, Kodak TM, et al. A comparison of methods for teaching receptive labeling to children with autism spectrum disorders. J Appl Behav Anal. Fall. 2011;44(3):475-98. X-3. [pmid: 21941380].
1003 Guiraud JA, Kushnerenko E, Tomalski P, et al. Differential habituation to repeated sounds in infants at high risk for autism. Neuroreport. Nov. 16. 2011;22(16):845-9. X-1, X-3, X-4. [pmid: 21934535].
1004 Guldberg K, Parsons S, MacLeod A, et al. Implications for Practice from “International Review of the Evidence on Best Practice in Educational Provision for Children on the Autism Spectrum”. European Journal of Special Needs Education. 2011;26(1):65-70. X-2, X-5.
1005 Gura GF, Champagne MT, Blood-Siegfried JE. Autism spectrum disorder screening in primary care. Journal of Developmental and Behavioral Pediatrics. 2011;32(1):48-51. X-5. [pmid: 21160437].
1006 Hagebeuk EEO, Koelman JHTM, Duran M, et al. Clinical and electroencephalographic effects of folinic acid treatment in Rett syndrome patients. Journal of Child Neurology. 2011;26(6):718-23. X-5. [pmid: 21427443].
1007 Hagopian LP, González ML, Rivet TT, et al. Response interruption and differential reinforcement of alternative behavior for the treatment of pica. Behavioral Interventions. 2011;26(4):309-25. X-3.
1008 Hall HR, Graff JC. The relationships among adaptive behaviors of children with autism, family support, parenting stress, and coping. Issues Compr Pediatr Nurs. 2011;34(1):4-25. X-3, X-4, X-5. [pmid: 21341964].
1009 Hamilton A, Marshal MP, Murray PJ. Autism spectrum disorders and menstruation. J Adolesc Health. Oct. 2011;49(4):443-5. X-5. [pmid: 21939879].
1010 Hammond JL, Iwata BA, Fritz JN, et al. Evaluation of Fixed Momentary DRO Schedules under Signaled and Unsignaled Arrangements. Journal of Applied Behavior Analysis. 2011;44(1):69-81. X-3. [pmid: 21541110].
1011 Hampson DR, Adusei DC, Pacey LK. The neurochemical basis for the treatment of autism spectrum disorders and Fragile X Syndrome. Biochem Pharmacol. May. 1. 2011;81(9):1078-86. X-5. [pmid: 21333634].
1012 Handen BL, Johnson CR, McAuliffe-Bellin S, et al. Safety and efficacy of donepezil in children and adolescents with autism: neuropsychological measures. J Child Adolesc Psychopharmacol. Feb. 2011;21(1):43-50. X-5. [pmid: 21309696].
1013 Hart C. Can We, Can't We, Can We, Can't We, Can We Help Him Join the Dance? The Need for Multimodal Processing in the Move towards Meaningful Communication. Journal of Child Psychotherapy. 2011;37(1):16-30. X-3, X-5.
1014 Hart JE, Whalon KJ. Creating Social Opportunities for Students with Autism Spectrum Disorder in Inclusive Settings. Intervention in School and Clinic. 2011;46(5):273-9. X-5.
1015 Hartley SL, Seltzer MM, Raspa M, et al. Exploring the adult life of men and women with fragile X syndrome: results from a national survey. Am J Intellect Dev Disabil. Jan. 2011;116(1):16-35. X-5. [pmid: 21291308].
1016 Hayakawa K, Kobayashi K. Physical and motor skill training for children with intellectual disabilities. Percept Mot Skills. Apr. 2011;112(2):573-80. X-5. [pmid: 21667765].
1017 Hayes S, McGuire B, O'Neill M, et al. Low mood and challenging behaviour in people with severe and profound intellectual disabilities. J Intellect Disabil Res. Feb. 2011;55(2):182-9. X-5. [pmid: 21129068].
1018 Hellings JA, Boehm D, Yeh HW, et al. Long-term aripiprazole in youth with developmental disabilities including autism. Journal of Mental Health Research in Intellectual Disabilities. 2011;4(1):40-52. X-1, X-3.
1019 Hernandez P, Ikkanda Z. Applied behavior analysis: behavior management of children with autism spectrum disorders in dental environments. J Am Dent Assoc. Mar. 2011;142(3):281-7. X-1, X-2, X-3 ,X-4. [pmid: 21357862].
1020 Hill DA, Martin DE, Nelson-Head C. Examination of Case Law (2007-2008) regarding Autism Spectrum Disorder and Violations of the Individuals with Disabilities Education Act. Routledge. 325 Chestnut Street Suite 800, Philadelphia, PA 19106. 2011:214-25. X-4.
1021 Hillier AJ, Fish T, Siegel JH, et al. Social and vocational skills training reduces self-reported anxiety and depression among young adults on the autism spectrum. Journal of Developmental and Physical Disabilities. 2011;23(3):267-76. X-5.
1022 Hillock AR, Powers AR, Wallace MT. Binding of sights and sounds: age-related changes in multisensory temporal processing. Neuropsychologia. Feb. 2011;49(3):461-7. X-5. [pmid: 21134385].
1023 Hines M, Balandin S, Togher L. Communication and AAC in the lives of adults with autism: the stories of their older parents. Augment Altern Commun. Dec. 2011;27(4):256-66. X-5. [pmid: 22136364].
1024 Hodgetts S, Magill-Evans J, Misiaszek J. Effects of Weighted Vests on Classroom Behavior for Children with Autism and Cognitive Impairments. Research in Autism Spectrum Disorders. 2011;5(1):495-505. X-4.
1025 Hodgetts S, Magill-Evans J, Misiaszek JE. Weighted vests, stereotyped behaviors and arousal in children with autism. J Autism Dev Disord. Jun. 2011;41(6):805-14. X-3. [pmid: 20839040].
1026 Holding E, Bray MA, Kehle TJ. Does Speed Matter? A Comparison of the Effectiveness of Fluency and Discrete Trial Training for Teaching Noun Labels to Children with Autism. Psychology in the Schools. 2011;48(2):166-83. X-3.
1027 Holtmann M, Steiner S, Hohmann S, et al. Neurofeedback in Autism Spectrum Disorders. Wiley-Blackwell. 350 Main Street, Malden, MA 02148. 2011:986-93. X-1, X-2.
1028 Hopkins IM, Gower MW, Perez TA, et al. Avatar assistant: improving social skills in students with an ASD through a computer-based intervention. J Autism Dev Disord. Nov. 2011;41(11):1543-55. X-1. [pmid: 21287255].
1029 Howlett MA, Sidener TM, Progar PR, et al. Manipulation of Motivating Operations and Use of a Script-Fading Procedure to Teach Mands for Location to Children with Language Delays. Journal of Applied Behavior Analysis. 2011;44(4):943-7. X-3. [pmid: 22219545].
1030 Hsieh H-H, Wilder DA, Abellon EO. The Effects of Training on Caregiver Implementation of Incidental Teaching. Journal of Applied Behavior Analysis. 2011;44(1):199-203. X-3. [pmid: 21541132].
1031 Hughes C. Changes and Challenges in 20 Years of Research into the Development of Executive Functions. Wiley-Blackwell. 111 River Street, Hoboken, NJ 07030-5774. 2011:251-71. X-4.
1032 Hume K, Boyd B, McBee M, et al. Assessing implementation of comprehensive treatment models for young children with ASD: Reliability and validity of two measures. Research in Autism Spectrum Disorders. 2011;5(4):1430-40. X-1, X-3, X-4.
1033 Hvidtjorn D, Grove J, Schendel D, et al. Risk of autism spectrum disorders in children born after assisted conception: a population-based follow-up study. J Epidemiol Community Health. Jun. 2011;65(6):497-502. X-5. [pmid: 20584728].
1034 Ingersoll B. The Differential Effect of Three Naturalistic Language Interventions on Language Use in Children with Autism. Journal of Positive Behavior Interventions. April. 2011. 2011;13(2):109-18. X-3.
1035 Ingvarsson ET, Hollobaugh T. A comparison of prompting tactics to establish intraverbals in children with autism. J Appl Behav Anal. Fall. 2011;44(3):659-64. X-3. [pmid: 21941400].
1036 Irwin JR, Tornatore LA, Brancazio L, et al. Can children with autism spectrum disorders “hear” a speaking face?. Child Dev. Sep-Oct. 2011;82(5):1397-403. X-5. [pmid: 21790542].
1037 Isbell JS, Jolivette K. Stop, Think, Proceed: Solving Problems in the Real World. Intervention in School and Clinic. 2011;47(1):31-8. X-2, X-5.
1038 Ishizuka M, Abe F, Sano Y, et al. Novel development of 5-aminolevurinic acid (ALA) in cancer diagnoses and therapy. Int Immunopharmacol. Mar. 2011;11(3):358-65. X-5. [pmid: 21144919].
1039 Jaber MA. Dental caries experience, oral health status and treatment needs of dental patients with autism. J Appl Oral Sci. May-Jun. 2011;19(3):212-7. X-5. [pmid: 21625735].
1040 Jang J, Dixon DR, Tarbox J, et al. Symptom Severity and Challenging Behavior in Children with ASD. Research in Autism Spectrum Disorders. 2011;5(3):1028-32. X-5.
1041 Jarocka-Cyrta E, Wasilewska J, Kaczmarski MG. Brief Report: Eosinophilic Esophagitis as a Cause of Feeding Problems in Autistic Boy. The First Reported Case. Journal of Autism and Developmental Disorders. 2011;41(3):372-4. X-5. [pmid: 20625807].
1042 Jepson B, Granpeesheh D, Tarbox J, et al. Controlled evaluation of the effects of hyperbaric oxygen therapy on the behavior of 16 children with autism spectrum disorders. J Autism Dev Disord. May. 2011;41(5):575-88. X-5. [pmid: 20680427].
1043 Johansson C, Ballard C, Hansson O, et al. Efficacy of memantine in PDD and DLB: an extension study including washout and open-label treatment. Int J Geriatr Psychiatry. Feb. 2011;26(2):206-13. X-5. [pmid: 20665553].
1044 Johnson JL, Brown S, Chang C, et al. The Cost of Serving Infants and Toddlers under Part C. Infants and Young Children. 2011;24(1):101-13. X-5.
1045 Jones WE, Hoerger M, Hughes CJ, et al. ABA and Diverse Cultural and Linguistic Environments: A Welsh Perspective. Journal of Behavioral Education. 2011;20(4):297-305. X-5.
1046 Jull S, Mirenda P. Parents as Play Date Facilitators for Preschoolers with Autism. Journal of Positive Behavior Interventions. 2011;13(1):17-30. X-3.
1047 Kaluzna-Czaplinska J, Michalska M, Rynkowski J. Vitamin supplementation reduces the level of homocysteine in the urine of autistic children. Nutr Res. Apr. 2011;31(4):318-21. X-4. [pmid: 21530806].
1048 Kaluzna-Czaplinska J, Socha E, Rynkowski J. B vitamin supplementation reduces excretion of urinary dicarboxylic acids in autistic children. Nutr Res. Jul. 2011;31(7):497-502. X-4. [pmid: 21840465].
1049 Kamp-Becker I, Schroder J, Muehlan H, et al. Health-related quality of life in children and adolescents with autism spectrum disorder. Z Kinder Jugendpsychiatr Psychother. Mar. 2011;39(2):123-31. X-5. [pmid: 21442600].
1050 Kanai C, Iwanami A, Ota H, et al. Clinical characteristics of adults with Asperger's Syndrome assessed with self-report questionnaires. Research in Autism Spectrum Disorders. 2011;5(1):185-90. X-5.
1051 Kang S, O'Reilly MF, Fragale CL, et al. Evaluation of the Rate of Problem Behavior Maintained by Different Reinforcers across Preference Assessments. Journal of Applied Behavior Analysis. 2011;44(4):835-46. X-5. [pmid: 22219533].
1052 Karsten AM, Carr JE, Lepper TL. Description of a practitioner model for identifying preferred stimuli with individuals with autism spectrum disorders. Behav Modif. Jul. 2011;35(4):347-69. X-5. [pmid: 21613240].
1053 Keenan M, Dillenburger K. When All You Have Is a Hammer...: RCTs and Hegemony in Science. Research in Autism Spectrum Disorders. 2011;5(1):1-13. X-5.
1054 Keintz KS, Miguel CF, Kao B, et al. Using Conditional Discrimination Training to Produce Emergent Relations between Coins and Their Values in Children with Autism. Journal of Applied Behavior Analysis. 2011;44(4):909-13. X-3. [pmid: 22219539].
1055 Kern JK, Fletcher CL, Garver CR, et al. Prospective trial of equine-assisted activities in autism spectrum disorder. Altern Ther Health Med. May-Jun. 2011;17(3):14-20. X-5. [pmid: 22164808].
1056 Kern JK, Geier DA, Adams JB, et al. A clinical trial of glutathione supplementation in autism spectrum disorders. Med Sci Monit. Dec. 2011;17(12):CR677-82. X-5. [pmid: 22129897].
1057 Khanna R, Madhavan SS, Smith MJ, et al. Assessment of health-related quality of life among primary caregivers of children with autism spectrum disorders. J Autism Dev Disord. Sep. 2011;41(9):1214-27. X-5. [pmid: 21103917].
1058 King CR. A novel embryological theory of autism causation involving endogenous biochemicals capable of initiating cellular gene transcription: a possible link between twelve autism risk factors and the autism ‘epidemic’. Med Hypotheses. May. 2011;76(5):653-60. X-5. [pmid: 21388746].
1059 Kishore MT, Basu A. Early concerns of mothers of children later diagnosed with autism: Implications for early identification. Research in Autism Spectrum Disorders. 2011;5(1):157-63. X-5.
1060 Kite DM, Tyson GA, Gullifer JM. Exploring the Perception of Asperger's Disorder. Australasian Journal of Special Education. 2011;35(2):204-19. X-5.
1061 Klenk JA, Pufpaff LA. A Case Study of Tack Tiles[R] Literacy Instruction for a Student with Multiple Disabilities Including Congenital Blindness. Physical Disabilities: Education and Related Services. 2011;30(2):48-66. X-3.
1062 Kliebert ML, Tiger JH. Direct and distal effects of noncontingent juice on rumination exhibited by a child with autism. J Appl Behav Anal. Winter. 2011;44(4):955-9. X-3. [pmid: 22219547].
1063 Klintwall L, Holm A, Eriksson M, et al. Sensory abnormalities in autism. A brief report. Res Dev Disabil. Mar-Apr. 2011;32(2):795-800. X-5. [pmid: 21111574].
1064 Kobak KA, Stone WL, Ousley OY, et al. Web-based training in early autism screening: results from a pilot study. Telemed J E Health. Oct. 2011;17(8):640-4. X-5. [pmid: 21939382].
1065 Kobak KA, Stone WL, Wallace E, et al. A Web-based tutorial for parents of young children with autism: Results from a pilot study. Telemedicine and e-Health. 2011;17(10):804-8. X-4, X-5. [pmid: 22011005].
1066 Kodak T, Fisher WW, Clements A, et al. Effects of Computer-Assisted Instruction on Correct Responding and Procedural Integrity during Early Intensive Behavioral Intervention. Research in Autism Spectrum Disorders. 2011;5(1):640-7. X-3.
1067 Kodak T, Fisher WW, Clements A, et al. Functional assessment of instructional variables: Linking assessment and treatment. Research in Autism Spectrum Disorders. 2011;5(3):1059-77. X-4.
1068 Koyama T, Wang HT. Use of Activity Schedule to Promote Independent Performance of Individuals with Autism and Other Intellectual Disabilities: A Review. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2011:2235-42. X-2.
1069 Krajnc N, Župančič N, Oražem J. Epilepsy treatment in Rett syndrome. Journal of Child Neurology. 2011;26(11):1429-33. X-5. [pmid: 21636780].
1070 Kroeger AK, Brown J. Placebo Medication Use for Behavior Management in an Adult with Autism. Education and Training in Autism and Developmental Disabilities. 2011;46(3):470-6. X-5.
1071 Kruck S, Bedke J, Hennenlotter J, et al. Virtual bladder tumor transurethral resection: an objective evaluation tool to overcome learning curves with and without photodynamic diagnostics. Urol Int. 2011;87(2):138-42. X-5. [pmid: 21860210].
1072 Kurtz PF, Boelter EW, Jarmolowicz DP, et al. An Analysis of Functional Communication Training as an Empirically Supported Treatment for Problem Behavior Displayed by Individuals with Intellectual Disabilities. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2011:2935-42. X-2, X-3, X-4.
1073 Lahiri U, Warren Z, Sarkar N. Design of a gaze-sensitive virtual social interactive system for children with autism. IEEE Trans Neural Syst Rehabil Eng. Aug. 2011;19(4):443-52. X-5. [pmid: 21609889].
1074 Lampi KM, Banerjee PN, Gissler M, et al. Finnish Prenatal Study of Autism and Autism Spectrum Disorders (FIPS-A): overview and design. J Autism Dev Disord. Aug. 2011;41(8):1090-6. X-5. [pmid: 21082229].
1075 Lang R, Kuriakose S, Lyons G, et al. Use of School Recess Time in the Education and Treatment of Children with Autism Spectrum Disorders: A Systematic Review. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2011:1296-305. X-4.
1076 Lanovaz MJ, Sladeczek IE. Vocal Stereotypy in Children with Autism: Structural Characteristics, Variability, and Effects of Auditory Stimulation. Research in Autism Spectrum Disorders. 2011;5(3):1159-68. X-3.
1077 Lanovaz MJ, Sladeczek IE, Rapp JT. Effects of music on vocal stereotypy in children with autism. J Appl Behav Anal. Fall. 2011;44(3):647-51. X-3. [pmid: 21941398].
1078 Larson HJ, Cooper LZ, Eskola J, et al. Addressing the vaccine confidence gap. Lancet. Aug. 6. 2011;378(9790):526-35. X-5. [pmid: 21664679].
1079 Larsson V, Engedal K, Aarsland D, et al. Quality of life and the effect of memantine in dementia with lewy bodies and Parkinson's disease dementia. Dement Geriatr Cogn Disord. 2011;32(4):227-34. X-5. [pmid: 22122992].
1080 LaRue RH, Sloman KN, Weiss MJ, et al. Correspondence between traditional models of functional analysis and a functional analysis of manding behavior. Res Dev Disabil. Nov-Dec. 2011;32(6):2449-57. X-3, X-5. [pmid: 21821393].
1081 Leach D, LaRocque M. Increasing Social Reciprocity in Young Children with Autism. Intervention in School and Clinic. 2011;46(3):150-6. X-5.
1082 Leaf RB, Taubman MT, McEachin JJ, et al. A program description of a community-based intensive behavioral intervention program for individuals with autism spectrum disorders. Education & Treatment of Children. 2011;34(2):259-85. X-5.
1083 Lecavalier L, Gadow KD, Devincent CJ, et al. Validity of DSM-IV syndromes in preschoolers with Autism spectrum disorders. Autism. 2011;15(5):527-43. X-5. [pmid: 21454388].
1084 Leekam SR, Prior MR, Uljarevic M. Restricted and Repetitive Behaviors in Autism Spectrum Disorders: A Review of Research in the Last Decade. Psychological Bulletin. 2011;137(4):562-93. X-1, X-2, X-3, X-4, X-5. [pmid: 21574682].
1085 Lehtimaki KA, Liimatainen S, Peltola J, et al. The serum level of interleukin-6 in patients with intellectual disability and refractory epilepsy. Epilepsy Res. Jun. 2011;95(1-2):184-7. X-5. [pmid: 21530175].
1086 Lemmon ME, Gregas M, Jeste SS. Risperidone use in autism spectrum disorders: a retrospective review of a clinic-referred patient population. J Child Neurol. Apr. 2011;26(4):428-32. X-5. [pmid: 20929907].
1087 Lenne BS, Waldby C. Sorting out autism spectrum disorders: Evidence-based medicine and the complexities of the clinical encounter. Health Sociology Review. 2011;20(1):70-83. X-5.
1088 Leoncini S, De Felice C, Signorini C, et al. Oxidative stress in Rett syndrome: natural history, genotype, and variants. Redox Rep. 2011;16(4):145-53. X-5. [pmid: 21888765].
1089 Leong HM, Stephenson J, Carter M. The Use of Sensory Integration Therapy by Intervention Service Providers in Malaysia. International Journal of Disability, Development and Education. 2011;58(4):341-58. X-1, X-3, X-4.
1090 Lerner MD, Mikami AY, Levine K. Socio-dramatic affective-relational intervention for adolescents with asperger syndrome & high functioning autism: pilot study. Autism. Jan. 2011;15(1):21-42. X-5. [pmid: 20923890].
1091 Leu RM, Beyderman L, Botzolakis EJ, et al. Relation of Melatonin to Sleep Architecture in Children with Autism. Journal of Autism and Developmental Disorders. 2011;41(4):427-33. X-5. [pmid: 20683768].
1092 Li J, Yan D, Duan L, et al. Percutaneous discectomy and drainage for postoperative intervertebral discitis. Arch Orthop Trauma Surg. Feb. 2011;131(2):173-8. X-5. [pmid: 20490522].
1093 Lierheimer K, Stichter J. Teaching Facial Expressions of Emotion. Beyond Behavior. 2011;21(1):20-7. X-3.
1094 Light J, McNaughton D. Supporting the communication, language, and literacy development of children with complex communication needs: state of the science and future research priorities. Assist Technol. Spring. 2011;24(1):34-44. X-2, X-3, X-4, X-5. [pmid: 22590798].
1095 Lim HA, Draper E. The effects of music therapy incorporated with applied behavior analysis verbal behavior approach for children with autism spectrum disorders. J Music Ther. Winter. 2011;48(4):532-50. X-5. [pmid: 22506303].
1096 Lindsay G. The Collection and Analysis of Data on Children with Speech, Language and Communication Needs: The Challenge to Education and Health Services. Child Language Teaching and Therapy. 2011;27(2):135-50. X-5.
1097 Liu ZH, Chuang DM, Smith CB. Lithium ameliorates phenotypic deficits in a mouse model of fragile X syndrome. Int J Neuropsychopharmacol. Jun. 2011;14(5):618-30. X-5. [pmid: 20497624].
1098 Loiacono V, Palumbo A. Principals Who Understand Applied Behavior Analysis Perceive They Are Better Able to Support Educators Who Teach Students with Autism. International Journal of Special Education. 2011;26(3):212-22. X-5.
1099 Longo N, Ardon O, Vanzo R, et al. Disorders of creatine transport and metabolism. Am J Med Genet C Semin Med Genet. Feb. 15. 2011;157(1):72-8. X-5. [pmid: 21308988].
1100 Low HM, Lee LW. Teaching of Speech, Language and Communication Skills for Young Children with Severe Autism Spectrum Disorders: What Do Educators Need to Know?. New Horizons in Education. 2011;59(3):16-27. X-5.
1101 Lyons G. Translation of Evidence-Based Practices in a Behaviour Support Implementation Model for Youth with Autism Spectrum Disorders. International Journal of Disability, Development and Education. 2011;58(4):409-15. X-5.
1102 Mace FC, Pratt JL, Prager KL, et al. An evaluation of three methods of saying “no” to avoid an escalating response class hierarchy. J Appl Behav Anal. Spring. 2011;44(1):83-94. X-5. [pmid: 21541139].
1103 MacFabe DF, Cain NE, Boon F, et al. Effects of the enteric bacterial metabolic product propionic acid on object-directed behavior, social behavior, cognition, and neuroinflammation in adolescent rats: Relevance to autism spectrum disorder. Behav Brain Res. Feb. 2. 2011;217(1):47-54. X-5. [pmid: 20937326].
1104 Magiati I, Moss J, Charman T, et al. Patterns of Change in Children with Autism Spectrum Disorders Who Received Community Based Comprehensive Interventions in Their Pre-School Years: A Seven Year Follow-Up Study. Research in Autism Spectrum Disorders. 2011;5(3):1016-27. X-5.
1105 Magiati I, Moss J, Yates R, et al. Is the Autism Treatment Evaluation Checklist a useful tool for monitoring progress in children with autism spectrum disorders?. J Intellect Disabil Res. Mar. 2011;55(3):302-12. X-4. [pmid: 21199043].
1106 Magnee MJ, de Gelder B, van Engeland H, et al. Multisensory integration and attention in autism spectrum disorder: evidence from event-related potentials. PLoS One. 2011;6(8):e24196. X-5. [pmid: 21887382].
1107 Makkonen I, Kokki H, Kuikka J, et al. Effects of fluoxetine treatment on striatal dopamine transporter binding and cerebrospinal fluid insulin-like growth factor-1 in children with autism. Neuropediatrics. Oct. 2011;42(5):207-9. X-4. [pmid: 22015434].
1108 Makkonen I, Riikonen R, Kuikka JT, et al. Brain derived neurotrophic factor and serotonin transporter binding as markers of clinical response to fluoxetine therapy in children with autism. Journal of Pediatric Neurology. 2011;9(1):1-8. X-5.
1109 Maljaars J, Noens I, Jansen R, et al. Intentional Communication in Nonverbal and Verbal Low-Functioning Children with Autism. Journal of Communication Disorders. 2011;44(6):601-14. X-5. [pmid: 21889773].
1110 Manning SE, Davin CA, Barfield WD, et al. Early diagnoses of autism spectrum disorders in Massachusetts birth cohorts, 2001–2005. Pediatrics. 2011;127(6):1043-51. X-4. [pmid: 21576313].
1111 Manor-Binyamini I. Mothers of Children with Developmental Disorders in the Bedouin Community in Israel: Family Functioning, Caregiver Burden, and Coping Abilities. Journal of Autism and Developmental Disorders. 2011;41(5):610-7. X-5. [pmid: 20694507].
1112 Marcus RN, Owen R, Manos G, et al. Aripiprazole in the treatment of irritability in pediatric patients (aged 6-17 years) with autistic disorder: results from a 52-week, open-label study. J Child Adolesc Psychopharmacol. Jun. 2011;21(3):229-36. X-5. [pmid: 21663425].
1113 Marcus RN, Owen R, Manos G, et al. Safety and tolerability of aripiprazole for irritability in pediatric patients with autistic disorder: a 52-week, open-label, multicenter study. J Clin Psychiatry. Sep. 2011;72(9):1270-6. X-5. [pmid: 21813076].
1114 Marcus SC, Durkin M. Stimulant adherence and academic performance in urban youth with attention-deficit/hyperactivity disorder. J Am Acad Child Adolesc Psychiatry. May. 2011;50(5):480-9. X-5. [pmid: 21515197].
1115 Marquenie K, Rodger S, Mangohig K, et al. Dinnertime and bedtime routines and rituals in families with a young child with an autism spectrum disorder. Aust Occup Ther J. Jun. 2011;58(3):145-54. X-5. [pmid: 21599679].
1116 Marui T, Funatogawa I, Koishi S, et al. The NADH‐ubiquinone oxidoreductase 1 alpha subcomplex 5 (NDUFA5) gene variants are associated with autism. Acta Psychiatrica Scandinavica. 2011;123(2):118-24. X-5. [pmid: 20825370].
1117 Marzullo-Kerth D, Reeve SA, Reeve KF, et al. Using multiple-exemplar training to teach a generalized repertoire of sharing to children with autism. J Appl Behav Anal. Summer. 2011;44(2):279-94. X-3. [pmid: 21709784].
1118 Mashal N, Kasirer A. Thinking maps enhance metaphoric competence in children with autism and learning disabilities. Research in Developmental Disabilities. 2011;32(6):2045-54. X-1, X-3. [pmid: 21985987].
1119 Mason MC. Head for bed. Nurs Stand. Jan 26-Feb 1. 2011;25(21):20. X-5. [pmid: 21329128].
1120 Mathewson KJ, Drmic IE, Jetha MK, et al. Behavioral and cardiac responses to emotional stroop in adults with autism spectrum disorders: influence of medication. Autism Res. Apr. 2011;4(2):98-108. X-5. [pmid: 21360828].
1121 Matson JL, Hess JA. Psychotropic Drug Efficacy and Side Effects for Persons with Autism Spectrum Disorders. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2011:230-6. X-2, X-3, X-4.
1122 Matson JL, Kozlowski AM, Worley JA, et al. What Is the Evidence for Environmental Causes of Challenging Behaviors in Persons with Intellectual Disabilities and Autism Spectrum Disorders?. Research in Developmental Disabilities: A Multidisciplinary Journal. 2011;32(2):693-8. X-5.
1123 Matson JL, Rieske RD, Tureck K. Additional Considerations for the Early Detection and Diagnosis of Autism: Review of Available Instruments. Research in Autism Spectrum Disorders. 2011;5(4):1319-26. X-5.
1124 Maurage P, Grynberg D, Noel X, et al. Dissociation between affective and cognitive empathy in alcoholism: a specific deficit for the emotional dimension. Alcohol Clin Exp Res. Sep. 2011;35(9):1662-8. X-5. [pmid: 21599717].
1125 Mavropoulou S, Papadopoulou E, Kakana D. Effects of task organization on the independent play of students with autism spectrum disorders. J Autism Dev Disord. Jul. 2011;41(7):913-25. X-3. [pmid: 20960042].
1126 Mays NM, Beal-Alvarez J, Jolivette K. Using Movement-Based Sensory Interventions to Address Self-Stimulatory Behaviors in Students with Autism. TEACHING Exceptional Children. 2011;43(6):46-52. X-1, X-2, X-3 ,X-4.
1127 Mazzei D, Lazzeri N, Billeci L, et al. Development and evaluation of a social robot platform for therapy in autism. Conf Proc IEEE Eng Med Biol Soc. 2011;2011:4515-8. X-1, X-3. [pmid: 22255342].
1128 McLaughlin MR. Speech and language delay in children. Am Fam Physician. May. 15. 2011;83(10):1183-8. X-5. [pmid: 21568252].
1129 McTiernan A, Leader G, Healy O, et al. Analysis of Risk Factors and Early Predictors of Challenging Behavior for Children with Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2011;5(3):1215-22. X-5.
1130 Meindl JN, Cannella-Malone HI. Initiating and Responding to Joint Attention Bids in Children with Autism: A Review of the Literature. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2011:1441-54. X-2, X-3, X-4.
1131 Meltzer EC, Rybin D, Saitz R, et al. Identifying prescription opioid use disorder in primary care: diagnostic characteristics of the Current Opioid Misuse Measure (COMM). Pain. Feb. 2011;152(2):397-402. X-5. [pmid: 21177035].
1132 Menear KS, Smith SC. Teaching Physical Education to Students with Autism Spectrum Disorders. Strategies: A Journal for Physical and Sport Educators. 2011;24(3):21-4. X-5.
1133 Mesibov GB, Shea V. Evidence-Based Practices and Autism. Autism: The International Journal of Research and Practice. January. 2011. 2011;15(1):114-33. X-5. [pmid: 20876165].
1134 Miller JS, Gabrielsen T, Villalobos M, et al. The each child study: systematic screening for autism spectrum disorders in a pediatric setting. Pediatrics. May. 2011;127(5):866-71. X-1, X-3, X-4, X-5. [pmid: 21482605].
1135 Minchella L, Preti L. Autism spectrum disorder: clinical considerations for the school nurse. NASN Sch Nurse. May. 2011;26(3):143-5. X-5. [pmid: 21675293].
1136 Ming X, Hashim A, Fleishman S, et al. Access to specialty care in autism spectrum disorders-a pilot study of referral source. BMC Health Serv Res. 2011;11:99. X-5. [pmid: 21569571].
1137 Minjarez MB, Williams SE, Mercier EM, et al. Pivotal response group treatment program for parents of children with autism. J Autism Dev Disord. Jan. 2011;41(1):92-101. X-5. [pmid: 20440638].
1138 Montes G, Halterman JS. White-black disparities in family-centered care among children with autism in the United States: evidence from the NS-CSHCN 2005-2006. Acad Pediatr. Jul-Aug. 2011;11(4):297-304. X-5. [pmid: 21622042].
1139 Montgomery J, Storey K, Post M, et al. The use of auditory prompting systems for increasing independent performance of students with autism in employment training. Int J Rehabil Res. Dec. 2011;34(4):330-5. X-3, X-5. [pmid: 21885987].
1140 Moore TR, a Timothy R, Symons FJ, et al. Adherence to Treatment in a Behavioral Intervention Curriculum for Parents of Children With Autism Spectrum Disorder. Behavior Modification. 2011;35(6):570-94. X-5. [pmid: 21885470].
1141 Morag A, Pasmanik-Chor M, Oron-Karni V, et al. Genome-wide expression profiling of human lymphoblastoid cell lines identifies CHL1 as a putative SSRI antidepressant response biomarker. Pharmacogenomics. Feb. 2011;12(2):171-84. X-5. [pmid: 21332311].
1142 Morrier MJ, Hess KL, Heflin JL. Teacher Training for Implementation of Teaching Strategies for Students with Autism Spectrum Disorders. Teacher Education and Special Education. 2011;34(2):119-32. X-5.
1143 Morrison H, Roscoe EM, Atwell A. An Evaluation of Antecedent Exercise on Behavior Maintained by Automatic Reinforcement Using a Three-Component Multiple Schedule. Journal of Applied Behavior Analysis. 2011;44(3):523-41. X-3. [pmid: 21941383].
1144 Mulloy A, Lang R, O'Reilly M, et al. Addendum to “Gluten-Free and Casein-Free Diets in Treatment of Autism Spectrum Disorders: A Systematic Review”. Research in Autism Spectrum Disorders. 2011. 2011;5(1):86-8. X-4.
1145 Murdock LC, Hobbs JQ. Tell Me What You Did Today: A Visual Cueing Strategy for Children with ASD. Focus on Autism and Other Developmental Disabilities. September. 2011. 2011;26(3):162-72. X-3.
1146 Murphy DGM, Beecham J, Craig M, et al. Autism in adults. New biologicial findings and their translational implications to the cost of clinical services. Brain Research. 2011;1380:22-33. X-5. [pmid: 20969835].
1147 Murrell AR, Scherbarth AJ. State of the Research and Literature Address: ACT with Children, Adolescents and Parents. Joseph Cautilli, Ph.D. & The Behavior Analyst Online Organization. 535 Queen Street, Philadelphia, PA 19147-3220. 2011:15-22. X-4.
1148 Murshid EZ. Characteristics and dental experiences of autistic children in Saudi Arabia: Cross-sectional study. Journal of Autism and Developmental Disorders. 2011;41(12):1629-34. X-5. [pmid: 21318643].
1149 Myck-Wayne J, Robinson S, Henson E. Serving and Supporting Young Children with a Dual Diagnosis of Hearing Loss and Autism: The Stories of Four Families. American Annals of the Deaf. 2011;156(4):379-90. X-5. [pmid: 22256539].
1150 Narendorf SC, Shattuck PT, Sterzing PR. Mental health service use among adolescents with an autism spectrum disorder. Psychiatr Serv. Aug. 2011;62(8):975-8. X-5. [pmid: 21807842].
1151 Nevin JA, Shahan TA. Behavioral Momentum Theory: Equations and Applications. Journal of Applied Behavior Analysis. 2011;44(4):877-95. X-5. [pmid: 22219536].
1152 Nicholson H, Kehle TJ, Bray MA, et al. The Effects of Antecedent Physical Activity on the Academic Engagement of Children with Autism Spectrum Disorder. Psychology in the Schools. 2011;48(2):198-213. X-3.
1153 Nicpon MF, Allmon A, Sieck B, et al. Empirical Investigation of Twice-Exceptionality: Where Have We Been and Where Are We Going?. Gifted Child Quarterly. 2011;55(1):3-17. X-5.
1154 Nielsen CMB. Towards Applied Integrationism--Integrating Autism in Teaching and Coaching Sessions. Language Sciences. 2011;33(4):593-602. X-5.
1155 Normand MP, Beaulieu L. Further evaluation of response-independent delivery of preferred stimuli and child compliance. J Appl Behav Anal. Fall. 2011;44(3):665-9. X-3. [pmid: 21941401].
1156 Nuner JE, Griffith AC. Early Signs of Autism: How to Support Families and Navigate Referral Procedures. Dimensions of Early Childhood. 2011;39(1):12-20. X-5.
1157 Obhi SS, Hogeveen J, Pascual-Leone A. Resonating with others: the effects of self-construal type on motor cortical output. J Neurosci. Oct. 12. 2011;31(41):14531-5. X-5. [pmid: 21994369].
1158 O'Brien K, Slaughter V, Peterson CC. Sibling influences on theory of mind development for children with ASD. J Child Psychol Psychiatry. Jun. 2011;52(6):713-9. X-5. [pmid: 21418062].
1159 Obrusnikova I, Dillon SR. Challenging situations when teaching children with autism spectrum disorders in general physical education. Adapt Phys Activ Q. Apr. 2011;28(2):113-31. X-5. [pmid: 21757784].
1160 O'Connor J, Barnes-Holmes Y, Barnes-Holmes D. Establishing Contextual Control over Symmetry and Asymmetry Performances in Typically Developing Children and Children with Autism. Psychological Record. 2011;61(2):287-311. X-4.
1161 O'Connor KV, Stichter JP. Using Problem-Solving Frameworks to Address Challenging Behavior of Students with High-Functioning Autism and/or Asperger Syndrome. Beyond Behavior. 2011;20(1):11-7. X-5.
1162 Olivar-Parra JS, De-La-Iglesia-Gutierrez M, Forns M. Training referential communicative skills to individuals with autism spectrum disorder: a pilot study. Psychol Rep. Dec. 2011;109(3):921-39. X-1, X-3. [pmid: 22420121].
1163 Olmos-Serrano JL, Corbin JG, Burns MP. The GABA(A) receptor agonist THIP ameliorates specific behavioral deficits in the mouse model of fragile X syndrome. Dev Neurosci. 2011;33(5):395-403. X-5. [pmid: 22067669].
1164 Ono T, Araki F, Yoshiyama F. Possibility of using cylindrical ionization chambers for percent depth-dose measurements in clinical electron beams. Med Phys. Aug. 2011;38(8):4647-54. X-5. [pmid: 21928637].
1165 Oriel KN, George CL, Peckus R, et al. The effects of aerobic exercise on academic engagement in young children with autism spectrum disorder. Pediatr Phys Ther. Summer. 2011;23(2):187-93. X-3. [pmid: 21552085].
1166 Orsmond GI, Kuo HY. The daily lives of adolescents with an autism spectrum disorder: discretionary time use and activity partners. Autism. Sep. 2011;15(5):579-99. X-5. [pmid: 21697194].
1167 Ostryn C, Wolfe PS. Teaching preschool children with autism spectrum disorders to expressively discriminate between “what's that?” and “where is it?”. Focus on Autism and Other Developmental Disabilities. 2011;26(4):195-205. X-3.
1168 Ozsivadjian A, Knott F. Anxiety problems in young people with autism spectrum disorder: A case series. Clin Child Psychol Psychiatry. 2011;16(2):203-14. X-3. [pmid: 21571763].
1169 Palmen A, Didden R, Korzilius H. An outpatient group training programme for improving leisure lifestyle in high-functioning young adults with ASD: a pilot study. Dev Neurorehabil. 2011;14(5):297-309. X-5. [pmid: 21870954].
1170 Pang KH, Croaker GD. Constipation in children with autism and autistic spectrum disorder. Pediatr Surg Int. Apr. 2011;27(4):353-8. X-5. [pmid: 20697898].
1171 Paparella T, Goods KS, Freeman S, et al. The Emergence of Nonverbal Joint Attention and Requesting Skills in Young Children with Autism. Journal of Communication Disorders. 2011;44(6):569-83. X-4. [pmid: 21907346].
1172 Papas RK, Sidle JE, Gakinya BN, et al. Treatment outcomes of a stage 1 cognitive-behavioral trial to reduce alcohol use among human immunodeficiency virus-infected out-patients in western Kenya. Addiction. Dec. 2011;106(12):2156-66. X-5. [pmid: 21631622].
1173 Papavasiliou AS, Nikaina I, Rizou J, et al. The effect of a psycho-educational program on CARS scores and short sensory profile in autistic children. Eur J Paediatr Neurol. Jul. 2011;15(4):338-44. X-5. [pmid: 21354837].
1174 Parker D, Kamps D. Effects of Task Analysis and Self-Monitoring for Children with Autism in Multiple Social Settings. Focus on Autism and Other Developmental Disabilities. 2011;26(3):131-42. X-3.
1175 Parker N, O'Brien P. Play Therapy-Reaching the Child with Autism. International Journal of Special Education. 2011;26(1):80-7. X-3, X-5.
1176 Parry-Cruwys DE, Neal CM, Ahearn WH, et al. Resistance to Disruption in a Classroom Setting. Journal of Applied Behavior Analysis. 2011;44(2):363-7. X-3. [pmid: 21709794].
1177 Pasco G, Tohill C. Predicting progress in Picture Exchange Communication System (PECS) use by children with autism. Int J Lang Commun Disord. Jan-Feb. 2011;46(1):120-5. X-4. [pmid: 20536353].
1178 Pascual-Leone A, Freitas C, Oberman L, et al. Characterizing brain cortical plasticity and network dynamics across the age-span in health and disease with TMS-EEG and TMS-fMRI. Brain Topogr. Oct. 2011;24(3-4):302-15. X-5. [pmid: 21842407].
1179 Patil RR. MMR vaccination and autism: learnings and implications. Hum Vaccin. Feb. 2011;7(2):281-2. X-5. [pmid: 21343697].
1180 Patten E, Watson LR. Interventions targeting attention in young children with autism. Am J Speech Lang Pathol. Feb. 2011;20(1):60-9. X-1, X-2, X-3, X-4. [pmid: 20739632].
1181 Patterson SY, Smith V. The Experience of Parents of Toddlers Diagnosed with Autism Spectrum Disorder in the More than Words Parent Education Program. Infants and Young Children. 2011;24(4):329-43. X-4, X-5.
1182 Pennington L, Pennington B. Understanding Asperger's through Cinematherapy: Part I--”Parenthood”. Parenting for High Potential. 2011;1(1):14-7. X-5.
1183 Pennington RC, Ault MJ, Schuster JW, et al. Using Simultaneous Prompting and Computer-Assisted Instruction to Teach Story Writing to Students with Autism. Assistive Technology Outcomes and Benefits. 2011;7(1):24-38. X-3.
1184 Peters B, Forlin C. Informing Educational Decisions in the Early Years: Can Evidence for Improving Pedagogy for Children with Autistic Spectrum Disorder Be Found from Neuroscience?. Wiley-Blackwell. 350 Main Street, Malden, MA 02148. 2011:135-42. X-2, X-4.
1185 Peters-Scheffer N, Didden R, Korzilius H, et al. A Meta-Analytic Study on the Effectiveness of Comprehensive ABA-Based Early Intervention Programs for Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2011;5(1):60-9. X-5.
1186 Petursdottir AI, Carr JE. A Review of Recommendations for Sequencing Receptive and Expressive Language Instruction. Journal of Applied Behavior Analysis. 2011;44(4):859-76. X-5. [pmid: 22219535].
1187 Pfeiffer BA, Koenig K, Kinnealey M, et al. Effectiveness of sensory integration interventions in children with autism spectrum disorders: a pilot study. Am J Occup Ther. Jan-Feb. 2011;65(1):76-85. X-5. [pmid: 21309374].
1188 Pillay M, Alderson-Day B, Wright B, et al. Autism Spectrum Conditions--enhancing Nurture and Development (ASCEND): an evaluation of intervention support groups for parents. Clin Child Psychol Psychiatry. Jan. 2011;16(1):5-20. X-5. [pmid: 20223793].
1189 Pituch KA, Green VA, Didden R, et al. Parent reported treatment priorities for children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2011;5(1):135-43. X-5.
1190 Plavnick JB, Ferreri SJ. Establishing verbal repertoires in children with autism using function-based video modeling. J Appl Behav Anal. Winter. 2011;44(4):747-66. X-3. [pmid: 22219527].
1191 Poon KK. The activities and participation of adolescents with autism spectrum disorders in Singapore: findings from an ICF-based instrument. J Intellect Disabil Res. Aug. 2011;55(8):790-800. X-5. [pmid: 21375640].
1192 Powell SG, Thomsen PH, Frydenberg M, et al. Long-term treatment of ADHD with stimulants: a large observational study of real-life patients. J Atten Disord. Aug. 2011;15(6):439-51. X-5. [pmid: 20631198].
1193 Prelock PA, Calhoun J, Morris H, et al. Supporting Parents to Facilitate Communication and Joint Attention in Their Young Children with Autism Spectrum Disorders: Two Pilot Studies. Topics in Language Disorders. 2011;31(3):210-34. X-3.
1194 Puleo CM, Kendall PC. Anxiety disorders in typically developing youth: autism spectrum symptoms as a predictor of cognitive-behavioral treatment. J Autism Dev Disord. Mar. 2011;41(3):275-86. X-5. [pmid: 20694508].
1195 Quigley SP, Peterson L, Frieder JE, et al. Effects of a Weighted Vest on Problem Behaviors during Functional Analyses in Children with Pervasive Developmental Disorders. Research in Autism Spectrum Disorders. 2011;5(1):529-38. X-3, X-4.
1196 Raglio A, Traficante D, Oasi O. Autism and music therapy. Intersubjective approach and music therapy assessment. Nordisk tidskrift for musikkterapi - Nordic Journal of Music Therapy. 2011;20(2):123-41. X-5.
1197 Rahman M, Ferdous MS, Ahmed SI, et al. Speech Development of Autistic Children by Interactive Computer Games. Interactive Technology and Smart Education. 2011;8(4):208-23. X-5.
1198 Ramdoss S, Lang R, Mulloy A, et al. Use of Computer-Based Interventions to Teach Communication Skills to Children with Autism Spectrum Disorders: A Systematic Review. Springer. 233 Spring Street, New York, NY 10013. 2011:55-76. X-4.
1199 Ramdoss S, Mulloy A, Lang R, et al. Use of Computer-Based Interventions to Improve Literacy Skills in Students with Autism Spectrum Disorders: A Systematic Review. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2011:1306-18. X-4.
1200 Randolph JK, Stichter JP, Schmidt CT, et al. Fidelity and Effectiveness of PRT Implemented by Caregivers without College Degrees. Focus on Autism and Other Developmental Disabilities. 2011;26(4):230-8. X-3.
1201 Rasovska H, Rektorova I. Instrumental activities of daily living in Parkinson's disease dementia as compared with Alzheimer's disease: relationship to motor disability and cognitive deficits: a pilot study. J Neurol Sci. Nov. 15. 2011;310(1-2):279-82. X-5. [pmid: 21851954].
1202 Ray-Subramanian CE, Huai N, Ellis Weismer S. Brief report: adaptive behavior and cognitive skills for toddlers on the autism spectrum. J Autism Dev Disord. May. 2011;41(5):679-84. X-5. [pmid: 20697794].
1203 Reaven J. The treatment of anxiety symptoms in youth with high-functioning autism spectrum disorders: developmental considerations for parents. Brain Res. Mar. 22. 2011;1380:255-63. X-5. [pmid: 20875799].
1204 Reed P, Clark C. Impact of intervening learning on resurgence in humans with autism spectrum disorders. Learning & Behavior. 2011;39(2):163-70. X-5. [pmid: 21264565].
1205 Reed P, Staytom L, Stott S, et al. Comparison of conditioning impairments in children with Down syndrome, autistic spectrum disorders and mental age-matched controls. J Intellect Disabil Res. Oct. 2011;55(10):988-97. X-1, X-3, X-4. [pmid: 21790825].
1206 Rehfeldt RA. Toward a technology of derived stimulus relations: An analysis of articles published in the Journal of Applied Behavior Analysis, 1992-2009. Journal of Applied Behavior Analysis. 2011;44(1):109-19. X-5. [pmid: 21541138].
1207 Reichow B, Wolery M. Comparison of progressive prompt delay with and without instructive feedback. J Appl Behav Anal. Summer. 2011;44(2):327-40. X-3. [pmid: 21709788].
1208 Reilly C, Ballantine R. Epilepsy in School-Aged Children: More than Just Seizures?. Support for Learning. 2011;26(4):144-51. X-2, X-5.
1209 Reith RM, Way S, McKenna J 3rd, et al. Loss of the tuberous sclerosis complex protein tuberin causes Purkinje cell degeneration. Neurobiol Dis. Jul. 2011;43(1):113-22. X-5. [pmid: 21419848].
1210 Renshaw TL, Kuriakose S. Pivotal Response Treatment for Children with Autism: Core Principles and Applications for School Psychologists. Journal of Applied School Psychology. 2011;27(2):181-200. X-5.
1211 Reynhout G, Carter M. Social Stories[TM]: A Possible Theoretical Rationale. European Journal of Special Needs Education. 2011. 2011;26(3):367-78. X-5.
1212 Reynhout G, Carter M. Evaluation of the Efficacy of Social Stories[TM] Using Three Single Subject Metrics. Research in Autism Spectrum Disorders. 2011. 2011;5(2):885-900. X-4.
1213 Reynolds KE. Autism spectrum disorders in childhood: a clinical update. Community Pract. Jul. 2011;84(7):36-8. X-5. [pmid: 21941709].
1214 Reynolds S, Bendixen RM, Lawrence T, et al. A pilot study examining activity participation, sensory responsiveness, and competence in children with high functioning autism spectrum disorder. Journal of Autism and Developmental Disorders. 2011;41(11):1496-506. X-5. [pmid: 21221753].
1215 Richling SM, Rapp JT, Carroll RA, et al. Using noncontingent reinforcement to increase compliance with wearing prescription prostheses. J Appl Behav Anal. Summer. 2011;44(2):375-9. X-3, X-5. [pmid: 21709796].
1216 Ridge K, Guerin S. Irish clinicians' views of interventions for children with autistic spectrum disorders. Autism. Mar. 2011;15(2):239-52. X-5. [pmid: 21325370].
1217 Riojas-Cortez M. Culture, Play, and Family: Supporting Children on the Autism Spectrum. Young Children. 2011;66(5):94-9. X-5.
1218 Rispoli M, O'Reilly M, Lang R, et al. Effects of Motivating Operations on Problem and Academic Behavior in Classrooms. Journal of Applied Behavior Analysis. 2011;44(1):187-92. X-3. [pmid: 21541143].
1219 Riviere V, Becquet M, Peltret E, et al. Increasing Compliance with Medical Examination Requests Directed to Children with Autism: Effects of a High-Probability Request Procedure. Journal of Applied Behavior Analysis. 2011;44(1):193-7. X-3. [pmid: 21541109].
1220 Roberts RM, Moar K, Scott R. Teachers' Opinions of Interdisciplinary Reports: The Children's Assessment Team. Australian Journal of Educational & Developmental Psychology. 2011;11:39-59. X-5.
1221 Roberts TP, Cannon KM, Tavabi K, et al. Auditory magnetic mismatch field latency: a biomarker for language impairment in autism. Biol Psychiatry. Aug. 1. 2011;70(3):263-9. X-5. [pmid: 21392733].
1222 Rolinski M, Ebmeier KP. Tackling dementia in patients with Parkinson's disease. Practitioner. Jan. 2011;255(1736):15-7. 2. X-5. [pmid: 21370709].
1223 Rosenblatt LE, Gorantla S, Torres JA, et al. Relaxation response-based yoga improves functioning in young children with autism: a pilot study. J Altern Complement Med. Nov. 2011;17(11):1029-35. X-5. [pmid: 21992466].
1224 Ross LA, Molholm S, Blanco D, et al. The development of multisensory speech perception continues into the late childhood years. Eur J Neurosci. Jun. 2011;33(12):2329-37. X-5. [pmid: 21615556].
1225 Rossignol DA, Frye RE. Melatonin in Autism Spectrum Disorders: A Systematic Review and Meta-Analysis. Developmental Medicine & Child Neurology. 2011;53(9):783-92. X-5. [pmid: 21518346].
1226 Rotheram-Fuller E, MacMullen L. Cognitive-Behavioral Therapy for Children with Autism Spectrum Disorders. Psychology in the Schools. 2011;48(3):263-71. X-2, X-5.
1227 Rothman SM. Health advocacy organizations and evidence-based medicine. JAMA. Jun. 22. 2011;305(24):2569-70. X-5. [pmid: 21693747].
1228 Ryan JB, Hughes EM, Katsiyannis A, et al. Research-Based Educational Practices for Students with Autism Spectrum Disorders. TEACHING Exceptional Children. 2011;43(3):56-64. X-5.
1229 Ryndak DL, Orlando A-M, Storch JF, et al. A Mother's Perceptions of Her Ongoing Advocacy Efforts for Her Son with Significant Disabilities: Her Twelve-Year Journey. International Journal of Whole Schooling. 2011;7(2):74-91. X-5.
1230 Saalasti S, Tiippana K, Katsyri J, et al. The effect of visual spatial attention on audiovisual speech perception in adults with Asperger syndrome. Exp Brain Res. Sep. 2011;213(2-3):283-90. X-5. [pmid: 21660467].
1231 Samson F, Hyde KL, Bertone A, et al. Atypical processing of auditory temporal complexity in autistics. Neuropsychologia. Feb. 2011;49(3):546-55. X-5. [pmid: 21192958].
1232 Samyn V, Roeyers H, Bijttebier P. Effortful control in typically developing boys and in boys with ADHD or autism spectrum disorder. Res Dev Disabil. Mar-Apr. 2011;32(2):483-90. X-5. [pmid: 21255973].
1233 Sansa G, Carlson C, Doyle W, et al. Medically refractory epilepsy in autism. Epilepsia. Jun. 2011;52(6):1071-5. X-1, X-3, X-4. [pmid: 21671922].
1234 Sarrett JC, Kushner HI. A Case for Preserving the Diversity of Madness. Annals of Science. 2011;68(4):547-54. X-5.
1235 Sayers N, Oliver C, Ruddick L, et al. Stereotyped Behaviour in Children with Autism and Intellectual Disability: An Examination of the Executive Dysfunction Hypothesis. Journal of Intellectual Disability Research. 2011;55(7):699-709. X-3, X-5. [pmid: 21199048].
1236 Schaaf RC, Toth-Cohen S, Johnson SL, et al. The everyday routines of families of children with autism: examining the impact of sensory processing difficulties on the family. Autism. May. 2011;15(3):373-89. X-5. [pmid: 21430016].
1237 Schertz HH, Baker C, Hurwitz S, et al. Principles of Early Intervention Reflected in Toddler Research in Autism Spectrum Disorders. Topics in Early Childhood Special Education. 2011;31(1):4-21. X-5.
1238 Schieve LA, Rice C, Devine O, et al. Have secular changes in perinatal risk factors contributed to the recent autism prevalence increase? Development and application of a mathematical assessment model. Ann Epidemiol. Dec. 2011;21(12):930-45. X-5. [pmid: 22000328].
1239 Schiff A, Tarbox J, Lanagan T, et al. Establishing Compliance with Liquid Medication Administration in a Child with Autism. Journal of Applied Behavior Analysis. 2011;44(2):381-5. X-3. [pmid: 21709797].
1240 Schleismann KD, Gillis JM. The Treatment of Social Phobia in a Young Boy with Asperger's Disorder. Cognitive and Behavioral Practice. 2011;18(4):515-29. X-3.
1241 Schlenker B, Gratzke C, Seitz M, et al. Fluorescence-guided laser therapy for penile carcinoma and precancerous lesions: long-term follow-up. Urol Oncol. Nov-Dec. 2011;29(6):788-93. X-5. [pmid: 19945305].
1242 Schlosser RW, Shane H, Sorce J, et al. Identifying performing and under performing graphic symbols for verbs and prepositions in animated and static formats: a research note. Augment Altern Commun. Sep. 2011;27(3):205-14. X-5. [pmid: 22008033].
1243 Schmid AM, Truog AW, Damian FJ. Care of the suicidal pediatric patient in the ED: a case study. Am J Nurs. Sep. 2011;111(9):34-43. quiz 4-5. X-5. [pmid: 21865931].
1244 Schneider HD, Hopp JP. The use of the Bilingual Aphasia Test for assessment and transcranial direct current stimulation to modulate language acquisition in minimally verbal children with autism. Clin Linguist Phon. Jun. 2011;25(6-7):640-54. X-1, X-3. [pmid: 21631313].
1245 Schoen E, Paul R, Chawarska K. Phonology and vocal behavior in toddlers with autism spectrum disorders. Autism Res. Jun. 2011;4(3):177-88. X-5. [pmid: 21308998].
1246 Schon T, Sandelin LL, Bonnedahl J, et al. A comparative study of three methods to evaluate an intervention to improve empirical antibiotic therapy for acute bacterial infections in hospitalized patients. Scand J Infect Dis. Apr. 2011;43(4):251-7. X-5. [pmid: 21171827].
1247 Schultz TR, Schmidt CT, Stichter JP. A Review of Parent Education Programs for Parents of Children with Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 2011;26(2):96-104. X-2, X-3, X-4.
1248 Schumacher BI, Rapp JT. Evaluation of the immediate and subsequent effects of response interruption and redirection on vocal stereotypy. J Appl Behav Anal. Fall. 2011;44(3):681-5. X-3. [pmid: 21941405].
1249 Seiverling L, Hendy HM, Williams K. The Screening Tool of Feeding Problems applied to children (STEP-CHILD): psychometric characteristics and associations with child and parent variables. Res Dev Disabil. May-Jun. 2011;32(3):1122-9. X-5. [pmid: 21316919].
1250 Semansky RM, Xie M, Mandell DS. Medicaid's increasing role in treating youths with autism spectrum disorders. Psychiatr Serv. Jun. 2011;62(6):588. X-5. [pmid: 21632723].
1251 Serpentine EC, Tarnai B, Drager KD, et al. Decision Making of Parents of Children with Autism Spectrum Disorder Concerning Augmentative and Alternative Communication in Hungary. Communication Disorders Quarterly. 2011;32(4):221-31. X-4.
1252 Sharp WG, Jaquess DL, Morton JF, et al. A retrospective chart review of dietary diversity and feeding behavior of children with autism spectrum disorder before and after admission to a day-treatment program. Focus on Autism and Other Developmental Disabilities. 2011;26(1):37-48. X-5.
1253 Shattuck PT, Wagner M, Narendorf S, et al. Post-high school service use among young adults with an autism spectrum disorder. Arch Pediatr Adolesc Med. Feb. 2011;165(2):141-6. X-5. [pmid: 21300654].
1254 Shillingsburg MA, Valentino AL. Teaching a child with autism to mand for information using “how”. Analysis of Verbal Behavior. 2011;27:179-84. X-3. [pmid: 22532762].
1255 Shogren KA, Lang R, Machalicek W, et al. Self-versus teacher management of behavior for elementary school students with asperger syndrome: Impact on classroom behavior. Journal of Positive Behavior Interventions. 2011;13(2):87-96. X-3.
1256 Silva K, Correia R, Lima M, et al. Can dogs prime autistic children for therapy? Evidence from a single case study. The Journal of Alternative and Complementary Medicine. 2011;17(7):655-9. X-3. [pmid: 21689015].
1257 Silva LM, Schalock M, Ayres R. A model and treatment for autism at the convergence of Chinese medicine and Western science: first 130 cases. Chin J Integr Med. Jun. 2011;17(6):421-9. X-2, X-3. [pmid: 21660676].
1258 Silva LM, Schalock M, Gabrielsen K. Early intervention for autism with a parent-delivered Qigong massage program: a randomized controlled trial. Am J Occup Ther. Sep-Oct. 2011;65(5):550-9. X-5. [pmid: 22026323].
1259 Simpson K, Keen D. Music Interventions for Children with Autism: Narrative Review of the Literature. Springer. 233 Spring Street, New York, NY 10013. 2011:1507-14. X-2, X-4.
1260 Singh NN, Lancioni GE, Manikam R, et al. A mindfulness-based strategy for self-management of aggressive behavior in adolescents with autism. Research in Autism Spectrum Disorders. 2011;5(3):1153-8. X-5.
1261 Siu AM, Lai CY, Chiu AS, et al. Development and Validation of a Fine-Motor Assessment Tool for Use with Young Children in a Chinese Population. Research in Developmental Disabilities: A Multidisciplinary Journal. 2011;32(1):107-14. X-5.
1262 Smith T, Eikeseth S. O. Ivar Lovaas: Pioneer of Applied Behavior Analysis and Intervention for Children with Autism. Journal of Autism and Developmental Disorders. 2011;41(3):375-8. X-5. [pmid: 21153872].
1263 Sofronoff K, Dark E, Stone V. Social vulnerability and bullying in children with Asperger syndrome. Autism. May. 2011;15(3):355-72. X-5. [pmid: 21430018].
1264 Southall CM, Gast DL. Self-Management Procedures: A Comparison across the Autism Spectrum. Education and Training in Autism and Developmental Disabilities. 2011;46(2):155-71. X-2, X-3, X-4.
1265 Sowden H, Perkins M, Clegg J. Context and Communication Strategies in Naturalistic Behavioural Intervention: A Framework for Understanding How Practitioners Facilitate Communication in Children with ASD. Child Language Teaching and Therapy. February. 2011. 2011;27(1):21-38. X-3, X-5.
1266 Specchio N, Fusco L, Claps D, et al. Childhood refractory focal epilepsy following acute febrile encephalopathy. Eur J Neurol. Jul. 2011;18(7):952-61. X-5. [pmid: 21087361].
1267 Spector JE. Sight word instruction for students with autism: an evaluation of the evidence base. J Autism Dev Disord. Oct. 2011;41(10):1411-22. X-2, X-3. [pmid: 21184159].
1268 Speight RJ, Esmail A, Weston SJ. Quality assurance of electron and photon beam energy using the BQ-CHECK phantom. J Appl Clin Med Phys. 2011;12(2):3366. X-5. [pmid: 21587183].
1269 Spencer L, Lyketsos CG, Samstad E, et al. A suicidal adult in crisis: an unexpected diagnosis of autism spectrum disorder. Am J Psychiatry. Sep. 2011;168(9):890-2. X-5. [pmid: 21890803].
1270 Stahmer AC, Akshoomoff N, Cunningham AB. Inclusion for toddlers with autism spectrum disorders: the first ten years of a community program. Autism. Sep. 2011;15(5):625-41. X-5. [pmid: 21486899].
1271 Stahmer AC, Brookman-Frazee L, Lee E, et al. Parent and Multidisciplinary Provider Perspectives on Earliest Intervention for Children at Risk for Autism Spectrum Disorders. Infants and Young Children. 2011;24(4):344-63. X-5. [pmid: 24058266].
1272 Star K, Caster O, Bate A, et al. Dose variations associated with formulations of NSAID prescriptions for children: a descriptive analysis of electronic health records in the UK. Drug Saf. Apr. 1. 2011;34(4):307-17. X-5. [pmid: 21417503].
1273 Stein LI, Polido JC, Mailloux Z, et al. Oral care and sensory sensitivities in children with autism spectrum disorders. Spec Care Dentist. May-Jun. 2011;31(3):102-10. X-5. [pmid: 21592164].
1274 Steiner AM. A Strength-Based Approach to Parent Education for Children with Autism. Journal of Positive Behavior Interventions. 2011;13(3):178-90. X-3, X-4.
1275 Stevens C, Sidener TM, Reeve SA, et al. Effects of behavior-specific and general praise, on acquisition of tacts in children with pervasive developmental disorders. Research in Autism Spectrum Disorders. 2011;5(1):666-9. X-3.
1276 Stevenson RA, VanDerKlok RM, Pisoni DB, et al. Discrete neural substrates underlie complementary audiovisual speech integration processes. Neuroimage. Apr. 1. 2011;55(3):1339-45. X-5. [pmid: 21195198].
1277 Stocco CS, Thompson RH, Rodriguez NM. Restricted Interests and Teacher Presentation of Items. Journal of Applied Behavior Analysis. 2011;44(3):499-512. X-5. [pmid: 21941381].
1278 Strain PS, Schwartz IS, Barton EE. Providing Interventions for Young Children with Autism Spectrum Disorders: What We Still Need to Accomplish. Journal of Early Intervention. 2011;33(4):321-32. X-5.
1279 Strehle EM. Dysmorphological and pharmacological studies in 4q- syndrome. Genet Couns. 2011;22(2):173-85. X-5. [pmid: 21848010].
1280 Stringfield SG, Luscre D, Gast DL. Effects of a Story Map on Accelerated Reader Postreading Test Scores in Students with High-Functioning Autism. Focus on Autism and Other Developmental Disabilities. 2011;26(4):218-29. X-3.
1281 Styles A. Social Stories[TM]: Does the Research Evidence Support the Popularity?. Routledge. 325 Chestnut Street Suite 800, Philadelphia, PA 19106. 2011:415-36. X-4.
1282 Suda M, Takei Y, Aoyama Y, et al. Autistic traits and brain activation during face-to-face conversations in typically developed adults. PLoS One. 2011;6(5). X-5.
1283 Sumiyoshi C, Kawakubo Y, Suga M, et al. Impaired ability to organize information in individuals with autism spectrum disorders and their siblings. Neurosci Res. Mar. 2011;69(3):252-7. X-5. [pmid: 21129422].
1284 Sundberg ML, Sundberg CA. Intraverbal Behavior and Verbal Conditional Discriminations in Typically Developing Children and Children with Autism. Analysis of Verbal Behavior. 2011;27:23-43. X-5. [pmid: 22532753].
1285 Suzuki M. Mental development and autistic behavior in children with pervasive developmental disorders. Research in Autism Spectrum Disorders. 2011;5(4):1517-25. X-5.
1286 Taft RJ, Mason LH. Examining Effects of Writing Interventions: Highlighting Results for Students with Primary Disabilities Other than Learning Disabilities. SAGE Publications and Hammill Institute on Disabilities. 2455 Teller Road, Thousand Oaks, CA 91320. 2011:359-70. X-2.
1287 Tamanaha AC, Perissinoto J. Comparison of the evolutional process of children with autism spectrum disorders in different language therapeutic interventions. J Soc Bras Fonoaudiol. Mar. 2011;23(1):8-12. X-5. [pmid: 21552726].
1288 Tarnai B. Establishing the Relative Importance of Applying Gray's Sentence Ratio as a Component in a 10-Step Social Stories Intervention Model for Students with ASD. International Journal of Special Education. 2011;26(3):58-79. X-3.
1289 Tekin İftar E, Kurt O, Çetin Ö. A comparison of constant time delay instruction with high and low treatment integrity. Kuram ve Uygulamada Eğitim Bilimleri. 2011;11(1):375-81. X-3.
1290 Thomas M, Hunt A, Hurley M, et al. Time-use diaries are acceptable to parents with a disabled preschool child and are helpful in understanding families' daily lives. Child Care Health Dev. Mar. 2011;37(2):168-74. X-5. [pmid: 20854450].
1291 Thomeer ML, Rodgers JD, Lopata C, et al. Open-Trial Pilot of “Mind Reading” and in Vivo Rehearsal for Children with HFASD. Focus on Autism and Other Developmental Disabilities. 2011;26(3):153-61. X-5.
1292 Thompson AL. Case in Point: Illuminations for the Future of Special Education Leadership. Journal of Special Education Leadership. 2011;24(2):111-3. X-5.
1293 Thompson CJ. Multi-Sensory Intervention Observational Research. International Journal of Special Education. 2011;26(1):202-14. X-3, X-4.
1294 Thompson MJ, McLaughlin TF, Derby KM. The use of differential reinforcement to decrease inappropriate verbalizations of a nine-year-old girl with autism. Electronic Journal of Research in Educational Psychology. 2011;9(1):183-96. X-3.
1295 Tiinanen S, Maatta A, Silfverhuth M, et al. HRV and EEG based indicators of stress in children with Asperger syndrome in audio-visual stimulus test. Conf Proc IEEE Eng Med Biol Soc. 2011;2011:2021-4. X-5. [pmid: 22254732].
1296 Tincani M, Devis K. Quantitative Synthesis and Component Analysis of Single-Participant Studies on the Picture Exchange Communication System. Remedial and Special Education. 2011;32(6):458-70. X-5.
1297 Tobiasova Z, van der Lingen KH, Scahill L, et al. Risperidone-related improvement of irritability in children with autism is not associated with changes in serum of epidermal growth factor and interleukin-13. J Child Adolesc Psychopharmacol. Dec. 2011;21(6):555-64. X-4. [pmid: 22070180].
1298 Trasande L, Liu Y. Reducing the staggering costs of environmental disease in children, estimated at $76.6 billion in 2008. Health Aff (Millwood). May. 2011;30(5):863-70. X-5. [pmid: 21543421].
1299 Trepagnier CY, Olsen DE, Boteler L, et al. Virtual conversation partner for adults with autism. Cyberpsychol Behav Soc Netw. Jan-Feb. 2011;14(1-2):21-7. X-5. [pmid: 21329439].
1300 Trottier N, Kamp L, Mirenda P. Effects of peer-mediated instruction to teach use of speech-generating devices to students with autism in social game routines. Augment Altern Commun. Mar. 2011;27(1):26-39. X-3. [pmid: 21284561].
1301 Tsakanikos E, Underwood L, Kravariti E, et al. Gender Differences in Co-Morbid Psychopathology and Clinical Management in Adults with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2011;5(2):803-8. X-5.
1302 Turnbull A, Turnbull R. Right Science and Right Results: Lifestyle Change, PBS, and Human Dignity. Journal of Positive Behavior Interventions. 2011;13(2):69-77. X-5.
1303 Turner-Brown LM, Lam KS, Holtzclaw TN, et al. Phenomenology and measurement of circumscribed interests in autism spectrum disorders. Autism. Jul. 2011;15(4):437-56. X-5. [pmid: 21454386].
1304 Tyler CV, Schramm SC, Karafa M, et al. Chronic disease risks in young adults with autism spectrum disorder: Forewarned is forearmed. American Journal on Intellectual and Developmental Disabilities. 2011;116(5):371-80. X-5. [pmid: 21905805].
1305 Umeda C, Deitz J. Effects of therapy cushions on classroom behaviors of children with autism spectrum disorder. Am J Occup Ther. Mar-Apr. 2011;65(2):152-9. X-3. [pmid: 21476362].
1306 Vaccarino FM, Urban AE, Stevens HE, et al. Annual Research Review: The Promise of Stem Cell Research for Neuropsychiatric Disorders. Journal of Child Psychology and Psychiatry. 2011;52(4):504-16. X-5. [pmid: 21204834].
1307 Vaidya CJ, Foss-Feig J, Shook D, et al. Controlling attention to gaze and arrows in childhood: an fMRI study of typical development and Autism Spectrum Disorders. Dev Sci. Jul. 2011;14(4):911-24. X-4, X-5. [pmid: 21676110].
1308 Valentino AL, Shillingsburg MA, Call NA, et al. An investigation of extinction-induced vocalizations. Behavior Modification. 2011;35(3):284-98. X-3. [pmid: 21398308].
1309 Van Adel JM, Geier JD, Perry A, et al. Credible knowledge: a pilot evaluation of a modified GRADE method using parent-implemented interventions for children with autism. BMC Health Serv Res. 2011;11:60. X-1, X-2, X-3, X-5. [pmid: 21426564].
1310 van Steensel FJ, Bogels SM, Perrin S. Anxiety disorders in children and adolescents with autistic spectrum disorders: a meta-analysis. Clin Child Fam Psychol Rev. Sep. 2011;14(3):302-17. X-5. [pmid: 21735077].
1311 Vanvuchelen M, Vochten C. How much change is true change? The smallest detectable difference of the Preschool Imitation and Praxis Scale (PIPS) in preschoolers with intellectual disabilities of heterogeneous aetiology. Res Dev Disabil. Jan-Feb. 2011;32(1):180-7. X-3, X-5. [pmid: 20952157].
1312 Virues-Ortega J, Segui-Duran D, Descalzo-Quero A, et al. Caregivers' agreement and validity of indirect functional analysis: A cross cultural evaluation across multiple problem behavior topographies. Journal of Autism and Developmental Disorders. 2011;41(1):82-91. X-5. [pmid: 20443134].
1313 Volkert VM, Vaz PC, Piazza CC, et al. Using a Flipped Spoon to Decrease Packing in Children with Feeding Disorders. Journal of Applied Behavior Analysis. 2011;44(3):617-21. X-3. [pmid: 21941393].
1314 Vollmer TR. Three Variations of Translational Research: Comments on Critchfield (2011). Behavior Analyst. 2011;34(1):31-5. X-5. [pmid: 22532727].
1315 von der Embse N, Brown A, Fortain J. Facilitating Inclusion by Reducing Problem Behaviors for Students with Autism Spectrum Disorders. SAGE Publications and Hammill Institute on Disabilities. 2455 Teller Road, Thousand Oaks, CA 91320. 2011:22-30. X-4.
1316 Vriend JL, Corkum PV, Moon EC, et al. Behavioral interventions for sleep problems in children with autism spectrum disorders: current findings and future directions. J Pediatr Psychol. Oct. 2011;36(9):1017-29. X-5. [pmid: 21745808].
1317 Wachtel LE, Dhossche DM, Kellner CH. When is electroconvulsive therapy appropriate for children and adolescents?. Med Hypotheses. Mar. 2011;76(3):395-9. X-5. [pmid: 21129852].
1318 Wainer AL, Ingersoll BR. The Use of Innovative Computer Technology for Teaching Social Communication to Individuals with Autism Spectrum Disorders. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2011:96-107. X-2, X-4.
1319 Wan CY, Bazen L, Baars R, et al. Auditory-motor mapping training as an intervention to facilitate speech output in non-verbal children with autism: a proof of concept study. PLoS One. 2011;6(9):e25505. X-3, X-4. [pmid: 21980480].
1320 Wang H-T, Sandall SR, Davis CA, et al. Social Skills Assessment in Young Children with Autism: A Comparison Evaluation of the SSRS and PKBS. Journal of Autism and Developmental Disorders. 2011;41(11):1487-95. X-5. [pmid: 21225453].
1321 Wang S-Y, Cui Y, Parrila R. Examining the Effectiveness of Peer-Mediated and Video-Modeling Social Skills Interventions for Children with Autism Spectrum Disorders: A Meta-Analysis in Single-Case Research Using HLM. Research in Autism Spectrum Disorders. 2011;5(1):562-9. X-5.
1322 Webber LS, McVilly KR, Chan J. Restrictive interventions for people with a disability exhibiting challenging behaviours: Analysis of a population database. Journal of Applied Research in Intellectual Disabilities. 2011;24(6):495-507. X-1, X-3, X-4.
1323 Weeden M, Poling A. Identifying Reinforcers in Skill Acquisition Studies Involving Participants with Autism: Procedures Reported from 2005 to 2009. Research in Autism Spectrum Disorders. 2011;5(1):388-91. X-2, X-5.
1324 Weeden M, Porter LK, Durgin A, et al. Reporting of medication information in applied studies of people with autism. Research in Autism Spectrum Disorders. 2011;5(1):108-11. X-2, X-5.
1325 Weinkauf SM, Zeug NM, Anderson CT, et al. Evaluating the effectiveness of a comprehensive staff training package for behavioral interventions for children with autism. Research in Autism Spectrum Disorders. 2011;5(2):864-71. X-5.
1326 Weintraub D, Somogyi M, Meng X. Rivastigmine in Alzheimer's disease and Parkinson's disease dementia: an ADAS-cog factor analysis. Am J Alzheimers Dis Other Demen. Sep. 2011;26(6):443-9. X-5. [pmid: 22009228].
1327 Werner S. Assessing female students' attitudes in various health and social professions toward working with people with autism: A preliminary study. Journal of Interprofessional Care. 2011;25(2):131-7. X-5. [pmid: 21182438].
1328 Westendorp M, Houwen S, Hartman E, et al. Are gross motor skills and sports participation related in children with intellectual disabilities?. Res Dev Disabil. May-Jun. 2011;32(3):1147-53. X-5. [pmid: 21310587].
1329 Wharff EA, Ginnis KB, Ross AM, et al. Predictors of psychiatric boarding in the pediatric emergency department: implications for emergency care. Pediatr Emerg Care. Jun. 2011;27(6):483-9. X-5. [pmid: 21629148].
1330 White P, O'Reilly M, Fragale C, et al. An Extended Functional Analysis Protocol Assesses the Role of Stereotypy in Aggression in Two Young Children with Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2011;5(2):784-9. X-3, X-5.
1331 White PJ, O'Reilly M, Streusand W, et al. Best Practices for Teaching Joint Attention: A Systematic Review of the Intervention Literature. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2011:1283-95. X-4.
1332 Whitehouse AJ, Maybery M, Wray JA, et al. No association between early gastrointestinal problems and autistic-like traits in the general population. Dev Med Child Neurol. May. 2011;53(5):457-62. X-5. [pmid: 21418197].
1333 Willette AA, Lubach GR, Knickmeyer RC, et al. Brain enlargement and increased behavioral and cytokine reactivity in infant monkeys following acute prenatal endotoxemia. Behav Brain Res. May. 16. 2011;219(1):108-15. X-1, X-3, X-4, X-5. [pmid: 21192986].
1334 Woodard CR, Van Reet J. Object identification and imagination: an alternative to the meta-representational explanation of autism. J Autism Dev Disord. Feb. 2011;41(2):213-26. X-2, X-5. [pmid: 20532603].
1335 Woods JJ, Brown JA. Integrating Family Capacity-Building and Child Outcomes to Support Social Communication Development in Young Children with Autism Spectrum Disorder. Topics in Language Disorders. 2011;31(3):235-46. X-5.
1336 Woolfson LM, Taylor RJ, Mooney L. Parental attributions of controllability as a moderator of the relationship between developmental disability and behaviour problems. Child Care Health Dev. Mar. 2011;37(2):184-94. X-5. [pmid: 20533916].
1337 Worley JA, Matson JL, Sipes M, et al. Prevalence of Autism Spectrum Disorders in Toddlers Receiving Early Intervention Services. Research in Autism Spectrum Disorders. 2011;5(2):920-5. X-5.
1338 Wright B, Sims D, Smart S, et al. Melatonin versus placebo in children with autism spectrum conditions and severe sleep problems not amenable to behaviour management strategies: a randomised controlled crossover trial. J Autism Dev Disord. Feb. 2011;41(2):175-84. X-5. [pmid: 20535539].
1339 Wright C, Conlon E, Wright M, et al. Sub-Lexical Reading Intervention in a Student with Dyslexia and Asperger's Disorder. Australian Journal of Educational & Developmental Psychology. 2011;11:11-25. X-3.
1340 Xia RR. Effectiveness of nutritional supplements for reducing symptoms in autism-spectrum disorder: A case report. The Journal of Alternative and Complementary Medicine. 2011;17(3):271-4. X-3. [pmid: 21417812].
1341 Xin JF, Sutman FX. Using the Smart Board in Teaching Social Stories to Students with Autism. TEACHING Exceptional Children. 2011;43(4):18-24. X-1, X-2, X-3, X-4.
1342 Yang M, Perry K, Weber MD, et al. Social peers rescue autism-relevant sociability deficits in adolescent mice. Autism Res. Feb. 2011;4(1):17-27. X-5. [pmid: 20928844].
1343 Yaw JS, Skinner CH, Parkhurst J, et al. Extending Research on a Computer-Based Sight-Word Reading Intervention to a Student with Autism. Journal of Behavioral Education. 2011;20(1):44-54. X-3.
1344 Youmans G, Youmans SR, Hancock AB. Script Training Treatment for Adults with Apraxia of Speech. American Journal of Speech-Language Pathology. 2011;20(1):23-37. X-5. [pmid: 20739633].
1345 Young D, Bebbington A, de Klerk N, et al. The relationship between MECP2 mutation type and health status and service use trajectories over time in a rett syndrome population. Research in Autism Spectrum Disorders. 2011;5(1):442-9. X-5. [pmid: 21057653].
1346 Zachor DA, Ben Itzchak E. Assisted reproductive technology and risk for autism spectrum disorder. Res Dev Disabil. Nov-Dec. 2011;32(6):2950-6. X-5. [pmid: 21658904].
1347 Zeiner P, Gjevik E, Weidle B. Response to atomoxetine in boys with high‐functioning autism spectrum disorders and attention deficit/hyperactivity disorder. Acta Paediatrica. 2011;100(9):1258-61. X-1, X-3. [pmid: 21392103].
1348 Zeman LD, Swanke J, Doktor J. Strengths Classification of Social Relationships among Cybermothers Raising Children with Autism Spectrum Disorders. School Community Journal. 2011;21(1):37-51. X-5.
1349 Zhang J, Wheeler JJ. A Meta-Analysis of Peer-Mediated Interventions for Young Children with Autism Spectrum Disorders. Education and Training in Autism and Developmental Disabilities. 2011;46(1):62-77. X-5.
1350 Zhu H, Sun Y, Zeng J, et al. Mirror neural training induced by virtual reality in brain-computer interfaces may provide a promising approach for the autism therapy. Med Hypotheses. May. 2011;76(5):646-7. X-5. [pmid: 21300442].
1351 Zirkel PA. Autism Litigation under the IDEA: A New Meaning of “Disproportionality”?. Journal of Special Education Leadership. September. 2011. 2011;24(2):92-103. X-5.
1352 Trialing targeted therapies for autism. Nat Med. Dec. 2012;18(12):1746-7. X-1, X-2, X-3, X-4. [pmid: 23223062].
1353 Improving support for staff and patients with Asperger's syndrome. Nurs Stand. Oct. 10-16. 2012;27(6):63. X-1, X-2, X-3, X-4. [pmid: 23189584].
1354 Abrahamse ME, Junger M, Chavannes EL, et al. Parent–child interaction therapy for preschool children with disruptive behaviour problems in the Netherlands. Child and Adolescent Psychiatry and Mental Health. 2012;6. X-3.
1355 Achmadi D, Kagohara DM, van der Meer L, et al. Teaching Advanced Operation of an iPod-Based Speech-Generating Device to Two Students with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2012;6(4):1258-64. X-3, X-5.
1356 Ackerman S, Reilly B, Bernier R. Tympanostomy tube placement in children with autism. J Dev Behav Pediatr. Apr. 2012;33(3):252-8. X-4, X-5. [pmid: 22343482].
1357 Adamo SM. The Aesthetic Experience in the Process of Recovery from Autistic States. Journal of Child Psychotherapy. 2012. 2012;38(1):61-77. X-2, X-5.
1358 Adams C, Lockton E, Freed J, et al. The Social Communication Intervention Project: A randomized controlled trial of the effectiveness of speech and language therapy for school‐age children who have pragmatic and social communication problems with or without autism spectrum disorder. International Journal of Language & Communication Disorders. 2012;47(3):233-44. X-3. [pmid: 22512510].
1359 Ahmad S, Aboumarzouk O, Somani B, et al. Oral 5-aminolevulinic acid in simultaneous photodynamic diagnosis of upper and lower urinary tract transitional cell carcinoma - a prospective audit. BJU Int. Dec. 2012;110(11 Pt B):E596-600. X-5. [pmid: 22758907].
1360 Ahmedani BK, Hock RM. Health care access and treatment for children with co-morbid autism and psychiatric conditions. Soc Psychiatry Psychiatr Epidemiol. Nov. 2012;47(11):1807-14. X-5. [pmid: 22322982].
1361 Alcantara JI, Cope TE, Cope W, et al. Auditory temporal-envelope processing in high-functioning children with Autism Spectrum Disorder. Neuropsychologia. Jun. 2012;50(7):1235-51. X-5. [pmid: 22349444].
1362 Allison J, Wilder DA, Chong I, et al. A comparison of differential reinforcement and noncontingent reinforcement to treat food selectivity in a child with autism. Journal of Applied Behavior Analysis. 2012;45(3):613-7. X-3. [pmid: 23060675].
1363 Altenmuller E, Demorest SM, Fujioka T, et al. Introduction to The neurosciences and music IV: learning and memory. Ann N Y Acad Sci. Apr. 2012;1252:1-16. X-5. [pmid: 22524334].
1364 Altgassen M, Koban N, Kliegel M. Do adults with autism spectrum disorders compensate in naturalistic prospective memory tasks?. Journal of Autism and Developmental Disorders. 2012;42(10):2141-51. X-5. [pmid: 22350339].
1365 Amirsalari S, Yousefi J, Radfar S, et al. Cochlear implant outcomes in children with motor developmental delay. Int J Pediatr Otorhinolaryngol. Jan. 2012;76(1):100-3. X-1, X-3, X-4. [pmid: 22100224].
1366 Ansorge C, Strommer L, Andren-Sandberg A, et al. Structured intraoperative assessment of pancreatic gland characteristics in predicting complications after pancreaticoduodenectomy. Br J Surg. Aug. 2012;99(8):1076-82. X-5. [pmid: 22556164].
1367 Argyropoulou Z, Papoudi D. The Training of a Child with Autism in a Greek Preschool Inclusive Class through Intensive Interaction: A Case Study. European Journal of Special Needs Education. 2012;27(1):99-114. X-3.
1368 Armstrong TK, Hughes MT. Exploring Computer and Storybook Interventions for Children with High Functioning Autism. International Journal of Special Education. 2012. 2012;27(3):88-99. X-3.
1369 Arnold LE, Aman MG, Hollway J, et al. Placebo-controlled pilot trial of mecamylamine for treatment of autism spectrum disorders. J Child Adolesc Psychopharmacol. Jun. 2012;22(3):198-205. X-5. [pmid: 22537359].
1370 Asaro-Saddler K, Bak N. Teaching Children with High-Functioning Autism Spectrum Disorders to Write Persuasive Essays. Topics in Language Disorders. 2012. 2012;32(4):361-78. X-3.
1371 Atladottir HO, Henriksen TB, Schendel DE, et al. Autism after infection, febrile episodes, and antibiotic use during pregnancy: an exploratory study. Pediatrics. Dec. 2012;130(6):e1447-54. X-5. [pmid: 23147969].
1372 Atzori M, Garcia-Oscos F, Mendez JA. Role of IL-6 in the etiology of hyperexcitable neuropsychiatric conditions: experimental evidence and therapeutic implications. Future Med Chem. Nov. 2012;4(17):2177-92. X-5. [pmid: 23190106].
1373 Audenet F, Traxer O, Yates DR, et al. Potential role of photodynamic techniques combined with new generation flexible ureterorenoscopes and molecular markers for the management of urothelial carcinoma of the upper urinary tract. BJU Int. Feb. 2012;109(4):608-13. discussion 13-4. X-5. [pmid: 21985291].
1374 Auert EJ, Trembath D, Arciuli J, et al. Parents' expectations, awareness, and experiences of accessing evidence-based speech-language pathology services for their children with autism. Int J Speech Lang Pathol. Apr. 2012;14(2):109-18. X-4, X-5. [pmid: 22390744].
1375 Babineau BA, Yang M, Crawley JN. Mainstreaming mice. Neuropsychopharmacology. Jan. 2012;37(1):300-1. X-5. [pmid: 22157866].
1376 Baghdadli A, Assouline B, Sonie S, et al. Developmental Trajectories of Adaptive Behaviors from Early Childhood to Adolescence in a Cohort of 152 Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2012;42(7):1314-25. X-4. [pmid: 21928042].
1377 Bagni C, Tassone F, Neri G, et al. Fragile X syndrome: causes, diagnosis, mechanisms, and therapeutics. J Clin Invest. Dec. 3. 2012;122(12):4314-22. X-5. [pmid: 23202739].
1378 Bahrami F, Movahedi A, Marandi SM, et al. Kata techniques training consistently decreases stereotypy in children with autism spectrum disorder. Res Dev Disabil. Jul-Aug. 2012;33(4):1183-93. X-5. [pmid: 22502844].
1379 Bailey DB Jr, Raspa M, Bishop E, et al. Medication utilization for targeted symptoms in children and adults with fragile X syndrome: US survey. J Dev Behav Pediatr. Jan. 2012;33(1):62-9. X-5. [pmid: 22064563].
1380 Ballan MS. Parental Perspectives of Communication about Sexuality in Families of Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2012;42(5):676-84. X-5. [pmid: 21681591].
1381 Baltruschat L, Hasselhorn M, Tarbox J, et al. The Effects of Multiple Exemplar Training on a Working Memory Task Involving Sequential Responding in Children with Autism. Psychological Record. 2012. 2012;62(3):549-61. X-3.
1382 Banerjee R, Guiberson M. Evaluating Young Children from Culturally and Linguistically Diverse Backgrounds for Special Education Services. Young Exceptional Children. 2012;15(1):33-45. X-2, X-5.
1383 Barnes RE, McCabe H. Should we welcome a cure for autism? A survey of the arguments. Med Health Care Philos. Aug. 2012;15(3):255-69. X-5. [pmid: 21837546].
1384 Barrett B, Byford S, Sharac J, et al. Service and wider societal costs of very young children with autism in the UK. Journal of Autism and Developmental Disorders. 2012;42(5):797-804. X-5. [pmid: 22089166].
1385 Barton EE, Lawrence K, Deurloo F. Individualizing Interventions for Young Children with Autism in Preschool. Journal of Autism and Developmental Disorders. 2012;42(6):1205-17. X-2, X-3, X-4. [pmid: 21336524].
1386 Barton EE, Pavilanis R. Teaching Pretend Play to Young Children with Autism. Young Exceptional Children. 2012;15(1):5-17. X-5.
1387 Bastidas N, Mackay DD, Taylor JA, et al. Analysis of the long-term outcomes of nonsyndromic bicoronal synostosis. Plast Reconstr Surg. Oct. 2012;130(4):877-83. X-5. [pmid: 22691840].
1388 Bauch CT, Bhattacharyya S. Evolutionary game theory and social learning can determine how vaccine scares unfold. PLoS Comput Biol. 2012;8(4):e1002452. X-5. [pmid: 22496631].
1389 Bazzano A, Zeldin A, Schuster E, et al. Vaccine-related beliefs and practices of parents of children with autism spectrum disorders. Am J Intellect Dev Disabil. May. 2012;117(3):233-42. X-5. [pmid: 22716265].
1390 Ben Said M, Robel L, Pellegrin-Touati M, et al. TEDIS, Pervasive Developmental Disorder' patients information system, preliminary results. Stud Health Technol Inform. 2012;180:285-9. X-4, X-5. [pmid: 22874197].
1391 Bent S, Bertoglio K, Ashwood P, et al. Brief Report: Hyperbaric Oxygen Therapy (HBOT) in Children with Autism Spectrum Disorder--A Clinical Trial. Journal of Autism and Developmental Disorders. 2012;42(6):1127-32. X-5. [pmid: 21818676].
1392 Berger KA. Praxis and autism: the psychomotor regulation sensory processing dimension-a report from the field. Front Integr Neurosci. 2012;6:129. X-5. [pmid: 23346051].
1393 Bergstrom R, Najdowski AC, Tarbox J. Teaching Children with Autism to Seek Help When Lost in Public. Journal of Applied Behavior Analysis. 2012;45(1):191-5. X-3. [pmid: 22403465].
1394 Berry J, Katsiyannis A. Service Animals for Students with Disabilities under IDEA and Section 504 of the Rehabilitation Act of 1973. Intervention in School and Clinic. 2012;47(5):312-5. X-5.
1395 Bevan Jones R, Thapar A, Lewis G, et al. The association between early autistic traits and psychotic experiences in adolescence. Schizophr Res. Mar. 2012;135(1-3):164-9. X-5. [pmid: 22245185].
1396 Bevan-Brown J, Bourke R, Butler P, et al. Essential Elements in a Professional Learning and Development Programme: A New Zealand Case Study of Autism Professional Development to Promote Collaborative Practices. Professional Development in Education. 2012;38(4):631-46. X-2, X-5.
1397 Bharat S, Parikh P, Noel C, et al. Motion-compensated estimation of delivered dose during external beam radiation therapy: implementation in Philips' Pinnacle(3) treatment planning system. Med Phys. Jan. 2012;39(1):437-43. X-5. [pmid: 22225314].
1398 Birman CS, Elliott EJ, Gibson WP. Pediatric cochlear implants: additional disabilities prevalence, risk factors, and effect on language outcomes. Otol Neurotol. Oct. 2012;33(8):1347-52. X-4, X-5. [pmid: 22975903].
1399 Blackburn C, McDermott M, Bourke B. Clinical presentation of and outcome for solitary rectal ulcer syndrome in children. J Pediatr Gastroenterol Nutr. Feb. 2012;54(2):263-5. X-5. [pmid: 22266488].
1400 Blake JJ, Lund EM, Zhou Q, et al. National Prevalence Rates of Bully Victimization among Students with Disabilities in the United States. School Psychology Quarterly. 2012;27(4):210-22. X-5. [pmid: 23294235].
1401 Bodner KE, Beversdorf DQ, Saklayen SS, et al. Noradrenergic moderation of working memory impairments in adults with autism spectrum disorder. J Int Neuropsychol Soc. May. 2012;18(3):556-64. X-5. [pmid: 22414705].
1402 Bolduc ME, du Plessis AJ, Sullivan N, et al. Regional cerebellar volumes predict functional outcome in children with cerebellar malformations. Cerebellum. Jun. 2012;11(2):531-42. X-5. [pmid: 21901523].
1403 Bonnal JL, Rock A Jr, Gagnat A, et al. Confocal laser endomicroscopy of bladder tumors associated with photodynamic diagnosis: an ex vivo pilot study. Urology. Nov. 2012;80(5):1162. e1-5. X-5. [pmid: 22950991].
1404 Borthwick L. Adulthood: Life lessons. Nature. Nov. 1. 2012;491(7422):S10-1. X-5. [pmid: 23136653].
1405 Bou Khalil R. Would some cannabinoids ameliorate symptoms of autism?. European Child & Adolescent Psychiatry. 2012;21(4):237-8. X-1, X-2, X-3, X-4. [pmid: 22350104].
1406 Boucher J. Research Review: Structural Language in Autistic Spectrum Disorder--Characteristics and Causes. Journal of Child Psychology and Psychiatry. 2012;53(3):219-33. X-5. [pmid: 22188468].
1407 Bourret JC, Iwata BA, Harper JM, et al. Elimination of Position-Biased Responding in Individuals with Autism and Intellectual Disabilities. Journal of Applied Behavior Analysis. 2012;45(2):241-50. X-3, X-5. [pmid: 22844134].
1408 Bourzac K. Child development: The first steps. Nature. Nov. 1. 2012;491(7422):S7-9. X-5. [pmid: 23136652].
1409 Boutot AE, Hume K. Beyond Time out and Table Time: Today's Applied Behavior Analysis for Students with Autism. Education and Training in Autism and Developmental Disabilities. 2012;47(1):23-38. X-2, X-5.
1410 Boyd BA, McDonough SG, Bodfish JW. Evidence-Based Behavioral Interventions for Repetitive Behaviors in Autism. Journal of Autism and Developmental Disorders. 2012;42(6):1236-48. X-2, X-5. [pmid: 21584849].
1411 Braiden HJ, McDaniel B, McCrudden E, et al. A Practice-Based Evaluation of Barnardo's Forward Steps Early Intervention Programme for Children Diagnosed with Autism. Child Care in Practice. 2012;18(3):227-42. X-5.
1412 Brookman-Frazee L, Baker-Ericzén M, Stadnick N, et al. Parent perspectives on community mental health services for children with autism spectrum disorders. Journal of Child and Family Studies. 2012;21(4):533-44. X-5.
1413 Brookman-Frazee L, Drahota A, Stadnick N, et al. Therapist perspectives on community mental health services for children with autism spectrum disorders. Adm Policy Ment Health. Sep. 2012;39(5):365-73. X-5. [pmid: 21533846].
1414 Brookman-Frazee LI, Drahota A, Stadnick N. Training community mental health therapists to deliver a package of evidence-based practice strategies for school-age children with autism spectrum disorders: a pilot study. J Autism Dev Disord. Aug. 2012;42(8):1651-61. X-5. [pmid: 22102293].
1415 Brown HK, Ouellette-Kuntz H, Hunter D, et al. Unmet Needs of Families of School-Aged Children with an Autism Spectrum Disorder. Journal of Applied Research in Intellectual Disabilities. 2012;25(6):497-508. X-5. [pmid: 23055284].
1416 Brown KF, Long SJ, Ramsay M, et al. U.K. parents' decision-making about measles-mumps-rubella (MMR) vaccine 10 years after the MMR-autism controversy: a qualitative analysis. Vaccine. Feb. 27. 2012;30(10):1855-64. X-5. [pmid: 22230590].
1417 Buchbinder M. “Sticky” brains and sticky encounters in a U.S. pediatric pain clinic. Cult Med Psychiatry. Mar. 2012;36(1):102-23. X-5. [pmid: 22006075].
1418 Buggey T. Effectiveness of Video Self-Modeling to Promote Social Initiations by 3-Year-Olds With Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. Jun. 2012. 2012;27(2):102-10. X-3.
1419 Buggey T, Ogle L. Video Self-Modeling. Psychology in the Schools. 2012;49(1):52-70. X-5.
1420 Burrell LT, Borrego J. Parents' Involvement in ASD Treatment: What Is Their Role?. Cognitive and Behavioral Practice. 2012;19(3):423-32. X-5.
1421 Busnelli M, Sauliere A, Manning M, et al. Functional selective oxytocin-derived agonists discriminate between individual G protein family subtypes. J Biol Chem. Feb. 3. 2012;287(6):3617-29. X-5. [pmid: 22069312].
1422 Cai SX, Kornspan AS. The Use of Exergaming with Developmentally Disabled Students. Strategies: A Journal for Physical and Sport Educators. 2012;25(3):15-8. X-1, X-2, X-3, X-4.
1423 Caldeira M, Edmunds A. Inconsistencies in Autism-Specific Emotion Interventions: Cause for Concern. Exceptionality Education International. 2012;22(1):17-36. X-1, X-2, X-3, X-4.
1424 Cannella-Malone HI, Wheaton JE, Wu P-F, et al. Comparing the Effects of Video Prompting with and without Error Correction on Skill Acquisition for Students with Intellectual Disability. Education and Training in Autism and Developmental Disabilities. 2012;47(3):332-44. X-3, X-5.
1425 Capozza LE, Bimstein E. Preferences of parents of children with autism spectrum disorders concerning oral health and dental treatment. Pediatr Dent. Nov-Dec. 2012;34(7):480-4. X-5. [pmid: 23265165].
1426 Cappadocia CM, Weiss JA, Pepler D. Bullying Experiences among Children and Youth with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2012;42(2):266-77. X-5. [pmid: 21499672].
1427 Cardon T, Azuma T. Visual Attending Preferences in Children with Autism Spectrum Disorders: A Comparison between Live and Video Presentation Modes. Research in Autism Spectrum Disorders. 2012;6(3):1061-7. X-5.
1428 Carnahan CR, Basham JD, Christman J, et al. Overcoming Challenges: “Going Mobile with Your Own Video Models”. TEACHING Exceptional Children. 2012;45(2):50-9. X-5.
1429 Carp CL, Peterson SP, Arkel AJ, et al. A further evaluation of picture prompts during auditory-visual conditional discrimination training. J Appl Behav Anal. Winter. 2012;45(4):737-51. X-3. [pmid: 23322929].
1430 Cascio AM. Neurodiversity: Autism Pride among Mothers of Children with Autism Spectrum Disorders. Intellectual and Developmental Disabilities. 2012;50(3):273-83. X-5. [pmid: 22731976].
1431 Cebula KR. Applied behavior analysis programs for autism: sibling psychosocial adjustment during and following intervention use. J Autism Dev Disord. May. 2012;42(5):847-62. X-4, X-5. [pmid: 21725720].
1432 Celebi O, Temucin CM, Elibol B, et al. Short latency afferent inhibition in Parkinson's disease patients with dementia. Mov Disord. Jul. 2012;27(8):1052-5. X-5. [pmid: 22605543].
1433 Chang MC, Parham LD, Blanche EI, et al. Autonomic and behavioral responses of children with autism to auditory stimuli. Am J Occup Ther. Sep-Oct. 2012;66(5):567-76. X-5. [pmid: 22917123].
1434 Cheng Y, Huang R. Using virtual reality environment to improve joint attention associated with pervasive developmental disorder. Res Dev Disabil. Nov-Dec. 2012;33(6):2141-52. X-3. [pmid: 22776822].
1435 Chia NKH, Li J. Design of a Generic Questionnaire for Reflective Evaluation of a Virtual Reality-Based Intervention Using Virtual Dolphins for Children with Autism. International Journal of Special Education. 2012. 2012;27(3):45-53. X-1, X-2, X-3, X-4.
1436 Ching H, Pringsheim T. Aripiprazole for autism spectrum disorders (ASD). Cochrane Database Syst Rev. 2012;5:CD009043. X-5. [pmid: 22592735].
1437 Chiri G, Warfield ME. Unmet need and problems accessing core health care services for children with autism spectrum disorder. Matern Child Health J. Jul. 2012;16(5):1081-91. X-5. [pmid: 21667201].
1438 Chitragran R, Poopitaya S, Tassanawipas W. Result of percutaneous disc decompression using nucleoplasty in Thailand: a randomized controlled trial. J Med Assoc Thai. Oct. 2012;95(Suppl 10):S198-205. X-5. [pmid: 23451463].
1439 Chou M-C, Chou W-J, Chiang H-L, et al. Sleep problems among Taiwanese children with autism, their siblings and typically developing children. Research in Autism Spectrum Disorders. 2012;6(2):665-72. X-5.
1440 Chuang IC, Tseng M-H, Lu L, et al. Sensory Correlates of Difficult Temperament Characteristics in Preschool Children with Autism. Research in Autism Spectrum Disorders. 2012;6(3):988-95. X-5.
1441 Chung Y-C, Carter EW, Sisco LG. A Systematic Review of Interventions to Increase Peer Interactions for Students with Complex Communication Challenges. TASH. 1025 Vermont Avenue 7th Floor, Washington, DC 20005. 2012:271-87. X-1, X-2, X-3, X-4.
1442 Cihak DF, Kildare LK, Smith CC, et al. Using video Social Stories to increase task engagement for middle school students with autism spectrum disorders. Behav Modif. May. 2012;36(3):399-425. X-1, X-3, X-5. [pmid: 22609764].
1443 Cihak DF, Smith CC, Cornett A, et al. The Use of Video Modeling with the Picture Exchange Communication System to Increase Independent Communicative Initiations in Preschoolers with Autism and Developmental Delays. Focus on Autism and Other Developmental Disabilities. 2012;27(1):3-11. X-3.
1444 Cimera RE, Wehman P, West M, et al. Do sheltered workshops enhance employment outcomes for adults with autism spectrum disorder?. Autism. Jan. 2012;16(1):87-94. X-5. [pmid: 21610189].
1445 Cleary A, Walsh F, Connolly H, et al. Monitoring and documentation of side effects from depot antipsychotic medication: an interdisciplinary audit of practice in a regional mental health service. J Psychiatr Ment Health Nurs. Jun. 2012;19(5):395-401. X-4, X-5. [pmid: 22070791].
1446 Cohen D, Bonnot O, Bodeau N, et al. Adverse effects of second-generation antipsychotics in children and adolescents: a Bayesian meta-analysis. J Clin Psychopharmacol. Jun. 2012;32(3):309-16. X-5. [pmid: 22544019].
1447 Colon CL, Ahearn WH, Clark KM, et al. The effects of verbal operant training and response interruption and redirection on appropriate and inappropriate vocalizations. J Appl Behav Anal. Spring. 2012;45(1):107-20. X-3. [pmid: 22403453].
1448 Constantine RJ, Jentz S, Bengtson M, et al. Exposure to antipsychotic medications over a 4-year period among children who initiated antipsychotic treatment before their sixth birthday. Pharmacoepidemiol Drug Saf. Feb. 2012;21(2):152-60. X-5. [pmid: 21793097].
1449 Coo H, Ouellette-Kuntz H, Lam M, et al. Correlates of age at diagnosis of autism spectrum disorders in six Canadian regions. Chronic Dis Inj Can. Mar. 2012;32(2):90-100. X-5. [pmid: 22414306].
1450 Cornish K, Cole V, Longhi E, et al. Does attention constrain developmental trajectories in fragile x syndrome? A 3-year prospective longitudinal study. Am J Intellect Dev Disabil. Mar. 2012;117(2):103-20. X-5. [pmid: 22515826].
1451 Corrigan NM, Shaw WD, Richards TL, et al. Proton Magnetic Resonance Spectroscopy and MRI Reveal No Evidence for Brain Mitochondrial Dysfunction in Children with Autism Spectrum Disorder. Journal of Autism and Developmental Disorders. 2012;42(1):105-15. X-5. [pmid: 21404085].
1452 Costigan FA, Light JC, Newell KM. Factors affecting computer mouse use for young children: implications for AAC. Augment Altern Commun. Jun. 2012;28(2):85-95. X-4, X-5. [pmid: 22670726].
1453 Coury DL, Anagnostou E, Manning-Courtney P, et al. Use of psychotropic medication in children and adolescents with autism spectrum disorders. Pediatrics. Nov. 2012;130(Suppl 2):S69-76. X-4, X-5. [pmid: 23118256].
1454 Cox DJ. From Interdisciplinary to Integrated Care of the Child with Autism: The Essential Role for a Code of Ethics. Journal of Autism and Developmental Disorders. 2012;42(12):2729-38. X-5. [pmid: 22527703].
1455 Crosland K, Dunlap G. Effective Strategies for the Inclusion of Children with Autism in General Education Classrooms. Behavior Modification. 2012;36(3):251-69. X-2, X-5. [pmid: 22563045].
1456 Cruz I, Vicaria I, Wang NY, et al. Language and behavioral outcomes in children with developmental disabilities using cochlear implants. Otol Neurotol. Jul. 2012;33(5):751-60. X-3, X-4. [pmid: 22699986].
1457 Cunningham AB. Measuring change in social interaction skills of young children with autism. J Autism Dev Disord. Apr. 2012;42(4):593-605. X-5. [pmid: 21638109].
1458 Danesh AA, Kaf WA. DPOAEs and contralateral acoustic stimulation and their link to sound hypersensitivity in children with autism. Int J Audiol. Apr. 2012;51(4):345-52. X-5. [pmid: 22299666].
1459 Danzer E, Siegle J, D'Agostino JA, et al. Early neurodevelopmental outcome of infants with high-risk fetal lung lesions. Fetal Diagn Ther. 2012;31(4):210-5. X-5. [pmid: 22539010].
1460 De Andres-Garcia S, Moya-Albiol L, Gonzalez-Bono E. Salivary cortisol and immunoglobulin A: responses to stress as predictors of health complaints reported by caregivers of offspring with autistic spectrum disorder. Horm Behav. Sep. 2012;62(4):464-74. X-5. [pmid: 22981424].
1461 de Boer A, Pijl SJ, Post W, et al. Which Variables Relate to the Attitudes of Teachers, Parents and Peers towards Students with Special Educational Needs in Regular Education?. Educational Studies. 2012;38(4):433-48. X-5.
1462 de Bruin EI, Verheij F. Social skills training in children with PDD-NOS: an exploratory study. Int J Psychiatry Clin Pract. Mar. 2012;16(1):60-7. X-5. [pmid: 22122657].
1463 De Bruyn L, Moelants D, Leman M. An embodied approach to testing musical empathy in participants with an autism spectrum disorder. Music and Medicine. 2012;4(1):28-36. X-5.
1464 de Hoogd S, Overbeek WA, Heerdink ER, et al. Differences in body mass index z-scores and weight status in a Dutch pediatric psychiatric population with and without use of second-generation antipsychotics. J Child Adolesc Psychopharmacol. Apr. 2012;22(2):166-73. X-3, X-4. [pmid: 22506734].
1465 de Winter FC, Bastiaanse PL, Hilgenkamp IT, et al. Overweight and Obesity in Older People with Intellectual Disability. Research in Developmental Disabilities: A Multidisciplinary Journal. 2012;33(2):398-405. X-5.
1466 DeLong G. Conflicts of interest in vaccine safety research. Account Res. 2012;19(2):65-88. X-5. [pmid: 22375842].
1467 Dente CL, Parkinson Coles K. Ecological Approaches to Transition Planning for Students with Autism and Asperger's Syndrome. Children & Schools. 2012;34(1):27-36. X-5.
1468 DePape AM, Hall GB, Tillmann B, et al. Auditory processing in high-functioning adolescents with Autism Spectrum Disorder. PLoS One. 2012;7(9):e44084. X-5. [pmid: 22984462].
1469 Desai MU, Divan G, Wertz FJ, et al. The discovery of autism: Indian parents' experiences of caring for their child with an autism spectrum disorder. Transcult Psychiatry. Jul. 2012;49(3-4):613-37. X-5. [pmid: 22722980].
1470 Deutsch SI, Pepe GJ, Burket JA, et al. D-cycloserine improves sociability and spontaneous stereotypic behaviors in 4-week old mice. Brain Res. Feb. 23. 2012;1439:96-107. X-5. [pmid: 22261249].
1471 Devic S, Tomic N, Aldelaijan S, et al. Linearization of dose-response curve of the radiochromic film dosimetry system. Med Phys. Aug. 2012;39(8):4850-7. X-5. [pmid: 22894411].
1472 Diehl JJ, Schmitt LM, Villano M, et al. The Clinical Use of Robots for Individuals with Autism Spectrum Disorders: A Critical Review. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2012:249-62. X-2, X-3, X-4.
1473 Dillenburger K. Why reinvent the wheel? A behaviour analyst's reflections on pedagogy for inclusion for students with intellectual and developmental disability. J Intellect Dev Disabil. Jun. 2012;37(2):169-80. X-2, X-5. [pmid: 22563693].
1474 Dillenburger K, Keenan M, Doherty A, et al. ABA-Based Programs for Children Diagnosed with Autism Spectrum Disorder: Parental and Professional Experiences at School and at Home. Child & Family Behavior Therapy. 2012;34(2):111-29. X-1, X-3, X-4.
1475 Divan G, Vajaratkar V, Desai MU, et al. Challenges, coping strategies, and unmet needs of families with a child with autism spectrum disorder in Goa, India. Autism Res. Jun. 2012;5(3):190-200. X-5. [pmid: 22473816].
1476 Donohue SE, Darling EF, Mitroff SR. Links between multisensory processing and autism. Exp Brain Res. Oct. 2012;222(4):377-87. X-5. [pmid: 22923209].
1477 Doucette S, DiGennaro Reed FD, Reed DD, et al. Implementation of a Posted Schedule to Increase Class-Wide Interobserver Agreement Assessment. Journal of Organizational Behavior Management. 2012;32(3):263-9. X-5.
1478 Draga RO, Grimbergen MC, Kok ET, et al. The quality of 5-aminolevulinic acid-induced photodynamic diagnosis and transurethral resection of bladder tumors: does the urologist play a role?. Urol Int. 2012;89(3):326-31. X-5. [pmid: 22986952].
1479 Drahota A, Aarons GA, Stahmer AC. Developing the Autism Model of Implementation for autism spectrum disorder community providers: study protocol. Implement Sci. 2012;7:85. X-5. [pmid: 22963616].
1480 Drake J, Johnson N, Stoneck AV, et al. Evaluation of a coping kit for children with challenging behaviors in a pediatric hospital. Pediatr Nurs. Jul-Aug. 2012;38(4):215-21. X-5. [pmid: 22970487].
1481 Dubois B, Tolosa E, Katzenschlager R, et al. Donepezil in Parkinson's disease dementia: a randomized, double-blind efficacy and safety study. Mov Disord. Sep. 1. 2012;27(10):1230-8. X-5. [pmid: 22915447].
1482 Ducharme JM, Ng O. Errorless Academic Compliance Training: A School-Based Application for Young Students with Autism. Behavior Modification. 2012;36(5):650-69. X-3. [pmid: 22421393].
1483 Dunkel-Jackson SM, Dixon MR, Szekely S. Portable Data Assistants: Potential in Evidence-Based Practice Autism Treatment. Research in Autism Spectrum Disorders. 2012;6(1):65-72. X-5.
1484 Dunn W, Cox J, Foster L, et al. Impact of a contextual intervention on child participation and parent competence among children with autism spectrum disorders: a pretest-posttest repeated-measures design. Am J Occup Ther. Sep-Oct. 2012;66(5):520-8. X-5. [pmid: 22917118].
1485 Dworzynski K, Ronald A, Bolton P, et al. How different are girls and boys above and below the diagnostic threshold for autism spectrum disorders?. J Am Acad Child Adolesc Psychiatry. Aug. 2012;51(8):788-97. X-5. [pmid: 22840550].
1486 Dykstra JR, Boyd BA, Watson LR, et al. The impact of the Advancing Social-communication And Play (ASAP) intervention on preschoolers with autism spectrum disorder. Autism. Jan. 2012;16(1):27-44. X-3. [pmid: 21788256].
1487 Early MC, Erickson CA, Wink LK, et al. Case Report: 16-Year-Old Male with Autistic Disorder with Preoccupation with Female Feet. Journal of Autism and Developmental Disorders. 2012;42(6):1133-7. X-5. [pmid: 21818675].
1488 Edwards TL, Watkins EE, Lotfizadeh AD, et al. Intervention Research to Benefit People with Autism: How Old Are the Participants?. Research in Autism Spectrum Disorders. 2012;6(3):996-9. X-5.
1489 Eisenberg E. Long-term outcomes in children born after assisted conception. Semin Reprod Med. Apr. 2012;30(2):123-30. X-5. [pmid: 22549712].
1490 Eisenstein M. Treatments: In the waiting room. Nature. Nov. 1. 2012;491(7422):S14-6. X-5. [pmid: 23136658].
1491 Emck C, Bosscher RJ, van Wieringen PC, et al. Psychiatric symptoms in children with gross motor problems. Adapt Phys Activ Q. Apr. 2012;29(2):161-78. X-5. [pmid: 22467835].
1492 Enticott PG, Kennedy HA, Rinehart NJ, et al. Mirror neuron activity associated with social impairments but not age in autism spectrum disorder. Biol Psychiatry. Mar. 1. 2012;71(5):427-33. X-5. [pmid: 21974786].
1493 Enticott PG, Rinehart NJ, Tonge BJ, et al. Repetitive transcranial magnetic stimulation (rTMS) improves movement-related cortical potentials in autism spectrum disorders. Brain Stimul. Jan. 2012;5(1):30-7. X-1, X-3. [pmid: 22037133].
1494 Eriksson MA, Westerlund J, Anderlid BM, et al. First-degree relatives of young children with autism spectrum disorders: some gender aspects. Res Dev Disabil. Sep-Oct. 2012;33(5):1642-8. X-5. [pmid: 22554810].
1495 Evans WE, Must A, Anderson SE, et al. Dietary Patterns and Body Mass Index in Children with Autism and Typically Developing Children. Research in Autism Spectrum Disorders. 2012;6(1):399-405. X-5. [pmid: 22936951].
1496 Eyler LT, Pierce K, Courchesne E. A failure of left temporal cortex to specialize for language is an early emerging and fundamental property of autism. Brain. Mar. 2012;135(Pt 3):949-60. X-5. [pmid: 22350062].
1497 Faja S, Webb SJ, Jones E, et al. The effects of face expertise training on the behavioral performance and brain activity of adults with high functioning autism spectrum disorders. J Autism Dev Disord. Feb. 2012;42(2):278-93. X-5. [pmid: 21484517].
1498 Falcomata TS, Roane HS, Muething CS, et al. Functional Communication Training and Chained Schedules of Reinforcement to Treat Challenging Behavior Maintained by Terminations of Activity Interruptions. Behavior Modification. 2012;36(5):630-49. X-3. [pmid: 22327267].
1499 Farrell L, Waters A, Milliner E, et al. Comorbidity and treatment response in pediatric obsessive-compulsive disorder: A pilot study of group cognitive-behavioral treatment. Psychiatry Research. 2012;199(2):115-23. X-1, X-3, X-4. [pmid: 22633155].
1500 Fava L, Vicari S, Valeri G, et al. Intensive Behavioral Intervention for School-Aged Children with Autism: Una Breccia nel Muro (UBM)--A Comprehensive Behavioral Model. Research in Autism Spectrum Disorders. 2012;6(4):1273-88. X-1, X-2, X-3, X-4.
1501 Felce D, Perry J. Diagnostic grouping among adults with intellectual disabilities and autistic spectrum disorders in staffed housing. J Intellect Disabil Res. Dec. 2012;56(12):1187-93. X-5. [pmid: 22044559].
1502 Fentress GM, Lerman DC. A Comparison of Two Prompting Procedures for Teaching Basic Skills to Children with Autism. Research in Autism Spectrum Disorders. 2012;6(3):1083-90. X-3.
1503 Fernandes FDM, De La Higuera Amato CA, Molini-Avejonas DR. Language therapy results with children of the autism spectrum. Revista de Logopedia, Foniatría y Audiología. 2012;32(1):2-6. X-5.
1504 Ferraioli SJ, Hansford A, Harris SL. Benefits of Including Siblings in the Treatment of Autism Spectrum Disorders. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2012:413-22. X-4.
1505 Fiks AG, Mayne S, Hughes CC, et al. Development of an instrument to measure parents' preferences and goals for the treatment of attention deficit-hyperactivity disorder. Acad Pediatr. Sep-Oct. 2012;12(5):445-55. X-5. [pmid: 22748759].
1506 Finn HE, Miguel CF, Ahearn WH. The Emergence of Untrained Mands and Tacts in Children with Autism. Journal of Applied Behavior Analysis. 2012;45(2):265-80. X-3. [pmid: 22844136].
1507 Fischetti AT, Wilder DA, Myers K, et al. An Evaluation of Evidence-Based Interventions to Increase Compliance among Children with Autism. Journal of Applied Behavior Analysis. 2012;45(4):859-63. X-3, X-5. [pmid: 23322942].
1508 Fleischer AS. Support to students with Asperger syndrome in higher education--the perspectives of three relatives and three coordinators. Int J Rehabil Res. Mar. 2012;35(1):54-61. X-5. [pmid: 22315142].
1509 Fleming AR, Fairweather JS. The Role of Postsecondary Education in the Path From High School to Work for Youth With Disabilities. Rehabilitation Counseling Bulletin. 2012;55(2):71-81. X-5.
1510 Fletcher PC, Markoulakis R, Bryden PJ. The costs of caring for a child with an autism spectrum disorder. Issues Compr Pediatr Nurs. 2012;35(1):45-69. X-5. [pmid: 22250966].
1511 Flores M, Musgrove K, Renner S, et al. A comparison of communication using the Apple iPad and a picture-based system. Augment Altern Commun. Jun. 2012;28(2):74-84. X-3. [pmid: 22263895].
1512 Flynn L, Healy O. A Review of Treatments for Deficits in Social Skills and Self-Help Skills in Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2012;6(1):431-41. X-1, X-2, X-3, X-4.
1513 Fogleman CD. Therapies for children with autism spectrum disorders. Am Fam Physician. May. 1. 2012;85(9):878-80. X-1, X-2, X-3, X-4. [pmid: 22612182].
1514 Foley AG, Gannon S, Rombach-Mullan N, et al. Class I histone deacetylase inhibition ameliorates social cognition and cell adhesion molecule plasticity deficits in a rodent model of autism spectrum disorder. Neuropharmacology. Sep. 2012;63(4):750-60. X-5. [pmid: 22683514].
1515 Forbes D, Parsons H. Essential fatty acids: food for mind and body. Acta Paediatr. Aug. 2012;101(8):808-10. X-5. [pmid: 22646925].
1516 Foster EM, Pearson E. Is inclusivity an indicator of quality of care for children with autism in special education?. Pediatrics. Nov. 2012;130(Suppl 2):S179-85. X-5. [pmid: 23118249].
1517 Fragale CL, O'Reilly MF, Aguilar J, et al. The influence of motivating operations on generalization probes of specific mands by children with autism. J Appl Behav Anal. Fall. 2012;45(3):565-77. X-3. [pmid: 23060669].
1518 Frank-Crawford MA, Borrero JC, Nguyen L, et al. Disruptive Effects of Contingent Food on High-Probability Behavior. Journal of Applied Behavior Analysis. 2012;45(1):143-8. X-3. [pmid: 22403457].
1519 Fraser R, Cotton S, Gentle E, et al. Non-expert clinicians' detection of autistic traits among attenders of a youth mental health service. Early Intervention in Psychiatry. 2012;6(1):83-6. X-5. [pmid: 21883974].
1520 Frazier TW, Youngstrom EA, Speer L, et al. Validation of Proposed “DSM-5” Criteria for Autism Spectrum Disorder. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(1):28-40. X-5. [pmid: 22176937].
1521 Freitag CM, Feineis-Matthews S, Valerian J, et al. The Frankfurt early intervention program FFIP for preschool aged children with autism spectrum disorder: A pilot study. Journal of Neural Transmission. 2012;119(9):1011-21. X-5. [pmid: 22460295].
1522 Fritz JN, Iwata BA, Rolider NU, et al. Analysis of Self-Recording in Self-Management Interventions for Stereotypy. Journal of Applied Behavior Analysis. 2012;45(1):55-68. X-1, X-3, X-4. [pmid: 22403449].
1523 Fryling MJ, Wallace MD, Yassine JN. Impact of Treatment Integrity on Intervention Effectiveness. Journal of Applied Behavior Analysis. 2012;45(2):449-53. X-5. [pmid: 22844155].
1524 Fung LK, Chahal L, Libove RA, et al. A retrospective review of the effectiveness of aripiprazole in the treatment of sensory abnormalities in autism. J Child Adolesc Psychopharmacol. Jun. 2012;22(3):245-8. X-1, X-3. [pmid: 22537360].
1525 Gabriels RL, Agnew JA, Holt KD, et al. Pilot study measuring the effects of therapeutic horseback riding on school-age children and adolescents with autism spectrum disorders. Research in Autism Spectrum Disorders. 2012;6(2):578-88. X-5.
1526 Gaesser GA, Angadi SS. Gluten-free diet: imprudent dietary advice for the general population?. J Acad Nutr Diet. Sep. 2012;112(9):1330-3. X-5. [pmid: 22939437].
1527 Galizia EC, Srikantha M, Palmer R, et al. Array comparative genomic hybridization: results from an adult population with drug-resistant epilepsy and co-morbidities. Eur J Med Genet. May. 2012;55(5):342-8. X-5. [pmid: 22342432].
1528 Gallagher S, Whiteley J. Social support is associated with blood pressure responses in parents caring for children with developmental disabilities. Res Dev Disabil. Nov-Dec. 2012;33(6):2099-105. X-5. [pmid: 22771985].
1529 Gantman A, Kapp SK, Orenski K, et al. Social skills training for young adults with high-functioning autism spectrum disorders: a randomized controlled pilot study. J Autism Dev Disord. Jun. 2012;42(6):1094-103. X-5. [pmid: 21915740].
1530 Ganz JB, Davis JL, Lund EM, et al. Meta-Analysis of PECS with Individuals with ASD: Investigation of Targeted versus Non-Targeted Outcomes, Participant Characteristics, and Implementation Phase. Research in Developmental Disabilities: A Multidisciplinary Journal. 2012;33(2):406-18. X-5.
1531 Ganz JB, Earles-Vollrath TL, Heath AK, et al. A Meta-Analysis of Single Case Research Studies on Aided Augmentative and Alternative Communication Systems with Individuals with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2012;42(1):60-74. X-5. [pmid: 21380612].
1532 Ganz JB, Heath AK, Lund EM, et al. Effects of peer-mediated implementation of visual scripts in middle school. Behav Modif. May. 2012;36(3):378-98. X-1, X-3, X-5. [pmid: 22582326].
1533 Garland KV, Vasquez E, Pearl C. Efficacy of Individualized Clinical Coaching in a Virtual Reality Classroom for Increasing Teachers' Fidelity of Implementation of Discrete Trial Teaching. Education and Training in Autism and Developmental Disabilities. 2012;47(4):502-15. X-5.
1534 Gau SS-F, Chou M-C, Chiang H-L, et al. Parental adjustment, marital relationship, and family function in families of children with autism. Research in Autism Spectrum Disorders. 2012;6(1):263-70. X-5.
1535 Gelbar NW, Anderson C, McCarthy S, et al. Video Self-Modeling as an Intervention Strategy for Individuals with Autism Spectrum Disorders. Psychology in the Schools. 2012;49(1):15-22. X-5.
1536 Geluk CA, Jansen LM, Vermeiren R, et al. Autistic Symptoms in Childhood Arrestees: Longitudinal Association with Delinquent Behavior. Journal of Child Psychology and Psychiatry. 2012;53(2):160-7. X-5. [pmid: 21884523].
1537 Geretsegger M, Holck U, Gold C. Randomised controlled trial of improvisational music therapy's effectiveness for children with autism spectrum disorders (TIME-A): study protocol. BMC Pediatr. 2012;12:2. X-5. [pmid: 22221670].
1538 Geurts HM, Jansen MD. A retrospective chart study: the pathway to a diagnosis for adults referred for ASD assessment. Autism. May. 2012;16(3):299-305. X-5. [pmid: 21949003].
1539 Giarelli E, Ruttenberg J, Segal A. Continuing education for nurses in the clinical management of autism spectrum disorders: results of a pilot evaluation. J Contin Educ Nurs. Apr. 2012;43(4):169-76. X-5. [pmid: 22106877].
1540 Giles AF, St Peter CC, Pence ST, et al. Preference for blocking or response redirection during stereotypy treatment. Res Dev Disabil. Nov-Dec. 2012;33(6):1691-700. X-3. [pmid: 22695072].
1541 Giovannetti T, Britnell P, Brennan L, et al. Everyday action impairment in Parkinson's disease dementia. J Int Neuropsychol Soc. Sep. 2012;18(5):787-98. X-5. [pmid: 22621995].
1542 Goffin D, Allen M, Zhang L, et al. Rett syndrome mutation MeCP2 T158A disrupts DNA binding, protein stability and ERP responses. Nat Neurosci. Feb. 2012;15(2):274-83. X-5. [pmid: 22119903].
1543 Golnik A, Maccabee-Ryaboy N, Scal P, et al. Shared decision making: improving care for children with autism. Intellect Dev Disabil. Aug. 2012;50(4):322-31. X-3, X-4, X-5. [pmid: 22861133].
1544 Golnik A, Scal P, Wey A, et al. Autism-specific primary care medical home intervention. J Autism Dev Disord. Jun. 2012;42(6):1087-93. X-4. [pmid: 21853373].
1545 Gongola L, Sweeney J. Discrete Trial Teaching: Getting Started. Intervention in School and Clinic. 2012;47(3):183-90. X-5.
1546 Goodarzi M, Hemayattalab R. Bone Mineral Density Accrual in Students with Autism Spectrum Disorders: Effects of Calcium Intake and Physical Training. Research in Autism Spectrum Disorders. 2012;6(2):690-5. X-4.
1547 Gor RA, Fuhrer J, Schober JM. A retrospective observational study of enuresis, daytime voiding symptoms, and response to medical therapy in children with attention deficit hyperactivity disorder and autism spectrum disorder. J Pediatr Urol. Jun. 2012;8(3):314-7. X-5. [pmid: 21131234].
1548 Graff RB, Karsten AM. Evaluation of a self-instruction package for conducting stimulus preference assessments. J Appl Behav Anal. Spring. 2012;45(1):69-82. X-5. [pmid: 22403450].
1549 Graham LJ. Disproportionate Over-Representation of Indigenous Students in New South Wales Government Special Schools. Cambridge Journal of Education. 2012;42(2):163-76. X-5.
1550 Grandgeorge M, Tordjman S, Lazartigues A, et al. Does pet arrival trigger prosocial behaviors in individuals with autism?. PLoS One. 2012;7(8). X-1, X-3, X-4.
1551 Granger S, des Rivieres-Pigeon C, Sabourin G, et al. Mothers' Reports of Their Involvement in Early Intensive Behavioral Intervention. Topics in Early Childhood Special Education. 2012;32(2):68-77. X-4, X-5.
1552 Grannan L, Rehfeldt RA. Emergent intraverbal responses via tact and match-to-sample instruction. J Appl Behav Anal. Fall. 2012;45(3):601-5. X-3, X-5. [pmid: 23060673].
1553 Greenberg AL, Tomaino MAE, Charlop MH. Assessing generalization of the Picture Exchange Communication System in children with autism. Journal of Developmental and Physical Disabilities. 2012;24(6):539-58. X-5.
1554 Griffith GM, Fletcher R, Hastings RP. A national UK census of Applied Behavior Analysis school provision for children with autism. Research in Autism Spectrum Disorders. 2012;6(2):798-805. X-5.
1555 Griffith GM, Totsika V, Nash S, et al. ‘I just don't fit anywhere’: support experiences and future support needs of individuals with Asperger syndrome in middle adulthood. Autism. Sep. 2012;16(5):532-46. X-5. [pmid: 21610188].
1556 Griffith GM, Totsika V, Nash S, et al. “We Are All There Silently Coping.” The Hidden Experiences of Parents of Adults with Asperger Syndrome. Journal of Intellectual & Developmental Disability”. 2012;37(3):237-47. X-5. [pmid: 22852754].
1557 Grindle CF, Hastings RP, Saville M, et al. Outcomes of a behavioral education model for children with autism in a mainstream school setting. Behav Modif. May. 2012;36(3):298-319. X-5. [pmid: 22569577].
1558 Grinker RR, Chambers N, Njongwe N, et al. “Communities” in community engagement: lessons learned from autism research in South Korea and South Africa. Autism Res. Jun. 2012;5(3):201-10. X-3, X-4, X-5. [pmid: 22566396].
1559 Grossman RB, Tager-Flusberg H. “Who said that?” Matching of low- and high-intensity emotional prosody to facial expressions by adolescents with ASD. J Autism Dev Disord. Dec. 2012;42(12):2546-57. X-5. [pmid: 22450703].
1560 Grynszpan O, Nadel J, Martin JC, et al. Self-monitoring of gaze in high functioning autism. J Autism Dev Disord. Aug. 2012;42(8):1642-50. X-1, X-3, X-4. [pmid: 22102292].
1561 Gurkan KC, Hagerman RJ. Targeted Treatments in Autism and Fragile X Syndrome. Research in Autism Spectrum Disorders. 2012;6(4):1311-20. X-5. [pmid: 23162607].
1562 Gutman SA, Raphael-Greenfield EI, Rao AK. Effect of a motor-based role-play intervention on the social behaviors of adolescents with high-functioning autism: multiple-baseline single-subject design. Am J Occup Ther. Sep-Oct. 2012;66(5):529-37. X-5. [pmid: 22917119].
1563 Guzinski EM, Cihon TM, Eshleman J. The Effects of Tact Training on Stereotypic Vocalizations in Children with Autism. Analysis of Verbal Behavior. 2012;28:101-10. X-3, X-5. [pmid: 22754107].
1564 Hagebeuk EEO, Duran M, Koelman JHTM, et al. Folinic acid supplementation in rett syndrome patients does not influence the course of the disease: A randomized study. Journal of Child Neurology. 2012;27(3):304-9. X-5. [pmid: 21868372].
1565 Hagner D, Kurtz A, Cloutier H, et al. Outcomes of a Family-Centered Transition Process for Students with Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 2012;27(1):42-50. X-5.
1566 Hahn S. Environments and autistic spectrum conditions. Nurs Times. Dec. 4-10. 2012;108(49):23-5. X-3, X-4, X-5. [pmid: 23342838].
1567 Hall SS, Lightbody AA, McCarthy BE, et al. Effects of intranasal oxytocin on social anxiety in males with fragile X syndrome. Psychoneuroendocrinology. Apr. 2012;37(4):509-18. X-5. [pmid: 21862226].
1568 Halpert J. Altering the primal environment: health effects associated with assisted reproductive technologies. Environ Health Perspect. Oct. 2012;120(10):a390-5. X-5. [pmid: 23026346].
1569 Hamilton A, Marshal MP, Sucato GS, et al. Rett syndrome and menstruation. J Pediatr Adolesc Gynecol. Apr. 2012;25(2):122-6. X-5. [pmid: 22206685].
1570 Hammock E, Veenstra-VanderWeele J, Yan Z, et al. Examining Autism Spectrum Disorders by Biomarkers: Example from the Oxytocin and Serotonin Systems. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(7):712-21. X-5. [pmid: 22721594].
1571 Hardan AY, Fung LK, Libove RA, et al. A randomized controlled pilot trial of oral N-acetylcysteine in children with autism. Biol Psychiatry. Jun. 1. 2012;71(11):956-61. X-5. [pmid: 22342106].
1572 Harfterkamp M, van de Loo-Neus G, Minderaa RB, et al. A randomized double-blind study of atomoxetine versus placebo for attention-deficit/hyperactivity disorder symptoms in children with autism spectrum disorder. J Am Acad Child Adolesc Psychiatry. Jul. 2012;51(7):733-41. X-5. [pmid: 22721596].
1573 Harjusola-Webb SM, Robbins SH. The Effects of Teacher-Implemented Naturalistic Intervention on the Communication of Preschoolers with Autism. Topics in Early Childhood Special Education. 2012;32(2):99-110. X-3.
1574 Hart JE, Whalon KJ. Using Video Self-Modeling via iPads to Increase Academic Responding of an Adolescent with Autism Spectrum Disorder and Intellectual Disability. Education and Training in Autism and Developmental Disabilities. December. 2012. 2012;47(4):438-46. X-5.
1575 Hasanzadeh E, Mohammadi MR, Ghanizadeh A, et al. A double-blind placebo controlled trial of Ginkgo biloba added to risperidone in patients with autistic disorders. Child Psychiatry Hum Dev. Oct. 2012;43(5):674-82. X-5. [pmid: 22392415].
1576 Hass MR, Brown RS, Brady J, et al. Validating the BASC-TRS for Use with Children and Adolescents with an Educational Diagnosis of Autism. Remedial and Special Education. 2012;33(3):173-83. X-5.
1577 Hassiotis A, Turk J. Mental Health Needs in Adolescents with Intellectual Disabilities: Cross-Sectional Survey of a Service Sample. Journal of Applied Research in Intellectual Disabilities. 2012;25(3):252-61. X-5. [pmid: 22489036].
1578 Hastings RP, Robertson J, Yasamy TM. Interventions for Children with Pervasive Developmental Disorders in Low and Middle Income Countries. Wiley-Blackwell. 350 Main Street, Malden, MA 02148. 2012:119-34. X-4.
1579 Heldt J, Schlinger HD. Increased Variability in Tacting under a Lag 3 Schedule of Reinforcement. Analysis of Verbal Behavior. 2012;28:131-6. X-3, X-5. [pmid: 22754111].
1580 Hewitt AS, Stancliffe RJ, Sirek AJ, et al. Characteristics of adults with autism spectrum disorder who use adult developmental disability services: Results from 25 US states. Research in Autism Spectrum Disorders. 2012;6(2):741-51. X-5.
1581 Hill DA, Hill SJ. Autism Spectrum Disorder, Individuals with Disabilities Education Act, and Case Law: Who Really Wins?. Preventing School Failure. 2012;56(3):157-64. X-5.
1582 Hillier A, Greher G, Poto N, et al. Positive outcomes following participation in a music intervention for adolescents and young adults on the autism spectrum. Psychology of Music. 2012;40(2):201-15. X-5.
1583 Hiraoka K, Okamura N, Funaki Y, et al. Cholinergic deficit and response to donepezil therapy in Parkinson's disease with dementia. Eur Neurol. 2012;68(3):137-43. X-5. [pmid: 22832236].
1584 Ho JG, Caldwell RL, McDougle CJ, et al. The effects of aripiprazole on electrocardiography in children with pervasive developmental disorders. J Child Adolesc Psychopharmacol. Aug. 2012;22(4):277-83. X-5. [pmid: 22849533].
1585 Hoddenbach E, Koot HM, Clifford P, et al. Individual differences in the efficacy of a short theory of mind intervention for children with autism spectrum disorder: a randomized controlled trial. Trials. 2012;13:206. X-5. [pmid: 23140338].
1586 Hollander E, Soorya L, Chaplin W, et al. A double-blind placebo-controlled trial of fluoxetine for repetitive behaviors and global severity in adult autism spectrum disorders. Am J Psychiatry. Mar. 2012;169(3):292-9. X-1, X-3, X-4, X-5. [pmid: 22193531].
1587 Holler K, Scalzo A. “I've heard some things that scare me” Responding with empathy to parents' fears of vaccinations. Mo Med. Jan-Feb. 2012;109(1):10-3. 6. 8. X-5. [pmid: 22428439].
1588 Holton A, Weberling B, Clarke CE, et al. The blame frame: Media attribution of culpability about the MMR–autism vaccination scare. Health Communication. 2012;27(7):690-701. X-5. [pmid: 22236220].
1589 Honaker D, Rosello SS, Candler C. Test-retest reliability of Family L.I.F.E. (Looking Into Family Experiences): an occupation-based assessment. Am J Occup Ther. Sep-Oct. 2012;66(5):617-20. X-3, X-4, X-5. [pmid: 22917128].
1590 Horovitz M, Matson JL, Barker A. The relationship between symptoms of autism spectrum disorders and psychotropic medication use in infants and toddlers. Research in Autism Spectrum Disorders. 2012;6(4):1406-11. X-4.
1591 Howell DM, Wittman P, Bundy MB. Interprofessional clinical education for occupational therapy and psychology students: a social skills training program for children with autism spectrum disorders. J Interprof Care. Jan. 2012;26(1):49-55. X-3, X-5. [pmid: 22233368].
1592 Hua Y, Hendrickson JM, Therrien WJ, et al. Effects of Combined Reading and Question Generation on Reading Fluency and Comprehension of Three Young Adults with Autism and Intellectual Disability. Focus on Autism and Other Developmental Disabilities. 2012;27(3):135-46. X-5.
1593 Hughes C, Kaplan L, Bernstein R, et al. Increasing Social Interaction Skills of Secondary School Students with Autism and/or Intellectual Disability: A Review of Interventions. Research and Practice for Persons with Severe Disabilities. 2012. 2012;37(4):288-307. X-5.
1594 Hughes H, Combes BH, Metha SS. Managing Autism: Knowledge and Training in Autism Spectrum Disorders among Special Education Administrators in Texas. Journal of Special Education Leadership. 2012;25(2):90-8. X-5.
1595 Hume K, Plavnick J, Odom SL. Promoting Task Accuracy and Independence in Students with Autism Across Educational Setting Through the Use of Individual Work Systems. J Autism Dev Disord. 2012. Feb. 3. X-3. [pmid: 22302509].
1596 Huskens B, Reijers H, Didden R. Staff training effective in increasing learning opportunities for school-aged children with autism spectrum disorders. Dev Neurorehabil. 2012;15(6):435-47. X-3. [pmid: 23030785].
1597 Hussein H, Shaker N, El-Sheikh M, et al. Pathways to child mental health services among patients in an urban clinical setting in Egypt. Psychiatr Serv. Dec. 2012;63(12):1225-30. X-5. [pmid: 23070112].
1598 Hyman SE. Revolution stalled. Sci Transl Med. Oct. 10. 2012;4(155):155cm11. X-5. [pmid: 23052291].
1599 Ingersoll B, Meyer K, Bonter N, et al. A Comparison of Developmental Social-Pragmatic and Naturalistic Behavioral Interventions on Language Use and Social Engagement in Children with Autism. Journal of Speech, Language, and Hearing Research. 2012;55(5):1301-13. X-3.
1600 Inoue K, Fukuhara H, Shimamoto T, et al. Comparison between intravesical and oral administration of 5-aminolevulinic acid in the clinical benefit of photodynamic diagnosis for nonmuscle invasive bladder cancer. Cancer. Feb. 15. 2012;118(4):1062-74. X-5. [pmid: 21773973].
1601 Irvin DW, McBee M, Boyd BA, et al. Child and Family Factors Associated with the Use of Services for Preschoolers with Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2012;6(1):565-72. X-5.
1602 Ishitobi M, Hiratani M, Kosaka H, et al. Switching to aripiprazole in subjects with pervasive developmental disorders showing tolerability issues with risperidone. Prog Neuropsychopharmacol Biol Psychiatry. Apr. 27. 2012;37(1):128-31. X-5. [pmid: 22245026].
1603 Iwasaki S, Nishio S, Moteki H, et al. Language development in Japanese children who receive cochlear implant and/or hearing aid. Int J Pediatr Otorhinolaryngol. Mar. 2012;76(3):433-8. X-5. [pmid: 22281374].
1604 Iwatani Y, Kagitani-Shimono K, Tominaga K, et al. Long-term developmental outcome in patients with West syndrome after epilepsy surgery. Brain Dev. Oct. 2012;34(9):731-8. X-5. [pmid: 22336751].
1605 Izawa J, Pekny SE, Marko MK, et al. Motor learning relies on integrated sensory inputs in ADHD, but over-selectively on proprioception in autism spectrum conditions. Autism Res. Apr. 2012;5(2):124-36. X-5. [pmid: 22359275].
1606 Jameson MJ, Walker R, Utley K, et al. A Comparison of Embedded Total Task Instruction in Teaching Behavioral Chains to Massed One-on-One Instruction for Students with Intellectual Disabilities: Accessing General Education Settings and Core Academic Content. Behavior Modification. 2012;36(3):320-40. X-3, X-4. [pmid: 22584370].
1607 Jang J, Dixon DR, Tarbox J, et al. Randomized Trial of an eLearning Program for Training Family Members of Children with Autism in the Principles and Procedures of Applied Behavior Analysis. Research in Autism Spectrum Disorders. 2012;6(2):852-6. X-4.
1608 Jawaid A, Riby MD, Owens J, et al. “Too Withdrawn” or “Too Friendly”: Considering Social Vulnerability in Two Neuro-Developmental Disorders. Journal of Intellectual Disability Research. 2012;56(4):335-50. X-5. [pmid: 21801261].
1609 Johnson P, Porter K, McPherson I. Autism Knowledge among Pre-Service Teachers Specialized in Children Birth through Age Five: Implications for Health Education. American Journal of Health Education. 2012;43(5):279-87. X-5.
1610 Jordan I, Robertson D, Catani M, et al. Aripiprazole in the treatment of challenging behaviour in adults with autism spectrum disorder. Psychopharmacology (Berl). Oct. 2012;223(3):357-60. X-5. [pmid: 22535309].
1611 Joshi G, Biederman J, Wozniak J, et al. Response to second generation antipsychotics in youth with comorbid bipolar disorder and autism spectrum disorder. CNS Neurosci Ther. Jan. 2012;18(1):28-33. X-5. [pmid: 21114638].
1612 Jurgens A, Anderson A, Moore DW. Parent-implemented picture exchange communication system (PECS) training: an analysis of YouTube videos. Dev Neurorehabil. 2012;15(5):351-60. X-5. [pmid: 22712574].
1613 Kadar M, McDonald R, Lentin P. Evidence-based practice in occupational therapy services for children with autism spectrum disorders in Victoria, Australia. Australian Occupational Therapy Journal. 2012;59(4):284-93. X-5. [pmid: 22934901].
1614 Kagohara DM, Sigafoos J, Achmadi D, et al. Teaching Children with Autism Spectrum Disorders to Check the Spelling of Words. Research in Autism Spectrum Disorders. 2012;6(1):304-10. X-3.
1615 Kagohara DM, van der Meer L, Achmadi D, et al. Teaching Picture Naming to Two Adolescents with Autism Spectrum Disorders Using Systematic Instruction and Speech-Generating Devices. Research in Autism Spectrum Disorders. 2012;6(3):1224-33. X-5.
1616 Kalas A. Joint attention responses of children with autism spectrum disorder to simple versus complex music. J Music Ther. Winter. 2012;49(4):430-52. X-5. [pmid: 23705346].
1617 Kalb LG, Freedman B, Foster C, et al. Determinants of appointment absenteeism at an outpatient pediatric autism clinic. Journal of Developmental and Behavioral Pediatrics. 2012;33(9):685-97. X-5. [pmid: 23095496].
1618 Kalb LG, Stuart EA, Freedman B, et al. Psychiatric-related emergency department visits among children with an autism spectrum disorder. Pediatr Emerg Care. Dec. 2012;28(12):1269-76. X-5. [pmid: 23187983].
1619 Kallstrand J, Nehlstedt SF, Skold ML, et al. Lateral asymmetry and reduced forward masking effect in early brainstem auditory evoked responses in schizophrenia. Psychiatry Res. Apr. 30. 2012;196(2-3):188-93. X-5. [pmid: 22326876].
1620 Kaluzna-Czaplinska J, Blaszczyk S. The level of arabinitol in autistic children after probiotic therapy. Nutrition. Feb. 2012;28(2):124-6. X-4. [pmid: 22079796].
1621 Kan MW, Leung LH, Yu PK. Verification and dosimetric impact of Acuros XB algorithm on intensity modulated stereotactic radiotherapy for locally persistent nasopharyngeal carcinoma. Med Phys. Aug. 2012;39(8):4705-14. X-5. [pmid: 22894395].
1622 Karst JS, Van Hecke AV. Parent and Family Impact of Autism Spectrum Disorders: A Review and Proposed Model for Intervention Evaluation. Clinical Child and Family Psychology Review. 2012;15(3):247-77. X-5. [pmid: 22869324].
1623 Kaslow NJ, Broth MR, Smith CO, et al. Family-Based Interventions for Child and Adolescent Disorders. Journal of Marital and Family Therapy. 2012;38(1):82-100. X-2, X-5. [pmid: 22283382].
1624 Katsnelson A. The autism pill. Sci Am. Nov. 2012;307(5):16. X-5. [pmid: 23120883].
1625 Kehle TJ, Bray MA, Byer-Alcorace GF, et al. Augmented Self-Modeling as an Intervention for Selective Mutism. Psychology in the Schools. 2012;49(1):93-103. X-1, X-3, X-4.
1626 Kellems RO, Morningstar ME. Using video modeling delivered through ipods to teach vocational tasks to young adults with autism spectrum disorders. Career Development and Transition for Exceptional Individuals. 2012;35(3):155-67. X-5.
1627 Khanna R, Jariwala K. Awareness and knowledge of autism among pharmacists. Res Social Adm Pharm. Sep-Oct. 2012;8(5):464-71. X-5. [pmid: 22222344].
1628 Khanna R, Madhavan SS, Smith MJ, et al. Psychometric properties of the Caregiver Strain Questionnaire (CGSQ) among caregivers of children with autism. Autism. Mar. 2012;16(2):179-99. X-5. [pmid: 21715548].
1629 Kheir NM, Ghoneim OM, Sandridge AL, et al. Concerns and considerations among caregivers of a child with autism in Qatar. BMC Res Notes. 2012;5:290. X-5. [pmid: 22695064].
1630 Kieffer V, Longaud A, Callu D, et al. Teachers' report of learning and behavioural difficulties in children treated for cerebellar tumours. Brain Inj. 2012;26(7-8):1014-20. X-5. [pmid: 22571388].
1631 Kim JJ, Freeman SF, Paparella T, et al. Five-Year Follow-up of Preschoolers with Autism and Comorbid Psychiatric Disorders. Behavioral Disorders. November. 2012. 2012;38(1):57-70. X-5.
1632 Kinnealey M, Pfeiffer B, Miller J, et al. Effect of classroom modification on attention and engagement of students with autism or dyspraxia. Am J Occup Ther. Sep-Oct. 2012;66(5):511-9. X-5. [pmid: 22917117].
1633 Klett LS, Turan Y. Generalized effects of social stories with task analysis for teaching menstrual care to three young girls with autism. Sexuality and Disability. 2012;30(3):319-36. X-3.
1634 Klintwall L, Eikeseth S. Number and Controllability of Reinforcers as Predictors of Individual Outcome for Children with Autism Receiving Early and Intensive Behavioral Intervention: A Preliminary Study. Research in Autism Spectrum Disorders. 2012;6(1):493-9. X-5.
1635 Klintwall L, Gillberg C, Bölte S, et al. The efficacy of intensive behavioral intervention for children with autism: A matter of allegiance?. Journal of Autism and Developmental Disorders. 2012;42(1):139-40. X-4. [pmid: 21424234].
1636 Klose LM, Plotts C, Kozeneski N, et al. A Review of Assessment Tools for Diagnosis of Autism Spectrum Disorders: Implications for School Practice. Assessment for Effective Intervention. 2012;37(4):236-42. X-5.
1637 Knox M, Rue HC, Wildenger L, et al. Intervention for Food Selectivity in a Specialized School Setting: Teacher Implemented Prompting, Reinforcement, and Demand Fading for an Adolescent Student with Autism. Education and Treatment of Children. 2012;35(3):407-17. X-5.
1638 Kocovska E, Fernell E, Billstedt E, et al. Vitamin D and Autism: Clinical Review. Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. 2012:1541-50. X-4.
1639 Kodak T, Fuchtman R, Paden A. A Comparison of Intraverbal Training Procedures for Children with Autism. Journal of Applied Behavior Analysis. 2012;45(1):155-60. X-3. [pmid: 22403459].
1640 Koegel L, Matos-Freden R, Lang R, et al. Interventions for Children with Autism Spectrum Disorders in Inclusive School Settings. Cognitive and Behavioral Practice. 2012;19(3):401-12. X-1, X-2, X-3, X-4.
1641 Koegel LK, Kuriakose S, Singh AK, et al. Improving generalization of peer socialization gains in inclusive school settings using initiations training. Behav Modif. May. 2012;36(3):361-77. X-3. [pmid: 22645399].
1642 Koegel RL, Bharoocha AA, Ribnick CB, et al. Using individualized reinforcers and hierarchical exposure to increase food flexibility in children with autism spectrum disorders. J Autism Dev Disord. Aug. 2012;42(8):1574-81. X-3. [pmid: 22042309].
1643 Koegel RL, Fredeen R, Kim S, et al. Using Perseverative Interests to Improve Interactions between Adolescents with Autism and Their Typical Peers in School Settings. Journal of Positive Behavior Interventions. 2012;14(3):133-41. X-5. [pmid: 24163577].
1644 Koenig KP, Buckley-Reen A, Garg S. Efficacy of the Get Ready to Learn yoga program among children with autism spectrum disorders: a pretest-posttest control group design. Am J Occup Ther. Sep-Oct. 2012;66(5):538-46. X-5. [pmid: 22917120].
1645 Kooistra ET, Buchmeier AL, Klatt KP. The effect of motivating operations on the transfer from tacts to mands for children diagnosed with autism. Research in Autism Spectrum Disorders. 2012;6(1):109-14. X-3.
1646 Kosaka H, Munesue T, Ishitobi M, et al. Long-term oxytocin administration improves social behaviors in a girl with autistic disorder. BMC Psychiatry. 2012. X-5.
1647 Kossyvaki L, Jones G, Guldberg K. The Effect of Adult Interactive Style on the Spontaneous Communication of Young Children with Autism at School. British Journal of Special Education. 2012;39(4):173-84. X-3.
1648 Koucky EM, Galovski TE, Nixon RD. Acute Stress Disorder: Conceptual Issues and Treatment Outcomes. Cognitive and Behavioral Practice. 2012;19(3):437-50. X-5.
1649 Kozlowski AM, Matson JL, Worley JA, et al. Defining Characteristics for Young Children Meeting Cutoff on the Modified Checklist for Autism in Toddlers. Research in Autism Spectrum Disorders. 2012;6(1):472-9. X-5.
1650 Kramer JM, Coster WJ, Kao YC, et al. A new approach to the measurement of adaptive behavior: development of the PEDI-CAT for children and youth with autism spectrum disorders. Phys Occup Ther Pediatr. Feb. 2012;32(1):34-47. X-5. [pmid: 21846290].
1651 Krieger B, Kinebanian A, Prodinger B, et al. Becoming a member of the work force: perceptions of adults with Asperger Syndrome. Work. 2012;43(2):141-57. X-5. [pmid: 22927626].
1652 Krizman J, Skoe E, Kraus N. Sex differences in auditory subcortical function. Clin Neurophysiol. Mar. 2012;123(3):590-7. X-5. [pmid: 21855407].
1653 Kuhn M, Grave S, Bransfield R, et al. Long term antibiotic therapy may be an effective treatment for children co-morbid with Lyme disease and autism spectrum disorder. Med Hypotheses. May. 2012;78(5):606-15. X-3, X-4, X-5. [pmid: 22361005].
1654 Kuppens S, Onghena P. Sequential Meta-Analysis to Determine the Sufficiency of Cumulative Knowledge: The Case of Early Intensive Behavioral Intervention for Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2012;6(1):168-76. X-5.
1655 Lajonchere C, Jones N, Coury DL, et al. Leadership in health care, research, and quality improvement for children and adolescents with autism spectrum disorders: Autism Treatment Network and Autism Intervention Research Network on Physical Health. Pediatrics. Nov. 2012;130(Suppl 2):S62-8. X-2, X-3, X-4. [pmid: 23118255].
1656 Lane SJ, Reynolds S, Dumenci L. Sensory overresponsivity and anxiety in typically developing children and children with autism and attention deficit hyperactivity disorder: cause or coexistence?. Am J Occup Ther. Sep-Oct. 2012;66(5):595-603. X-5. [pmid: 22917126].
1657 Lang R, O'Reilly M, Healy O, et al. Sensory Integration Therapy for Autism Spectrum Disorders: A Systematic Review. Research in Autism Spectrum Disorders. 2012;6(3):1004-18. X-5.
1658 Lanovaz MJ, Rapp JT, Ferguson S. The Utility of Assessing Musical Preference before Implementation of Noncontingent Music to Reduce Vocal Stereotypy. Journal of Applied Behavior Analysis. 2012;45(4):845-51. X-3. [pmid: 23322940].
1659 Lanovaz MJ, Sladeczek IE. Vocal Stereotypy in Individuals with Autism Spectrum Disorders: A Review of Behavioral Interventions. Behavior Modification. March. 2012. 2012;36(2):146-64. X-2. [pmid: 22127117].
1660 Larsson PG, Bakke KA, Bjornaes H, et al. The effect of levetiracetam on focal nocturnal epileptiform activity during sleep--a placebo-controlled double-blind cross-over study. Epilepsy Behav. May. 2012;24(1):44-8. X-5. [pmid: 22494796].
1661 Laugeson EA, Frankel F, Gantman A, et al. Evidence-based social skills training for adolescents with autism spectrum disorders: the UCLA PEERS program. J Autism Dev Disord. Jun. 2012;42(6):1025-36. X-5. [pmid: 21858588].
1662 Laws G, Bates G, Feuerstein M, et al. Peer Acceptance of Children with Language and Communication Impairments in a Mainstream Primary School: Associations with Type of Language Difficulty, Problem Behaviours and a Change in Placement Organization. Child Language Teaching and Therapy. 2012;28(1):73-86. X-5.
1663 Leaf JB, Oppenheim-Leaf ML, Call NA, et al. Comparing the Teaching Interaction Procedure to Social Stories for People with Autism. Journal of Applied Behavior Analysis. 2012;45(2):281-98. X-3. [pmid: 22844137].
1664 Leaf JB, Oppenheim-Leaf ML, Leaf R, et al. Observational Effects on the Preferences of Children with Autism. Journal of Applied Behavior Analysis. 2012;45(3):473-83. X-3, X-4. [pmid: 23060662].
1665 Lee MS, Choi T-Y, Shin B-C, et al. Acupuncture for Children with Autism Spectrum Disorders: A Systematic Review of Randomized Clinical Trials. Journal of Autism and Developmental Disorders. 2012;42(8):1671-83. X-5. [pmid: 22124580].
1666 Lemonnier E, Degrez C, Phelep M, et al. A randomised controlled trial of bumetanide in the treatment of autism in children. Transl Psychiatry. 2012;2:e202. X-5. [pmid: 23233021].
1667 Lennertz L, Wagner M, Wolwer W, et al. A promoter variant of SHANK1 affects auditory working memory in schizophrenia patients and in subjects clinically at risk for psychosis. Eur Arch Psychiatry Clin Neurosci. Mar. 2012;262(2):117-24. X-5. [pmid: 21901269].
1668 Lerna A, Esposito D, Conson M, et al. Social-communicative effects of the Picture Exchange Communication System (PECS) in autism spectrum disorders. Int J Lang Commun Disord. Sep-Oct. 2012;47(5):609-17. X-5. [pmid: 22938071].
1669 Leroi I, McDonald K, Pantula H, et al. Cognitive impairment in Parkinson disease: impact on quality of life, disability, and caregiver burden. J Geriatr Psychiatry Neurol. Dec. 2012;25(4):208-14. X-5. [pmid: 23172765].
1670 Lian WB, Ho SK, Choo SH, et al. Children with developmental and behavioural concerns in Singapore. Singapore Med J. Jul. 2012;53(7):439-45. X-5. [pmid: 22815011].
1671 Lickel A, MacLean WE Jr, Blakeley-Smith A, et al. Assessment of the prerequisite skills for cognitive behavioral therapy in children with and without autism spectrum disorders. J Autism Dev Disord. Jun. 2012;42(6):992-1000. X-4. [pmid: 21818677].
1672 Lieberman RG, Yoder P. Play and Communication in Children with Autism Spectrum Disorder: A Framework for Early Intervention. Journal of Early Intervention. 2012;34(2):82-103. X-2, X-5.
1673 Lin LY, Yu SN, Yu YT. A study of activities of daily living and employment in adults with autism spectrum disorders in Taiwan. Int J Rehabil Res. Jun. 2012;35(2):109-15. X-5. [pmid: 22334003].
1674 Lindberg N, Sailas E, Kaltiala-Heino R. The copycat phenomenon after two Finnish school shootings: an adolescent psychiatric perspective. BMC Psychiatry. 2012;12:91. X-5. [pmid: 22839726].
1675 Lindberg S, von Post I, Eriksson K. The experiences of parents of children with severe autism in connection with their children's anaesthetics, in the presence and absence of the perioperative dialogue: A hermeneutic study. Scandinavian Journal of Caring Sciences. 2012;26(4):627-34. X-5. [pmid: 22324909].
1676 Ling CY, Mak WW. Coping with challenging behaviours of children with autism: effectiveness of brief training workshop for frontline staff in special education settings. J Intellect Disabil Res. Mar. 2012;56(3):258-69. X-5. [pmid: 21955252].
1677 Lit L, Sharp FR, Bertoglio K, et al. Gene expression in blood is associated with risperidone response in children with autism spectrum disorders. Pharmacogenomics J. Oct. 2012;12(5):368-71. X-5. [pmid: 21647175].
1678 Lo SY. Diagnosis, treatment and prevention of autism via meridian theory. Am J Chin Med. 2012;40(1):39-56. X-3, X-4. [pmid: 22298447].
1679 Locke J, Rotheram-Fuller E, Kasari C. Exploring the Social Impact of Being a Typical Peer Model for d Children with Autism Spectrum Disorder. Journal of Autism and Developmental Disorders. 2012;42(9):1895-905. X-1, X-3, X-4. [pmid: 22215436].
1680 Logan SL, Nicholas JS, Carpenter LA, et al. High prescription drug use and associated costs among Medicaid-eligible children with autism spectrum disorders identified by a population-based surveillance network. Ann Epidemiol. Jan. 2012;22(1):1-8. X-5. [pmid: 22153288].
1681 Lokhandwala T, Khanna R, West-Strum D. Hospitalization burden among individuals with autism. J Autism Dev Disord. Jan. 2012;42(1):95-104. X-5. [pmid: 21404084].
1682 Lopata C, Thomeer ML, Volker MA, et al. Feasibility and Initial Efficacy of a Comprehensive School-Based Intervention for High-Functioning Autism Spectrum Disorders. Psychology in the Schools. 2012;49(10):963-74. X-5.
1683 Lopatina O, Inzhutova A, Salmina AB, et al. The roles of oxytocin and CD38 in social or parental behaviors. Front Neurosci. 2012;6:182. X-5. [pmid: 23335873].
1684 Lopez M, Bellando J. An informal survey on family/caregiver wishes for individuals with autism in Arkansas. J Ark Med Soc. Dec. 2012;109(7):137-9. X-5. [pmid: 23304848].
1685 Lopez M, Schulz EG, Baroud T, et al. The Arkansas Autism Developmental Disabilities Monitoring (AR ADDM) project: statewide autism surveillance in a rural state. J Ark Med Soc. Mar. 2. 2012;108(10):220-4. X-5. [pmid: 22479981].
1686 Love JJ, Miguel CF, Fernand JK, et al. The effects of matched stimulation and response interruption and redirection on vocal stereotypy. Journal of Applied Behavior Analysis. 2012;45(3):549-64. X-3. [pmid: 23060668].
1687 Lovell B, Moss M, Wetherell M. The psychosocial, endocrine and immune consequences of caring for a child with autism or ADHD. Psychoneuroendocrinology. Apr. 2012;37(4):534-42. X-5. [pmid: 21889267].
1688 Lovell B, Moss M, Wetherell MA. With a Little Help from My Friends: Psychological, Endocrine and Health Corollaries of Social Support in Parental Caregivers of Children with Autism or ADHD. Research in Developmental Disabilities: A Multidisciplinary Journal. 2012;33(2):682-7. X-5.
1689 LoVullo SV, Matson JL. Development of a Critical Item Algorithm for the Baby and Infant Screen for Children with aUtIsm Traits. Research in Autism Spectrum Disorders. 2012;6(1):378-84. X-5.
1690 Lowdermilk J, Martinez D, Pecina J, et al. Behavior Breakthroughs[TM]: Future Teachers Reflect on a Focused Game Designed to Teach ABA Techniques. TechTrends: Linking Research and Practice to Improve Learning. 2012;56(3):29-35. X-1, X-3, X-4.
1691 Luman M, van Meel CS, Oosterlaan J, et al. Reward and Punishment Sensitivity in Children with ADHD: Validating the Sensitivity to Punishment and Sensitivity to Reward Questionnaire for Children (SPSRQ-C). Journal of Abnormal Child Psychology. 2012;40(1):145-57. X-5. [pmid: 21789519].
1692 Lutz HR, Patterson BJ, Klein J. Coping with autism: a journey toward adaptation. J Pediatr Nurs. Jun. 2012;27(3):206-13. X-5. [pmid: 22525808].
1693 Lyall K, Pauls DL, Spiegelman D, et al. Fertility therapies, infertility and autism spectrum disorders in the Nurses' Health Study II. Paediatr Perinat Epidemiol. Jul. 2012;26(4):361-72. X-5. [pmid: 22686388].
1694 MacDonald M, Esposito P, Hauck J, et al. Bicycle Training for Youth with Down Syndrome and Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 2012;27(1):12-21. X-1, X-3, X-4.
1695 Mackintosh VH, Goin-Kochel RP, Myers BJ. “What Do You Like/Dislike about the Treatments You're Currently Using?”: A Qualitative Study of Parents of Children with Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 2012;27(1):51-60. X-5.
1696 Madaus MR, Ruberto LM. Application of Self-Modeling to Externalizing and Internalizing Disorders. Psychology in the Schools. 2012;49(1):42-51. X-2, X-3, X-4, X-5.
1697 Magana S, Parish SL, Rose RA, et al. Racial and ethnic disparities in quality of health care among children with autism and other developmental disabilities. Intellect Dev Disabil. Aug. 2012;50(4):287-99. X-3, X-4, X-5. [pmid: 22861130].
1698 Magyar CI, Pandolfi V. Considerations for Establishing a Multi-Tiered Problem-Solving Model for Students with Autism Spectrum Disorders and Comorbid Emotional-Behavioral Disorders. Psychology in the Schools. 2012;49(10):975-87. X-1, X-2, X-3, X-4.
1699 Mahdavi SR, Rezaeejam H, Shirazi A, et al. Conformal fields in prostate radiotherapy: a comparison between measurement, calculation and simulation. J Cancer Res Ther. Jan-Mar. 2012;8(1):34-9. X-5. [pmid: 22531511].
1700 Maich K, Belcher CE. Using Picture Books to Create Peer Awareness about Autism Spectrum Disorders in the Inclusive Classroom. Intervention in School and Clinic. 2012;47(4):206-13. X-2, X-5.
1701 Maiello S. Prenatal Experiences of Containment in the Light of Bion's Model of Container/Contained. Journal of Child Psychotherapy. 2012;38(3):250-67. X-5.
1702 Malow B, Adkins KW, McGrew SG, et al. Melatonin for sleep in children with autism: a controlled trial examining dose, tolerability, and outcomes. J Autism Dev Disord. Aug. 2012;42(8):1729-37. author reply 38. X-5. [pmid: 22160300].
1703 Malow BA, Byars K, Johnson K, et al. A practice pathway for the identification, evaluation, and management of insomnia in children and adolescents with autism spectrum disorders. Pediatrics. Nov. 2012;130(Suppl 2):S106-24. X-5. [pmid: 23118242].
1704 Mandell DS. Understanding and addressing the impact of autism on the family. LDI Issue Brief. Apr-May. 2012;17(7):1-4. X-5. [pmid: 22666896].
1705 Mandell DS, Xie M, Morales KH, et al. The interplay of outpatient services and psychiatric hospitalization among Medicaid-enrolled children with autism spectrum disorders. Arch Pediatr Adolesc Med. Jan. 2012;166(1):68-73. X-5. [pmid: 22213753].
1706 Marchese NV, Carr JE, LeBlanc LA, et al. The effects of the question “What is this?” on tact-training outcomes of children with autism. Journal of Applied Behavior Analysis. 2012;45(3):539-47. X-3. [pmid: 23060667].
1707 Marion C, Martin GL, Yu CT, et al. Teaching children with autism spectrum disorder to mand for information using “which?”. J Appl Behav Anal. Winter. 2012;45(4):865-70. X-3. [pmid: 23322944].
1708 Marsanic VB, Dodig-Curkovic K, Juretic Z. Outpatient treatment of children and adolescents with antipsychotic drugs in Croatia. Nord J Psychiatry. Feb. 2012;66(1):2-7. X-5. [pmid: 21306199].
1709 Marshall K, Ferris J. Utilising behavioural family therapy (BFT) to help support the system around a person with intellectual disability and complex mental health needs: A case study. Journal of Intellectual Disabilities. 2012;16(2):109-18. X-5. [pmid: 22496309].
1710 Marsteller TM, St. Peter CC. Resurgence during treatment challenges. Revista Mexicana de Análisis de la Conducta. 2012;38(1):7-23. X-3.
1711 Martinez-Rovira I, Sempau J, Prezado Y. Development and commissioning of a Monte Carlo photon beam model for the forthcoming clinical trials in microbeam radiation therapy. Med Phys. Jan. 2012;39(1):119-31. X-5. [pmid: 22225281].
1712 Mashal N, Kasirer A. Principal component analysis study of visual and verbal metaphoric comprehension in children with autism and learning disabilities. Res Dev Disabil. Jan-Feb. 2012;33(1):274-82. X-5. [pmid: 22001558].
1713 Mason RA, Rispoli M, Ganz JB, et al. Effects of video modeling on communicative social skills of college students with Asperger syndrome. Dev Neurorehabil. 2012;15(6):425-34. X-5. [pmid: 23030681].
1714 Masschelein J, Verstraete P. Living in the Presence of Others: Towards a Reconfiguration of Space, Asylum and Inclusion. International Journal of Inclusive Education. 2012;16(11):1189-202. X-5.
1715 Matone M, Localio R, Huang YS, et al. The relationship between mental health diagnosis and treatment with second-generation antipsychotics over time: a national study of U.S. Medicaid-enrolled children. Health Serv Res. Oct. 2012;47(5):1836-60. X-5. [pmid: 22946905].
1716 Matson JL, Hattier MA, Belva B. Treating Adaptive Living Skills of Persons with Autism Using Applied Behavior Analysis: A Review. Research in Autism Spectrum Disorders. 2012;6(1):271-6. X-1, X-2, X-3, X-4, X-5.
1717 Matson JL, Tureck K. Early Diagnosis of Autism: Current Status of the Baby and Infant Screen for Children with aUtIsm Traits (BISCUIT-Parts 1, 2, and 3). Research in Autism Spectrum Disorders. 2012;6(3):1135-41. X-5.
1718 Matson JL, Tureck K, Turygin N, et al. Trends and Topics in Early Intensive Behavioral Interventions for Toddlers with Autism. Research in Autism Spectrum Disorders. 2012;6(4):1412-7. X-5.
1719 Matson JL, Turygin NC, Beighley J, et al. Status of Single-Case Research Designs for Evidence-Based Practice. Research in Autism Spectrum Disorders. 2012;6(2):931-8. X-5.
1720 Matson JL, Turygin NC, Beighley J, et al. Applied Behavior Analysis in Autism Spectrum Disorders: Recent Developments, Strengths, and Pitfalls. Research in Autism Spectrum Disorders. 2012;6(1):144-50. X-1, X-2, X-3, X-4, X-5.
1721 Matsuzaki A, Yamamoto J-i. Effects of an early intervention program on preverbal communication in a child with autism: Developmental and behavioral analysis with a multiple-baseline design. Japanese Journal of Special Education. 2012;49(6):657-69. X-3.
1722 Matsuzaki J, Kagitani-Shimono K, Goto T, et al. Differential responses of primary auditory cortex in autistic spectrum disorder with auditory hypersensitivity. Neuroreport. Jan. 25. 2012;23(2):113-8. X-5. [pmid: 22146579].
1723 May ME, Brandt RC, Bohannan JK. Moderating Effects of Autism on Parent Views of Genetic Screening for Aggression. Intellectual and Developmental Disabilities. October. 2012. 2012;50(5):415-25. X-5. [pmid: 23025643].
1724 Mayor S. Advertising watchdog orders website to remove claims linking MMR vaccine with autism. BMJ. 2012;345:e5420. X-5. [pmid: 22879643].
1725 Mazurek MO, Kanne SM, Miles JH. Predicting Improvement in Social-Communication Symptoms of Autism Spectrum Disorders Using Retrospective Treatment Data. Research in Autism Spectrum Disorders. 2012;6(1):535-45. X-5.
1726 McClean B, Grey I. An evaluation of an intervention sequence outline in positive behaviour support for people with autism and severe escape-motivated challenging behaviour. J Intellect Dev Disabil. Sep. 2012;37(3):209-20. X-3, X-5. [pmid: 22873574].
1727 McCrimmon AW, Altomare AA, Matchullis RL, et al. School-Based Practices for Asperger Syndrome: A Canadian Perspective. Canadian Journal of School Psychology. 2012;27(4):319-36. X-5.
1728 McDonald ME, Pace D, Blue E, et al. Critical Issues in Causation and Treatment of Autism: Why Fads Continue to Flourish. Child & Family Behavior Therapy. 2012;34(4):290-304. X-5.
1729 McDuffie AS, Lieberman RG, Yoder PJ. Object interest in autism spectrum disorder: a treatment comparison. Autism. Jul. 2012;16(4):398-405. X-5. [pmid: 22133872].
1730 McGill P, Poynter J. High cost residential placements for adults with intellectual disabilities. J Appl Res Intellect Disabil. Nov. 2012;25(6):584-7. X-5. [pmid: 23055291].
1731 McGrew SG, Peters BR, Crittendon JA, et al. Diagnostic yield of chromosomal microarray analysis in an autism primary care practice: Which guidelines to implement?. Journal of Autism and Developmental Disorders. 2012;42(8):1582-91. X-5. [pmid: 22089167].
1732 McGuinty E, Armstrong D, Nelson J, et al. Externalizing metaphors: anxiety and high-functioning autism. J Child Adolesc Psychiatr Nurs. Feb. 2012;25(1):9-16. X-5. [pmid: 22299802].
1733 MdYusof MSB, Chia NKH. Dolphin Encounter for Special Children (DESC) Program: Effectiveness of Dolphin-Assisted Therapy for Children with Autism. International Journal of Special Education. 2012. 2012;27(3):54-67. X-5.
1734 Mechling LC, Youhouse IR. Comparison of Task Performance by Students with Autism and Moderate Intellectual Disabilities when Presenting Video Models on Large and Small Screen Sizes. Journal of Special Education Technology. 2012. 2012;27(1):1-14. X-3, X-5.
1735 Medeiros K, Kozlowski AM, Beighley JS, et al. The Effects of Developmental Quotient and Diagnostic Criteria on Challenging Behaviors in Toddlers with Developmental Disabilities. Research in Developmental Disabilities: A Multidisciplinary Journal. 2012;33(4):1110-6. X-5.
1736 Meier AE, Fryling MJ, Wallace MD. Using high-probability foods to increase the acceptance of low-probability foods. J Appl Behav Anal. Spring. 2012;45(1):149-53. X-3, X-5. [pmid: 22403458].
1737 Melogno S, D'Ardia C, Pinto MA, et al. Metaphor Comprehension in Autistic Spectrum Disorders: Case Studies of Two High-Functioning Children. Child Language Teaching and Therapy. 2012;28(2):177-88. X-3.
1738 Memari AH, Kordi R, Ziaee V, et al. Weight status in Iranian children with autism spectrum disorders: Investigation of underweight, overweight and obesity. Research in Autism Spectrum Disorders. 2012;6(1):234-9. X-5.
1739 Memari AH, Ziaee V, Beygi S, et al. Overuse of psychotropic medications among children and adolescents with autism spectrum disorders: perspective from a developing country. Res Dev Disabil. Mar-Apr. 2012;33(2):563-9. X-3, X-4, X-5. [pmid: 22119705].
1740 Migliore A, Timmons J, Butterworth J, et al. Predictors of employment and postsecondary education of youth with autism. Rehabilitation Counseling Bulletin. 2012;55(3):176-84. X-5.
1741 Milas M, Mester J, Metzger R, et al. Should patients with Cowden syndrome undergo prophylactic thyroidectomy?. Surgery. Dec. 2012;152(6):1201-10. X-5. [pmid: 23158187].
1742 Miliotis A, Sidener TM, Reeve KF, et al. An evaluation of the number of presentations of target sounds during stimulus-stimulus pairing trials. J Appl Behav Anal. Winter. 2012;45(4):809-13. X-3. [pmid: 23322934].
1743 Miller E. Focusing on prevention. Imprint. Nov-Dec. 2012;59(5):12. X-5. [pmid: 23409627].
1744 Miller VA, Schreck KA, Mulick JA, et al. Factors related to parents' choices of treatments for their children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2012;6(1):87-95. X-5.
1745 Mims PJ, Hudson ME, Browder DM. Using Read-Alouds of Grade-Level Biographies and Systematic Prompting to Promote Comprehension for Students with Moderate and Severe Developmental Disabilities. Focus on Autism and Other Developmental Disabilities. 2012;27(2):67-80. X-3.
1746 Minne EP, Semrud-Clikeman M. A Social Competence Intervention for Young Children with High Functioning Autism and Asperger Syndrome: A Pilot Study. Autism: The International Journal of Research and Practice. 2012;16(6):586-602. X-3, X-4. [pmid: 22087045].
1747 Miyaoka T, Wake R, Furuya M, et al. Yokukansan (TJ-54) for treatment of pervasive developmental disorder not otherwise specified and Asperger's disorder: A 12-week prospective, open-label study. BMC Psychiatry. 2012:12. X-3, X-5. [pmid: 22339984].
1748 Moody AK. Family Connections: Visual Supports for Promoting Social Skills in Young Children--A Family Perspective. Childhood Education. 2012;88(3):191-4. X-1, X-2, X-3, X-4.
1749 Morgan PL, Sideridis G, Hua Y. Initial and Over-Time Effects of Fluency Interventions for Students with or at Risk for Disabilities. Journal of Special Education. 2012;46(2):94-116. X-1, X-3, X-4.
1750 Morrier MJ, Hess KL. Ethnic Differences in Autism Eligibility in the United States Public Schools. Journal of Special Education. 2012;46(1):49-63. X-5.
1751 Morrison RD, Blobaum AL, Byers FW, et al. The role of aldehyde oxidase and xanthine oxidase in the biotransformation of a novel negative allosteric modulator of metabotropic glutamate receptor subtype 5. Drug Metab Dispos. Sep. 2012;40(9):1834-45. X-5. [pmid: 22711749].
1752 Murphy D, Spooren W. EU-AIMS: a boost to autism research. Nat Rev Drug Discov. Nov. 2012;11(11):815-6. X-5. [pmid: 23123927].
1753 Najdowski AC, Tarbox J, Wilke AE. Utilizing Antecedent Manipulations and Reinforcement in the Treatment of Food Selectivity by Texture. Education and Treatment of Children. 2012;35(1):101-10. X-3.
1754 Neely J, Amatea ES, Echevarria-Doan S, et al. Working with families living with autism: potential contributions of marriage and family therapists. J Marital Fam Ther. Jun. 2012;38(Suppl 1):211-26. X-5. [pmid: 22765335].
1755 Nicholson MS, Leask J. Lessons from an online debate about measles-mumps-rubella (MMR) immunization. Vaccine. May. 28. 2012;30(25):3806-12. X-5. [pmid: 22063388].
1756 Novarino G, El-Fishawy P, Kayserili H, et al. Mutations in BCKD-kinase lead to a potentially treatable form of autism with epilepsy. Science. Oct. 19. 2012;338(6105):394-7. X-5. [pmid: 22956686].
1757 Nygren G, Sandberg E, Gillstedt F, et al. A New Screening Programme for Autism in a General Population of Swedish Toddlers. Research in Developmental Disabilities: A Multidisciplinary Journal. 2012;33(4):1200-10. X-5.
1758 Oberman L, Eldaief M, Fecteau S, et al. Abnormal modulation of corticospinal excitability in adults with Asperger's syndrome. Eur J Neurosci. Sep. 2012;36(6):2782-8. X-5. [pmid: 22738084].
1759 Obrusnikova I, Bibik JM, Cavalier AR, et al. Integrating Therapy Dog Teams in a Physical Activity Program for Children with Autism Spectrum Disorders. Journal of Physical Education, Recreation & Dance. 2012;83(6):37-41. X-1, X-2, X-3, X-4.
1760 O'Connor K. Auditory processing in autism spectrum disorder: a review. Neurosci Biobehav Rev. Feb. 2012;36(2):836-54. X-5. [pmid: 22155284].
1761 Odluyurt S, Tekin-Iftar E, Adalioglu I. Does treatment integrity matter in promoting learning among children with developmental disabilities?. Topics in Early Childhood Special Education. 2012;32(3):143-50. X-3.
1762 Odom S, Hume K, Boyd B, et al. Moving beyond the Intensive Behavior Treatment versus Eclectic Dichotomy: Evidence-Based and Individualized Programs for Learners with ASD. Behavior Modification. 2012;36(3):270-97. X-1, X-2, X-3, X-4. [pmid: 22645398].
1763 Ogletree BT, Davis P, Hambrecht G, et al. Using milieu training to promote photograph exchange for a young child with autism. Focus on Autism and Other Developmental Disabilities. 2012;27(2):93-101. X-3.
1764 Ohashi KJ, Mirenda P, Marinova-Todd S, et al. Comparing Early Language Development in Monolingual- and Bilingual- Exposed Young Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2012;6(2):890-7. X-5.
1765 O'Reilly M, Aguilar J, Fragale C, et al. Effects of a Motivating Operation Manipulation on the Maintenance of Mands. Journal of Applied Behavior Analysis. 2012;45(2):443-7. X-3. [pmid: 22844154].
1766 O'Reilly M, Cook L, Karim K. Complementary or controversial care? The opinions of professionals on complementary and alternative interventions for Autistic Spectrum Disorder. Clin Child Psychol Psychiatry. Oct. 2012;17(4):602-15. X-5. [pmid: 22371629].
1767 O'Reilly M, Fragale C, Gainey S, et al. Examination of an antecedent communication intervention to reduce tangibly maintained challenging behavior: a controlled analog analysis. Res Dev Disabil. Sep-Oct. 2012;33(5):1462-8. X-3. [pmid: 22543058].
1768 Orekhova EV, Tsetlin MM, Butorina AV, et al. Auditory cortex responses to clicks and sensory modulation difficulties in children with autism spectrum disorders (ASD). PLoS One. 2012;7(6):e39906. X-5. [pmid: 22768163].
1769 Orellana LM, Silvestre FJ, Martinez-Sanchis S, et al. Oral manifestations in a group of adults with autism spectrum disorder. Med Oral Patol Oral Cir Bucal. May. 2012;17(3):e415-9. X-5. [pmid: 22143726].
1770 Osiecka B, Jurczyszyn K, Ziolkowski P. The application of Levulan-based photodynamic therapy with imiquimod in the treatment of recurrent basal cell carcinoma. Med Sci Monit. Feb. 2012;18(2):PI5-9. X-5. [pmid: 22293891].
1771 Ostmeyer K, Scarpa A. Examining School-Based Social Skills Program Needs and Barriers for Students with High-Functioning Autism Spectrum Disorders Using Participatory Action Research. Psychology in the Schools. 2012;49(10):932-41. X-5.
1772 Ozsivadjian A, Knott F, Magiati I. Parent and child perspectives on the nature of anxiety in children and young people with autism spectrum disorders: a focus group study. Autism. Mar. 2012;16(2):107-21. X-5. [pmid: 22297200].
1773 Paden AR, Kodak T, Fisher WW, et al. Teaching Children with Autism to Engage in Peer-Directed Mands Using a Picture Exchange Communication System. Journal of Applied Behavior Analysis. 2012;45(2):425-9. X-3. [pmid: 22844150].
1774 Pajareya K, Nopmaneejumruslers K. A one-year prospective follow-up study of a DIR/Floortime parent training intervention for pre-school children with autistic spectrum disorders. J Med Assoc Thai. Sep. 2012;95(9):1184-93. X-5. [pmid: 23140036].
1775 Palmen A, Didden R. Task Engagement in Young Adults with High-Functioning Autism Spectrum Disorders: Generalization Effects of Behavioral Skills Training. Research in Autism Spectrum Disorders. 2012;6(4):1377-88. X-5.
1776 Palmen A, Didden R, Lang R. A Systematic Review of Behavioral Intervention Research on Adaptive Skill Building in High-Functioning Young Adults with Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 2012;6(2):602-17. X-5.
1777 Palmen A, Didden R, Verhoeven L. A personal digital assistant for improving independent transitioning in adolescents with high-functioning autism spectrum disorder. Dev Neurorehabil. 2012;15(6):401-13. X-5. [pmid: 23030628].
1778 Pardini M, Elia M, Garaci FG, et al. Long-term cognitive and behavioral therapies, combined with augmentative communication, are related to uncinate fasciculus integrity in autism. J Autism Dev Disord. Apr. 2012;42(4):585-92. X-1, X-3, X-4. [pmid: 21573693].
1779 Parish S, Magana S, Rose R, et al. Health Care of Latino Children with Autism and Other Developmental Disabilities: Quality of Provider Interaction Mediates Utilization. American Journal on Intellectual and Developmental Disabilities. 2012;117(4):304-15. X-5. [pmid: 22809076].
1780 Parish S, Thomas K, Rose R, et al. State insurance parity legislation for autism services and family financial burden. Intellect Dev Disabil. Jun. 2012;50(3):190-8. X-5. [pmid: 22731968].
1781 Park HY, Lin SC, Harwood RL, et al. Autism Intervention Research Programs of the Maternal and Child Health Bureau. Pediatrics. Nov. 2012;130(Suppl 2):S59-61. X-1, X-2, X-3, X-4. [pmid: 23118254].
1782 Park M. Pleasure, throwing breaches, and embodied metaphors: Tracing transformations-in-participation for a child with autism to a sensory integration-based therapy session. OTJR: Occupation, Participation and Health. 2012;32(Suppl 1):S34-S47. X-3.
1783 Patterson SY, Smith V, Mirenda P. A Systematic Review of Training Programs for Parents of Children with Autism Spectrum Disorders: Single Subject Contributions. Autism: The International Journal of Research and Practice. 2012;16(5):498-522. X-5. [pmid: 22250194].
1784 Peacock G, Lin SC. Enhancing early identification and coordination of intervention services for young children with autism spectrum disorders: report from the Act Early Regional Summit Project. Disabil Health J. Jan. 2012;5(1):55-9. X-5. [pmid: 22226299].
1785 Pearson DA, Aman MG, Arnold LE, et al. High concordance of parent and teacher attention-deficit/hyperactivity disorder ratings in medicated and unmedicated children with autism spectrum disorders. J Child Adolesc Psychopharmacol. Aug. 2012;22(4):284-91. X-5. [pmid: 22849541].
1786 Pearson GS. The transition experience of developmentally impaired young adults living in a structured apartment setting. ANS Adv Nurs Sci. Jul-Sep. 2012;35(3):E73-89. X-5. [pmid: 22869219].
1787 Pellicano E. Do Autistic Symptoms Persist across Time? Evidence of Substantial Change in Symptomatology over a 3-Year Period in Cognitively Able Children with Autism. American Journal on Intellectual and Developmental Disabilities. 2012;117(2):156-66. X-4. [pmid: 22515829].
1788 Pelosi S, Rivas A, Haynes DS, et al. Stimulation rate reduction and auditory development in poorly performing cochlear implant users with auditory neuropathy. Otol Neurotol. Dec. 2012;33(9):1502-6. X-5. [pmid: 22972423].
1789 Pennesi CM, Klein LC. Effectiveness of the gluten-free, casein-free diet for children diagnosed with autism spectrum disorder: Based on parental report. Nutritional Neuroscience. 2012;15(2):85-91. X-4. [pmid: 22564339].
1790 Pennington R, Strange C, Stenhoff D, et al. Leave the Running Shoes at Home: Addressing Elopement in the Classroom. Beyond Behavior. 2012;21(3):3-7. X-3.
1791 Pennington RC, Stenhoff DM, Gibson J, et al. Using Simultaneous Prompting to Teach Computer-Based Story Writing to a Student with Autism. Education and Treatment of Children. August. 2012. 2012;35(3):389-406. X-3.
1792 Penrod B, Gardella L, Fernand J. An evaluation of a progressive high-probability instructional sequence combined with low-probability demand fading in the treatment of food selectivity. Journal of Applied Behavior Analysis. 2012;45(3):527-37. X-3. [pmid: 23060666].
1793 Pepin G, Stagnitti K. Come play with me: an argument to link autism spectrum disorders and anorexia nervosa through early childhood pretend play. Eat Disord. May. 2012;20(3):254-9. X-5. [pmid: 22519903].
1794 Perrin CJ, Neef NA. Further Analysis of Variables That Affect Self-Control with Aversive Events. Journal of Applied Behavior Analysis. 2012;45(2):299-313. X-3, X-4. [pmid: 22844138].
1795 Perrin JM, Coury DL, Jones N, et al. The Autism Treatment Network and Autism Intervention Research Network on Physical Health: future directions. Pediatrics. Nov. 2012;130(Suppl 2):S198-201. X-5. [pmid: 23118252].
1796 Perry A. Autism beyond pediatrics: why bioethicists ought to rethink consent in light of chronicity and genetic identity. Bioethics. Jun. 2012;26(5):236-41. X-5. [pmid: 22571426].
1797 Peterson CC, Wellman HM, Slaughter V. The mind behind the message: advancing theory-of-mind scales for typically developing children, and those with deafness, autism, or Asperger syndrome. Child Dev. Mar-Apr. 2012;83(2):469-85. X-5. [pmid: 22304467].
1798 Peters-Scheffer N, Didden R, Korzilius H, et al. Cost comparison of early intensive behavioral intervention and treatment as usual for children with autism spectrum disorder in The Netherlands. Res Dev Disabil. Nov-Dec. 2012;33(6):1763-72. X-5. [pmid: 22705454].
1799 Pillay Y, Bhat CS. Facilitating Support for Students with Asperger's Syndrome. Journal of College Student Psychotherapy. 2012;26(2):140-54. X-5.
1800 Pillmann F, Wustmann T, Marneros A. Acute and transient psychotic disorders versus persistent delusional disorders: a comparative longitudinal study. Psychiatry Clin Neurosci. Feb. 2012;66(1):44-52. X-5. [pmid: 22250609].
1801 Pinborough-Zimmerman J, Bakian AV, Fombonne E, et al. Changes in the Administrative Prevalence of Autism Spectrum Disorders: Contribution of Special Education and Health from 2002-2008. Journal of Autism and Developmental Disorders. 2012;42(4):521-30. X-5. [pmid: 21538173].
1802 Pindiprolu SS. A Review of Naturalistic Interventions with Young Children with Autism. Journal of the International Association of Special Education. 2012;13(1):69-78. X-2, X-5.
1803 Pineda JA, Juavinett A, Datko M. Self-regulation of brain oscillations as a treatment for aberrant brain connections in children with autism. Med Hypotheses. Dec. 2012;79(6):790-8. X-5. [pmid: 22999736].
1804 Plavnick JB, Ferreri SJ. Collateral Effects of Mand Training for Children with Autism. Research in Autism Spectrum Disorders. 2012;6(4):1366-76. X-3.
1805 Polick AS, Carr JE, Hanney NM. A comparison of general and descriptive praise in teaching intraverbal behavior to children with autism. Journal of Applied Behavior Analysis. 2012;45(3):593-9. X-3. [pmid: 23060672].
1806 Pollard JS, Betz AM, Higbee TS. Script Fading to Promote Unscripted Bids for Joint Attention in Children with Autism. Journal of Applied Behavior Analysis. 2012;45(2):387-93. X-3. [pmid: 22844144].
1807 Poon KK. Supporting Adults with Autism Spectrum Disorders: Lessons from Six Decades of International Research. International Journal of Special Education. 2012. 2012;27(3):134-47. X-5.
1808 Powell G, McCauley AW. Blogging as a Way to Promote Family-Professional Partnerships. Young Exceptional Children. 2012;15(2):20-31. X-1, X-2, X-3, X-4.
1809 Pozzi-Monzo M. Ritalin for Whom? Revisited: Further Thinking on ADHD. Journal of Child Psychotherapy. 2012;38(1):49-60. X-5.
1810 Prater MA, Carter N, Hitchcock C, et al. Video Self-Modeling to Improve Academic Performance: A Literature Review. Psychology in the Schools. 2012;49(1):71-81. X-2, X-3, X-4.
1811 Pratt K, Baird G, Gringras P. Ensuring successful admission to hospital for young people with learning difficulties, autism and challenging behaviour: a continuous quality improvement and change management programme. Child Care Health Dev. Nov. 2012;38(6):789-97. X-5. [pmid: 22017703].
1812 Pringle B, Colpe LJ, Blumberg SJ, et al. Diagnostic history and treatment of school-aged children with autism spectrum disorder and special health care needs. NCHS Data Brief. May. 2012;(97):1-8. X-5. [pmid: 23050521].
1813 Rama I, Kontu E. Searching for Pedagogical Adaptations by Exploring Teacher's Tacit Knowledge and Interactional Co-Regulation in the Education of Pupils with Autism. European Journal of Special Needs Education. 2012;27(4):417-31. X-3, X-5.
1814 Ramisch J. Marriage and Family Therapists Working with Couples Who Have Children with Autism. Journal of Marital and Family Therapy. 2012;38(2):305-16. X-1, X-2, X-3, X-4. [pmid: 22512293].
1815 Ravindran N, Myers BJ. Cultural Influences on Perceptions of Health, Illness, and Disability: A Review and Focus on Autism. Journal of Child and Family Studies. 2012;21(2):311-9. X-5.
1816 Reichow B. Overview of Meta-Analyses on Early Intensive Behavioral Intervention for Young Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2012;42(4):512-20. X-5. [pmid: 21404083].
1817 Reszka SS, Odom SL, Hume KA. Ecological Features of Preschools and the Social Engagement of Children with Autism. Journal of Early Intervention. 2012;34(1):40-56. X-5.
1818 Richardson S, Garcia-Ramirez J, Lu W, et al. Design and dosimetric characteristics of a new endocavitary contact radiotherapy system using an electronic brachytherapy source. Med Phys. Nov. 2012;39(11):6838-46. X-5. [pmid: 23127076].
1819 Richman DM, Dotson WH, Rose CA, et al. Effects of Age on the Types and Severity of Excessive Fear or the Absence of Fear in Children and Young Adults with Autism. Journal of Mental Health Research in Intellectual Disabilities. 2012;5(3):1-21. X-5.
1820 Rivard M, Forget J. Verbal behavior in young children with autism spectrum disorder at the onset of an early behavioral intervention program. The Psychological Record. 2012;62(2):167-86. X-4.
1821 Roberts TP, Heiken K, Kahn SY, et al. Delayed magnetic mismatch negativity field, but not auditory M100 response, in specific language impairment. Neuroreport. May. 30. 2012;23(8):463-8. X-5. [pmid: 22551948].
1822 Rodriguez NM, Thompson RH, Schlichenmeyer K, et al. Functional analysis and treatment of arranging and ordering by individuals with an autism spectrum disorder. J Appl Behav Anal. Spring. 2012;45(1):1-22. X-3. [pmid: 22403446].
1823 Roke Y, Buitelaar JK, Boot AM, et al. Risk of hyperprolactinemia and sexual side effects in males 10–20 years old diagnosed with autism spectrum disorders or disruptive behavior disorder and treated with risperidone. Journal of Child and Adolescent Psychopharmacology. 2012;22(6):432-9. X-1, X-3. [pmid: 23234586].
1824 Roke Y, van Harten PN, Buitelaar JK, et al. Antipsychotic-induced hyperprolactinemia and testosterone levels in boys. Horm Res Paediatr. 2012;77(4):235-40. X-1, X-3, X-4. [pmid: 22538969].
1825 Roke Y, van Harten PN, Buitelaar JK, et al. Bone mineral density in male adolescents with autism spectrum disorders and disruptive behavior disorder with or without antipsychotic treatment. Eur J Endocrinol. Dec. 2012;167(6):855-63. X-1, X-3. [pmid: 23011870].
1826 Roux AM, Herrera P, Wold CM, et al. Developmental and autism screening through 2-1-1: Reaching underserved families. American Journal of Preventive Medicine. 2012;43(6, Suppl 5):S457-S63. X-5. [pmid: 23157765].
1827 Ruble L, McGrew JH, Toland MD. Goal Attainment Scaling as an Outcome Measure in Randomized Controlled Trials of Psychosocial Interventions in Autism. Journal of Autism and Developmental Disorders. 2012;42(9):1974-83. X-4. [pmid: 22271197].
1828 Russell B. Reflections on ‘autistic integrity’. Bioethics. Mar. 2012;26(3):164-70. X-5. [pmid: 20497166].
1829 Russell G, Golding J, Norwich B, et al. Social and Behavioural Outcomes in Children Diagnosed with Autism Spectrum Disorders: A Longitudinal Cohort Study. Journal of Child Psychology and Psychiatry. 2012;53(7):735-44. X-5. [pmid: 22111544].
1830 Russo N, Mottron L, Burack JA, et al. Parameters of semantic multisensory integration depend on timing and modality order among people on the autism spectrum: evidence from event-related potentials. Neuropsychologia. Jul. 2012;50(9):2131-41. X-5. [pmid: 22613013].
1831 Ryan S, Salisbury H. ‘You know what boys are like’: pre-diagnosis experiences of parents of children with autism spectrum conditions. Br J Gen Pract. May. 2012;62(598):e378-83. X-5. [pmid: 22546598].
1832 Saalasti S, Katsyri J, Tiippana K, et al. Audiovisual speech perception and eye gaze behavior of adults with asperger syndrome. J Autism Dev Disord. Aug. 2012;42(8):1606-15. X-5. [pmid: 22068821].
1833 Salgueiro E, Nunes L, Barros A, et al. Effects of a dolphin interaction program on children with autism spectrum disorders: an exploratory research. BMC Res Notes. 2012;5:199. X-5. [pmid: 22537536].
1834 Samios C, Pakenham KI, Sofronoff K. Sense Making and Benefit Finding in Couples Who Have a Child with Asperger Syndrome: An Application of the Actor-Partner Interdependence Model. Autism: The International Journal of Research and Practice. 2012;16(3):275-92. X-5. [pmid: 21949006].
1835 Sampanthavivat M, Singkhwa W, Chaiyakul T, et al. Hyperbaric oxygen in the treatment of childhood autism: a randomised controlled trial. Diving Hyperb Med. Sep. 2012;42(3):128-33. X-5. [pmid: 22987458].
1836 Samuels R, Stansfield J. The Effectiveness of Social Stories[TM] to Develop Social Interactions with Adults with Characteristics of Autism Spectrum Disorder. British Journal of Learning Disabilities. 2012;40(4):272-85. X-5.
1837 Sansosti FJ. Reducing the Threatening and Aggressive Behavior of a Middle School Student with Asperger's Syndrome. Preventing School Failure. 2012. 2012;56(1):8-18. X-5.
1838 Sansosti FJ, Lavik KB, Sansosti JM. Family Experiences through the Autism Diagnostic Process. Focus on Autism and Other Developmental Disabilities. 2012;27(2):81-92. X-5.
1839 Sansosti JM, Sansosti FJ. Inclusion for students with high-functioning autism spectrum disorders: Definitions and decision making. Psychology in the Schools. 2012;49(10):917-31. X-5.
1840 Sato S, Ikebuchi E, Anzai N, et al. Effects of psychosocial program for preparing long-term hospitalized patients with schizophrenia for discharge from hospital: randomized controlled trial. Psychiatry Clin Neurosci. Oct. 2012;66(6):474-81. X-5. [pmid: 23066765].
1841 Satory PR. Calculation of midplane dose for total body irradiation from entrance and exit dose MOSFET measurements. Australas Phys Eng Sci Med. Mar. 2012;35(1):101-4. X-5. [pmid: 22298238].
1842 Sauer C, Montag C, Worner C, et al. Effects of a common variant in the CD38 gene on social processing in an oxytocin challenge study: possible links to autism. Neuropsychopharmacology. May. 2012;37(6):1474-82. X-5. [pmid: 22278094].
1843 Sawicka K, Zukin RS. Dysregulation of mTOR signaling in neuropsychiatric disorders: therapeutic implications. Neuropsychopharmacology. Jan. 2012;37(1):305-6. X-5. [pmid: 22157871].
1844 Saylor S, Sidener TM, Reeve SA, et al. Effects of Three Types of Noncontingent Auditory Stimulation on Vocal Stereotypy in Children with Autism. Journal of Applied Behavior Analysis. 2012;45(1):185-90. X-3. [pmid: 22403464].
1845 Scahill L, McCracken JT, Bearss K, et al. Design and subject characteristics in the federally-funded citalopram trial in children with pervasive developmental disorders. J Autism Dev Disord. Mar. 2012;42(3):432-40. X-2, X-3, X-4, X-5. [pmid: 21667200].
1846 Schaaf RC, Benevides TW, Kelly D, et al. Occupational therapy and sensory integration for children with autism: a feasibility, safety, acceptability and fidelity study. Autism. May. 2012;16(3):321-7. X-4. [pmid: 22318118].
1847 Schaal DW. Introduction to “The Behavior-Analytic Origins of Constraint-Induced Movement Therapy: An Example of Behavioral Neurorehabilitation”. Behavior Analyst. 2012;35(2):153-4. X-5. [pmid: 23450912].
1848 Scheflen SC, Freeman SF, Paparella T. Using Video Modeling to Teach Young Children with Autism Developmentally Appropriate Play and Connected Speech. Education and Training in Autism and Developmental Disabilities. 2012;47(3):302-18. X-3.
1849 Schertz HH, Reichow B, Tan P, et al. Interventions for Toddlers with Autism Spectrum Disorders: An Evaluation of Research Evidence. SAGE Publications. 2455 Teller Road, Thousand Oaks, CA 91320. 2012:166-89. X-4.
1850 Schipul SE, Williams DL, Keller TA, et al. Distinctive neural processes during learning in autism. Cereb Cortex. Apr. 2012;22(4):937-50. X-1, X-3, X-4. [pmid: 21725037].
1851 Schmidt C, Stichter JP. The Use of Peer-Mediated Interventions to Promote the Generalization of Social Competence for Adolescents with High-Functioning Autism and Asperger's Syndrome. Exceptionality. 2012;20(2):94-113. X-5.
1852 Seiverling L, Williams K, Sturmey P, et al. Effects of behavioral skills training on parental treatment of children's food selectivity. J Appl Behav Anal. Spring. 2012;45(1):197-203. X-3, X-5. [pmid: 22403466].
1853 Sharma A, Gokulchandran N, Chopra G, et al. Administration of autologous bone marrow-derived mononuclear cells in children with incurable neurological disorders and injury is safe and improves their quality of life. Cell Transplant. 2012;21(Suppl 1):S79-90. X-5. [pmid: 22507683].
1854 Sharma A, Shaw SR. Efficacy of risperidone in managing maladaptive behaviors for children with autistic spectrum disorder: A meta-analysis. Journal of Pediatric Health Care. 2012;26(4):291-9. X-5. [pmid: 22726714].
1855 Sharma S, Woolfson LM, Hunter SC. Confusion and inconsistency in diagnosis of Asperger syndrome: A review of studies from 1981 to 2010. Autism. 2012;16(5):465-86. X-5. [pmid: 21810909].
1856 Sharp RA, Phillips KJ, Mudford OC. Comparisons of Interventions for Rumination Maintained by Automatic Reinforcement. Research in Autism Spectrum Disorders. 2012;6(3):1107-12. X-3.
1857 Shield A, Meier RP. Palm reversal errors in native-signing children with autism. J Commun Disord. Nov. 2012;45(6):439-54. X-5. [pmid: 22981637].
1858 Shin H, Youn J, Kim JS, et al. Caregiver burden in Parkinson disease with dementia compared to Alzheimer disease in Korea. J Geriatr Psychiatry Neurol. Dec. 2012;25(4):222-6. X-5. [pmid: 23172764].
1859 Shin S, Koh M-s, Yeo M-H. A Comparative Study of the Preliminary Effects in the Levels of Adaptive Behaviors: Learning Program for the Development of Children with Autism (LPDCA). Journal of the International Association of Special Education. 2012;13(1):6-15. X-4.
1860 Shogren KA, Plotner AJ. Transition planning for students with intellectual disability, autism, or other disabilities: data from the National Longitudinal Transition Study-2. Intellect Dev Disabil. Feb. 2012;50(1):16-30. X-5. [pmid: 22316223].
1861 Shultz S, Vouloumanos A, Pelphrey K. The superior temporal sulcus differentiates communicative and noncommunicative auditory signals. J Cogn Neurosci. May. 2012;24(5):1224-32. X-5. [pmid: 22360624].
1862 Siegel M. Psychopharmacology of autism spectrum disorder: evidence and practice. Child Adolesc Psychiatr Clin N Am. Oct. 2012;21(4):957-73. X-5. [pmid: 23040909].
1863 Siegel M, Beaulieu AA. Psychotropic Medications in Children with Autism Spectrum Disorders: A Systematic Review and Synthesis for Evidence-Based Practice. Journal of Autism and Developmental Disorders. 2012;42(8):1592-605. X-5. [pmid: 22068820].
1864 Siegel M, Doyle K, Chemelski B, et al. Specialized inpatient psychiatry units for children with autism and developmental disorders: a United States survey. J Autism Dev Disord. Sep. 2012;42(9):1863-9. X-5. [pmid: 22189962].
1865 Silva LM, Schalock M. Autism Parenting Stress Index: Initial Psychometric Evidence. Journal of Autism and Developmental Disorders. 2012;42(4):566-74. X-5. [pmid: 21556967].
1866 Silverman JL, Smith DG, Rizzo SJ, et al. Negative allosteric modulation of the mGluR5 receptor reduces repetitive behaviors and rescues social deficits in mouse models of autism. Sci Transl Med. Apr. 25. 2012;4(131):131ra51. X-5. [pmid: 22539775].
1867 Siniscalco D, Sapone A, Giordano C, et al. The Expression of Caspases Is Enhanced in Peripheral Blood Mononuclear Cells of Autism Spectrum Disorder Patients. Journal of Autism and Developmental Disorders. 2012;42(7):1403-10. X-5. [pmid: 21969075].
1868 Sira BK, Fryling MJ. Using Peer Modeling and Differential Reinforcement in the Treatment of Food Selectivity. Education and Treatment of Children. 2012;35(1):91-100. X-3.
1869 Slocum SK, Miller SJ, Tiger JH. Using a blocked-trials procedure to teach identity matching to a child with autism. Journal of Applied Behavior Analysis. 2012;45(3):619-24. X-3. [pmid: 23060677].
1870 Smith LE, Maenner MJ, Seltzer MM. Developmental trajectories in adolescents and adults with autism: the case of daily living skills. J Am Acad Child Adolesc Psychiatry. Jun. 2012;51(6):622-31. X-5. [pmid: 22632621].
1871 Smith T. Evolution of Research on Interventions for Individuals with Autism Spectrum Disorder: Implications for Behavior Analysts. Behavior Analyst. 2012. 2012;35(1):101-13. X-5. [pmid: 22942539].
1872 Snyder K, Higbee TS, Dayton E. Preliminary Investigation of a Video-Based Stimulus Preference Assessment. Journal of Applied Behavior Analysis. 2012;45(2):413-8. X-3, X-5. [pmid: 22844148].
1873 Soden SE, Garrison CB, Egan AM, et al. Nutrition, physical activity, and bone mineral density in youth with autistic spectrum disorders. Journal of Developmental and Behavioral Pediatrics. 2012;33(8):618-24. X-5. [pmid: 23027134].
1874 Sokhadze EM, Baruth JM, Sears L, et al. Prefrontal neuromodulation using rTMS improves error monitoring and correction function in autism. Appl Psychophysiol Biofeedback. Jun. 2012;37(2):91-102. X-1, X-3, X-4. [pmid: 22311204].
1875 South M, Newton T, Chamberlain PD. Delayed reversal learning and association with repetitive behavior in autism spectrum disorders. Autism Res. Dec. 2012;5(6):398-406. X-5. [pmid: 23097376].
1876 Sowa M, Meulenbroek R. Effects of Physical Exercise on Autism Spectrum Disorders: A Meta-Analysis. Research in Autism Spectrum Disorders. 2012;6(1):46-57. X-1, X-3, X-4.
1877 Spencer TD, Higbee TS. Using Transfer of Stimulus Control Technology to Promote Generalization and Spontaneity of Language. Focus on Autism and Other Developmental Disabilities. 2012;27(4):225-36. X-3.
1878 Stagnitti K, O'Connor C, Sheppard L. Impact of the Learn to Play program on play, social competence and language for children aged 5-8 years who attend a specialist school. Aust Occup Ther J. Aug. 2012;59(4):302-11. X-4. [pmid: 22934903].
1879 State TM, Kern L. A Comparison of Video Feedback and in Vivo Self-Monitoring on the Social Interactions of an Adolescent with Asperger Syndrome. Journal of Behavioral Education. 2012;21(1):18-33. X-5.
1880 Stein BD, Sorbero MJ, Goswami U, et al. Impact of a private health insurance mandate on public sector autism service use in Pennsylvania. J Am Acad Child Adolesc Psychiatry. Aug. 2012;51(8):771-9. X-5. [pmid: 22840548].
1881 Stein LI, Polido JC, Cermak SA. Oral care and sensory concerns in autism. Am J Occup Ther. Sep-Oct. 2012;66(5):e73-6. X-5. [pmid: 22917131].
1882 Stein LI, Polido JC, Najera SO, et al. Oral care experiences and challenges in children with autism spectrum disorders. Pediatr Dent. Sep-Oct. 2012;34(5):387-91. X-5. [pmid: 23211914].
1883 Steiner AM, Goldsmith TR, Snow AV, et al. Practitioner's Guide to Assessment of Autism Spectrum Disorders in Infants and Toddlers. Journal of Autism and Developmental Disorders. 2012;42(6):1183-96. X-2, X-5. [pmid: 22057879].
1884 Steiner AM, Koegel LK, Koegel RL, et al. Issues and Theoretical Constructs regarding Parent Education for Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2012;42(6):1218-27. X-2, X-4, X-5. [pmid: 21336525].
1885 Stephenson J, Carter M, Kemp C. Quality of the Information on Educational and Therapy Interventions Provided on the Web Sites of National Autism Associations. Research in Autism Spectrum Disorders. 2012;6(1):11-8. X-5.
1886 Stichter JP, Herzog MJ, O'Connor KV, et al. A Preliminary Examination of a General Social Outcome Measure. Assessment for Effective Intervention. 2012;38(1):40-52. X-1, X-3, X-4.
1887 Stichter JP, O'Connor KV, Herzog MJ, et al. Social Competence Intervention for Elementary Students with Aspergers Syndrome and High Functioning Autism. Journal of Autism and Developmental Disorders. 2012;42(3):354-66. X-5. [pmid: 21503797].
1888 Stigler KA, Mullett JE, Erickson CA, et al. Paliperidone for irritability in adolescents and young adults with autistic disorder. Psychopharmacology (Berl). Sep. 2012;223(2):237-45. X-5. [pmid: 22549762].
1889 Storch EA, Arnold EB, Jones AM, et al. The role of co-occurring disruptive behavior in the clinical presentation of children and adolescents with anxiety in the context of autism spectrum disorders. Child Psychiatry Hum Dev. Oct. 2012;43(5):734-46. X-4. [pmid: 22407279].
1890 Strain PS, Barton EE, Dunlap G. Lessons Learned about the Utility of Social Validity. Education and Treatment of Children. 2012;35(2):183-200. X-5.
1891 Stratta P, de Cataldo S, Bonanni R, et al. Mental health in L'Aquila after the earthquake. Ann Ist Super Sanita. 2012;48(2):132-7. X-5. [pmid: 22751555].
1892 Strauss LV. Comparing a narcissistic and an autistic retreat: ‘looking through or at the window’. Int J Psychoanal. Feb. 2012;93(1):97-116. X-5. [pmid: 22320137].
1893 Sturm JM. An Enriched Writers' Workshop for Beginning Writers with Developmental Disabilities. Topics in Language Disorders. 2012. 2012;32(4):335-60. X-5.
1894 Sun P, Krueger D, Liu J, et al. Surgical resection of subependymal giant cell astrocytomas (SEGAs) and changes in SEGA-related conditions: a US national claims database study. Curr Med Res Opin. Apr. 2012;28(4):651-6. X-5. [pmid: 22375957].
1895 Susa C, Schlinger HD. Using a lag schedule to increase variability of verbal responding in an individual with autism. Analysis of Verbal Behavior. 2012;28:125-30. X-3. [pmid: 22754110].
1896 Syriopoulou-Delli CK, Cassimos DC, Tripsianis GI, et al. Teachers' perceptions regarding the management of children with autism spectrum disorders. J Autism Dev Disord. May. 2012;42(5):755-68. X-5. [pmid: 21698499].
1897 Szeftel R, Federico C, Hakak R, et al. Improved access to mental health evaluation for patients with developmental disabilities using telepsychiatry. J Telemed Telecare. Sep. 2012;18(6):317-21. X-5. [pmid: 22892376].
1898 Szymanski CA. Managing Behavior by Managing the Classroom: Making Learning Accessible for Deaf and Hard of Hearing Students with Autism Spectrum Disorders. Odyssey: New Directions in Deaf Education. 2012;13:26-31. X-5.
1899 Taheri A, Perry A. Exploring the proposed DSM-5 criteria in a clinical sample. J Autism Dev Disord. Sep. 2012;42(9):1810-7. X-5. [pmid: 22806000].
1900 Tanpowpong P, Broder-Fingert S, Katz AJ, et al. Predictors of gluten avoidance and implementation of a gluten-free diet in children and adolescents without confirmed celiac disease. J Pediatr. Sep. 2012;161(3):471-5. X-5. [pmid: 22484356].
1901 Taylor BA, DeQuinzio JA. Observational learning and children with autism. Behav Modif. May. 2012;36(3):341-60. X-5. [pmid: 22569578].
1902 Taylor BA, DeQuinzio JA, Stine J. Increasing Observational Learning of Children with Autism: A Preliminary Analysis. Journal of Applied Behavior Analysis. 2012;45(4):815-20. X-3, X-5. [pmid: 23322935].
1903 Taylor JL, Warren ZE. Maternal depressive symptoms following autism spectrum diagnosis. J Autism Dev Disord. Jul. 2012;42(7):1411-8. X-5. [pmid: 21965086].
1904 Tek S, Landa RJ. Differences in Autism Symptoms between Minority and Non-Minority Toddlers. Journal of Autism and Developmental Disorders. 2012;42(9):1967-73. X-5. [pmid: 22271196].
1905 Thomas KC, Parish SL, Rose RA, et al. Access to care for children with autism in the context of state Medicaid reimbursement. Maternal and Child Health Journal. 2012;16(8):1636-44. X-5. [pmid: 21833759].
1906 Thomas RH, Meeking MM, Mepham JR, et al. The enteric bacterial metabolite propionic acid alters brain and plasma phospholipid molecular species: further development of a rodent model of autism spectrum disorders. J Neuroinflammation. 2012;9:153. X-5. [pmid: 22747852].
1907 Thomeer ML. Collaborative Development and Component Trials of a Comprehensive School-Based Intervention for Children with HFASDS. Psychology in the Schools. 2012;49(10):955-62. X-3, X-5.
1908 Thomson KM, Martin GL, Fazzio D, et al. Evaluation of a self-instructional package for teaching tutors to conduct discrete-trials teaching with children with autism. Research in Autism Spectrum Disorders. 2012;6(3):1073-82. X-5.
1909 Thorpe EL, Zimmerman RK, Steinhart JD, et al. Homeschooling parents' practices and beliefs about childhood immunizations. Vaccine. Feb. 1. 2012;30(6):1149-53. X-5. [pmid: 22178729].
1910 Tilford JM, Payakachat N, Kovacs E, et al. Preference-based health-related quality-of-life outcomes in children with autism spectrum disorders: a comparison of generic instruments. Pharmacoeconomics. Aug. 1. 2012;30(8):661-79. X-5. [pmid: 22788258].
1911 Torres C, Farley CA, Cook BG. A Special Educator's Guide to Successfully Implementing Evidence-Based Practices. TEACHING Exceptional Children. 2012;45(1):64-73. X-5.
1912 Toussaint KA, Tiger JH. Reducing Covert Self-Injurious Behavior Maintained by Automatic Reinforcement through a Variable Momentary DRO Procedure. Journal of Applied Behavior Analysis. 2012;45(1):179-84. X-1, X-3. [pmid: 22403463].
1913 Tsao L-L, Davenport R, Schmiege C. Supporting Siblings of Children with Autism Spectrum Disorders. Early Childhood Education Journal. 2012;40(1):47-54. X-5.
1914 Tsiouri I, Schoen Simmons E, Paul R. Enhancing the application and evaluation of a discrete trial intervention package for eliciting first words in preverbal preschoolers with ASD. J Autism Dev Disord. Jul. 2012;42(7):1281-93. X-3. [pmid: 21918912].
1915 Tudor ME, Hoffman CD, Sweeney DP. Children with Autism: Sleep Problems and Symptom Severity. Focus on Autism and Other Developmental Disabilities. 2012;27(4):254-62. X-5.
1916 Turan MK, Moroz L, Croteau NP. Comparing the effectiveness of error-correction strategies in discrete trial training. Behav Modif. Mar. 2012;36(2):218-34. X-3. [pmid: 22133991].
1917 Tzanakaki P, Grindle C, Hastings RP, et al. How and why do parents choose early intensive behavioral intervention for their young child with autism. Education and Training in Autism and Developmental Disabilities. 2012;47(1):58-71. X-5.
1918 Uno Y, Uchiyama T, Kurosawa M, et al. The combined measles, mumps, and rubella vaccines and the total number of vaccines are not associated with development of autism spectrum disorder: the first case-control study in Asia. Vaccine. Jun. 13. 2012;30(28):4292-8. X-5. [pmid: 22521285].
1919 Valayannopoulos V, Boddaert N, Chabli A, et al. Treatment by oral creatine, L-arginine and L-glycine in six severely affected patients with creatine transporter defect. J Inherit Metab Dis. Jan. 2012;35(1):151-7. X-5. [pmid: 21660517].
1920 Valenti M, Ciprietti T, Di Egidio C, et al. Adaptive Response of Children and Adolescents with Autism to the 2009 Earthquake in L'Aquila, Italy. Journal of Autism and Developmental Disorders. 2012;42(6):954-60. X-5. [pmid: 21717269].
1921 Valentine RM, Wood K, Brown CT, et al. Monte Carlo simulations for optimal light delivery in photodynamic therapy of non-melanoma skin cancer. Phys Med Biol. Oct. 21. 2012;57(20):6327-45. X-5. [pmid: 22990348].
1922 Valentino AL, Shillingsburg MA, Call NA. Comparing the effects of echoic prompts and echoic prompts plus modeled prompts on intraverbal behavior. J Appl Behav Anal. Summer. 2012;45(2):431-5. X-5. [pmid: 22844151].
1923 Valicenti-McDermott M, Hottinger K, Seijo R, et al. Age at diagnosis of autism spectrum disorders. J Pediatr. Sep. 2012;161(3):554-6. X-5. [pmid: 22683037].
1924 van der Meer L, Kagohara D, Achmadi D, et al. Speech-generating devices versus manual signing for children with developmental disabilities. Res Dev Disabil. Sep-Oct. 2012;33(5):1658-69. X-3. [pmid: 22554812].
1925 van der Meer L, Sutherland D, O'Reilly MF, et al. A Further Comparison of Manual Signing, Picture Exchange, and Speech-Generating Devices as Communication Modes for Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 2012;6(4):1247-57. X-3.
1926 van Gent T, Goedhart AW, Treffers PD. Characteristics of Children and Adolescents in the Dutch National in- and Outpatient Mental Health Service for Deaf and Hard of Hearing Youth over a Period of 15 Years. Research in Developmental Disabilities: A Multidisciplinary Journal. 2012;33(5):1333-42. X-5.
1927 van Nijnatten C, Heestermans M. Communicative empowerment of people with intellectual disability. J Intellect Dev Disabil. Jun. 2012;37(2):100-11. X-5. [pmid: 22563691].
1928 van Steensel FJA, Bögels S, Dirksen C. Anxiety and quality of life: Clinically anxious children with and without autism spectrum disorders compared. Journal of Clinical Child and Adolescent Psychology. 2012;41(6):731-8. X-5. [pmid: 22775580].
1929 van Tongerloo MAMM, Bor HHJ, Lagro-Janssen ALM. Detecting autism spectrum disorders in the general practitioner's practice. Journal of Autism and Developmental Disorders. 2012;42(8):1531-8. X-5. [pmid: 22038290].
1930 Van Waelvelde H, Hellinckx T, Peersman W, et al. SOS: A Screening Instrument to Identify Children with Handwriting Impairments. Physical & Occupational Therapy in Pediatrics. 2012;32(3):306-19. X-5. [pmid: 22515913].
1931 Vandbakk M, Arntzen E, Gisnaas A, et al. Effect of Training Different Classes of Verbal Behavior to Decrease Aberrant Verbal Behavior. Analysis of Verbal Behavior. 2012;28:137-44. X-5. [pmid: 22754112].
1932 Vande Wydeven K, Kwan A, Hardan AY, et al. Underutilization of genetics services for autism: the importance of parental awareness and provider recommendation. J Genet Couns. Dec. 2012;21(6):803-13. X-5. [pmid: 22415587].
1933 Vanderborght B, Simut R, Saldien J, et al. Using the social robot Probo as a social story telling agent for children with ASD. Interaction Studies: Social Behaviour and Communication in Biological and Artificial Systems. 2012;13(3):348-72. X-3.
1934 Varni JW, Handen BL, Corey-Lisle PK, et al. Effect of aripiprazole 2 to 15 mg/d on health-related quality of life in the treatment of irritability associated with autistic disorder in children: a post hoc analysis of two controlled trials. Clin Ther. Apr. 2012;34(4):980-92. X-5. [pmid: 22444782].
1935 Veenstra-VanderWeele J. In this issue/abstract thinking: evolving picture of susceptibility factors in autism spectrum disorders. J Am Acad Child Adolesc Psychiatry. May. 2012;51(5):453-4. X-5. [pmid: 22525947].
1936 Verhoeven EW, Marijnissen N, Berger HJ, et al. Brief report: relationship between self-awareness of real-world behavior and treatment outcome in autism spectrum disorders. J Autism Dev Disord. May. 2012;42(5):889-94. X-5. [pmid: 21698498].
1937 Vernon TW, Koegel RL, Dauterman H, et al. An Early Social Engagement Intervention for Young Children with Autism and Their Parents. Journal of Autism and Developmental Disorders. 2012;42(12):2702-17. X-3. [pmid: 22527708].
1938 Vladescu JC, Carroll R, Paden A, et al. The Effects of Video Modeling with Voiceover Instruction on Accurate Implementation of Discrete-Trial Instruction. Journal of Applied Behavior Analysis. 2012;45(2):419-23. X-3, X-5. [pmid: 22844149].
1939 Wabulembo G, Demer JL. Long-term outcome of medial rectus recession and pulley posterior fixation in esotropia with high AC/A ratio. Strabismus. Sep. 2012;20(3):115-20. X-5. [pmid: 22906381].
1940 Waligorska A, Pisula E, Waligorski M, et al. AutismPro system in supporting treatment of children with autism in Poland. Pediatr Int. Oct. 2012;54(5):693-700. X-3. [pmid: 22469462].
1941 Wallace S, Fein D, Rosanoff M, et al. A global public health strategy for autism spectrum disorders. Autism Res. Jun. 2012;5(3):211-7. X-5. [pmid: 22605577].
1942 Walton KM, Ingersoll BR. Evaluation of a Sibling-Mediated Imitation Intervention for Young Children with Autism. Journal of Positive Behavior Interventions. 2012;14(4):241-53. X-3.
1943 Wang J, Zhou X, Xia W, et al. Autism awareness and attitudes towards treatment in caregivers of children aged 3–6 years in Harbin, China. Social Psychiatry and Psychiatric Epidemiology. 2012;47(8):1301-8. X-5. [pmid: 22009414].
1944 Wang J, Zhou X, Xia W, et al. Parent-reported health care expenditures associated with autism spectrum disorders in Heilongjiang province, China. BMC Health Serv Res. 2012;12:7. X-5. [pmid: 22230043].
1945 Wanzek M, Jenson WR, Houlihan D. Recognizing and Treating Rett Syndrome in Schools. School Psychology International. 2012;33(2):151-66. X-5.
1946 Weil TN, Inglehart MR. Three- to 21-year-old patients with autism spectrum disorders: parents' perceptions of severity of symptoms, oral health, and oral health-related behavior. Pediatr Dent. Nov-Dec. 2012;34(7):473-9. X-5. [pmid: 23265164].
1947 Welterlin A, Turner-Brown LM, Harris S, et al. The Home TEACCHing Program for Toddlers with Autism. Journal of Autism and Developmental Disorders. 2012;42(9):1827-35. X-5. [pmid: 22160347].
1948 Wentz E, Nyden A, Krevers B. Development of an internet-based support and coaching model for adolescents and young adults with ADHD and autism spectrum disorders: a pilot study. Eur Child Adolesc Psychiatry. Nov. 2012;21(11):611-22. X-5. [pmid: 22736195].
1949 White SW. Growing Pains: How Psychologists Can Help to Meet the Clinical Needs of Clients with Autism Spectrum Disorders. Cognitive and Behavioral Practice. 2012;19(3):433-6. X-5.
1950 White SW, Schry AR, Maddox BB. Brief Report: The Assessment of Anxiety in High-Functioning Adolescents with Autism Spectrum Disorder. Journal of Autism and Developmental Disorders. 2012;42(6):1138-45. X-5. [pmid: 21874396].
1951 Whiteley P, Shattock P, Knivsberg AM, et al. Gluten- and casein-free dietary intervention for autism spectrum conditions. Front Hum Neurosci. 2012;6:344. X-1, X-2, X-3, X-4. [pmid: 23316152].
1952 Williams PG, Tomchek S, Grau R, et al. Parent and physician perceptions of medical home care for children with autism spectrum disorders in the state of Kentucky. Clin Pediatr (Phila). Nov. 2012;51(11):1071-8. X-5. [pmid: 22984194].
1953 Williams PG, Woods C, Stevenson M, et al. Psychotropic medication use in children with autism in the Kentucky Medicaid population. Clin Pediatr (Phila). Oct. 2012;51(10):923-7. X-5. [pmid: 22492834].
1954 Williams RT, Mackness J, Gumtau S. Footprints of Emergence. International Review of Research in Open and Distance Learning. October. 2012. 2012;13(4):49-90. X-5.
1955 Williams SC. Genetics: Searching for answers. Nature. Nov. 1. 2012;491(7422):S4-6. X-5. [pmid: 23136651].
1956 Williamson ED, Martin A. Psychotropic Medications in Autism: Practical Considerations for Parents. Journal of Autism and Developmental Disorders. 2012;42(6):1249-55. X-5. [pmid: 21170674].
1957 Wilson KP, Dykstra JR, Watson LR, et al. Coaching in early education classrooms serving children with autism: A pilot study. Early Childhood Education Journal. 2012;40(2):97-105. X-3, X-4.
1958 Wolfberg P, Bottema-Beutel K, DeWitt M. Including Children with Autism in Social and Imaginary Play with Typical Peers: Integrated Play Groups Model. American Journal of Play. 2012;5(1):55-80. X-1, X-2, X-3, X-4.
1959 Wong C, Kasari C. Play and Joint Attention of Children with Autism in the Preschool Special Education Classroom. Journal of Autism and Developmental Disorders. 2012;42(10):2152-61. X-4. [pmid: 22350340].
1960 Wong JD, Seltzer MM, Greenberg JS, et al. Stressful life events and daily stressors affect awakening cortisol level in midlife mothers of individuals with autism spectrum disorders. Aging Ment Health. 2012;16(8):939-49. X-5. [pmid: 22640177].
1961 Woodward JF, Swigonski NL, Ciccarelli MR. Assessing the health, functional characteristics, and health needs of youth attending a noncategorical transition support program. J Adolesc Health. Sep. 2012;51(3):272-8. X-5. [pmid: 22921138].
1962 Wright SD, D'Astous V, Wright CA, et al. Grandparents of grandchildren with autism spectrum disorders (ASD): strengthening relationships through technology activities. Int J Aging Hum Dev. 2012;75(2):169-84. X-3, X-5. [pmid: 23185859].
1963 Yaddanapudi S, Oddiraju S, Rodriguez V, et al. Independent verification of transferred delivery sinogram between two dosimetrically matched helical tomotherapy machines: a protocol for patient-specific quality assurance. Phys Med Biol. Sep. 7. 2012;57(17):5617-31. X-5. [pmid: 22892686].
1964 Yamazaki H, Yamamoto R, Moroto S, et al. Cochlear implantation in children with congenital cytomegalovirus infection accompanied by psycho-neurological disorders. Acta Otolaryngol. Apr. 2012;132(4):420-7. X-3, X-5. [pmid: 22443855].
1965 Ying KC, Browne G, Hutchinson M, et al. Autism in Vietnam: the case for the development and evaluation of an information book to be distributed at the time of diagnosis. Issues Ment Health Nurs. May. 2012;33(5):288-92. X-5. [pmid: 22545635].
1966 Young KL, Boris AL, Thomson KM, et al. Evaluation of a self-instructional package on discrete-trials teaching to parents of children with autism. Research in Autism Spectrum Disorders. 2012;6(4):1321-30. X-5.
1967 Yui K, Koshiba M, Nakamura S, et al. Effects of large doses of arachidonic acid added to docosahexaenoic acid on social impairment in individuals with autism spectrum disorders: a double-blind, placebo-controlled, randomized trial. J Clin Psychopharmacol. Apr. 2012;32(2):200-6. X-1, X-3. [pmid: 22370992].
1968 Zarb P, Amadeo B, Muller A, et al. Antimicrobial prescribing in hospitalized adults stratified by age: data from the ESAC point-prevalence surveys. Drugs Aging. Jan. 1. 2012;29(1):53-62. X-5. [pmid: 22191723].
1969 Zeglam AM, Maouna A. Is there a need for a focused health care service for children with autistic spectrum disorders? A keyhole look at this problem in Tripoli, Libya. Autism. 2012;16(4):337-9. X-5. [pmid: 21920990].
1970 Zhang R, Jia MX, Zhang JS, et al. Transcutaneous electrical acupoint stimulation in children with autism and its impact on plasma levels of arginine-vasopressin and oxytocin: a prospective single-blinded controlled study. Res Dev Disabil. Jul-Aug. 2012;33(4):1136-46. X-5. [pmid: 22502839].
1971 Zimmer MH, Hart LC, Manning-Courtney P, et al. Food variety as a predictor of nutritional status among children with autism. Journal of Autism and Developmental Disorders. 2012;42(4):549-56. X-5. [pmid: 21556968].
1972 Abu-Asab MS, Abu-Asab N, Loffredo CA, et al. Identifying early events of gene expression in breast cancer with systems biology phylogenetics. Cytogenet Genome Res. 2013;139(3):206-14. X-5. [pmid: 23548567].
1973 Adluru N, Hanlon BM, Lutz A, et al. Penalized likelihood phenotyping: unifying voxelwise analyses and multi-voxel pattern analyses in neuroimaging: penalized likelihood phenotyping. Neuroinformatics. Apr. 2013;11(2):227-47. X-5. [pmid: 23397550].
1974 Alaghband-Rad J, Nikvarz N, Tehrani-Doost M, et al. Memantine-induced speech problems in two patients with autistic disorder. Daru. 2013;21(1):54. X-5. [pmid: 23819879].
1975 Alanazi AS. The role of nutraceuticals in the management of autism. Saudi Pharm J. Jul. 2013;21(3):233-43. X-5. [pmid: 24151428].
1976 Al-Ayadhi LY, Elamin NE. Camel Milk as a Potential Therapy as an Antioxidant in Autism Spectrum Disorder (ASD). Evid Based Complement Alternat Med. 2013;2013:602834. X-5. [pmid: 24069051].
1977 Aldinger KA, Plummer JT, Levitt P. Comparative DNA methylation among females with neurodevelopmental disorders and seizures identifies TAC1 as a MeCP2 target gene. J Neurodev Disord. 2013;5(1):15. X-5. [pmid: 23759142].
1978 Amir D. The Psychic Organ Point of Autistic Syntax. Journal of Child Psychotherapy. 2013;39(1):3-21. X-5.
1979 Anderson DK, Liang JW, Lord C. Predicting young adult outcome among more and less cognitively able individuals with autism spectrum disorders. J Child Psychol Psychiatry. 2013. Dec. 9. X-5. [pmid: 24313878].
1980 Angst PD, Piccinin FB, Oppermann RV, et al. Response of molars and non-molars to a strict supragingival control in periodontal patients. Braz Oral Res. Jan-Feb. 2013;27(1):55-60. X-5. [pmid: 23306627].
1981 Arber C, Li M. Cortical interneurons from human pluripotent stem cells: prospects for neurological and psychiatric disease. Front Cell Neurosci. 2013;7:10. X-5. [pmid: 23493959].
1982 Armstrong K, Kimonis ER. Parent–child interaction therapy for the treatment of Asperger's disorder in early childhood: A case study. Clinical Case Studies. 2013;12(1):60-72. X-3.
1983 Asadabadi M, Mohammadi M-R, Ghanizadeh A, et al. Celecoxib as adjunctive treatment to risperidone in children with autistic disorder: A randomized, double-blind, placebo-controlled trial. Psychopharmacology. 2013;225(1):51-9. X-5. [pmid: 22782459].
1984 Asahi Y, Omichi S, Adachi S, et al. Ventilation via cut nasotracheal tube during general anesthesia. Anesth Prog. Spring. 2013;60(1):11-4. X-4, X-5. [pmid: 23506278].
1985 Ashburner J, Rodger S, Ziviani J, et al. Occupational therapy services for people with autism spectrum disorders: Current state of play, use of evidence and future learning priorities. Aust Occup Ther J. 2013. Oct. 9. X-5. [pmid: 24118044].
1986 Assaf M, Hyatt CJ, Wong CG, et al. Mentalizing and motivation neural function during social interactions in autism spectrum disorders. Neuroimage Clin. 2013;3:321-31. X-5. [pmid: 24273716].
1987 Badgett N, Falcomata TS. A comparison of methodologies of brief functional analysis. Dev Neurorehabil. 2013. Jul. 19. X-3, X-5. [pmid: 23869515].
1988 Bang J, Burns J, Nadig A. Brief report: Conveying subjective experience in conversation: production of mental state terms and personal narratives in individuals with high functioning autism. J Autism Dev Disord. Jul. 2013;43(7):1732-40. X-5. [pmid: 23179342].
1989 Barakova EI, Gillesen JCC, Huskens BEBM, et al. End-user programming architecture facilitates the uptake of robots in social therapies. Robotics and Autonomous Systems. 2013;61(7):704-13. X-5.
1990 Barlow KE, Tiger JH, Slocum SK, et al. Comparing acquisition of exchange-based and signed mands with children with autism. Analysis of Verbal Behavior. 2013;29:59-69. X-3. [pmid: 23814367].
1991 Barnes CS, Rehfeldt RA. Effects of Fluency Instruction on Selection-Based and Topography-Based Comprehension Measures. Research in Autism Spectrum Disorders. June. 2013. 2013;7(6):639-47. X-3, X-4, X-5.
1992 Baron-Cohen S, Jaffa T, Davies S, et al. Do girls with anorexia nervosa have elevated autistic traits?. Mol Autism. 2013;4(1):24. X-5. [pmid: 23915495].
1993 Barraza JA, Grewal NS, Ropacki S, et al. Effects of a 10-day oxytocin trial in older adults on health and well-being. Exp Clin Psychopharmacol. Apr. 2013;21(2):85-92. X-5. [pmid: 23421352].
1994 Barton ML, Robins DL, Jashar D, et al. Sensitivity and Specificity of Proposed DSM-5 Criteria for Autism Spectrum Disorder in Toddlers. Journal of Autism and Developmental Disorders. May. 2013. 2013;43(5):1184-95. X-5. [pmid: 23543293].
1995 Bashir S. Hope and great opportunity for young neuroscientist. Pak J Med Sci. Jul. 2013;29(4):897-8. X-5. [pmid: 24353654].
1996 Bauer AZ, Kriebel D. Prenatal and perinatal analgesic exposure and autism: an ecological link. Environ Health. 2013;12:41. X-5. [pmid: 23656698].
1997 Bauer NS, Sturm LA, Carroll AE, et al. Computer decision support to improve autism screening and care in community pediatric clinics. Infants & Young Children. 2013;26(4):306-17. X-5.
1998 Bauman MD, Schumann CM. Is ‘bench-to-bedside’ realistic for autism? An integrative neuroscience approach. Neuropsychiatry (London). Apr. 2013;3(2):159-68. X-5. [pmid: 24000295].
1999 Bauminger-Zviely N, Eden S, Zancanaro M, et al. Increasing social engagement in children with high-functioning autism spectrum disorder using collaborative technologies in the school environment. Autism. 2013;17(3):317-39. X-1. [pmid: 23614935].
2000 Bay B, Mortensen EL, Hvidtjorn D, et al. Fertility treatment and risk of childhood and adolescent mental disorders: register based cohort study. BMJ. 2013;347:f3978. X-5. [pmid: 23833075].
2001 Bayes DA, Heath AK, Williams C, et al. Pardon the Interruption: Enhancing Communication Skills for Students with Intellectual Disability. TEACHING Exceptional Children. 2013. 2013;45(3):64-70. X-2, X-3.
2002 Bearss K, Johnson C, Handen B, et al. A Pilot Study of Parent Training in Young Children with Autism Spectrum Disorders and Disruptive Behavior. Journal of Autism and Developmental Disorders. April. 2013. 2013;43(4):829-40. X-5. [pmid: 22941342].
2003 Bearss K, Lecavalier L, Minshawi N, et al. Toward an exportable parent training program for disruptive behaviors in autism spectrum disorders. Neuropsychiatry (London). Apr. 2013;3(2):169-80. X-4. [pmid: 23772233].
2004 Becker B, Kruppert S, Kostev K. Economic prescribing of corticosteroid nasal sprays in Germany: comparison of mometasone and budesonide nasal sprays on the basis of the DDD, the PDD and reference prices. Int J Clin Pharmacol Ther. Jan. 2013;51(1):12-8. X-5. [pmid: 23110787].
2005 Bedford R, Gliga T, Frame K, et al. Failure to learn from feedback underlies word learning difficulties in toddlers at risk for autism. J Child Lang. Jan. 2013;40(1):29-46. X-5. [pmid: 23217290].
2006 Begeer S, Mandell D, Wijnker-Holmes B, et al. Sex differences in the timing of identification among children and adults with autism spectrum disorders. J Autism Dev Disord. May. 2013;43(5):1151-6. X-5. [pmid: 23001766].
2007 Bekele ET, Lahiri U, Swanson AR, et al. A step towards developing adaptive robot-mediated intervention architecture (ARIA) for children with autism. IEEE Trans Neural Syst Rehabil Eng. Mar. 2013;21(2):289-99. X-3, X-5. [pmid: 23221831].
2008 Bekhet AK, Zauszniewski JA. Psychometric Properties of the Resourcefulness Scale Among Caregivers of Persons With Autism Spectrum Disorder. West J Nurs Res. 2013. Oct. 21. X-5. [pmid: 24151172].
2009 Belgard TG, Jankovic I, Lowe JK, et al. Population structure confounds autism genetic classifier. Mol Psychiatry. 2013. Apr. 2. X-5. [pmid: 23546168].
2010 Belmonte MK, Saxena-Chandhok T, Cherian R, et al. Oral motor deficits in speech-impaired children with autism. Front Integr Neurosci. 2013;7:47. X-5. [pmid: 23847480].
2011 Benevides TW, Lane SJ. A Review of Cardiac Autonomic Measures: Considerations for Examination of Physiological Response in Children with Autism Spectrum Disorder. J Autism Dev Disord. 2013. Oct. 24. X-5. [pmid: 24154761].
2012 Bennett KD, Ramasamy R, Honsberger T. The Effects of Covert Audio Coaching on Teaching Clerical Skills to Adolescents with Autism Spectrum Disorder. Journal of Autism and Developmental Disorders. 2013;43(3):585-93. X-5. [pmid: 22798051].
2013 Ben-Sasson A, Amit-Ben-Simhon H, Meyer S. Cross-parent reliability in rating ASD markers in infants. Dev Neurorehabil. 2013. Aug. 7. X-5. [pmid: 23924084].
2014 Ben-Sasson A, Habib S, Tirosh E. Feasibility and Validity of Early Screening for Identifying Infants With Poor Social-Communication Development in a Well-Baby Clinic System. J Pediatr Nurs. 2013. Nov. 25. X-5. [pmid: 24333238].
2015 Benvenuto A, Marciano S, Capuano I, et al. An update on autism spectrum disorders in children. Minerva Pediatr. Feb. 2013;65(1):19-36. X-2, X-5. [pmid: 23422571].
2016 Berger KA. Resource list for cognitive motor and sensory supports in persons with autism. Front Integr Neurosci. 2013;7:7. X-5. [pmid: 23447743].
2017 Berris T, Mazonakis M, Stratakis J, et al. Calculation of organ doses from breast cancer radiotherapy: a Monte Carlo study. J Appl Clin Med Phys. 2013;14(1):4029. X-5. [pmid: 23318389].
2018 Berry R, Firth G, Leeming C, et al. Clinical Psychologists' Views of Intensive Interaction as an Intervention in Learning Disability Services. Clin Psychol Psychother. 2013. May. 20. X-5. [pmid: 23696471].
2019 Bhatti I, Thome A, Smith PO, et al. A retrospective study of amitriptyline in youth with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2013;43(5):1017-27. X-5. [pmid: 23135317].
2020 Billeci L, Sicca F, Maharatna K, et al. On the application of quantitative EEG for characterizing autistic brain: a systematic review. Front Hum Neurosci. 2013;7:442. X-5. [pmid: 23935579].
2021 Bishop MR, Kenzer AL, Coffman CM, et al. Using stimulus fading without escape extinction to increase compliance with toothbrushing in children with autism. Research in Autism Spectrum Disorders. 2013;7(6):680-6. X-3.
2022 Bishop-Fitzpatrick L, Minshew NJ, Eack SM. A Systematic Review of Psychosocial Interventions for Adults with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2013;43(3):687-94. X-5. [pmid: 22825929].
2023 Blood GW, Blood IM, Coniglio AD, et al. Familiarity Breeds Support: Speech-Language Pathologists' Perceptions of Bullying of Students with Autism Spectrum Disorders. Journal of Communication Disorders. 2013. 2013;46(2):169-80. X-5. [pmid: 23497960].
2024 Boesch MC, Wendt O, Subramanian A, et al. Comparative Efficacy of the Picture Exchange Communication System (PECS) versus a Speech-Generating Device: Effects on Requesting Skills. Research in Autism Spectrum Disorders. March. 2013. 2013;7(3):480-93. X-3.
2025 Bondad J, Aboumarzouk OM, Moseley H, et al. Oral 5-aminolevulinic acid induced Photodynamic Diagnostic Ureterorenoscopy--does the blood pressure require monitoring?. Photodiagnosis Photodyn Ther. Feb. 2013;10(1):39-41. X-5. [pmid: 23465371].
2026 Bottema-Beutel K, Smith N. The Interactional Construction of Identity: An Adolescent with Autism in Interaction with Peers. Linguistics and Education: An International Research Journal. June. 2013. 2013;24(2):197-214. X-5.
2027 Bouck EC, Satsangi R, Doughty TT, et al. Virtual and Concrete Manipulatives: A Comparison of Approaches for Solving Mathematics Problems for Students with Autism Spectrum Disorder. J Autism Dev Disord. 2013. Jun. 7. X-5. [pmid: 23743958].
2028 Boyd BA, Woodard CR, Bodfish JW. Feasibility of exposure response prevention to treat repetitive behaviors of children with autism and an intellectual disability: a brief report. Autism. Mar. 2013;17(2):196-204. X-3. [pmid: 21975037].
2029 Bozdagi O, Tavassoli T, Buxbaum JD. Insulin-like growth factor-1 rescues synaptic and motor deficits in a mouse model of autism and developmental delay. Mol Autism. 2013;4(1):9. X-5. [pmid: 23621888].
2030 Bradley SJ. The importance of early intervention with children and youth in the autism spectrum. J Can Acad Child Adolesc Psychiatry. Aug. 2013;22(3):197-8. X-1, X-2, X-3, X-4. [pmid: 23970907].
2031 Brandwein AB, Foxe JJ, Butler JS, et al. The development of multisensory integration in high-functioning autism: high-density electrical mapping and psychophysical measures reveal impairments in the processing of audiovisual inputs. Cereb Cortex. Jun. 2013;23(6):1329-41. X-5. [pmid: 22628458].
2032 Brignell A, Morgan AT, Woolfenden S, et al. How relevant is the framework being used with autism spectrum disorder today?. Int J Speech Lang Pathol. 2013. Dec. 9. X-5. [pmid: 24313935].
2033 Broder-Fingert S, Shui A, Pulcini CD, et al. Racial and ethnic differences in subspecialty service use by children with autism. Pediatrics. Jul. 2013;132(1):94-100. X-5. [pmid: 23776121].
2034 Brondino N, De Silvestri A, Re S, et al. A Systematic Review and Meta-Analysis of Ginkgo biloba in Neuropsychiatric Disorders: From Ancient Tradition to Modern-Day Medicine. Evid Based Complement Alternat Med. 2013;2013:915691. X-5. [pmid: 23781271].
2035 Brundage SB, Whelan CJ, Burgess CM. Brief report: Treating stuttering in an adult with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2013;43(2):483-9. X-5. [pmid: 22790383].
2036 Bui LTD, Moore DW, Anderson A. Using escape extinction and reinforcement to increase eating in a young child with autism. Behaviour Change. 2013;30(1):48-55. X-3.
2037 Bullough A, Booth J. Science for All. Education in Science. February. 2013. 2013;(251):12-3. X-5.
2038 Burton CE, Anderson DH, Prater MA, et al. Video Self-Modeling on an iPad to Teach Functional Math Skills to Adolescents with Autism and Intellectual Disability. Focus on Autism and Other Developmental Disabilities. June. 2013. 2013;28(2):67-77. X-5.
2039 Butterworth TW, Hodge MA, Sofronoff K, et al. Validation of the Emotion Regulation and Social Skills Questionnaire for Young People with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Dec. 14. X-5. [pmid: 24337829].
2040 Buxbaum JD, Baron-Cohen S. DSM-5: the debate continues. Mol Autism. 2013;4(1):11. X-5. [pmid: 23676181].
2041 Cadogan S, McCrimmon AW. Pivotal response treatment for children with autism spectrum disorder: A systematic review of research quality. Dev Neurorehabil. 2013. Nov. 1. X-4. [pmid: 24180635].
2042 Cai Y, Chia NK, Thalmann D, et al. Design and development of a Virtual Dolphinarium for children with autism. IEEE Trans Neural Syst Rehabil Eng. Mar. 2013;21(2):208-17. X-5. [pmid: 23362251].
2043 Call NA, Zangrillo AN, Delfs CH, et al. A comparison of brief functional analyses with and without consequences. Behavioral Interventions. 2013;28(1):22-39. X-3, X-5.
2044 Campillo C, Herrera G, Remirez de Ganuza C, et al. Using Tic-Tac software to reduce anxiety-related behaviour in adults with autism and learning difficulties during waiting periods: A pilot study. Autism. 2013. Oct. 3. X-5. [pmid: 24092839].
2045 Carbone PS, Murphy NA, Norlin C, et al. Parent and pediatrician perspectives regarding the primary care of children with autism spectrum disorders. J Autism Dev Disord. Apr. 2013;43(4):964-72. X-5. [pmid: 22948548].
2046 Carigi T, Muratori F, Termine C, et al. Diagnostic Boundaries of Autism Disorder Vs Pervasive Developmental Disorder Nos: Comparative Observational Study and Literature Review. Curr Clin Pharmacol. 2013. Sep. 20. X-5. [pmid: 24050746].
2047 Carlon S, Carter M, Stephenson J. A Review of Declared Factors Identified by Parents of Children with Autism Spectrum Disorders (ASD) in Making Intervention Decisions. Research in Autism Spectrum Disorders. February. 2013. 2013;7(2):369-81. X-5.
2048 Carroll RA, Kodak T, Fisher WW. An evaluation of programmed treatment-integrity errors during discrete-trial instruction. Journal of Applied Behavior Analysis. 2013;46(2):379-94. X-3. [pmid: 24114154].
2049 Cashin A, Browne G, Bradbury J, et al. The effectiveness of narrative therapy with young people with autism. Journal of Child and Adolescent Psychiatric Nursing. 2013;26(1):32-41. X-1, X-3. [pmid: 23351106].
2050 Castro S, Pinto AI. Identification of core functioning features for assessment and intervention in Autism Spectrum Disorders. Disabil Rehabil. Jan. 2013;35(2):125-33. X-5. [pmid: 22671037].
2051 Cavalari RNS, DuBard M, Luiselli JK, et al. Teaching an adolescent with autism and intellectual disability to tolerate routine medical examination: Effects of a behavioral compliance training package. Clinical Practice in Pediatric Psychology. 2013;1(2):121-8. X-5.
2052 Chamberlain PD, Rodgers J, Crowley MJ, et al. A potentiated startle study of uncertainty and contextual anxiety in adolescents diagnosed with autism spectrum disorder. Mol Autism. 2013;4(1):31. X-5. [pmid: 24007557].
2053 Chang YC, Laugeson EA, Gantman A, et al. Predicting treatment success in social skills training for adolescents with autism spectrum disorders: The UCLA Program for the Education and Enrichment of Relational Skills. Autism. 2013. Oct. 9. X-5. [pmid: 24108192].
2054 Charbonneau G, Bertone A, Lepore F, et al. Multilevel alterations in the processing of audio-visual emotion expressions in autism spectrum disorders. Neuropsychologia. Apr. 2013;51(5):1002-10. X-5. [pmid: 23462241].
2055 Charlot L, Beasley JB. Intellectual Disabilities and Mental Health: United States-Based Research. Journal of Mental Health Research in Intellectual Disabilities. 2013. 2013;6(2):74-105. X-5.
2056 Cheak-Zamora NC, Yang X, Farmer JE, et al. Disparities in transition planning for youth with autism spectrum disorder. Pediatrics. Mar. 2013;131(3):447-54. X-5. [pmid: 23400613].
2057 Chen YW, Cordier R, Brown N. A preliminary study on the reliability and validity of using experience sampling method in children with autism spectrum disorders. Dev Neurorehabil. 2013. Dec. 4. X-3, X-5. [pmid: 24304202].
2058 Cheremshynski C, Lucyshyn JM, Olson DL. Implementation of a culturally appropriate positive behavior support plan with a japanese mother of a child with autism: An experimental and qualitative analysis. Journal of Positive Behavior Interventions. 2013;15(4):242-53. X-3.
2059 Cheung G, Trembath D, Arciuli J, et al. The impact of workplace factors on evidence-based speech-language pathology practice for children with autism spectrum disorders. International Journal of Speech-Language Pathology. 2013;15(4):396-406. X-5. [pmid: 22967045].
2060 Chiu AW, Langer DA, McLeod BD, et al. Effectiveness of modular CBT for child anxiety in elementary schools. Sch Psychol Q. Jun. 2013;28(2):141-53. X-5. [pmid: 23750860].
2061 Choi KYK, Kovshoff H. Do maternal attributions play a role in the acceptability of behavioural interventions for problem behaviour in children with autism spectrum disorders?. Research in Autism Spectrum Disorders. 2013;7(8):984-96. X-4.
2062 Chok JT, Koesler B. Distinguishing Obsessive-Compulsive Behavior From Stereotypy: A Preliminary Investigation. Behav Modif. 2013. Oct. 31. X-3, X-5. [pmid: 24177034].
2063 Christ JB, Fruhmann Berger M, Riedl E, et al. How precise are activities of daily living scales for the diagnosis of Parkinson's disease dementia? A pilot study. Parkinsonism Relat Disord. Mar. 2013;19(3):371-4. X-5. [pmid: 23231974].
2064 Christensen J, Gronborg TK, Sorensen MJ, et al. Prenatal valproate exposure and risk of autism spectrum disorders and childhood autism. JAMA. Apr. 24. 2013;309(16):1696-703. X-5. [pmid: 23613074].
2065 Cidav Z, Lawer L, Marcus SC, et al. Age-related variation in health service use and associated expenditures among children with autism. Journal of Autism and Developmental Disorders. 2013;43(4):924-31. X-5. [pmid: 22941343].
2066 Clay CJ, Samaha AL, Bloom SE, et al. Assessing preference for social interactions. Res Dev Disabil. Jan. 2013;34(1):362-71. X-3, X-5. [pmid: 23009945].
2067 Clifford T, Minnes P. Logging on: evaluating an online support group for parents of children with autism spectrum disorders. J Autism Dev Disord. Jul. 2013;43(7):1662-75. X-5. [pmid: 23143075].
2068 Clopper CG, Rohrbeck KL, Wagner L. Perception of talker age by young adults with high-functioning autism. J Autism Dev Disord. Jan. 2013;43(1):134-46. X-5. [pmid: 22638967].
2069 Coffman MC, Anderson LC, Naples AJ, et al. Sex Differences in Social Perception in Children with ASD. J Autism Dev Disord. 2013. Nov. 30. X-5. [pmid: 24293083].
2070 Cohen D, Raffin M, Canitano R, et al. Risperidone or Aripiprazole in Children and Adolescents with Autism and/or Intellectual Disability: A Bayesian Meta-Analysis of Efficacy and Secondary Effects. Research in Autism Spectrum Disorders. January. 2013. 2013;7(1):167-75. X-1, X-3.
2071 Cohen JP, Ruha AM, Curry SC, et al. Plasma and urine dimercaptopropanesulfonate concentrations after dermal application of transdermal DMPS (TD-DMPS). J Med Toxicol. Mar. 2013;9(1):9-15. X-5. [pmid: 23143832].
2072 Coman D, Alessandri M, Gutierrez A, et al. Commitment to Classroom Model Philosophy and Burnout Symptoms among High Fidelity Teachers Implementing Preschool Programs for Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2013;43(2):345-60. X-5. [pmid: 22706583].
2073 Conner CM, Maddox BB, White SW. Parents' state and trait anxiety: Relationships with anxiety severity and treatment response in adolescents with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2013;43(8):1811-8. X-5. [pmid: 23224592].
2074 Consoli A, Cohen J, Bodeau N, et al. Electroconvulsive therapy in adolescents with intellectual disability and severe self-injurious behavior and aggression: A retrospective study. European Child & Adolescent Psychiatry. 2013;22(1):55-62. X-3, X-5. [pmid: 22923049].
2075 Constable S, Grossi B, Moniz A, et al. Meeting the Common Core State Standards for Students with Autism: The Challenge for Educators. TEACHING Exceptional Children. 2013. 2013;45(3):6-13. X-5.
2076 Corbett BA, Swain DM, Coke C, et al. Improvement in Social Deficits in Autism Spectrum Disorders Using a Theatre-Based, Peer-Mediated Intervention. Autism Res. 2013. Oct. 22. X-5. [pmid: 24150989].
2077 Crais ER, Watson LR. Challenges and opportunities in early identification and intervention for children at-risk for autism spectrum disorders. Int J Speech Lang Pathol. 2013. Dec. 13. X-5. [pmid: 24328367].
2078 Dadds MR, Macdonald E, Cauchi A, et al. Nasal Oxytocin for Social Deficits in Childhood Autism: A Randomized Controlled Trial. J Autism Dev Disord. 2013. Jul. 26. X-1, X-3. [pmid: 23888359].
2079 Dalsgaard S, Nielsen HS, Simonsen M. Five-fold increase in national prevalence rates of attention-deficit/hyperactivity disorder medications for children and adolescents with autism spectrum disorder, attention-deficit/hyperactivity disorder, and other psychiatric disorders: A Danish register-based study. Journal of Child and Adolescent Psychopharmacology. 2013;23(7):432-9. X-5. [pmid: 24015896].
2080 Daniels AM, Mandell DS. Children's compliance with American Academy of Pediatrics' well-child care visit guidelines and the early detection of autism. Journal of Autism and Developmental Disorders. 2013;43(12):2844-54. X-5. [pmid: 23619952].
2081 Daniels AM, Mandell DS. Explaining differences in age at autism spectrum disorder diagnosis: A critical review. Autism. 2013. Jun. 20. X-5. [pmid: 23787411].
2082 Davidson C, Greenwood N, Stansfield A, et al. Prevalence of Asperger syndrome among patients of an Early Intervention in Psychosis team. Early Interv Psychiatry. 2013. Mar. 8. X-5. [pmid: 23472601].
2083 Davis TN, O'Reilly M, Kang S, et al. Chelation Treatment for Autism Spectrum Disorders: A Systematic Review. Research in Autism Spectrum Disorders. January. 2013. 2013;7(1):49-55. X-5.
2084 Dawson G. Early intensive behavioral intervention appears beneficial for young children with autism spectrum disorders. J Pediatr. May. 2013;162(5):1080-1. X-1, X-2, X-3, X-4. [pmid: 23617979].
2085 de Bartolomeis A, Latte G, Tomasetti C, et al. Glutamatergic Postsynaptic Density Protein Dysfunctions in Synaptic Plasticity and Dendritic Spines Morphology: Relevance to Schizophrenia and Other Behavioral Disorders Pathophysiology, and Implications for Novel Therapeutic Approaches. Mol Neurobiol. 2013. Sep. 3. X-5. [pmid: 23999870].
2086 de Boer A, Pijl SJ, Minnaert A, et al. Evaluating the Effectiveness of an Intervention Program to Influence Attitudes of Students Towards Peers with Disabilities. J Autism Dev Disord. 2013. Aug. 28. X-5. [pmid: 23982486].
2087 de Theije CG, Bavelaar BM, Lopes da Silva S, et al. Food allergy and food-based therapies in neurodevelopmental disorders. Pediatr Allergy Immunol. 2013. Nov. 17. X-5. [pmid: 24236934].
2088 Deakin J, Lennox B. Psychotic symptoms in young people warrant urgent referral. Practitioner. Mar. 2013;257(1759):25-8. 3. X-5. [pmid: 23634636].
2089 Del'guidice T, Lemay F, Lemasson M, et al. Stimulation of 5-HT Receptors Improves Cognitive Deficits Induced by Human Tryptophan Hydroxylase 2 Loss of Function Mutation. Neuropsychopharmacology. 2013. Nov. 7. X-5. [pmid: 24196946].
2090 D'Elia L, Valeri G, Sonnino F, et al. A Longitudinal Study of the Teacch Program in Different Settings: The Potential Benefits of Low Intensity Intervention in Preschool Children with Autism Spectrum Disorder. J Autism Dev Disord. 2013. Aug. 15. X-5. [pmid: 23949000].
2091 Demurie E, Roeyers H, Baeyens D, et al. Domain-General and Domain-Specific Aspects of Temporal Discounting in Children with ADHD and Autism Spectrum Disorders (ASD): A Proof of Concept Study. Research in Developmental Disabilities: A Multidisciplinary Journal. June. 2013. 2013;34(6):1870-80. X-1, X-3.
2092 Dezfoolian L, Zarei M, Ashayeri H, et al. A pilot study on the effects of Orff-based therapeutic music in children with autism spectrum disorder. Music and Medicine. 2013;5(3):162-8. X-3.
2093 Di Pietro NC, Whiteley L, Mizgalewicz A, et al. Treatments for neurodevelopmental disorders: Evidence, advocacy, and the Internet. Journal of Autism and Developmental Disorders. 2013;43(1):122-33. X-5. [pmid: 22592952].
2094 Dixon G, Clarke C. The effect of falsely balanced reporting of the autism–vaccine controversy on vaccine safety perceptions and behavioral intentions. Health Education Research. 2013;28(2):352-9. X-5. [pmid: 23193194].
2095 Doggett RA, Krasno AM, Koegel LK, et al. Acquisition of multiple questions in the context of social conversation in children with autism. Journal of Autism and Developmental Disorders. 2013;43(9):2015-25. X-3, X-4. [pmid: 23292139].
2096 Domes G, Heinrichs M, Kumbier E, et al. Effects of intranasal oxytocin on the neural basis of face processing in autism spectrum disorder. Biol Psychiatry. Aug. 1. 2013;74(3):164-71. X-1, X-3. [pmid: 23510581].
2097 Douglas JF, Sanders KB, Benneyworth MH, et al. Brief report: Retrospective case series of oxcarbazepine for irritability/agitation symptoms in autism spectrum disorder. Journal of Autism and Developmental Disorders. 2013;43(5):1243-7. X-1. [pmid: 22976374].
2098 Duffy FH, Eksioglu YZ, Rotenberg A, et al. The frequency modulated auditory evoked response (FMAER), a technical advance for study of childhood language disorders: cortical source localization and selected case studies. BMC Neurol. 2013;13:12. X-5. [pmid: 23351174].
2099 Eack SM, Bahorik AL, Hogarty SS, et al. Brief report: Is cognitive rehabilitation needed in verbal adults with autism? Insights from initial enrollment in a trial of cognitive enhancement therapy. Journal of Autism and Developmental Disorders. 2013;43(9):2233-7. X-5. [pmid: 23381484].
2100 Eack SM, Greenwald DP, Hogarty SS, et al. Cognitive enhancement therapy for adults with autism spectrum disorder: Results of an 18-month feasibility study. Journal of Autism and Developmental Disorders. 2013;43(12):2866-77. X-5. [pmid: 23619953].
2101 Eapen V, Crncec R, Walter A. Clinical outcomes of an early intervention program for preschool children with Autism Spectrum Disorder in a community group setting. BMC Pediatr. 2013;13(1):3. X-5. [pmid: 23294523].
2102 Eapen V, Crncec R, Walter A. Exploring Links between Genotypes, Phenotypes, and Clinical Predictors of Response to Early Intensive Behavioral Intervention in Autism Spectrum Disorder. Front Hum Neurosci. 2013;7:567. X-2, X-5. [pmid: 24062668].
2103 Egan AM, Dreyer ML, Odar CC, et al. Obesity in young children with autism spectrum disorders: prevalence and associated factors. Child Obes. Apr. 2013;9(2):125-31. X-5. [pmid: 23485020].
2104 Eikeseth S, Smith DP. An analysis of verbal stimulus control in intraverbal behavior: implications for practice and applied research. Anal Verbal Behav. 2013;29(1):125-35. X-5. [pmid: 23814373].
2105 El Zein F, Solis M, Vaughn S, et al. Reading Comprehension Interventions for Students with Autism Spectrum Disorders: A Synthesis of Research. J Autism Dev Disord. 2013. Nov. 12. X-5. [pmid: 24218240].
2106 El-Baz F, Hamza RT, Ayad MS, et al. Hyperandrogenemia in male autistic children and adolescents: relation to disease severity. Int J Adolesc Med Health. Apr. 2013;20:1-6. X-5. [pmid: 23612632].
2107 Eldevik S, Ondire I, Hughes JC, et al. Effects of computer simulation training on in vivo discrete trial teaching. J Autism Dev Disord. Mar. 2013;43(3):569-78. X-5. [pmid: 22790382].
2108 Ellis Weismer S. Developmental Language Disorders: Challenges and Implications of Cross-Group Comparisons. Folia Phoniatr Logop. Aug. 12. 2013;65(2):68-77. X-5. [pmid: 23942044].
2109 Emerson A, Dearden J. Accommodating to motor difficulties and communication impairments in people with autism: the MORE intervention model. Front Integr Neurosci. 2013;7:45. X-1, X-2, X-3, X-4. [pmid: 23785315].
2110 Enticott PG, Fitzgibbon BM, Kennedy HA, et al. A Double-blind, Randomized Trial of Deep Repetitive Transcranial Magnetic Stimulation (rTMS) for Autism Spectrum Disorder. Brain Stimul. 2013. Oct. 27. X-5. [pmid: 24280031].
2111 Enticott PG, Kennedy HA, Rinehart NJ, et al. Interpersonal motor resonance in autism spectrum disorder: Evidence against a global “mirror system” deficit. Frontiers in Human Neuroscience. 2013. X-5.
2112 Enticott PG, Kennedy HA, Rinehart NJ, et al. GABAergic activity in autism spectrum disorders: An investigation of cortical inhibition via transcranial magnetic stimulation. Neuropharmacology. 2013;68:202-9. X-5. [pmid: 22727823].
2113 Erickson CA, Wink LK, Early MC, et al. Brief Report: Pilot Single-Blind Placebo Lead-In Study of Acamprosate in Youth with Autistic Disorder. J Autism Dev Disord. 2013. Sep. 20. X-5. [pmid: 24052275].
2114 Eriksson MA, Westerlund J, Hedvall A, et al. Medical conditions affect the outcome of early intervention in preschool children with autism spectrum disorders. Eur Child Adolesc Psychiatry. Jan. 2013;22(1):23-33. X-5. [pmid: 22836733].
2115 Essa MM, Subash S, Braidy N, et al. Role of NAD(+), Oxidative Stress, and Tryptophan Metabolism in Autism Spectrum Disorders. Int J Tryptophan Res. 2013;6(Suppl 1):15-28. X-5. [pmid: 23922500].
2116 Estes A, Olson E, Sullivan K, et al. Parenting-related stress and psychological distress in mothers of toddlers with autism spectrum disorders. Brain Dev. Feb. 2013;35(2):133-8. X-5. [pmid: 23146332].
2117 Evans B. How autism became autism: The radical transformation of a central concept of child development in Britain. Hist Human Sci. Jul. 2013;26(3):3-31. X-5. [pmid: 24014081].
2118 Fahmy SF, El-hamamsy MH, Zaki OK, et al. L-Carnitine supplementation improves the behavioral symptoms in autistic children. Research in Autism Spectrum Disorders. 2013;7(1):159-66. X-5.
2119 Farmer JE, Clark MJ, Mayfield WA, et al. The Relationship Between the Medical Home and Unmet Needs for Children with Autism Spectrum Disorders. Matern Child Health J. 2013. Jun. 23. X-5. [pmid: 23793533].
2120 Feinberg E, Augustyn M, Fitzgerald E, et al. Improving Maternal Mental Health After a Child's Diagnosis of Autism Spectrum Disorder: Results From a Randomized Clinical Trial. JAMA Pediatr. 2013. Nov. 11. X-5. [pmid: 24217336].
2121 Feinberg E, Silverstein M, Ferreira-Cesar Z. Integrating mental health services for mothers of children with autism. Psychiatric Services. 2013;64(9):930. X-5. [pmid: 24026841].
2122 Fernández-Jaén A, Fernández-Mayoralas DM, Calleja-Pérez B, et al. Efficacy of atomoxetine for the treatment of ADHD symptoms in patients with pervasive developmental disorders: A prospective, open-label study. Journal of Attention Disorders. 2013;17(6):497-505. X-5. [pmid: 22366240].
2123 Fernell E, Eriksson MA, Gillberg C. Early diagnosis of autism and impact on prognosis: a narrative review. Clin Epidemiol. 2013;5:33-43. X-1, X-2, X-3, X-4. [pmid: 23459124].
2124 Ferraioli SJ, Harris SL. Comparative effects of mindfulness and skills-based parent training programs for parents of children with autism: Feasibility and preliminary outcome data. Mindfulness. 2013;4(2):89-101. X-5.
2125 Fisher WW, Rodriguez NM, Owen TM. Functional assessment and treatment of perseverative speech about restricted topics in an adolescent with Asperger syndrome. Journal of Applied Behavior Analysis. 2013;46(1):307-11. X-1, X-3, X-5. [pmid: 24114104].
2126 Flechas J. Jorge Flechas, MD: the potential of oxytocin, nitric oxide, and iodine. Altern Ther Health Med. Jul-Aug. 2013;19(4):50-6. X-1, X-2, X-3, X-4. [pmid: 23981372].
2127 Foster L, Dunn W, Lawson LM. Coaching Mothers of Children with Autism: A Qualitative Study for Occupational Therapy Practice. Physical & Occupational Therapy in Pediatrics. May. 2013. 2013;33(2):253-63. X-1, X-3, X-4, X-5. [pmid: 23253014].
2128 Foxe JJ, Molholm S, Del Bene VA, et al. Severe Multisensory Speech Integration Deficits in High-Functioning School-Aged Children with Autism Spectrum Disorder (ASD) and Their Resolution During Early Adolescence. Cereb Cortex. 2013. Aug. 28. X-1, X-4. [pmid: 23985136].
2129 Franklin AV, King MK, Palomo V, et al. Glycogen Synthase Kinase-3 Inhibitors Reverse Deficits in Long-term Potentiation and Cognition in Fragile X Mice. Biol Psychiatry. 2013. Sep. 13. X-5. [pmid: 24041505].
2130 Franz DN. Everolimus in the treatment of subependymal giant cell astrocytomas, angiomyolipomas, and pulmonary and skin lesions associated with tuberous sclerosis complex. Biologics. 2013;7:211-21. X-5. [pmid: 24143074].
2131 Freitag CM, Cholemkery H, Elsuni L, et al. The group-based social skills training SOSTA-FRA in children and adolescents with high functioning autism spectrum disorder--study protocol of the randomised, multi-centre controlled SOSTA--net trial. Trials. 2013;14:6. X-1, X-2, X-3, X-4, X-5. [pmid: 23289935].
2132 Frenette P, Dodds L, MacPherson K, et al. Factors affecting the age at diagnosis of autism spectrum disorders in Nova Scotia, Canada. Autism. Mar. 2013;17(2):184-95. X-5. [pmid: 21788254].
2133 Freuler AC, Baranek GT, Tashjian C, et al. Parent reflections of experiences of participating in a randomized controlled trial of a behavioral intervention for infants at risk of autism spectrum disorders. Autism. 2013. Oct. 8. X-4. [pmid: 24104508].
2134 Frohlich J, Van Horn JD. Reviewing the ketamine model for schizophrenia. J Psychopharmacol. 2013. Nov. 20. X-5. [pmid: 24257811].
2135 Frye RE, DeLatorre R, Taylor HB, et al. Metabolic effects of sapropterin treatment in autism spectrum disorder: a preliminary study. Transl Psychiatry. 2013;3:e237. X-3. [pmid: 23462988].
2136 Frye RE, Melnyk S, Fuchs G, et al. Effectiveness of methylcobalamin and folinic Acid treatment on adaptive behavior in children with autistic disorder is related to glutathione redox status. Autism Res Treat. 2013;2013:609705. X-5. [pmid: 24224089].
2137 Frye RE, Rossignol D, Casanova MF, et al. A Review of Traditional and Novel Treatments for Seizures in Autism Spectrum Disorder: Findings from a Systematic Review and Expert Panel. Front Public Health. 2013;1:31. X-5. [pmid: 24350200].
2138 Frye RE, Sequeira JM, Quadros EV, et al. Cerebral folate receptor autoantibodies in autism spectrum disorder. Molecular Psychiatry. 2013;18(3):369-81. X-5. [pmid: 22230883].
2139 Gal E, Ben Meir A, Katz N. Development and reliability of the Autism Work Skills Questionnaire (AWSQ). Am J Occup Ther. Jan-Feb. 2013;67(1):e1-5. X-5. [pmid: 23245792].
2140 Gan SM, Tung LC, Yeh CH, et al. The ICF-CY-based structural equation model of factors associated with participation in children with autism. Dev Neurorehabil. 2013. Oct. 2. X-5. [pmid: 24087923].
2141 Gan SM, Tung LC, Yeh CY, et al. ICF-CY based assessment tool for children with autism. Disabil Rehabil. Apr. 2013;35(8):678-85. X-5. [pmid: 22897818].
2142 Ganz JB, Hong ER, Goodwyn F, et al. Impact of PECS tablet computer app on receptive identification of pictures given a verbal stimulus. Dev Neurorehabil. 2013. Aug. 19. X-3. [pmid: 23957298].
2143 Ganz JB, Rispoli MJ, Mason RA, et al. Moderation of effects of AAC based on setting and types of aided AAC on outcome variables: An aggregate study of single-case research with individuals with ASD. Dev Neurorehabil. 2013. Oct. 8. X-5. [pmid: 24102440].
2144 Geier DA, Kern JK, Geier MR. A Comparison of the Autism Treatment Evaluation Checklist (ATEC) and the Childhood Autism Rating Scale (CARS) for the Quantitative Evaluation of Autism. J Ment Health Res Intellect Disabil. Oct. 2013;6(4):255-67. X-5. [pmid: 23914277].
2145 Gentile I, Bravaccio C, Bonavolta R, et al. Response to measles-mumps-rubella vaccine in children with autism spectrum disorders. In Vivo. May-Jun. 2013;27(3):377-82. X-5. [pmid: 23606694].
2146 Georgiades S, Szatmari P, Boyle M, et al. Investigating phenotypic heterogeneity in children with autism spectrum disorder: A factor mixture modeling approach. Journal of Child Psychology and Psychiatry. 2013;54(2):206-15. X-5. [pmid: 22862778].
2147 Gershon ES, Grennan K, Busnello J, et al. A rare mutation of CACNA1C in a patient with bipolar disorder, and decreased gene expression associated with a bipolar-associated common SNP of CACNA1C in brain. Mol Psychiatry. 2013. Aug. 27. X-5. [pmid: 23979604].
2148 Ghaleiha A, Asadabadi M, Mohammadi MR, et al. Memantine as adjunctive treatment to risperidone in children with autistic disorder: a randomized, double-blind, placebo-controlled trial. Int J Neuropsychopharmacol. May. 2013;16(4):783-9. X-5. [pmid: 22999292].
2149 Ghaleiha A, Ghyasvand M, Mohammadi MR, et al. Galantamine efficacy and tolerability as an augmentative therapy in autistic children: A randomized, double-blind, placebo-controlled trial. J Psychopharmacol. 2013. Oct. 15. X-5. [pmid: 24132248].
2150 Ghanizadeh A, Moghimi-Sarani E. A randomized double blind placebo controlled clinical trial of N-Acetylcysteine added to risperidone for treating autistic disorders. BMC Psychiatry. 2013;13:196. X-5. [pmid: 23886027].
2151 Gillespie-Smith K, Riby DM, Hancock PJ, et al. Children with autism spectrum disorder (ASD) attend typically to faces and objects presented within their picture communication systems. J Intellect Disabil Res. 2013. Apr. 19. X-1, X-3, X-4. [pmid: 23600472].
2152 Goetz CG, Stebbins GT, Chung KA, et al. Which dyskinesia scale best detects treatment response?. Mov Disord. Mar. 2013;28(3):341-6. X-5. [pmid: 23390076].
2153 Gokey KM, Wilder DA, Welch T, et al. Fading a concurrent activity during self-control training for children with autism. J Appl Behav Anal. 2013. Aug. 12. X-3. [pmid: 24114520].
2154 Goldingay S, Stagnitti K, Sheppard L, et al. An intervention to improve social participation for adolescents with autism spectrum disorder: Pilot study. Dev Neurorehabil. 2013. Nov. 8. X-5. [pmid: 24206240].
2155 Goldman LE, Chu PW, Osmond D, et al. Accuracy of do not resuscitate (DNR) in administrative data. Med Care Res Rev. Feb. 2013;70(1):98-112. X-5. [pmid: 22955698].
2156 Golubchik P, Sever J, Weizman A. Reboxetine treatment for autistic spectrum disorder of pediatric patients with depressive and inattentive/hyperactive symptoms: An open-label trial. Clinical Neuropharmacology. 2013;36(2):37-41. X-1, X-3, X-5. [pmid: 23503544].
2157 Graf-Myles J, Farmer C, Thurm A, et al. Dietary adequacy of children with autism compared with controls and the impact of restricted diet. Journal of Developmental and Behavioral Pediatrics. 2013;34(7):449-59. X-5. [pmid: 24042076].
2158 Granovetter M. Let's talk therapy: treatments for children with autism. Lancet. Aug. 31. 2013;382(9894):753. X-1, X-2, X-3, X-4. [pmid: 23993177].
2159 Grant PJ, Joseph LA, Farmer CA, et al. 12-Week Placebo-Controlled Trial of Add-on Riluzole in the Treatment of Childhood-Onset Obsessive Compulsive Disorder. Neuropsychopharmacology. 2013. Dec. 19. X-1, X-3. [pmid: 24356715].
2160 Grether JK, Qian Y, Croughan MS, et al. Is infertility associated with childhood autism?. J Autism Dev Disord. Mar. 2013;43(3):663-72. X-5. [pmid: 22777105].
2161 Grodberg D, Weinger PM, Halpern D, et al. The Autism Mental Status Exam: Sensitivity and Specificity Using DSM-5 Criteria for Autism Spectrum Disorder in Verbally Fluent Adults. J Autism Dev Disord. 2013. Aug. 29. X-5. [pmid: 23989909].
2162 Grondhuis SN, Aman MG. Overweight and obesity in youth with developmental disabilities: a call to action. J Intellect Disabil Res. 2013. Sep. 10. X-5. [pmid: 24020517].
2163 Grynszpan O, Weiss PL, Perez-Diaz F, et al. Innovative technology-based interventions for autism spectrum disorders: A meta-analysis. Autism. 2013. Oct. 3. X-1. [pmid: 24092843].
2164 Guevara JP, Gerdes M, Localio R, et al. Effectiveness of developmental screening in an urban setting. Pediatrics. Jan. 2013;131(1):30-7. X-3, X-4, X-5. [pmid: 23248223].
2165 Gunn KS, Trembath D, Hudry K. An examination of interactions among children with autism and their typically developing peers. Dev Neurorehabil. 2013. Jul. 19. X-4. [pmid: 23869995].
2166 Hadjikhani N, Zurcher NR, Rogier O, et al. Improving emotional face perception in autism with diuretic bumetanide: A proof-of-concept behavioral and functional brain imaging pilot study. Autism. 2013. Dec. 16. X-1, X-3. [pmid: 24343334].
2167 Hammond RK, Campbell JM, Ruble LA. Considering Identification and Service Provision for Students with Autism Spectrum Disorders within the Context of Response to Intervention. Exceptionality. 2013;21(1):34-50. X-5.
2168 Hanney NM, Jostad CM, LeBlanc LA, et al. Intensive behavioral treatment of urinary incontinence of children with autism spectrum disorders: An archival analysis of procedures and outcomes from an outpatient clinic. Focus on Autism and Other Developmental Disabilities. 2013;28(1):26-31. X-5.
2169 Hardy MW, Lagasse AB. Rhythm, movement, and autism: using rhythmic rehabilitation research as a model for autism. Front Integr Neurosci. 2013;7:19. X-5. [pmid: 23543915].
2170 Harfterkamp M, Buitelaar JK, Minderaa RB, et al. Long-term treatment with atomoxetine for attention-deficit/hyperactivity disorder symptoms in children and adolescents with autism spectrum disorder: An open-label extension study. Journal of Child and Adolescent Psychopharmacology. 2013;23(3):194-9. X-5. [pmid: 23578015].
2171 Harris B, Barton EE, Albert C. Evaluating Autism Diagnostic and Screening Tools for Cultural and Linguistic Responsiveness. J Autism Dev Disord. 2013. Nov. 2. X-5. [pmid: 24186120].
2172 Harrop C, McConachie H, Emsley R, et al. Restricted and Repetitive Behaviors in Autism Spectrum Disorders and Typical Development: Cross-Sectional and Longitudinal Comparisons. J Autism Dev Disord. 2013. Nov. 14. X-5. [pmid: 24234675].
2173 Hazen EP, McDougle CJ, Volkmar FR. Changes in the diagnostic criteria for autism in DSM-5: controversies and concerns. J Clin Psychiatry. Jul. 2013;74(7):739-40. X-1, X-2, X-3, X-4. [pmid: 23945452].
2174 Hebron J, Humphrey N. Exposure to bullying among students with autism spectrum conditions: A multi-informant analysis of risk and protective factors. Autism. 2013. Jul. 25. X-5. [pmid: 23886576].
2175 Hedvall A, Westerlund J, Fernell E, et al. Autism and developmental profiles in preschoolers: stability and change over time. Acta Paediatr. 2013. Oct. 8. X-4. [pmid: 24237479].
2176 Henninger NA, Taylor JL. Outcomes in Adults with Autism Spectrum Disorders: A Historical Perspective. Autism: The International Journal of Research and Practice. January. 2013. 2013;17(1):103-16. X-5. [pmid: 22914775].
2177 Henriksen N, Peterson S. Behavioral treatment of bedwetting in an adolescent with autism. Journal of Developmental and Physical Disabilities. 2013;25(3):313-23. X-3, X-5.
2178 Hesselmark E, Plenty S, Bejerot S. Group cognitive behavioural therapy and group recreational activity for adults with autism spectrum disorders: A preliminary randomized controlled trial. Autism. 2013. Nov. 8. X-5. [pmid: 24089423].
2179 Hill DA, Belcher L, Brigman HE, et al. The Apple iPad TM as an innovative employment support for young adults with autism spectrum disorder and other developmental disabilities. Journal of Applied Rehabilitation Counseling. 2013;44(1):28-37. X-5.
2180 Himuro N, Kozuka N, Mori M. Measurement of family-centred care: translation, adaptation and validation of the Measure of Processes of Care (MPOC-56 and -20) for use in Japan. Child Care Health Dev. May. 2013;39(3):358-65. X-5. [pmid: 22372945].
2181 Hinckson EA, Dickinson A, Water T, et al. Physical activity, dietary habits and overall health in overweight and obese children and youth with intellectual disability or autism. Res Dev Disabil. Apr. 2013;34(4):1170-8. X-1, X-3, X-4. [pmid: 23400004].
2182 Hines M, Balandin S, Togher L. The Stories of Older Parents of Adult Sons and Daughters with Autism: A Balancing Act. J Appl Res Intellect Disabil. 2013. Jun. 17. X-5. [pmid: 23775710].
2183 Hinton R, Budimirovic DB, Marschik PB, et al. Parental reports on early language and motor milestones in fragile X syndrome with and without autism spectrum disorders. Dev Neurorehabil. 2013;16(1):58-66. X-5. [pmid: 23249372].
2184 Holloway R. On Emerging from Autism and into the Terror of Relationships. Journal of Child Psychotherapy. 2013;39(1):39-58. X-5.
2185 Holm MB, Baird JM, Kim YJ, et al. Therapeutic Horseback Riding Outcomes of Parent-Identified Goals for Children with Autism Spectrum Disorder: An ABA' Multiple Case Design Examining Dosing and Generalization to the Home and Community. J Autism Dev Disord. 2013. Oct. 4. X-3. [pmid: 24091469].
2186 Horbrand F, Bramlage P, Fischaleck J, et al. A population-based study comparing biosimilar versus originator erythropoiesis-stimulating agent consumption in 6,117 patients with renal anaemia. Eur J Clin Pharmacol. Apr. 2013;69(4):929-36. X-5. [pmid: 23052412].
2187 Hosenbocus S, Chahal R. Memantine: a review of possible uses in child and adolescent psychiatry. J Can Acad Child Adolesc Psychiatry. May. 2013;22(2):166-71. X-1, X-2, X-3, X-4. [pmid: 23667364].
2188 Hsia Y, Wong AY, Murphy DG, et al. Psychopharmacological prescriptions for people with autism spectrum disorder (ASD): a multinational study. Psychopharmacology (Berl). 2013. Sep. 5. X-4. [pmid: 24005531].
2189 Hsieh YL, Lo JL. Occupational experiences and subjective well-being of mothers of children with ASD in Taiwan. Occupational Therapy International. 2013;20(1):45-53. X-5. [pmid: 23147991].
2190 Hu X, Zhang J, Jin C, et al. Association study of NRXN3 polymorphisms with schizophrenia and risperidone-induced bodyweight gain in Chinese Han population. Prog Neuropsychopharmacol Biol Psychiatry. Jun. 3. 2013;43:197-202. X-5. [pmid: 23306218].
2191 Hua X, Thompson PM, Leow AD, et al. Brain growth rate abnormalities visualized in adolescents with autism. Hum Brain Mapp. Feb. 2013;34(2):425-36. X-5. [pmid: 22021093].
2192 Huang CY, Yen HC, Tseng MH, et al. Impacts of Autistic Behaviors Emotional and Behavioral Problems on Parenting Stress in Caregivers of Children with Autism. J Autism Dev Disord. 2013. Nov. 28. X-5. [pmid: 24287878].
2193 Huang H, Michetti C, Busnelli M, et al. Chronic and Acute Intranasal Oxytocin Produce Divergent Social Effects in Mice. Neuropsychopharmacology. 2013. Nov. 4. X-5. [pmid: 24190025].
2194 Hughes C, Harvey M, Cosgriff J, et al. A Peer-Delivered Social Interaction Intervention for High School Students with Autism. Research and Practice for Persons with Severe Disabilities. 2013. 2013;38(1):1-16. X-5.
2195 Huke V, Turk J, Saeidi S, et al. The Clinical Implications of High Levels of Autism Spectrum Disorder Features in Anorexia Nervosa: A Pilot Study. Eur Eat Disord Rev. 2013. Nov. 26. X-5. [pmid: 24277715].
2196 Humble MB, Uvnas-Moberg K, Engstrom I, et al. Plasma oxytocin changes and anti-obsessive response during serotonin reuptake inhibitor treatment: a placebo controlled study. BMC Psychiatry. Dec. 23. 2013;13(1):344. X-5. [pmid: 24359174].
2197 Hutchins TL, Prelock PA. The social validity of Social StoriesTM for supporting the behavioural and communicative functioning of children with autism spectrum disorder. International Journal of Speech-Language Pathology. 2013;15(4):383-95. X-5. [pmid: 23216418].
2198 Ibrahim KS, El-Sayed EM. Proposed remedies for some developmental disorders. Toxicol Ind Health. May. 2013;29(4):367-84. X-1, X-2, X-3, X-4. [pmid: 22301819].
2199 Imaizumi Y, Okano H. Modeling human neurological disorders with induced pluripotent stem cells. J Neurochem. 2013. Nov. 29. X-5. [pmid: 24286589].
2200 Imbrici P, Camerino DC, Tricarico D. Major channels involved in neuropsychiatric disorders and therapeutic perspectives. Front Genet. 2013;4:76. X-5. [pmid: 23675382].
2201 Iskander JM, Rosales R. An evaluation of the components of a Social StoriesTM intervention package. Research in Autism Spectrum Disorders. 2013;7(1):1-8. X-3.
2202 Iwanaga R, Honda S, Nakane H, et al. Pilot Study: Efficacy of Sensory Integration Therapy for Japanese Children with High-Functioning Autism Spectrum Disorder. Occup Ther Int. 2013. Jul. 25. X-5. [pmid: 23893373].
2203 Jacob J, Ribes V, Moore S, et al. Valproic Acid silencing of ascl1b/ascl1 results in the failure of serotonergic differentiation in a zebrafish model of Fetal Valproate Syndrome. Dis Model Mech. 2013. Oct. 17. X-5. [pmid: 24135485].
2204 Jain R, Juneja M, Sairam S. Children with developmental disabilities in India: Age of initial concern and referral for rehabilitation services, and reasons for delay in referral. Journal of Child Neurology. 2013;28(4):455-60. X-5. [pmid: 22752480].
2205 Jenkins SR, DiGennaro Reed FD. An experimental analysis of the effects of therapeutic horseback riding on the behavior of children with autism. Research in Autism Spectrum Disorders. 2013;7(6):721-40. X-3.
2206 Jeon SJ, Kim JW, Kim KC, et al. Translational Regulation of NeuroD1 Expression by FMRP: Involvement in Glutamatergic Neuronal Differentiation of Cultured Rat Primary Neural Progenitor Cells. Cell Mol Neurobiol. 2013. Dec. 12. X-5. [pmid: 24338128].
2207 Jerrell JM, Hrisko S. A comparison of the PANSS pentagonal and Van Der Gaag 5-factor models for assessing change over time. Psychiatry Res. May. 15. 2013;207(1-2):134-9. X-5. [pmid: 23313304].
2208 Jin CS, Hanley GP, Beaulieu L. An individualized and comprehensive approach to treating sleep problems in young children. Journal of Applied Behavior Analysis. 2013;46(1):161-80. X-3. [pmid: 24114092].
2209 Jones EJ, Gliga T, Bedford R, et al. Developmental pathways to autism: A review of prospective studies of infants at risk. Neurosci Biobehav Rev. 2013. Dec. 18. X-5. [pmid: 24361967].
2210 Joshi G, Wozniak J, Petty C, et al. Psychiatric Comorbidity and Functioning in a Clinically Referred Population of Adults with Autism Spectrum Disorders: A Comparative Study. Journal of Autism and Developmental Disorders. June. 2013. 2013;43(6):1314-25. X-5. [pmid: 23076506].
2211 Jung NH, Janzarik WG, Delvendahl I, et al. Impaired induction of long-term potentiation-like plasticity in patients with high-functioning autism and Asperger syndrome. Developmental Medicine & Child Neurology. 2013;55(1):83-9. X-5. [pmid: 23157428].
2212 Jung S, Sainato DM. Teaching Play Skills to Young Children with Autism. Journal of Intellectual & Developmental Disability. March. 2013. 2013;38(1):74-90. X-1, X-2, X-3, X-4. [pmid: 23157647].
2213 Kaat AJ, Lecavalier L, Aman MG. Validity of the Aberrant Behavior Checklist in Children with Autism Spectrum Disorder. J Autism Dev Disord. 2013. Oct. 29. X-5. [pmid: 24165702].
2214 Kaiser AP, Roberts MY. Parent-implemented enhanced milieu teaching with preschool children who have intellectual disabilities. Journal of Speech, Language, and Hearing Research. 2013;56(1):295-309. X-3.
2215 Kajiume A, Aoyama-Setoyama S, Saito-Hori Y, et al. Reduced brain activation during imitation and observation of others in children with pervasive developmental disorder: A pilot study. Behavioral and Brain Functions. 2013:9. X-5. [pmid: 23425335].
2216 Kakooza-Mwesige A, Ssebyala K, Karamagi C, et al. Adaptation of the ‘ten questions’ to screen for autism and other neuro-developmental disorders in Uganda. Autism. 2013. Nov. 8. X-5. [pmid: 23536263].
2217 Kaluzna-Czaplinska J, Zurawicz E, Jozwik J. Chromatographic techniques coupled with mass spectrometry for the determination of organic acids in the study of autism. J Chromatogr B Analyt Technol Biomed Life Sci. 2013. Oct. 22. X-5. [pmid: 24210941].
2218 Kamio Y, Inada N, Koyama T. A Nationwide Survey on Quality of Life and Associated Factors of Adults with High-Functioning Autism Spectrum Disorders. Autism: The International Journal of Research and Practice. January. 2013. 2013;17(1):15-26. X-5. [pmid: 22399449].
2219 Kandalaft MR, Didehbani N, Krawczyk DC, et al. Virtual reality social cognition training for young adults with high-functioning autism. J Autism Dev Disord. Jan. 2013;43(1):34-44. X-5. [pmid: 22570145].
2220 Kang S, O'Reilly M, Rojeski L, et al. Effects of tangible and social reinforcers on skill acquisition, stereotyped behavior, and task engagement in three children with autism spectrum disorders. Res Dev Disabil. Feb. 2013;34(2):739-44. X-3. [pmid: 23220050].
2221 Kang-Yi CD, Grinker RR, Mandell DS. Korean Culture and Autism Spectrum Disorders. Springer. 233 Spring Street, New York, NY 10013. 2013:503-20. X-4.
2222 Kanne SM, Mazurek MO, Sikora D, et al. The Autism Impact Measure (AIM): Initial Development of a New Tool for Treatment Outcome Measurement. J Autism Dev Disord. 2013. Jun. 8. X-5. [pmid: 23748386].
2223 Karaaslan O, Diken IH, Mahoney G. A Randomized Control Study of Responsive Teaching with Young Turkish Children and Their Mothers. Topics in Early Childhood Special Education. 2013;33(1):18-27. X-3.
2224 Kas MJ, Glennon JC, Buitelaar J, et al. Assessing behavioural and cognitive domains of autism spectrum disorders in rodents: current status and future perspectives. Psychopharmacology (Berl). 2013. Sep. 19. X-5. [pmid: 24048469].
2225 Kato K, Mikami K, Akama F, et al. Clinical features of suicide attempts in adults with autism spectrum disorders. Gen Hosp Psychiatry. Jan. 2013;35(1):50-3. X-5. [pmid: 23141028].
2226 Kats D, Payne L, Parlier M, et al. Prevalence of selected clinical problems in older adults with autism and intellectual disability. J Neurodev Disord. 2013;5(1):27. X-5. [pmid: 24066979].
2227 Kelly A, Barnes-Holmes D. Implicit attitudes towards children with autism versus normally developing children as predictors of professional burnout and psychopathology. Res Dev Disabil. Jan. 2013;34(1):17-28. X-5. [pmid: 22940155].
2228 Kent JM, Kushner S, Ning X, et al. Risperidone dosing in children and adolescents with autistic disorder: A double-blind, placebo-controlled study. Journal of Autism and Developmental Disorders. 2013;43(8):1773-83. X-5. [pmid: 23212807].
2229 Khanna R, Jariwala K, Bentley JP. Health utility assessment using EQ-5D among caregivers of children with autism. Value Health. Jul-Aug. 2013;16(5):778-88. X-5. [pmid: 23947971].
2230 Khanna R, Jariwala K, West-Strum D. Use and cost of psychotropic drugs among recipients with autism in a state Medicaid fee-for-service programme. J Intellect Disabil Res. Feb. 2013;57(2):161-71. X-5. [pmid: 22471524].
2231 Khor AS, Melvin GA, Reid SC, et al. Coping Daily Hassles and Behavior and Emotional Problems in Adolescents with High-Functioning Autism/Asperger's Disorder. J Autism Dev Disord. 2013. Aug. 11. X-5. [pmid: 23933998].
2232 Kim ES, Berkovits LD, Bernier EP, et al. Social Robots as Embedded Reinforcers of Social Behavior in Children with Autism. Journal of Autism and Developmental Disorders. May. 2013. 2013;43(5):1038-49. X-5. [pmid: 23111617].
2233 Kim KC, Lee DK, Go HS, et al. Pax6-Dependent Cortical Glutamatergic Neuronal Differentiation Regulates Autism-Like Behavior in Prenatally Valproic Acid-Exposed Rat Offspring. Mol Neurobiol. 2013. Sep. 13. X-5. [pmid: 24030726].
2234 Kim P, Park JH, Kwon KJ, et al. Effects of Korean red ginseng extracts on neural tube defects and impairment of social interaction induced by prenatal exposure to valproic acid. Food Chem Toxicol. Jan. 2013;51:288-96. X-5. [pmid: 23104247].
2235 King BH, Dukes K, Donnelly CL, et al. Baseline Factors Predicting Placebo Response to Treatment in Children and Adolescents With Autism Spectrum Disorders: A Multisite Randomized Clinical Trial. JAMA Pediatr. 2013. Sep. 23. X-5. [pmid: 24061784].
2236 Kingston C, Hibberd C, Ozsivadjian A. Parent experiences of a specialist intervention service for mental health difficulties in children with autistic spectrum disorder. Child and Adolescent Mental Health. 2013;18(2):109-15. X-5.
2237 Kirby A, Sugden D, Purcell C. Diagnosing developmental coordination disorders. Arch Dis Child. 2013. Nov. 19. X-5. [pmid: 24255567].
2238 Klaiman C, Huffman L, Masaki L, et al. Tetrahydrobiopterin as a Treatment for Autism Spectrum Disorders: A Double-Blind, Placebo-Controlled Trial. Journal of Child and Adolescent Psychopharmacology. 2013;23(5):320-8. X-5. [pmid: 23782126].
2239 Klintwall L, Eldevik S, Eikeseth S. Narrowing the gap: Effects of intervention on developmental trajectories in autism. Autism. 2013. Nov. 8. X-5. [pmid: 24212258].
2240 Kocsis B, Lee P, Deth R. Enhancement of gamma activity after selective activation of dopamine D4 receptors in freely moving rats and in a neurodevelopmental model of schizophrenia. Brain Struct Funct. 2013. Jul. 10. X-5. [pmid: 23839116].
2241 Koegel LK, Koegel RL, Ashbaugh K, et al. The importance of early identification and intervention for children with or at risk for autism spectrum disorders. Int J Speech Lang Pathol. 2013. Dec. 11. X-5. [pmid: 24328352].
2242 Koegel LK, Krasno AM, Taras H, et al. Is medication information for children with autism spectrum disorder monitored and coordinated across professionals? Findings from a teacher survey. School Mental Health. 2013;5(1):48-57. X-5. [pmid: 23526921].
2243 Koegel LK, Park MN, Koegel RL. Using Self-Management to Improve the Reciprocal Social Conversation of Children with Autism Spectrum Disorder. J Autism Dev Disord. 2013. Oct. 15. X-3. [pmid: 24127164].
2244 Koegel RL, Bradshaw JL, Ashbaugh K, et al. Improving Question-Asking Initiations in Young Children with Autism Using Pivotal Response Treatment. J Autism Dev Disord. 2013. Sep. 7. X-3. [pmid: 24014174].
2245 Koehler-Platten K, Grow LL, Schulze KA, et al. Using a lag reinforcement schedule to increase phonemic variability in children with autism spectrum disorders. Anal Verbal Behav. 2013;29(1):71-83. X-3. [pmid: 23814368].
2246 Kohlstadt I, Wharton G. Clinician uptake of obesity-related drug information: a qualitative assessment using continuing medical education activities. Nutr J. 2013;12:44. X-5. [pmid: 23575242].
2247 Kondo N, Sakai M, Kuroda Y, et al. General condition of hikikomori (prolonged social withdrawal) in Japan: psychiatric diagnosis and outcome in mental health welfare centres. Int J Soc Psychiatry. Feb. 2013;59(1):79-86. X-5. [pmid: 22094722].
2248 Korkiakangas TK, Rae JP. Gearing up to a new activity: how teachers use object adjustments to manage the attention of children with autism. Augment Altern Commun. Mar. 2013;29(1):83-103. X-5. [pmid: 23521354].
2249 Kouijzer ME, van Schie HT, Gerrits BJ, et al. Is EEG-biofeedback an effective treatment in autism spectrum disorders? A randomized controlled trial. Appl Psychophysiol Biofeedback. Mar. 2013;38(1):17-28. X-1, X-3. [pmid: 22903518].
2250 Krstovska-Guerrero I, Jones EA. Joint attention in Autism: Teaching smiling coordinated with gaze to respond to joint attention bids. Research in Autism Spectrum Disorders. 2013;7(1):93-108. X-3.
2251 Krueger DD, Brose N. Evidence for a common endocannabinoid-related pathomechanism in autism spectrum disorders. Neuron. May. 8. 2013;78(3):408-10. X-5. [pmid: 23664608].
2252 Kuroda M, Kawakubo Y, Kuwabara H, et al. A cognitive-behavioral intervention for emotion regulation in adults with high-functioning autism spectrum disorders: study protocol for a randomized controlled trial. Trials. 2013;14:231. X-5. [pmid: 23880333].
2253 Lahav O, Apter A, Ratzon NZ. Psychological adjustment and levels of self esteem in children with visual-motor integration difficulties influences the results of a randomized intervention trial. Res Dev Disabil. Jan. 2013;34(1):56-64. X-5. [pmid: 22940159].
2254 Lahiri U, Bekele E, Dohrmann E, et al. Design of a virtual reality based adaptive response technology for children with autism. IEEE Trans Neural Syst Rehabil Eng. Jan. 2013;21(1):55-64. X-5. [pmid: 23033333].
2255 Lai MC, Lombardo MV, Baron-Cohen S. Autism. Lancet. 2013. Sep. 25. X-5. [pmid: 24074734].
2256 Landsberger SA, Diaz DR, Spring NZ, et al. Psychiatric Diagnoses and Psychosocial Needs of Outpatient Deaf Children and Adolescents. Child Psychiatry Hum Dev. 2013. Mar. 16. X-5. [pmid: 23504290].
2257 Langdon PE, Murphy GH, Clare IC, et al. An evaluation of the EQUIP treatment programme with men who have intellectual or other developmental disabilities. J Appl Res Intellect Disabil. Mar. 2013;26(2):167-80. X-5. [pmid: 23281218].
2258 Langdon PE, Murphy GH, Wilson E, et al. Asperger syndrome and anxiety disorders (PAsSA) treatment trial: a study protocol of a pilot, multicentre, single-blind, randomised crossover trial of group cognitive behavioural therapy. BMJ Open. 2013;3(7). X-5. [pmid: 23901031].
2259 Lange N, McDougle C. Help for the child with autism. Sci Am. Oct. 2013;309(4):72-7. X-1, X-2, X-3, X-4. [pmid: 24137859].
2260 Lanovaz MJ, Rapp JT, Ferguson S. Assessment and treatment of vocal stereotypy associated with television: A pilot study. Journal of Applied Behavior Analysis. 2013;46(2):544-8. X-3, X-5. [pmid: 24114171].
2261 Lanz TA, Guilmette E, Gosink MM, et al. Transcriptomic analysis of genetically defined autism candidate genes reveals common mechanisms of action. Mol Autism. Nov. 15. 2013;4(1):45. X-1, X-3, X-4. [pmid: 24238429].
2262 Latta A, Rampton T, Rosemann J, et al. Snapshots reflecting the lives of siblings of children with autism spectrum disorders. Child Care Health Dev. 2013. Aug. 19. X-5. [pmid: 23952538].
2263 Leaf JB, Tsuji KH, Lentell AE, et al. A comparison of discrete trial teaching implemented in a one-to-one instructional format and in a group instructional format. Behavioral Interventions. 2013;28(1):82-106. X-3.
2264 Lecavalier L, Wood JJ, Halladay AK, et al. Measuring Anxiety as a Treatment Endpoint in Youth with Autism Spectrum Disorder. J Autism Dev Disord. 2013. Oct. 26. X-4. [pmid: 24158679].
2265 Lee A, Lang R, Davenport K, et al. Comparison of therapist implemented and iPad-assisted interventions for children with autism. Dev Neurorehabil. 2013. Oct. 2. X-3. [pmid: 24088050].
2266 Lee DR, McKeith I, Mosimann U, et al. Examining carer stress in dementia: the role of subtype diagnosis and neuropsychiatric symptoms. Int J Geriatr Psychiatry. Feb. 2013;28(2):135-41. X-5. [pmid: 22422615].
2267 Lehti V, Brown AS, Gissler M, et al. Autism spectrum disorders in IVF children: a national case-control study in Finland. Hum Reprod. Mar. 2013;28(3):812-8. X-5. [pmid: 23293220].
2268 Lemaire M, Thomazeau B, Bonnet-Brilhault F. Gender Identity Disorder and Autism Spectrum Disorder in a 23-Year-Old Female. Arch Sex Behav. 2013. Jul. 9. X-5. [pmid: 23835847].
2269 Lipton J, Sahin M. Fragile X syndrome therapeutics: translation, meet translational medicine. Neuron. Jan. 23. 2013;77(2):212-3. X-5. [pmid: 23352156].
2270 Liu X, Lack D, Rakowski JT, et al. Fast Monte Carlo simulation for total body irradiation using a (60)Co teletherapy unit. J Appl Clin Med Phys. 2013;14(3):4214. X-5. [pmid: 23652253].
2271 Liyanage VR, Zachariah RM, Rastegar M. Decitabine alters the expression of Mecp2 isoforms via dynamic DNA methylation at the Mecp2 regulatory elements in neural stem cells. Mol Autism. Nov. 15. 2013;4(1):46. X-5. [pmid: 24238559].
2272 Lloyd-Fox S, Blasi A, Elwell CE, et al. Reduced neural sensitivity to social stimuli in infants at risk for autism. Proc Biol Sci. May. 7. 2013;280(1758):20123026. X-5. [pmid: 23486434].
2273 Lo-Castro A, Curatolo P. Epilepsy associated with autism and attention deficit hyperactivity disorder: Is there a genetic link?. Brain Dev. 2013. May. 29. X-5. [pmid: 23726375].
2274 Lock RH, Bradley L, Hendricks B, et al. Evaluating the success of a parent-professional autism network: Implications for family counselors. The Family Journal. 2013;21(3):288-96. X-5.
2275 Locke J, Rotheram-Fuller E, Xie M, et al. Correlation of cognitive and social outcomes among children with autism spectrum disorder in a randomized trial of behavioral intervention. Autism. 2013. Oct. 8. X-5. [pmid: 24104511].
2276 Lofkvist U, Almkvist O, Lyxell B, et al. Lexical and semantic ability in groups of children with cochlear implants, language impairment and autism spectrum disorder. Int J Pediatr Otorhinolaryngol. 2013. Nov. 25. X-4. [pmid: 24332667].
2277 Lopata C, Toomey JA, Fox JD, et al. Prevalence and Predictors of Psychotropic Use in Children with High-Functioning ASDs. Autism Res Treat. 2013;2013:384527. X-1, X-4. [pmid: 23762550].
2278 Lopes AM, Aston KI, Thompson E, et al. Human spermatogenic failure purges deleterious mutation load from the autosomes and both sex chromosomes, including the gene DMRT1. PLoS Genet. Mar. 2013;9(3):e1003349. X-5. [pmid: 23555275].
2279 Lopez-Pison J, Garcia-Jimenez MC, Monge-Galindo L, et al. Our experience with the aetiological diagnosis of global developmental delay and intellectual disability: 2006-2010. Neurologia. 2013. Dec. 10. X-5. [pmid: 24332781].
2280 Lorenzo G, Pomares J, Lledo A. Inclusion of Immersive Virtual Learning Environments and Visual Control Systems to Support the Learning of Students with Asperger Syndrome. Computers & Education. March. 2013. 2013;62(3):88-101. X-5.
2281 Louw K-A, Bentley J, Sorsdahl K, et al. Prevalence and patterns of medication use in children and adolescents with autism spectrum disorders in the Western Cape, South Africa. Journal of Child and Adolescent Mental Health. 2013;25(1):69-79. X-1, X-4.
2282 Lundqvist L-O. Prevalence and Risk Markers of Behavior Problems among Adults with Intellectual Disabilities: A Total Population Study in Orebro County, Sweden. Research in Developmental Disabilities: A Multidisciplinary Journal. April. 2013. 2013;34(4):1346-56. X-5.
2283 Lyall K, Munger KL, O'Reilly EJ, et al. Maternal dietary fat intake in association with autism spectrum disorders. Am J Epidemiol. Jul. 15. 2013;178(2):209-20. X-5. [pmid: 23813699].
2284 Ma WJ, Hashii M, Munesue T, et al. Non-synonymous single-nucleotide variations of the human oxytocin receptor gene and autism spectrum disorders: a case-control study in a Japanese population and functional analysis. Mol Autism. 2013;4(1):22. X-5. [pmid: 23815867].
2285 MacDonald M, Lord C, Ulrich D. The relationship of motor skills and adaptive behavior skills in young children with autism spectrum disorders. Research in Autism Spectrum Disorders. 2013;7(11):1383-90. X-5.
2286 Maenner MJ, Smith LE, Hong J, et al. Evaluation of an activities of daily living scale for adolescents and adults with developmental disabilities. Disabil Health J. Jan. 2013;6(1):8-17. X-5. [pmid: 23260606].
2287 Magaña S, Lopez K, Aguinaga A, et al. Access to diagnosis and treatment services among Latino children with autism spectrum disorders. Intellectual and Developmental Disabilities. 2013;51(3):141-53. X-5. [pmid: 23834211].
2288 Majewska MD, Hill M, Urbanowicz E, et al. Marked elevation of adrenal steroids, especially androgens, in saliva of prepubertal autistic children. Eur Child Adolesc Psychiatry. 2013. Sep. 17. X-5. [pmid: 24043498].
2289 Mandell DS, Stahmer AC, Shin S, et al. The role of treatment fidelity on outcomes during a randomized field trial of an autism intervention. Autism. May. 2013;17(3):281-95. X-5. [pmid: 23592849].
2290 Manoach DS, Agam Y. Neural markers of errors as endophenotypes in neuropsychiatric disorders. Front Hum Neurosci. 2013;7:350. X-5. [pmid: 23882201].
2291 Manseau M, Case BG. Racial-Ethnic Disparities in Outpatient Mental Health Visits to U.S. Physicians, 1993-2008. Psychiatr Serv. 2013. Oct. 15. X-5. [pmid: 24129773].
2292 Mari-Bauset S, Zazpe I, Mari-Sanchis A, et al. Food Selectivity in Autism Spectrum Disorders: A Systematic Review. J Child Neurol. 2013. Oct. 4. X-5. [pmid: 24097852].
2293 Marrus N, Veenstra-Vanderweele J, Hellings JA, et al. Training of child and adolescent psychiatry fellows in autism and intellectual disability. Autism. 2013. Oct. 10. X-5. [pmid: 24113341].
2294 Marshall J, Hill RJ, Dodrill P. A survey of practice for clinicians working with children with autism spectrum disorders and feeding difficulties. Int J Speech Lang Pathol. Jun. 2013;15(3):279-85. X-5. [pmid: 23577744].
2295 Marshall J, Hill RJ, Ziviani J, et al. Features of feeding difficulty in children with Autism Spectrum Disorder. Int J Speech Lang Pathol. 2013. Sep. 3. X-1, X-2. [pmid: 24001171].
2296 Martel-Laferriere V, Laflamme P, Ghannoum M, et al. Treatment of prosthetic joint infections: validation of a surgical algorithm and proposal of a simplified alternative. J Arthroplasty. Mar. 2013;28(3):395-400. X-5. [pmid: 23151368].
2297 Marti LF. Dietary Interventions in Children with Autism Spectrum Disorders- An Updated Review of The Research Evidence. Curr Clin Pharmacol. 2013. Sep. 20. X-6. [pmid: 24050740].
2298 Maruta H. Herbal Therapeutics that Block the Oncogenic Kinase PAK1: A Practical Approach towards PAK1-dependent Diseases and Longevity. Phytother Res. 2013. Aug. 14. X-5. [pmid: 23943274].
2299 Mascaro JS, Rilling JK, Tenzin Negi L, et al. Compassion meditation enhances empathic accuracy and related neural activity. Soc Cogn Affect Neurosci. Jan. 2013;8(1):48-55. X-1, X-5. [pmid: 22956676].
2300 Mathersul D, McDonald S, Rushby JA. Psychophysiological correlates of social judgement in high-functioning adults with autism spectrum disorder. Int J Psychophysiol. Jan. 2013;87(1):88-94. X-5. [pmid: 23183316].
2301 Matson JL, Adams HL, Williams LW, et al. Why Are There so Many Unsubstantiated Treatments in Autism?. Research in Autism Spectrum Disorders. March. 2013. 2013;7(3):466-74. X-5.
2302 Matson JL, Konst MJ. What Is the Evidence for Long Term Effects of Early Autism Interventions?. Research in Autism Spectrum Disorders. March. 2013. 2013;7(3):475-9. X-1, X-2, X-3, X-4.
2303 Matson JL, Kozlowski AM, Fitzgerald ME, et al. True versus False Positives and Negatives on the “Modified Checklist for Autism in Toddlers”. Research in Autism Spectrum Disorders. January. 2013. 2013;7(1):17-22. X-5.
2304 Mavranezouli I, Megnin-Viggars O, Cheema N, et al. The cost-effectiveness of supported employment for adults with autism in the United Kingdom. Autism. 2013. Oct. 14. X-5. [pmid: 24126866].
2305 May RJ, Hawkins E, Dymond S. Brief Report: Effects of Tact Training on Emergent Intraverbal Vocal Responses in Adolescents with Autism. Journal of Autism and Developmental Disorders. April. 2013. 2013;43(4):996-1004. X-5. [pmid: 22923037].
2306 Mayr R, Burger M. Value of fluorescence cystoscopy in high risk non-muscle invasive bladder cancer. Curr Urol Rep. Apr. 2013;14(2):90-3. X-5. [pmid: 23341375].
2307 Mazefsky CA, Schreiber DR, Olino TM, et al. The association between emotional and behavioral problems and gastrointestinal symptoms among children with high-functioning autism. Autism. 2013. Oct. 8. X-5. [pmid: 24104507].
2308 Mazurek MO, Engelhardt CR. Video game use in boys with autism spectrum disorder, ADHD, or typical development. Pediatrics. Aug. 2013;132(2):260-6. X-5. [pmid: 23897915].
2309 Mbadiwe T, Millis RM. Epigenetics and Autism. Autism Res Treat. 2013;2013:826156. X-2, X-5. [pmid: 24151554].
2310 McCartney M. MMR, measles, and the South Wales Evening Post. BMJ. 2013;346:f2598. X-5. [pmid: 23610382].
2311 McCleery JP, Elliott NA, Sampanis DS, et al. Motor development and motor resonance difficulties in autism: relevance to early intervention for language and communication skills. Front Integr Neurosci. 2013;7:30. X-5. [pmid: 23630476].
2312 McConachie H, McLaughlin E, Grahame V, et al. Group therapy for anxiety in children with autism spectrum disorder. Autism. 2013. Oct. 7. X-1. [pmid: 24101715].
2313 McCurdy EE, Cole CL. Use of a Peer Support Intervention for Promoting Academic Engagement of Students with Autism in General Education Settings. J Autism Dev Disord. 2013. Oct. 22. X-3. [pmid: 24146130].
2314 McGinnis AA, Blakely EQ, Harvey AC, et al. The behavioral effects of a procedure used by pediatric occupational therapists. Behavioral Interventions. 2013;28(1):48-57. X-3.
2315 McGregor KK, Rost G, Arenas R, et al. Children with ASD can use gaze in support of word recognition and learning. J Child Psychol Psychiatry. Jul. 2013;54(7):745-53. X-5. [pmid: 23574387].
2316 McGuinness TM, Johnson K. DSM-5 changes in the diagnosis of autism spectrum disorder. J Psychosoc Nurs Ment Health Serv. Apr. 2013;51(4):17-9. X-5. [pmid: 23445685].
2317 McGuinty E, Armstrong D, Carriere AM. A Clinical Treatment Intervention for Dysphoria: Externalizing Metaphors Therapy. Clin Psychol Psychother. 2013. May. 20. X-5. [pmid: 23686568].
2318 McMahon CM, Lerner MD, Britton N. Group-based social skills interventions for adolescents with higher-functioning autism spectrum disorder: a review and looking to the future. Adolesc Health Med Ther. Jan. 22. 2013;2013(4):23-8. X-5. [pmid: 23956616].
2319 Memari AH, Ghaheri B, Ziaee V, et al. Physical activity in children and adolescents with autism assessed by triaxial accelerometry. Pediatr Obes. Apr. 2013;8(2):150-8. X-5. [pmid: 23042790].
2320 Memari AH, Shayestehfar M, Mirfazeli FS, et al. Cross-cultural adaptation, reliability, and validity of the autism treatment evaluation checklist in persian. Iran J Pediatr. Jun. 2013;23(3):269-75. X-5. [pmid: 23795248].
2321 Messinger D, Young GS, Ozonoff S, et al. Beyond Autism: A Baby Siblings Research Consortium Study of High-Risk Children at Three Years of Age. Journal of the American Academy of Child & Adolescent Psychiatry. March. 2013. 2013;52(3):300-8. X-5. [pmid: 23452686].
2322 Miltenberger CA, Charlop MH. Increasing the Athletic Group Play of Children with Autism. J Autism Dev Disord. 2013. May. 23. X-3. [pmid: 23700189].
2323 Minjarez MB, Mercier EM, Williams SE, et al. Impact of pivotal response training group therapy on stress and empowerment in parents of children with autism. Journal of Positive Behavior Interventions. 2013;15(2):71-8. X-5.
2324 Mire SS, Nowell KP, Kubiszyn T, et al. Psychotropic medication use among children with autism spectrum disorders within the Simons Simplex Collection: Are core features of autism spectrum disorder related?. Autism. 2013. Sep. 26. X-1, X-4. [pmid: 24031086].
2325 Miyajima T, Kumada T, Saito K, et al. Autism in siblings with autosomal dominant nocturnal frontal lobe epilepsy. Brain Dev. Feb. 2013;35(2):155-7. X-5. [pmid: 22883468].
2326 Molteni M, Cattaneo D, Nobile M, et al. Potential Benefits and Limits of Psychopharmacological Therapies in Pervasive Developmental Disorders. Curr Clin Pharmacol. 2013. Sep. 20. X-5. [pmid: 24050744].
2327 Molteni P, Guldberg K, Logan N. Autism and multidisciplinary teamwork through the SCERTS model. British Journal of Special Education. 2013;40(3):137-45. X-1, X-3, X-4.
2328 Monahan M, Classen S, Helsel PV. Pre-driving evaluation of a teen with attention deficit hyperactivity disorder and autism spectrum disorder. Can J Occup Ther. Feb. 2013;80(1):35-41. X-5. [pmid: 23550495].
2329 Moore DW, Venkatesh S, Anderson A, et al. TOBY play-pad application to teach children with ASD - A pilot trial. Dev Neurorehabil. 2013. Jul. 19. X-1, X-4. [pmid: 23869435].
2330 Moran MF, Foley JT, Parker ME, et al. Two-legged hopping in autism spectrum disorders. Front Integr Neurosci. 2013;7:14. X-5. [pmid: 23532337].
2331 Moss J, Oliver C, Nelson L, et al. Delineating the profile of autism spectrum disorder characteristics in Cornelia de Lange and Fragile X syndromes. Am J Intellect Dev Disabil. Jan. 2013;118(1):55-73. X-5. [pmid: 23301903].
2332 Moyal WN, Lord C, Walkup JT. Quality of Life in Children and Adolescents with Autism Spectrum Disorders: What Is Known About the Effects of Pharmacotherapy?. Paediatr Drugs. 2013. Oct. 24. X-1, X-2, X-3, X-4. [pmid: 24155138].
2333 Mucchetti CA. Adapted shared reading at school for minimally verbal students with Autism. Autism. May. 2013. 2013;17(3):358-72. X-3, X-4. [pmid: 23592847].
2334 Mukherjee S, Rupani K, Dave M, et al. Evaluation of Effectiveness of Integrated Intervention in Autistic Children. Indian J Pediatr. 2013. Sep. 21. X-5. [pmid: 24057967].
2335 Mulligan CK, Trauner DA. Incidence and Behavioral Correlates of Epileptiform Abnormalities in Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jul. 20. X-5. [pmid: 23872941].
2336 Murray KE, Nyp SS, Wassom MC. Journal article reviews. Journal of Developmental and Behavioral Pediatrics. 2013;34(2):141-5. X-5.
2337 Murray ML, Hsia Y, Glaser K, et al. Pharmacological treatments prescribed to people with autism spectrum disorder (ASD) in primary health care. Psychopharmacology (Berl). 2013. May. 17. X-1, X-3, X-4. [pmid: 23681164].
2338 Myers CL, Gross AD, McReynolds BM. Broadband Behavior Rating Scales as Screeners for Autism?. J Autism Dev Disord. 2013. Nov. 28. X-5. [pmid: 24287879].
2339 Naber FB, Poslawsky IE, van Ijzendoorn MH, et al. Brief Report: Oxytocin Enhances Paternal Sensitivity to a Child with Autism--A Double-Blind Within-Subject Experiment with Intranasally Administered Oxytocin. Journal of Autism and Developmental Disorders. 2013;43(1):224-9. X-5. [pmid: 22544470].
2340 Narayanan S, Georgiou PG. Behavioral Signal Processing: Deriving Human Behavioral Informatics From Speech and Language: Computational techniques are presented to analyze and model expressed and perceived human behavior-variedly characterized as typical, atypical, distressed, and disordered-from speech and language cues and their applications in health, commerce, education, and beyond. Proc IEEE Inst Electr Electron Eng. Feb. 7. 2013;101(5):1203-33. X-5. [pmid: 24039277].
2341 Narcisa V, Discenza M, Vaccari E, et al. Parental interest in a genetic risk assessment test for autism spectrum disorders. Clin Pediatr (Phila). Feb. 2013;52(2):139-46. X-5. [pmid: 23193169].
2342 Narzisi A, Colombi C, Balottin U, et al. Non- Pharmacological Treatments in Autism Spectrum Disorders: An Overview on Early Interventions for Pre-schoolers. Curr Clin Pharmacol. 2013. Sep. 20. X-2. [pmid: 24050743].
2343 Neal D, Matson JL, Belva BC. An examination of the reliability of a new observation measure for Autism spectrum disorders: The autism spectrum disorder observation for children. Research in Autism Spectrum Disorders. 2013;7(1):29-34. X-5.
2344 Neece CL. Mindfulness-Based Stress Reduction for Parents of Young Children with Developmental Delays: Implications for Parental Mental Health and Child Behavior Problems. J Appl Res Intellect Disabil. 2013. Jul. 1. X-1, X-4. [pmid: 23813562].
2345 Neuhaus E, Bernier R, Beauchaine TP. Brief Report: Social Skills, Internalizing and Externalizing Symptoms, and Respiratory Sinus Arrhythmia in Autism. J Autism Dev Disord. 2013. Aug. 28. X-5. [pmid: 23982488].
2346 Neumeyer AM, Gates A, Ferrone C, et al. Bone density in peripubertal boys with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2013;43(7):1623-9. X-5. [pmid: 23124396].
2347 Norbury CF. Practitioner Review: Social (pragmatic) communication disorder conceptualization, evidence and clinical implications. J Child Psychol Psychiatry. 2013. Oct. 9. X-5. [pmid: 24117874].
2348 Nosik MR, Williams WL, Garrido N, et al. Comparison of computer based instruction to behavior skills training for teaching staff implementation of discrete-trial instruction with an adult with autism. Res Dev Disabil. Jan. 2013;34(1):461-8. X-5. [pmid: 23041660].
2349 Nousen EK, Franco JG, Sullivan EL. Unraveling the Mechanisms Responsible for the Comorbidity between Metabolic Syndrome and Mental Health Disorders. Neuroendocrinology. 2013. Sep. 21. X-5. [pmid: 24080959].
2350 Occelli V, Esposito G, Venuti P, et al. The Takete-Maluma phenomenon in autism spectrum disorders. Perception. 2013;42(2):233-41. X-5. [pmid: 23700961].
2351 Ogletree BT, Morrow-Odom KL, Westling D. Understanding the brain-behaviour relationship in persons with ASD: Implications for PECS as a treatment choice. Dev Neurorehabil. 2013. Sep. 24. X-2, X-5. [pmid: 24063565].
2352 O'Haire ME. Animal-Assisted Intervention for Autism Spectrum Disorder: A Systematic Literature Review. Journal of Autism and Developmental Disorders. Jul. 2013. 2013;43(7):1606-22. X-5. [pmid: 23124442].
2353 O'Haire ME, McKenzie SJ, McCune S, et al. Effects of Classroom Animal-Assisted Activities on Social Functioning in Children with Autism Spectrum Disorder. J Altern Complement Med. 2013. Oct. 24. X-5. [pmid: 24156772].
2354 O'Hearn K, Franconeri S, Wright C, et al. The development of individuation in autism. J Exp Psychol Hum Percept Perform. Apr. 2013;39(2):494-509. X-5. [pmid: 22963232].
2355 Omori M, Yamamoto J. Stimulus pairing training for Kanji reading skills in students with developmental disabilities. Res Dev Disabil. Apr. 2013;34(4):1109-18. X-3, X-5. [pmid: 23357673].
2356 Onore CE, Careaga M, Babineau BA, et al. Inflammatory macrophage phenotype in BTBR T+tf/J mice. Front Neurosci. 2013;7:158. X-5. [pmid: 24062633].
2357 Oranje B, Lahuis B, van Engeland H, et al. Sensory and sensorimotor gating in children with multiple complex developmental disorders (MCDD) and autism. Psychiatry Res. Apr. 30. 2013;206(2-3):287-92. X-5. [pmid: 23164481].
2358 Orellana LM, Martinez-Sanchis S, Silvestre FJ. Training Adults and Children with an Autism Spectrum Disorder to be Compliant with a Clinical Dental Assessment Using a TEACCH-Based Approach. J Autism Dev Disord. 2013. Sep. 4. X-5. [pmid: 24002415].
2359 Ozdemir S, Tuncer U, Tarkan O, et al. Factors contributing to limited or non-use in the cochlear implant systems in children: 11 years experience. Int J Pediatr Otorhinolaryngol. Mar. 2013;77(3):407-9. X-5. [pmid: 23280278].
2360 Pahnke J, Lundgren T, Hursti T, et al. Outcomes of an acceptance and commitment therapy-based skills training group for students with high-functioning autism spectrum disorder: A quasi-experimental pilot study. Autism. 2013. Oct. 18. X-5. [pmid: 24142796].
2361 Panerai S, Tasca D, Lanuzza B, et al. Effects of repetitive transcranial magnetic stimulation in performing eye-hand integration tasks: Four preliminary studies with children showing low-functioning autism. Autism. 2013. Oct. 10. X-2, X-3, X-5. [pmid: 24113340].
2362 Pardo CA, Buckley A, Thurm A, et al. A pilot open-label trial of minocycline in patients with autism and regressive features. J Neurodev Disord. Apr. 8. 2013;5(1):9. X-5. [pmid: 23566357].
2363 Parellada M, Boada L, Moreno C, et al. Specialty care programme for autism spectrum disorders in an urban population: A case-management model for health care delivery in an ASD population. European Psychiatry. 2013;28(2):102-9. X-5. [pmid: 21907549].
2364 Parenteau RE, Luiselli JK, Keeley M. Direct and collateral effects of staff-worn protective equipment on injury prevention from child aggression. Dev Neurorehabil. 2013;16(1):73-7. X-5. [pmid: 23249373].
2365 Park DH, Lim S, Park ES, et al. A nine-month-old boy with isodicentric chromosome 15: a case report. Ann Rehabil Med. Apr. 2013;37(2):291-4. X-5. [pmid: 23705128].
2366 Park S, Park M-H, Kim HJ, et al. Anxiety and Depression Symptoms in Children with Asperger Syndrome Compared with Attention-Deficit/Hyperactivity Disorder and Depressive Disorder. Journal of Child and Family Studies. 2013;22(4):559-68. X-5.
2367 Pascoe JM. Foreword. Curr Probl Pediatr Adolesc Health Care. Jan. 2013;43(1):1. X-5. [pmid: 23332396].
2368 Pasquali M, Schwarz E, Jensen M, et al. Feasibility of newborn screening for guanidinoacetate methyltransferase (GAMT) deficiency. J Inherit Metab Dis. 2013. Nov. 26. X-5. [pmid: 24276113].
2369 Pasterski V, Gilligan L, Curtis R. Traits of Autism Spectrum Disorders in Adults with Gender Dysphoria. Arch Sex Behav. 2013. Jul. 18. X-5. [pmid: 23864402].
2370 Patten E, Baranek GT, Watson LR, et al. Child and family characteristics influencing intervention choices in autism spectrum disorders. Focus on Autism and Other Developmental Disabilities. 2013;28(3):138-46. X-5. [pmid: 24089593].
2371 Paul R, Campbell D, Gilbert K, et al. Comparing Spoken Language Treatments for Minimally Verbal Preschoolers with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2013;43(2):418-31. X-5. [pmid: 22733301].
2372 Pavone P, Striano P, Falsaperla R, et al. Infantile spasms syndrome, West syndrome and related phenotypes: What we know in 2013. Brain Dev. 2013. Nov. 19. X-5. [pmid: 24268986].
2373 Pearson DA, Santos CW, Aman MG, et al. Effects of extended release methylphenidate treatment on ratings of attention-deficit/hyperactivity disorder (ADHD) and associated behavior in children with autism spectrum disorders and ADHD symptoms. Journal of Child and Adolescent Psychopharmacology. 2013;23(5):337-51. X-5. [pmid: 23782128].
2374 Pedersen L, Parlar S, Kvist K, et al. Data mining the ScanBrit study of a gluten- and casein-free dietary intervention for children with autism spectrum disorders: Behavioural and psychometric measures of dietary response. Nutr Neurosci. 2013. Sep. 7. X-5. [pmid: 24075141].
2375 Penjweini R, Loew HG, Eisenbauer M, et al. Modifying excitation light dose of novel photosensitizer PVP-Hypericin for photodynamic diagnosis and therapy. J Photochem Photobiol B. Mar. 5. 2013;120:120-9. X-5. [pmid: 23375215].
2376 Perou R, Bitsko RH, Blumberg SJ, et al. Mental health surveillance among children--United States, 2005-2011. MMWR Surveill Summ. May. 17. 2013;62(Suppl 2):1-35. X-5. [pmid: 23677130].
2377 Persicke A, Tarbox J, Ranick J, et al. Teaching children with autism to detect and respond to sarcasm. Research in Autism Spectrum Disorders. 2013;7(1):193-8. X-3.
2378 Perumal N, Balan N, Stanfield A. Psychopharmacology in children with intellectual disability and autism—A cross-sectional analysis (2010). International Journal of Developmental Disabilities. 2013;59(1):11-9. X-5.
2379 Peters B, Williams KC, Gorrindo P, et al. Rigid-Compulsive Behaviors are Associated with Mixed Bowel Symptoms in Autism Spectrum Disorder. J Autism Dev Disord. 2013. Nov. 29. X-5. [pmid: 24293040].
2380 Peters LC, Thompson RH. Some indirect effects of positive practice overcorrection. Journal of Applied Behavior Analysis. 2013;46(3):613-25. X-5. [pmid: 24114224].
2381 Pettygrove S, Pinborough-Zimmerman J, John Meaney F, et al. Predictors of ascertainment of autism spectrum disorders across nine US communities. Journal of Autism and Developmental Disorders. 2013;43(8):1867-79. X-5. [pmid: 23239097].
2382 Plumb AM, Plexico LW. Autism spectrum disorders: experience, training, and confidence levels of school-based speech-language pathologists. Lang Speech Hear Serv Sch. Jan. 2013;44(1):89-104. X-5. [pmid: 23087159].
2383 Politte LC, McDougle CJ. Atypical antipsychotics in the treatment of children and adolescents with pervasive developmental disorders. Psychopharmacology (Berl). 2013. Apr. 4. X-2. [pmid: 23552907].
2384 Polo-Kantola P, Lampi KM, Hinkka-Yli-Salomaki S, et al. Obstetric Risk Factors and Autism Spectrum Disorders in Finland. J Pediatr. 2013. Oct. 30. X-5. [pmid: 24183209].
2385 Poon KK, Koh L, Magiati I. Parental Perspectives on the Importance and Likelihood of Adult Outcomes for Children with Autism Spectrum Disorders, Intellectual Disabilities or Multiple Disabilities. Research in Autism Spectrum Disorders. February. 2013. 2013;7(2):382-90. X-5.
2386 Poot M. Towards identification of individual etiologies by resolving genomic and biological conundrums in patients with autism spectrum disorders. Mol Syndromol. Jun. 2013;4(5):213-26. X-5. [pmid: 23885228].
2387 Pop AS, Gomez-Mancilla B, Neri G, et al. Fragile X syndrome: a preclinical review on metabotropic glutamate receptor 5 (mGluR5) antagonists and drug development. Psychopharmacology (Berl). 2013. Nov. 15. X-5. [pmid: 24232444].
2388 Post SG, Pomeroy J, Keirns CC, et al. Brief report: Stony Brook Guidelines on the ethics of the care of people with autism and their families. Journal of Autism and Developmental Disorders. 2013;43(6):1473-6. X-5. [pmid: 23086685].
2389 Potter JN, Hanley GP, Augustine M, et al. Treating stereotypy in adolescents diagnosed with autism by refining the tactic of “using stereotypy as reinforcement”. Journal of Applied Behavior Analysis. 2013;46(2):407-23. X-5. [pmid: 24114156].
2390 Poustka L, Brandeis D, Hohmann S, et al. Neurobiologically based interventions for autism spectrum disorders-rationale and new directions. Restor Neurol Neurosci. 2013. Apr. 17. X-1, X-2, X-3, X-4. [pmid: 23603445].
2391 Pugliese CE, White SW. Brief Report: Problem Solving Therapy in College Students with Autism Spectrum Disorders: Feasibility and Preliminary Efficacy. J Autism Dev Disord. 2013. Aug. 21. X-5. [pmid: 23963592].
2392 Qiao J, Gao J, Shu Q, et al. Long-lasting sensitization induced by repeated risperidone treatment in adolescent Sprague-Dawley rats: a possible D receptor mediated phenomenon?. Psychopharmacology (Berl). 2013. Dec. 21. X-5. [pmid: 24363078].
2393 Rada RE. Treatment needs and adverse events related to dental treatment under general anesthesia for Individuals with autism. Intellectual and Developmental Disabilities. 2013;51(4):246-52. X-5. [pmid: 23909586].
2394 Radonovich KJ, Fournier KA, Hass CJ. Relationship between postural control and restricted, repetitive behaviors in autism spectrum disorders. Front Integr Neurosci. 2013;7:28. X-5. [pmid: 23675326].
2395 Radulescu E, Minati L, Ganeshan B, et al. Abnormalities in fronto-striatal connectivity within language networks relate to differences in grey-matter heterogeneity in Asperger syndrome. Neuroimage Clin. 2013;2:716-26. X-5. [pmid: 24179823].
2396 Rafferty A, Martin J, Strachan D, et al. Cochlear implantation in children with complex needs - outcomes. Cochlear Implants Int. Mar. 2013;14(2):61-6. X-3, X-4. [pmid: 22333941].
2397 Rai D, Lee BK, Dalman C, et al. Parental depression, maternal antidepressant use during pregnancy, and risk of autism spectrum disorders: population based case-control study. BMJ. 2013;346:f2059. X-5. [pmid: 23604083].
2398 Ramaekers VT, Quadros EV, Sequeira JM. Role of folate receptor autoantibodies in infantile autism. Molecular Psychiatry. 2013;18(3):270-1. X-5. [pmid: 22488256].
2399 Ramirez PL, Barnhill K, Gutierrez A, et al. Improvements in Behavioral Symptoms following Antibiotic Therapy in a 14-Year-Old Male with Autism. Case Rep Psychiatry. 2013;2013:239034. X-5. [pmid: 23853732].
2400 Ramsey JM, Guest PC, Broek JA, et al. Identification of an age-dependent biomarker signature in children and adolescents with autism spectrum disorders. Mol Autism. 2013;4(1):27. X-5. [pmid: 23915542].
2401 Ranick J, Persicke A, Tarbox J, et al. Teaching children with autism to detect and respond to deceptive statements. Research in Autism Spectrum Disorders. 2013;7(4):503-8. X-3.
2402 Ravindran N, Myers BJ. Beliefs and Practices Regarding Autism in Indian Families Now Settled Abroad: An Internet Survey. Focus on Autism and Other Developmental Disabilities. March. 2013. 2013;28(1):44-53. X-5.
2403 Raz R, Lerner-Geva L, Leon O, et al. A survey of out-of-pocket expenditures for children with autism spectrum disorder in Israel. Journal of Autism and Developmental Disorders. 2013;43(10):2295-302. X-5. [pmid: 23381487].
2404 Redhair EI, McCoy KM, Zucker SH, et al. Identification of printed nonsense words for an individual with autism: A comparison of constant time delay and stimulus fading. Education and Training in Autism and Developmental Disabilities. 2013;48(3):351-62. X-3.
2405 Reeves GM, Keeton C, Correll CU, et al. Improving metabolic parameters of antipsychotic child treatment (IMPACT) study: rationale, design, and methods. Child Adolesc Psychiatry Ment Health. 2013;7(1):31. X-1, X-2, X-3, X-4. [pmid: 23947389].
2406 Reichow B, Volkmar FR, Bloch MH. Systematic Review and Meta-analysis of Pharmacological Treatment of the Symptoms of Attention-Deficit/Hyperactivity Disorder in Children with Pervasive Developmental Disorders. J Autism Dev Disord. 2013. Mar. 7. X-5. [pmid: 23468071].
2407 Renzi C, Schiavi S, Carbon CC, et al. Processing of featural and configural aspects of faces is lateralized in dorsolateral prefrontal cortex: a TMS study. Neuroimage. Jul. 1. 2013;74:45-51. X-5. [pmid: 23435211].
2408 Reser JE. Solitary Mammals Provide an Animal Model for Autism Spectrum Disorders. J Comp Psychol. 2013. Nov. 4. X-5. [pmid: 24188618].
2409 Reszka SS, Boyd BA, McBee M, et al. Brief Report: Concurrent Validity of Autism Symptom Severity Measures. J Autism Dev Disord. 2013. Jun. 27. X-5. [pmid: 23807205].
2410 Rieger A, McGrail JP. Coping humor and family functioning in parents of children with disabilities. Rehabil Psychol. Feb. 2013;58(1):89-97. X-5. [pmid: 23438005].
2411 Rieske RD, Matson JL, Davis TE 3rd, et al. Examination and validation of a measure of anxiety specific to children with autism spectrum disorders. Dev Neurorehabil. 2013;16(1):9-16. X-5. [pmid: 23030738].
2412 Rispoli M, Lang R, Neely L, et al. A Comparison of within- and across-Activity Choices for Reducing Challenging Behavior in Children with Autism Spectrum Disorders. Journal of Behavioral Education. 2013;22(1):66-83. X-3.
2413 Robertson RE, Wehby JH, King SM. Increased parent reinforcement of spontaneous requests in children with autism spectrum disorder: effects on problem behavior. Res Dev Disabil. Mar. 2013;34(3):1069-82. X-3, X-5. [pmid: 23299185].
2414 Robins DL, Casagrande K, Barton M, et al. Validation of the Modified Checklist for Autism in Toddlers, Revised With Follow-up (M-CHAT-R/F). Pediatrics. 2013. Dec. 23. X-5. [pmid: 24366990].
2415 Rossignol DA. My experience learning about autism. Glob Adv Health Med. Nov. 2013;2(6):74-7. X-5. [pmid: 24349885].
2416 Rossignol DA, Frye RE. Melatonin in Autism Spectrum Disorders. Curr Clin Pharmacol. 2013. Sep. 20. X-6. [pmid: 24050742].
2417 Roux G, Sofronoff K, Sanders M. A randomized controlled trial of group Stepping Stones Triple P: A mixed-disability trial. Family Process. 2013;52(3):411-24. X-3, X-4. [pmid: 24033239].
2418 Rubin DH, Althoff RR, Ehli EA, et al. Candidate gene associations with withdrawn behavior. J Child Psychol Psychiatry. Dec. 2013;54(12):1337-45. X-5. [pmid: 23808549].
2419 Ruble LA, McGrew JH, Toland MD, et al. A Randomized Controlled Trial of Compass Web-Based and Face-to-Face Teacher Coaching in Autism. Journal of Consulting and Clinical Psychology. June. 2013. 2013;81(3):566-72. X-5. [pmid: 23438314].
2420 Ruggeri B, Sarkans U, Schumann G, et al. Biomarkers in autism spectrum disorder: the old and the new. Psychopharmacology (Berl). 2013. Oct. 6. X-5. [pmid: 24096533].
2421 Russell AJ, Jassi A, Fullana MA, et al. Cognitive behavior therapy for comorbid obsessive-compulsive disorder in high-functioning autism spectrum disorders: A randomized controlled trial. Depression and Anxiety. 2013;30(8):697-708. X-5. [pmid: 23389964].
2422 Saemundsen E, Magnusson P, Georgsdottir I, et al. Prevalence of autism spectrum disorders in an Icelandic birth cohort. BMJ Open. 2013;3(6). X-5. [pmid: 23788511].
2423 Sahu JK, Gulati S, Sapra S, et al. Effectiveness and safety of donepezil in boys with fragile x syndrome: a double-blind, randomized, controlled pilot study. J Child Neurol. May. 2013;28(5):570-5. X-5. [pmid: 22752489].
2424 Samadi SA, McConkey R, Kelly G. Enhancing parental well-being and coping through a family-centred short course for Iranian parents of children with an autism spectrum disorder. Autism. Jan. 2013;17(1):27-43. X-5. [pmid: 22297201].
2425 Sandell C, Kjellberg A, Taylor RR. Participating in diagnostic experience: adults with neuropsychiatric disorders. Scand J Occup Ther. Mar. 2013;20(2):136-42. X-5. [pmid: 23152985].
2426 Sandiford GA, Mainess KJ, Daher NS. A Pilot Study on the Efficacy of Melodic Based Communication Therapy for Eliciting Speech in Nonverbal Children with Autism. Journal of Autism and Developmental Disorders. June. 2013. 2013;43(6):1298-307. X-5. [pmid: 23065117].
2427 Sandin S, Nygren KG, Iliadou A, et al. Autism and mental retardation among offspring born after in vitro fertilization. JAMA. Jul. 3. 2013;310(1):75-84. X-5. [pmid: 23821091].
2428 Santoleri F, Sorice P, Lasala R, et al. Patient adherence and persistence with Imatinib, Nilotinib, Dasatinib in clinical practice. PLoS One. 2013;8(2):e56813. X-5. [pmid: 23437249].
2429 Sappok T, Budczies J, Dziobek I, et al. The Missing Link: Delayed Emotional Development Predicts Challenging Behavior in Adults with Intellectual Disability. J Autism Dev Disord. 2013. Sep. 4. X-5. [pmid: 24002416].
2430 Sappok T, Diefenbacher A, Budczies J, et al. Diagnosing Autism in a Clinical Sample of Adults with Intellectual Disabilities: How Useful Are the “ADOS” and the “ADI-R”?. Research in Developmental Disabilities: A Multidisciplinary Journal. May. 2013. 2013;34(5):1642-55. X-5.
2431 Scahill L, Aman MG, Lecavalier L, et al. Measuring repetitive behaviors as a treatment endpoint in youth with autism spectrum disorder. Autism. 2013. Nov. 20. X-5. [pmid: 24259748].
2432 Scahill L, Hallett V, Aman MG, et al. Brief Report: social disability in autism spectrum disorder: results from Research Units on Pediatric Psychopharmacology (RUPP) Autism Network trials. J Autism Dev Disord. Mar. 2013;43(3):739-46. X-4. [pmid: 23104617].
2433 Schaaf RC, Benevides T, Mailloux Z, et al. An Intervention for Sensory Difficulties in Children with Autism: A Randomized Trial. J Autism Dev Disord. 2013. Nov. 10. X-5. [pmid: 24214165].
2434 Schaaf RC, Benevides TW, Leiby BE, et al. Autonomic Dysregulation During Sensory Stimulation in Children with Autism Spectrum Disorder. J Autism Dev Disord. 2013. Aug. 31. X-5. [pmid: 23996198].
2435 Schafer EC, Mathews L, Mehta S, et al. Personal FM systems for children with autism spectrum disorders (ASD) and/or attention-deficit hyperactivity disorder (ADHD): an initial investigation. J Commun Disord. Jan. 2013;46(1):30-52. X-3. [pmid: 23123089].
2436 Schmidt JD, Luiselli JK, Rue H, et al. Graduated exposure and positive reinforcement to overcome setting and activity avoidance in an adolescent with autism. Behavior Modification. 2013;37(1):128-42. X-5. [pmid: 22987915].
2437 Schmunk G, Gargus JJ. Channelopathy pathogenesis in autism spectrum disorders. Front Genet. 2013;4:222. X-5. [pmid: 24204377].
2438 Schneider AB, Codding RS, Tryon GS. Comparing and Combining Accommodation and Remediation Interventions to Improve the Written-Language Performance of Children with Asperger Syndrome. Focus on Autism and Other Developmental Disabilities. June. 2013. 2013;28(2):101-14. X-3.
2439 Schohl KA, Van Hecke AV, Carson AM, et al. A Replication and Extension of the PEERS Intervention: Examining Effects on Social Skills and Social Anxiety in Adolescents with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jul. 27. X-1, X-3. [pmid: 23893101].
2440 Schubart JR, Camacho F, Leslie D. Psychotropic medication trends among children and adolescents with autism spectrum disorder in the Medicaid program. Autism. 2013. Oct. 28. X-5. [pmid: 24165274].
2441 Schwartzberg ET, Silverman MJ. Effects of music-based social stories on comprehension and generalization of social skills in children with autism spectrum disorders: A randomized effectiveness study. The Arts in Psychotherapy. 2013;40(3):331-7. X-1, X-3.
2442 Sears KM, Blair K-SC, Iovannone R, et al. Using the prevent-teach-reinforce model with families of young children with ASD. Journal of Autism and Developmental Disorders. 2013;43(5):1005-16. X-3, X-4. [pmid: 22972500].
2443 Sellers TP, Bloom SE, Samaha AL, et al. Evaluation of some components of choice making. Journal of Applied Behavior Analysis. 2013;46(2):455-64. X-3. [pmid: 24114160].
2444 Sharma A, Gokulchandran N, Sane H, et al. Autologous bone marrow mononuclear cell therapy for autism: an open label proof of concept study. Stem Cells Int. 2013;2013:623875. X-1. [pmid: 24062774].
2445 Sharma S, Woolfson LM, Hunter SC. Maladaptive cognitive appraisals in children with high-functioning autism: Associations with fear, anxiety and theory of mind. Autism. 2013. Oct. 3. X-5. [pmid: 24092841].
2446 Sharp WG, Jaquess DL, Lukens CT. Multi-Method Assessment of Feeding Problems among Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. January. 2013. 2013;7(1):56-65. X-5.
2447 Shrestha A, Anderson A, Moore DW. Using Point-of-View Video Modeling and Forward Chaining to Teach a Functional Self-Help Skill to a Child with Autism. Journal of Behavioral Education. June. 2013. 2013;22(2):157-67. X-3.
2448 Shrestha M, Shrestha R. Symptom Recognition to Diagnosis of Autism in Nepal. J Autism Dev Disord. 2013. Nov. 29. X-5. [pmid: 24293038].
2449 Siller M, Reyes N, Hotez E, et al. Longitudinal change in the use of services in autism spectrum disorder: Understanding the role of child characteristics, family demographics, and parent cognitions. Autism. 2013. Oct. 9. X-5. [pmid: 24108191].
2450 Silva L, Schalock M. Treatment of tactile impairment in young children with autism: results with qigong massage. Int J Ther Massage Bodywork. 2013;6(4):12-20. X-5. [pmid: 24298297].
2451 Silverman JL, Crawley JN. The promising trajectory of autism therapeutics discovery. Drug Discov Today. 2013. Dec. 18. X-5. [pmid: 24362109].
2452 Simonoff E, Taylor E, Baird G, et al. Randomized controlled double-blind trial of optimal dose methylphenidate in children and adolescents with severe attention deficit hyperactivity disorder and intellectual disability. J Child Psychol Psychiatry. May. 2013;54(5):527-35. X-1, X-3, X-4. [pmid: 22676856].
2453 Simo-Pinatella D, Font-Roura J, Planella-Morato J, et al. Types of Motivating Operations in Interventions with Problem Behavior: A Systematic Review. Behavior Modification. January. 2013. 2013;37(1):3-38. X-4. [pmid: 22798637].
2454 Simpson W, Brown C, Nisbet N, et al. Innovations in Practice: A new model of autism spectrum disorder assessment and diagnosis by multiagency community-based teams in primary schools. Child and Adolescent Mental Health. 2013;18(3):187-90. X-5.
2455 Siniscalco D, Bradstreet JJ, Sych N, et al. Perspectives on the Use of Stem Cells for Autism Treatment. Stem Cells Int. 2013;2013:262438. X-5. [pmid: 24222772].
2456 Skotko BG, Davidson EJ, Weintraub GS. Contributions of a specialty clinic for children and adolescents with Down syndrome. Am J Med Genet A. Mar. 2013;161A(3):430-7. X-5. [pmid: 23401090].
2457 Smile S, Dupuis A, MacArthur C, et al. Autism Spectrum Disorder Phenotype in Children with Ambulatory Cerebral Palsy: A Descriptive Cross-Sectional Study. Research in Autism Spectrum Disorders. February. 2013. 2013;7(2):391-7. X-5.
2458 Smith J, Hand L, Dowrick PW. Video Feedforward for Rapid Learning of a Picture-Based Communication System. J Autism Dev Disord. 2013. Sep. 26. X-3. [pmid: 24068486].
2459 Sofronoff K, Lee J, Sheffield J, et al. The construction and evaluation of three measures of affectionate behaviour for children with Asperger's syndrome. Autism. 2013. Dec. 16. X-5. [pmid: 24343335].
2460 Solomon M, Yoon JH, Ragland JD, et al. The Development of the Neural Substrates of Cognitive Control in Adolescents with Autism Spectrum Disorders. Biol Psychiatry. 2013. Oct. 24. X-5. [pmid: 24209777].
2461 Solomon O, Lawlor MC. “And I look down and he is gone”: Narrating autism, elopement and wandering in Los Angeles. Social Science & Medicine. 2013;94:106-14. X-5. [pmid: 23890970].
2462 Song Z, Giannotti T, Reichow B. Resources and services for children with autism spectrum disorders and their families in China. Infants & Young Children. 2013;26(3):204-12. X-5.
2463 Soorya L, Kolevzon A, Zweifach J, et al. Prospective investigation of autism and genotype-phenotype correlations in 22q13 deletion syndrome and SHANK3 deficiency. Mol Autism. 2013;4(1):18. X-5. [pmid: 23758760].
2464 Spek AA, van Ham NC, Nyklicek I. Mindfulness-based therapy in adults with an autism spectrum disorder: a randomized controlled trial. Res Dev Disabil. Jan. 2013;34(1):246-53. X-5. [pmid: 22964266].
2465 Spoladore A. A Young Boy Grows Away from Autism. Journal of Child Psychotherapy. 2013;39(1):22-38. X-5.
2466 Sprinkle EC, Miguel CF. Establishing derived textual activity schedules in children with autism. Behavioral Interventions. 2013;28(3):185-202. X-3, X-5.
2467 Srinivasan SM, Bhat AN. A review of “music and movement” therapies for children with autism: embodied interventions for multisystem development. Front Integr Neurosci. 2013;7:22. X-1, X-2, X-3, X-4. [pmid: 23576962].
2468 Stadnick NA, Drahota A, Brookman-Frazee L. Parent Perspectives of an Evidence-Based Intervention for Children with Autism Served in Community Mental Health Clinics. Journal of Child and Family Studies. 2013;22(3):414-22. X-1, X-3, X-4. [pmid: 24019736].
2469 Stefansson H, Meyer-Lindenberg A, Steinberg S, et al. CNVs conferring risk of autism or schizophrenia affect cognition in controls. Nature. 2013. Dec. 18. X-5. [pmid: 24352232].
2470 Stein JL, Parikshak NN, Geschwind DH. Rare inherited variation in autism: beginning to see the forest and a few trees. Neuron. Jan. 23. 2013;77(2):209-11. X-5. [pmid: 23352155].
2471 Stein TP, Schluter MD, Steer RA, et al. Autism and phthalate metabolite glucuronidation. Journal of Autism and Developmental Disorders. 2013;43(11):2677-85. X-5. [pmid: 23575644].
2472 Steiner AM, Gengoux GW, Klin A, et al. Pivotal response treatment for infants at-risk for autism spectrum disorders: a pilot study. J Autism Dev Disord. Jan. 2013;43(1):91-102. X-3. [pmid: 22573001].
2473 Sterling AM, Mailick M, Greenberg J, et al. Language Dysfluencies in Females with the “FMR1” Premutation. Brain and Cognition. June. 2013. 2013;82(1):84-9. X-5. [pmid: 23523717].
2474 Stevenson RA, Wallace MT. Multisensory temporal integration: task and stimulus dependencies. Exp Brain Res. Jun. 2013;227(2):249-61. X-5. [pmid: 23604624].
2475 Stichter JP, Laffey J, Galyen K, et al. iSocial: Delivering the Social Competence Intervention for Adolescents (SCI-A) in a 3D Virtual Learning Environment for Youth with High Functioning Autism. J Autism Dev Disord. 2013. Jun. 28. X-1, X-3. [pmid: 23812663].
2476 Stockler-Ipsiroglu S, van Karnebeek C, Longo N, et al. Guanidinoacetate methyltransferase (GAMT) deficiency: Outcomes in 48 individuals and recommendations for diagnosis, treatment and monitoring. Mol Genet Metab. 2013. Nov. 7. X-1, X-2, X-3, X-4. [pmid: 24268530].
2477 Stoppelbein L, Greening L, Luebbe A, et al. The role of cortisol and psychopathic traits in aggression among at-risk girls: Tests of mediating hypotheses. Aggress Behav. 2013. Dec. 2. X-5. [pmid: 24302544].
2478 Strickland DC, Coles CD, Southern LB. JobTIPS: A transition to employment program for individuals with autism spectrum disorders. Journal of Autism and Developmental Disorders. 2013;43(10):2472-83. X-5. [pmid: 23494559].
2479 Sukhodolsky DG, Bloch MH, Panza KE, et al. Cognitive-Behavioral Therapy for Anxiety in Children With High-Functioning Autism: A Meta-analysis. Pediatrics. Nov. 2013;132(5):e1341-50. X-5. [pmid: 24167175].
2480 Sun X, Allison C, Auyeung B, et al. A Review of Healthcare Service and Education Provision of Autism Spectrum Condition in Mainland China. Research in Developmental Disabilities: A Multidisciplinary Journal. January. 2013. 2013;34(1):469-79. X-5.
2481 Sun X, Allison C, Auyeung B, et al. Service provision for autism in mainland China: A service providers' perspective. Research in Developmental Disabilities. 2013;34(1):440-51. X-5. [pmid: 23041658].
2482 Suren P, Roth C, Bresnahan M, et al. Association between maternal use of folic acid supplements and risk of autism spectrum disorders in children. JAMA. Feb. 13. 2013;309(6):570-7. X-5. [pmid: 23403681].
2483 Surette S, Vanderjagt L, Vohra S. Surveys of complementary and alternative medicine usage: a scoping study of the paediatric literature. Complement Ther Med. Apr. 2013;21(Suppl 1):S48-53. X-2, X-5. [pmid: 23578917].
2484 Sutterland AL, Dieleman J, Storosum JG, et al. Annual incidence rate of schizophrenia and schizophrenia spectrum disorders in a longitudinal population-based cohort study. Social Psychiatry and Psychiatric Epidemiology. 2013;48(9):1357-65. X-5. [pmid: 23340770].
2485 Sutton LR, Hughes TL, Huang A, et al. Identifying individuals with autism in a state facility for adolescents adjudicated as sexual offenders: A pilot study. Focus on Autism and Other Developmental Disabilities. 2013;28(3):175-83. X-5.
2486 Swanson AR, Warren ZE, Stone WL, et al. The diagnosis of autism in community pediatric settings: Does advanced training facilitate practice change?. Autism. 2013. Jul. 11. X-5. [pmid: 23847130].
2487 Tachibana M, Kagitani-Shimono K, Mohri I, et al. Long-term administration of intranasal oxytocin is a safe and promising therapy for early adolescent boys with autism spectrum disorders. Journal of Child and Adolescent Psychopharmacology. 2013;23(2):123-7. X-3. [pmid: 23480321].
2488 Taubman MT, Leaf RB, McEachin JJ, et al. A comparison of data collection techniques used with discrete trial teaching. Research in Autism Spectrum Disorders. 2013;7(9):1026-34. X-3.
2489 Taylor LJ, Maybery MT, Whitehouse AJ. Moving beyond behaviour-only assessment: Incorporating biomarkers to improve the early detection and diagnosis of autism spectrum disorders. Int J Speech Lang Pathol. 2013. Nov. 18. X-5. [pmid: 24236911].
2490 Tchanturia K, Smith E, Weineck F, et al. Exploring autistic traits in anorexia: a clinical study. Mol Autism. Nov. 12. 2013;4(1):44. X-5. [pmid: 24220604].
2491 Thapar A, Cooper M, Eyre O, et al. Practitioner Review: What Have We Learnt about the Causes of ADHD?. Journal of Child Psychology and Psychiatry. 2013;54(1):3-16. X-5. [pmid: 22963644].
2492 Thompson GA, McFerran KS, Gold C. Family-centred music therapy to promote social engagement in young children with severe autism spectrum disorder: a randomized controlled study. Child Care Health Dev. 2013. Nov. 22. X-5. [pmid: 24261547].
2493 Tostanoski A, Lang R, Raulston T, et al. Voices from the past: Comparing the rapid prompting method and facilitated communication. Dev Neurorehabil. 2013. Oct. 8. X-2, X-5. [pmid: 24102487].
2494 Towle PO, Vacanti-Shova K, Shah S, et al. School-Aged Functioning of Children Diagnosed with Autism Spectrum Disorder Before Age Three: Parent-Reported Diagnostic, Adaptive, Medication, and School Placement Outcomes. J Autism Dev Disord. 2013. Dec. 18. X-5. [pmid: 24346492].
2495 Travers JC, Tincani M, Krezmien MP. A Multiyear National Profile of Racial Disparity in Autism Identification. Journal of Special Education. 2013;47(1):41-9. X-5.
2496 Treasure J. Coherence and other autistic spectrum traits and eating disorders: building from mechanism to treatment. The Birgit Olsson lecture. Nord J Psychiatry. Feb. 2013;67(1):38-42. X-5. [pmid: 22468644].
2497 Trembath D, Vivanti G. Problematic but predictive: Individual differences in children with autism spectrum disorders. Int J Speech Lang Pathol. 2013. Dec. 18. X-2, X-5. [pmid: 24345003].
2498 Trevarthen C, Delafield-Butt JT. Autism as a developmental disorder in intentional movement and affective engagement. Front Integr Neurosci. 2013;7:49. X-5. [pmid: 23882192].
2499 Tsiouris JA, Kim S-Y, Brown TW, et al. Prevalence of Psychotropic Drug Use in Adults with Intellectual Disability: Positive and Negative Findings from a Large Scale Study. Journal of Autism and Developmental Disorders. 2013;43(3):719-31. X-5. [pmid: 22829245].
2500 Tureck K, Matson JL, Turygin N, et al. Rates of psychotropic medication use in children with ASD compared to presence and severity of problem behaviors. Research in Autism Spectrum Disorders. 2013;7(11):1377-82. X-1, X-4.
2501 Turygin N, Matson JL, Tureck K. The relationship of attention-deficit hyperactivity disorder and autism spectrum disorder to adaptive skills in young children. Dev Neurorehabil. 2013. Dec. 4. X-5. [pmid: 24303981].
2502 Ung D, Wood JJ, Ehrenreich-May J, et al. Clinical characteristics of high-functioning youth with autism spectrum disorder and anxiety. Neuropsychiatry (London). Apr. 2013;3(2). X-5. [pmid: 24179485].
2503 Vaiouli P, Grimmet K, Ruich LJ. “Bill is now singing”: Joint engagement and the emergence of social communication of three young children with autism. Autism. 2013. Nov. 19. X-3. [pmid: 24254638].
2504 van der Meer L, Kagohara D, Roche L, et al. Teaching multi-step requesting and social communication to two children with autism spectrum disorders with three AAC options. AAC: Augmentative and Alternative Communication. 2013;29(3):222-34. X-3.
2505 van Gelder MM, Bretveld RW, Roukema J, et al. Rationale and design of the PRegnancy and Infant DEvelopment (PRIDE) Study. Paediatr Perinat Epidemiol. Jan. 2013;27(1):34-43. X-5. [pmid: 23215710].
2506 Van Hecke AV, Stevens S, Carson AM, et al. Measuring the Plasticity of Social Approach: A Randomized Controlled Trial of the Effects of the PEERS Intervention on EEG Asymmetry in Adolescents with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jun. 28. X-1, X-3. [pmid: 23812665].
2507 van Steensel FJ, Bogels SM, de Bruin EI. Psychiatric Comorbidity in Children with Autism Spectrum Disorders: A Comparison with Children with ADHD. Journal of Child and Family Studies. 2013;22(3):368-76. X-5. [pmid: 23524401].
2508 Vandermeer J, Beamish W, Milford T, et al. iPad-presented social stories for young children with autism. Dev Neurorehabil. 2013. Jul. 1. X-3. [pmid: 23815083].
2509 Vannucchi G, Masi G, Toni C, et al. Clinical features, developmental course, and psychiatric comorbidity of adult autism spectrum disorders. CNS Spectr. Dec. 2013;19:1-8. X-5. [pmid: 24352005].
2510 Vaz I. Visual symbols in healthcare settings for children with learning disabilities and autism spectrum disorder. Br J Nurs. Feb. 14-28. 2013;22(3):156-9. X-5. [pmid: 23411823].
2511 Veiby G, Daltveit AK, Schjolberg S, et al. Exposure to antiepileptic drugs in utero and child development: a prospective population-based study. Epilepsia. Aug. 2013;54(8):1462-72. X-5. [pmid: 23865818].
2512 Verpelli C, Galimberti I, Gomez-Mancilla B, et al. Molecular basis for prospective pharmacological treatment strategies in intellectual disability syndromes. Dev Neurobiol. 2013. May. 22. X-5. [pmid: 23695997].
2513 Vicario CM, Nitsche MA. Non-invasive brain stimulation for the treatment of brain diseases in childhood and adolescence: state of the art, current limits and future challenges. Front Syst Neurosci. 2013;7:94. X-5. [pmid: 24324410].
2514 Virues-Ortega J, Rodríguez V, Yu CT. Prediction of treatment outcomes and longitudinal analysis in children with autism undergoing intensive behavioral intervention. International Journal of Clinical and Health Psychology. 2013;13(2):91-100. X-5.
2515 Vismara LA, Young GS, Rogers SJ. Community Dissemination of the Early Start Denver Model: Implications for Science and Practice. Topics in Early Childhood Special Education. 2013;32(4):223-33. X-1, X-3, X-4.
2516 Visser JC, Rommelse N, Vink L, et al. Narrowly versus broadly defined autism spectrum disorders: differences in pre- and perinatal risk factors. J Autism Dev Disord. Jul. 2013;43(7):1505-16. X-5. [pmid: 23076505].
2517 Vivanti G, Dissanayake C, Zierhut C, et al. Brief report: Predictors of outcomes in the Early Start Denver Model delivered in a group setting. J Autism Dev Disord. Jul. 2013;43(7):1717-24. X-5. [pmid: 23124361].
2518 Volkmar FR, Reichow B. Infants and toddlers with autism: The promise and the challenges. Int J Speech Lang Pathol. 2013. Dec. 18. X-2, X-5. [pmid: 24345000].
2519 Voos AC, Pelphrey KA, Tirrell J, et al. Neural mechanisms of improvements in social motivation after pivotal response treatment: Two case studies. Journal of Autism and Developmental Disorders. 2013;43(1):1-10. X-3. [pmid: 23104615].
2520 Wainer AL, Ingersoll BR. Disseminating ASD interventions: a pilot study of a distance learning program for parents and professionals. J Autism Dev Disord. Jan. 2013;43(1):11-24. X-3. [pmid: 22547028].
2521 Wake R, Miyaoka T, Inagaki T, et al. Yokukansan (TJ-54) for irritability associated with pervasive developmental disorder in children and adolescents: A 12-week prospective, open-label study. Journal of Child and Adolescent Psychopharmacology. 2013;23(5):329-36. X-1. [pmid: 23782127].
2522 Walsh S, Horgan J, May RJ, et al. Facilitating relational framing in children and individuals with developmental delay using the relational completion procedure. J Exp Anal Behav. 2013. Dec. 11. X-3, X-5. [pmid: 24338682].
2523 Walton KM, Ingersoll BR. Improving Social Skills in Adolescents and Adults with Autism and Severe to Profound Intellectual Disability: A Review of the Literature. Springer. 233 Spring Street, New York, NY 10013. 2013:594-615. X-4.
2524 Wang L, Mandell DS, Lawer L, et al. Healthcare service use and costs for autism spectrum disorder: A comparison between Medicaid and private insurance. Journal of Autism and Developmental Disorders. 2013;43(5):1057-64. X-5. [pmid: 22965299].
2525 Wang Q, Sourina O. Real-time mental arithmetic task recognition from EEG signals. IEEE Trans Neural Syst Rehabil Eng. Mar. 2013;21(2):225-32. X-5. [pmid: 23314778].
2526 Wang X, Bey AL, Chung L, et al. Therapeutic approaches for shankopathies. Dev Neurobiol. 2013. Mar. 27. X-5. [pmid: 23536326].
2527 Ward SC, Whalon K, Rusnak K, et al. The association between therapeutic horseback riding and the social communication and sensory reactions of children with autism. Journal of Autism and Developmental Disorders. 2013;43(9):2190-8. X-5. [pmid: 23371511].
2528 Ware TL, Earl J, Salomons GS, et al. Typical and atypical phenotypes of PNPO deficiency with elevated CSF and plasma pyridoxamine on treatment. Dev Med Child Neurol. 2013. Nov. 23. X-5. [pmid: 24266778].
2529 Waris P, Lindberg N, Kettunen K, et al. The relationship between Asperger's syndrome and schizophrenia in adolescence. Eur Child Adolesc Psychiatry. Apr. 2013;22(4):217-23. X-5. [pmid: 23065028].
2530 Warren ZE, Zheng Z, Swanson AR, et al. Can Robotic Interaction Improve Joint Attention Skills?. J Autism Dev Disord. 2013. Sep. 8. X-3. [pmid: 24014194].
2531 Wass SV, Porayska-Pomsta K. The uses of cognitive training technologies in the treatment of autism spectrum disorders. Autism. 2013. Oct. 15. X-2, X-5. [pmid: 24129912].
2532 Wehman PH, Schall CM, McDonough J, et al. Competitive Employment for Youth with Autism Spectrum Disorders: Early Results from a Randomized Clinical Trial. J Autism Dev Disord. 2013. Jul. 27. X-5. [pmid: 23893098].
2533 Weiss JA, Viecili MA, Sloman L, et al. Direct and Indirect Psychosocial Outcomes for Children with Autism Spectrum Disorder and their Parents Following a Parent-involved Social Skills Group Intervention. J Can Acad Child Adolesc Psychiatry. Nov. 2013;22(4):303-9. X-5. [pmid: 24223050].
2534 Weitlauf AS, Gotham KO, Vehorn AC, et al. Brief Report: DSM-5 “Levels of Support:” A Comment on Discrepant Conceptualizations of Severity in ASD. J Autism Dev Disord. 2013. Jun. 28. X-5. [pmid: 23812664].
2535 Whitby PJ. The Effects of “Solve It!” on the Mathematical Word Problem Solving Ability of Adolescents with Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. June. 2013. 2013;28(2):78-88. X-5.
2536 White SJ. The Triple I Hypothesis: taking another('s) perspective on executive dysfunction in autism. J Autism Dev Disord. Jan. 2013;43(1):114-21. X-5. [pmid: 22584617].
2537 White SW, Ollendick T, Albano AM, et al. Randomized controlled trial: Multimodal anxiety and social skill intervention for adolescents with autism spectrum disorder. Journal of Autism and Developmental Disorders. 2013;43(2):382-94. X-5. [pmid: 22735897].
2538 White SW, Smith LA, Schry AR. Assessment of global functioning in adolescents with autism spectrum disorders: Utility of the Developmental Disability-Child Global Assessment Scale. Autism. 2013. Aug. 21. X-5. [pmid: 23965288].
2539 Whitehouse AJO, Holt BJ, Serralha M, et al. Maternal vitamin D levels and the autism phenotype among offspring. Journal of Autism and Developmental Disorders. 2013;43(7):1495-504. X-5. [pmid: 23070790].
2540 Wiggins LD, Robins DL, Yeargin-Allsopp M. Short report: Improving record–review surveillance of young children with an autism spectrum disorder. Autism. 2013;17(5):623-9. X-5. [pmid: 22987886].
2541 Williams K, Brignell A, Randall M, et al. Selective serotonin reuptake inhibitors (SSRIs) for autism spectrum disorders (ASD). Cochrane Database Syst Rev. 2013;8:CD004677. X-5. [pmid: 23959778].
2542 Williamson RL, Casey LB, Robertson JS, et al. Video Self-Modeling in Children with Autism: A Pilot Study Validating Prerequisite Skills and Extending the Utilization of VSM across Skill Sets. Assistive Technology. 2013. 2013;25(2):63-71. X-3. [pmid: 23923688].
2543 Wilson BJ, Berg JL, Zurawski ME, et al. Autism and Externalizing Behaviors: Buffering Effects of Parental Emotion Coaching. Research in Autism Spectrum Disorders. June. 2013. 2013;7(6):767-76. X-4.
2544 Wilson BJ, Manangan CN, Dauterman HA, et al. ADHD Symptoms Moderate the Relation Between ASD Status and Internalizing Symptoms in 3-6-Year-Old Children. J Autism Dev Disord. 2013. Nov. 16. X-5. [pmid: 24242972].
2545 Wilson KP. Incorporating video modeling into a school-based intervention for students with autism spectrum disorders. Lang Speech Hear Serv Sch. Jan. 2013;44(1):105-17. X-5. [pmid: 23087158].
2546 Winarni TI, Utari A, Mundhofir FE, et al. Fragile X Syndrome: Clinical, Cytogenetics and Molecular Screening among Autism Spectrum Disorder Children in Indonesia. Clin Genet. 2013. Jan. 16. X-5. [pmid: 23320543].
2547 Wincik S. Learning from Katie. Nursing. Jul. 2013;43(7):40-1. X-5. [pmid: 23778213].
2548 Wolff JJ, Hupp SC, Symons FJ. Brief report: Avoidance extinction as treatment for compulsive and ritual behavior in autism. J Autism Dev Disord. Jul. 2013;43(7):1741-6. X-5. [pmid: 23179345].
2549 Wolff JJ, Symons FJ. An evaluation of multi-component exposure treatment of needle phobia in an adult with autism and intellectual disability. Journal of Applied Research in Intellectual Disabilities. 2013;26(4):344-8. X-5. [pmid: 23225704].
2550 Won H, Mah W, Kim E. Autism spectrum disorder causes, mechanisms, and treatments: focus on neuronal synapses. Front Mol Neurosci. 2013;6:19. X-5. [pmid: 23935565].
2551 Wong KA, Zisengwe G, Athanasiou T, et al. Outpatient laser ablation of non-muscle-invasive bladder cancer: is it safe, tolerable and cost-effective?. BJU Int. Sep. 2013;112(5):561-7. X-5. [pmid: 23819486].
2552 Woo CC, Leon M. Environmental enrichment as an effective treatment for autism: A randomized controlled trial. Behavioral Neuroscience. 2013;127(4):487-97. X-5. [pmid: 23688137].
2553 Wu MS, McGuire JF, Arnold EB, et al. Psychometric Properties of the Children's Yale-Brown Obsessive Compulsive Scale in Youth with Autism Spectrum Disorders and Obsessive-Compulsive Symptoms. Child Psychiatry Hum Dev. 2013. Jul. 5. X-1, X-4. [pmid: 23827959].
2554 Xu P, Grueter BA, Britt JK, et al. Double deletion of melanocortin 4 receptors and SAPAP3 corrects compulsive behavior and obesity in mice. Proc Natl Acad Sci U S A. Jun. 25. 2013;110(26):10759-64. X-5. [pmid: 23754400].
2555 Yakubova G, Taber-Doughty T. Brief Report: Learning via the Electronic Interactive Whiteboard for Two Students with Autism and a Student with Moderate Intellectual Disability. Journal of Autism and Developmental Disorders. June. 2013. 2013;43(6):1465-72. X-3. [pmid: 23080208].
2556 Yanardag M, Akmanoglu N, Yilmaz I. The effectiveness of video prompting on teaching aquatic play skills for children with autism. Disabil Rehabil. Jan. 2013;35(1):47-56. X-3. [pmid: 22624856].
2557 Yazawa M, Dolmetsch RE. Modeling Timothy syndrome with iPS cells. J Cardiovasc Transl Res. Feb. 2013;6(1):1-9. X-5. [pmid: 23299782].
2558 Zachor DA, Curatolo P. Recommendations for early diagnosis and intervention in autism spectrum disorders: An Italian-Israeli consensus conference. Eur J Paediatr Neurol. 2013. Sep. 25. X-5. [pmid: 24095105].
2559 Zerbo O, Iosif AM, Walker C, et al. Is maternal influenza or fever during pregnancy associated with autism or developmental delays? Results from the CHARGE (CHildhood Autism Risks from Genetics and Environment) study. J Autism Dev Disord. Jan. 2013;43(1):25-33. X-5. [pmid: 22562209].
2560 Zito JM, Burcu M, Ibe A, et al. Antipsychotic use by medicaid-insured youths: impact of eligibility and psychiatric diagnosis across a decade. Psychiatr Serv. Mar. 1. 2013;64(3):223-9. X-4, X-5. [pmid: 23242390].