# Quality of the Literature

Table D-1 Quality of the literature

First Author Year | Group Design | Random Assignment | Appropriate Comparison Group | Correct Randomization | Systematic Diagnostic Approach | Clear Sample Characterization | Clear Inclusion/Exclusion Criteria | Attrition Reported | Drop out Characteristics Evaluated | Intervention Fully Described | Treatment Fidelity Monitored | Concomitant Interventions Held Steady/Reported | Outcome Measures Reliable and Valid | Primary Outcomes Specified a priori | Outcome Data Collected From Appropriate Sources | Outcomes Coded Blindly | Appropriate Statistical Analysis | Rating
Boyd 2013 1 | + | - | + | NA | + | + | + | + | NA | + | + | - | + | + | + | - | - | F
Casenhiser 2013 2 | + | + | + | + | + | + | + | + | NA | + | + | - | + | + | + | + | + | F
Fujii 2013 3 | + | + | + | - | + | + | + | + | NA | + | + | + | + | + | + | + | - | F
Goods 2013 4 | + | + | + | + | + | + | + | + | NA | + | + | NA | + | + | + | + | + | G
Ichikawa 2013 5 | + | + | + | + | - | + | + | + | NA | + | - | - | + | + | + | - | + | P
Kasari 2013 6 | + | + | + | + | - | + | + | + | NA | + | + | - | + | + | + | - | + | F
Kenworthy 2013 7 | + | + | + | - | + | + | + | + | + | + | + | + | + | + | + | + | - | G
Malow 2013 8 | + | + | + | + | + | + | + | + | - | + | + | - | + | + | + | - | - | F
McNally-Keehn 2013 9 | + | + | + | + | + | + | + | + | NA | + | + | + | + | + | + | - | + | G
Paynter 2013 10 | + | - | + | - | + | + | - | + | NA | + | - | - | + | - | + | - | - | F
Peters-Scheffer 2013 11 | + | - | + | NA | + | + | + | + | - | + | + | - | + | - | + | - | + | G
Reed 2013 12 | + | - | + | NA | + | + | + | - | - | + | - | - | + | - | + | - | - | P
Schertz 2013 13 | + | + | + | - | + | + | + | + | NA | + | + | - | + | + | + | + | + | F
Schreibman 2013 14 | + | + | + | + | + | + | + | + | NA | + | + | + | + | + | + | - | + | G
Sharp 2013 15 | + | + | + | - | - | - | + | + | + | + | - | - | + | + | + | - | - | P
Storch 2013 16 | + | + | + | - | + | + | + | + | NA | + | + | + | + | + | + | + | - | G
Warreyn 2013 17 | + | + | + | - | + | + | + | + | - | + | - | - | + | + | + | - | - | F
Adkins 2012 18 | + | + | + | - | + | + | + | + | NA | + | - | + | + | + | + | - | + | F
Cortesi 2010 19 | + | + | + | + | + | + | + | + | + | + | - | + | + | + | + | - | - | F
Eikeseth 2012 20 | + | - | + | NA | - | + | - | + | - | + | - | - | + | + | + | - | - | F
Eldevik 2012 21 | + | - | + | NA | - | + | + | + | NA | + | - | - | + | - | + | - | + | F
Flanagan 2012^22-27^ | + | - | + | NA | + | + | + | NA | - | + | - | - | + | + | + | - | + | F
Kaale 2012 28 | + | + | + | + | + | + | + | + | NA | + | + | + | + | + | + | + | + | F
Kasari 2012 29 | + | + | + | + | + | + | + | + | NA | + | - | - | + | + | + | - | + | F
Lawton 2012 30 | + | + | + | + | + | + | + | + | NA | + | + | + | + | + | + | + | - | F
Lerner 2012 31 | + | + | + | - | - | + | - | + | NA | + | + | - | + | + | + | + | + | F
Reaven 2012 32 | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | G
Rogers 2012^33, 34^ | + | + | + | + | + | + | + | - | - | + | + | + | + | + | + | - | - | F
Strauss 2012^35, 36^ | + | - | + | NA | + | + | + | + | NA | + | + | - | + | + | + | - | + | G
Thomeer 2012 37 | + | + | + | - | - | + | + | + | NA | + | + | + | + | + | + | - | + | F
Venker 2012 38 | + | + | + | - | + | + | - | - | - | + | + | - | + | + | + | - | + | F
Williams 2012 39 | + | + | + | + | + | + | + | + | NA | + | + | - | + | + | + | + | + | G
Young 2012 40 | + | + | + | - | + | + | + | + | NA | + | + | - | + | + | + | - | + | F
Begeer 2011 41 | + | + | + | + | + | + | + | + | NA | + | + | - | + | + | + | - | + | F
Carter 2011 42 | + | + | + | + | + | + | + | + | - | + | + | - | + | + | + | + | + | F
Castorina 2011 43 | + | - | + | NA | - | + | + | + | NA | + | + | - | + | + | + | - | + | F
DeRosier 2011 44 | + | + | + | - | - | + | + | + | + | + | + | - | + | + | + | - | + | F
Landa 2011^45, 46^ | + | + | + | - | + | + | + | + | NA | + | + | + | + | + | + | + | + | G
Murdock 2011 47 | + | - | + | NA | - | + | + | + | NA | + | - | - | + | + | + | - | - | P
Pajareya 2011 48 | + | + | + | + | + | + | + | + | NA | + | - | + | + | + | + | - | + | F
Roberts 2011 49 | + | + | + | + | + | + | + | + | - | + | + | + | + | + | + | + | + | G
Scarpa 2011 50 | + | + | + | - | + | + | + | + | NA | + | - | - | - | + | + | - | + | F
Strain 2011 51 | + | + | + | - | - | + | + | + | NA | + | + | - | + | + | + | - | + | F
Sung 2011 52 | + | + | + | - | + | + | + | + | - | + | + | + | + | + | + | - | - | G
Wood 2011^53-55^ | + | + | + | + | + | + | + | + | - | + | + | - | + | + | + | + | + | G
Ingersoll 2010^56, 57^ | + | + | + | - | + | + | + | + | NA | + | + | - | + | + | + | + | + | G
Itzchak 2010^58, 59^ | + | - | + | NA | + | + | + | - | - | + | - | - | + | + | + | - | - | F
Kasari 2010 60 | + | + | + | + | + | + | + | + | NA | + | + | + | + | + | + | + | + | G
Keen 2010 61 | + | - | + | NA | + | + | - | + | NA | + | + | - | + | + | + | - | + | G
Koenig 2010 62 | + | + | + | + | + | + | + | + | NA | + | + | + | + | + | + | + | - | G
Kouijzer 2010 63 | + | + | + | - | + | + | + | + | NA | + | NA | - | + | + | + | - | - | F
Lopata 2010 64 | + | + | + | + | - | + | + | + | NA | + | + | + | + | + | + | - | + | F
McConkey 2010 65 | + | - | - | NA | - | + | + | + | - | + | - | - | + | - | + | - | + | P
Oosterling 2010 66 | + | + | + | - | + | + | + | + | - | + | + | - | + | + | + | - | - | F
Peters-Sheffer 2010 67 | + | - | + | NA | + | + | + | + | NA | + | - | + | + | + | + | - | + | F
Reed 2010 68 | + | - | + | NA | + | + | + | - | - | + | - | - | + | + | + | + | - | F
Siller 2010 69 | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | + | F
Wong 2010 70 | + | + | + | - | + | + | + | + | NA | - | - | - | + | + | + | + | - | P
Dawson 2009^71, 72^ | + | + | + | + | + | + | + | + | - | + | + | + | + | + | - | - | - | G
Kouizjer 2009^73, 74^ | + | - | + | NA | - | + | + | NA | NA | + | - | - | + | - | + | - | - | P
RUPP 2009^75-78^ | + | + | + | - | + | + | + | + | - | + | + | + | + | + | + | - | + | F
Remington 2007^79, 80^ | + | - | + | NA | + | + | + | + | - | - | - | + | + | + | + | - | - | P
Kasari 2006^81-84^ | + | + | + | - | + | + | + | + | - | + | + | - | + | + | + | + | + | F
Aldred 2004^85, 86^ | + | + | + | + | + | + | + | + | NA | + | - | - | + | + | + | + | + | G

F=fair; G=good; NA=not applicable; P=poor

## Quality/Risk of Bias Assessment Approach

### Study Design

1. Did the study employ a group design?
  - Group designs may include randomized controlled trials, prospective or retrospective cohorts, case-control studies
    + = yes
    − = no
2. Were the groups randomly assigned?
  - + = yes
    − = no
3. Was there an appropriate comparison group?
  - The comparison group should accurately represent the characteristics of the intervention group in the absence of the intervention. Specifically, factors that are likely to be associated with the intervention selected and with outcomes observed should be evenly distributed between groups, if possible. These factors may include, for example, age, IQ, severity, etc.
    + = yes
    − = no or not reported (NR)
4. If an RCT, was randomization done correctly?
  - + = yes
    − = no
    NR
    NA for all non-RCTs
  - Considerations:
    Was the approach to randomization described? Were random techniques like computer-generated, sequentially numbered opaque envelope used?
    Were technically non-random techniques, like alternate days of the week used?
    Any studies with randomization techniques not reported (NR) will also be reviewed by the team.

### Participant Ascertainment/Inclusion

1. Was a valid diagnostic approach for ASD used within the study, or were referred participants diagnosed using a valid approach?
  A. clinical DSM-IV-based diagnosis + ADI-R and/or ADOS
  B. [clinical DSM-IV-based diagnosis + other] OR [ADOS + other, such as SRS, CARS, SCQ, CAST, ASSQ, OR STAT, MCHAT for under 30 months]
  C. Only clinical DSM-IV-based diagnosis OR Only ADOS
  D. Neither clinical DSM-IV-based diagnosis NOR ADOS
2. Was the sample clearly characterized (e.g., information provided to characterize participants in terms of impairments associated with their ASD, such as cognitive or developmental level)?
  - + = yes
    − = no or not reported (NR)
  - Considerations:
    Are baseline measures of IQ, mental age, language facility, etc. reported?
    How reproducible is the study in terms of the sample participants? Do the authors provide enough information that you could recreate the study population in a new study?
3. Were inclusion and exclusion criteria clearly stated?
  - + = yes
    − = no or not reported (NR)
  - Considerations:
    Did the authors report this information?
4. Do the authors report attrition?
  - + = yes
    − = no
  - Considerations:
    Do they report loss to follow-up and/or drop-out?
    If there is no attrition (i.e., baseline and follow up Ns are the same), score as YES
5. Were characteristics of drop-out group evaluated for differences with the participant group as a whole?
  - + = yes
    − = no or not reported (NR)
    NA or attrition was minimal
  - Considerations:
    Were reasons for dropping out evaluated?
    Does the paper describe a comparison between drop-outs and the whole group?
    Score as NA if attrition was minimal.

### Intervention

1. Was the intervention fully described?
  - + = yes
    − = no or not reported (NR)
  - Considerations:
    Is there sufficient detail to allow replication of the intervention?
    Does the study describe the dosage, formulation, timing, duration, intensity, etc. of the intervention?
    Do the authors refer to a treatment manual (score as YES if so, even is manual is unpublished)?
2. For behavioral studies, was treatment fidelity monitored in a systematic way?
  - + = yes
    − = no or not reported (NR)
    NA
  - Considerations:
    Was a method in place to assess whether people providing he intervention were adherent to a manual/process? We're not assessing the quality of the fidelity, just whether it was performed.
3. Did the authors measure and report adherence to the intended treatment process?
  - + = yes
    − = no or not reported (NR)
  - Considerations:
    Does the study report number of hours of treatment or treatment sessions or time period receiving therapy (planned vs. actually received)? Do they provide pill count data or parental medication diary, etc. for pharmacologic interventions?
4. Did the authors report differences in or hold steady all concomitant interventions?
  - + = yes
    − = no or not reported (NR)
  - Considerations:
    Was an attempt made to assess/determine if other interventions were ongoing?

### Outcome Measurement

1. Did outcome measures demonstrate adequate reliability and validity (including interobserver reliability for behavior observation coding)?
  - + = yes
    − = no or not reported (NR)
  - Considerations:
    If the study used an established measure, has validity been established previously and do the authors provide a reference?
    If the study used a new measure, was validity established?
    For interobserver coding, was reliability and /or validity tested?
2. Were the primary & secondary outcomes clearly specified a priori?
  - + = yes
    − = no or not reported (NR)
  - Considerations:
    Was there a “called shot?”
3. Were outcome data collected from sources appropriate to the target outcome (e.g. parent report, teacher report, direct behavior observation)?
  - + = yes
    − = no or not reported (NR)
  - Considerations:
    Ex: Parent report for home-focused outcomes, teacher report for academic/school-focused, etc.
4. Were outcomes coded by individuals blinded to the intervention status of the participants?
  - + = yes
    − = no or not reported (NR)

### Analysis

1 Was an appropriate statistical analysis used?
  - + = yes
    − = no
1a For RCT's, was there an intent-to treat analysis?
  - + = yes
    − = no
    NA
  - Considerations:
    Does the study report ITT analyses or last observation carried forward or note that all subjects were included in the final analyses?
    If ≤2 participants were lost to follow-up, consider the analysis as ITT.
1b For negative studies, was a power calculation provided?
  - + = yes
    − = no
    NA
1c Did the study correct for multiple testing?
  - + = yes
    − = no
    NA
1d For observational studies, were potential confounders and effect measure modifiers captured?
  - + = yes
    − = no
    NA
  - Considerations:
    Were the groups well categorized at baseline? Were baseline differences assessed?
1e For observational studies, were potential confounders and effect measure modifiers handled appropriately?
  - + = appropriate analysis
    − = inappropriate analysis
    NA
  - Considerations:
    Confounders are variables that are associated both with the intervention and the outcome and that change the relationship of the intervention to the outcome. These are variables that we would control for in analysis.
    Effect measure modifiers are variables that we think of as stratifying, in that the relationship between the intervention and outcome is fundamentally different in different strata of the effect modifier. Observational research should include an assessment of potential confounders and modifiers, and if they are observed, analysis should control for or stratify on them.
    Was the candidate variable selection discussed/noted?
    Was the model-building approach described?
    Were any variables unrelated to the studied variables that could have altered the outcome handled appropriately?
    Were any variables not under study that affected the causal factors handled appropriately?

## References

1 Boyd BA, Hume K, McBee MT, et al. Comparative Efficacy of LEAP, TEACCH and Non-Model-Specific Special Education Programs for Preschoolers with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jun. 28. [pmid: 23812661].
2 Casenhiser DM, Shanker SG, Stieben J. Learning through interaction in children with autism: preliminary data from asocial-communication-based intervention. Autism. Mar. 2013;17(2):220-41. [pmid: 21949005].
3 Fujii C, Renno P, McLeod BD, et al. Intensive cognitive behavioral therapy for anxiety disorders in school-aged children with autism: A preliminary comparison with treatment-as-usual. School Mental Health. 2013;5(1):25-37.
4 Goods KS, Ishijima E, Chang Y-C, et al. Preschool Based JASPER Intervention in Minimally Verbal Children with Autism: Pilot RCT. Journal of Autism and Developmental Disorders. May. 2013. 2013;43(5):1050-6. [pmid: 22965298].
5 Ichikawa K, Takahashi Y, Ando M, et al. TEACCH-based group social skills training for children with high-functioning autism: a pilot randomized controlled trial. Biopsychosoc Med. 2013;7(1):14. [pmid: 24083413].
6 Wong CS. A play and joint attention intervention for teachers of young children with Autism: A randomized controlled pilot study. Autism. May. 2013. 2013;17(3):340-57. [pmid: 23610236].
7 Kenworthy L, Anthony LG, Naiman DQ, et al. Randomized controlled effectiveness trial of executive function intervention for children on the autism spectrum. J Child Psychol Psychiatry. 2013. Nov. 21. [pmid: 24256459].
8 Malow BA, Adkins KW, Reynolds A, et al. Parent-Based Sleep Education for Children with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jun. 11. [pmid: 23754339].
9 McNally Keehn RH, Lincoln AJ, Brown MZ, et al. The Coping Cat program for children with anxiety and autism spectrum disorder: A pilot randomized controlled trial. Journal of Autism and Developmental Disorders. 2013;43(1):57-67. [pmid: 22588377].
10 Paynter J, Peterson CC. Further Evidence of Benefits of Thought-Bubble Training for Theory of Mind Development in Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. February. 2013. 2013;7(2):344-8.
11 Peters-Scheffer N, Didden R, Mulders M, et al. Effectiveness of low intensity behavioral treatment for children with autism spectrum disorder and intellectual disability. Research in Autism Spectrum Disorders. 2013;7(9):1012-25.
12 Reed P, Osborne LA, Makrygianni M, et al. Evaluation of the Barnet Early Autism Model (BEAM) Teaching Intervention Programme in a “Real World” Setting. Research in Autism Spectrum Disorders. June. 2013. 2013;7(6):631-8.
13 Schertz HH, Odom SL, Baggett KM, et al. Effects of Joint Attention Mediated Learning for Toddlers with Autism Spectrum Disorders: An Initial Randomized Controlled Study. Early Childhood Research Quarterly. 2013. 2013;28(2):249-58.
14 Schreibman L, Stahmer AC. A Randomized Trial Comparison of the Effects of Verbal and Pictorial Naturalistic Communication Strategies on Spoken Language for Young Children with Autism. J Autism Dev Disord. 2013. Nov. 23. [pmid: 24272416].
15 Sharp WG, Burrell TL, Jaquess DL. The Autism MEAL Plan: A parent-training curriculum to manage eating aversions and low intake among children with autism. Autism. 2013. Oct. 7. [pmid: 24101716].
16 Storch EA, Arnold EB, Lewin AB, et al. The effect of cognitive-behavioral therapy versus treatment as usual for anxiety in children with autism spectrum disorders: A randomized, controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2013;52(2):132-42. [pmid: 23357440].
17 Warreyn P, Roeyers H. See what I see, do as I do: Promoting joint attention and imitation in preschoolers with autism spectrum disorder. Autism. 2013. Oct. 8. [pmid: 24104513].
18 Adkins KW, Molloy C, Weiss SK, et al. Effects of a standardized pamphlet on insomnia in children with autism spectrum disorders. Pediatrics. Nov. Suppl 2. 2012;130:S139-44. [pmid: 23118244].
19 Cortesi F, Giannotti F, Sebestiani T, et al. Controlled‐release melatonin, singly and combined with cognitive behavioural therapy, for persistent insomnia in children with autism spectrum disorders: A randomized placebo‐controlled trial. Journal of Sleep Research. 2012;21(6):700-9. [pmid: 22616853].
20 Eikeseth S, Klintwall L, Jahr E, et al. Outcome for Children with Autism Receiving Early and Intensive Behavioral Intervention in Mainstream Preschool and Kindergarten Settings. Research in Autism Spectrum Disorders. 2012;6(2):829-35.
21 Eldevik S, Hastings RP, Jahr E, et al. Outcomes of behavioral intervention for children with autism in mainstream pre-school settings. J Autism Dev Disord. Feb. 2012;42(2):210-20. [pmid: 21472360].
22 Flanagan HE, Perry A, Freeman NL. Effectiveness of large-scale community-based intensive Behavioral Intervention: A waitlist comparison study exploring outcomes and predictors. Research in Autism Spectrum Disorders. 2012;6(2):673-82.
23 Perry A, Cummings A, Geier JD, et al. Effectiveness of Intensive Behavioral Intervention in a Large, Community-Based Program. Research in Autism Spectrum Disorders. Oct. 2008;2(4):621-42.
24 Shine R, Perry A. The relationship between parental stress and intervention outcome of children with autism. Journal on Developmental Disabilities. 2010;16(2):64-6.
25 Freeman N, Perry A. Outcomes of intensive behavioural intervention in the Toronto Preschool Autism Service. Journal on Developmental Disabilities. 2010;16(2):17-32.
26 Perry A, Cummings A, Geier JD, et al. Predictors of Outcome for Children Receiving Intensive Behavioral Intervention in a Large, Community-Based Program. Research in Autism Spectrum Disorders. 2011;5(1):592-603.
27 Perry A, Blacklock K, Dunn Geier J. The relative importance of age and IQ as predictors of outcomes in Intensive Behavioral Intervention. Research in Autism Spectrum Disorders. 2013;7(9):1142-50.
28 Kaale A, Smith L, Sponheim E. A randomized controlled trial of preschool-based joint attention intervention for children with autism. J Child Psychol Psychiatry. Jan. 2012;53(1):97-105. [pmid: 21883204].
29 Kasari C, Rotheram-Fuller E, Locke J, et al. Making the connection: randomized controlled trial of social skills at school for children with autism spectrum disorders. J Child Psychol Psychiatry. Apr. 2012;53(4):431-9. [pmid: 22118062].
30 Lawton K, Kasari C. Teacher-implemented joint attention intervention: pilot randomized controlled study for preschoolers with autism. J Consult Clin Psychol. Aug. 2012;80(4):687-93. [pmid: 22582764].
31 Lerner MD, Mikami AY. A preliminary randomized controlled trial of two social skills interventions for youth with high-functioning autism spectrum disorders. Focus on Autism and Other Developmental Disabilities. 2012;27(3):147-57.
32 Reaven J, Blakeley-Smith A, Culhane-Shelburne K, et al. Group cognitive behavior therapy for children with high-functioning autism spectrum disorders and anxiety: a randomized trial. J Child Psychol Psychiatry. Apr. 2012;53(4):410-9. [pmid: 22435114].
33 Rogers SJ, Estes A, Lord C, et al. Effects of a brief Early Start Denver Model (ESDM)–based parent intervention on toddlers at risk for autism spectrum disorders: A randomized controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(10):1052-65. [pmid: 23021480].
34 Estes A, Vismara L, Mercado C, et al. The Impact of Parent-Delivered Intervention on Parents of Very Young Children with Autism. J Autism Dev Disord. 2013. Jul. 10. [pmid: 23838727].
35 Strauss K, Vicari S, Valeri G, et al. Parent inclusion in Early Intensive Behavioral Intervention: the influence of parental stress, parent treatment fidelity and parent-mediated generalization of behavior targets on child outcomes. Res Dev Disabil. Mar-Apr. 2012;33(2):688-703. [pmid: 22188793].
36 Fava L, Strauss K, Valeri G, et al. The Effectiveness of a Cross-Setting Complementary Staff- and Parent-Mediated Early Intensive Behavioral Intervention for Young Children with ASD. Research in Autism Spectrum Disorders. 2011;5(4):1479-92.
37 Thomeer ML, Lopata C, Volker MA, et al. Randomized clinical trial replication of a psychosocial treatment for children with high‐functioning autism spectrum disorders. Psychology in the Schools. 2012;49(10):942-54.
38 Venker CE, McDuffie A, Weismer SE, et al. Increasing Verbal Responsiveness in Parents of Children with Autism: A Pilot Study. Autism: The International Journal of Research and Practice. 2012;16(6):568-85. [pmid: 21846665].
39 Williams BT, Gray KM, Tonge BJ. Teaching Emotion Recognition Skills to Young Children with Autism: A Randomised Controlled Trial of an Emotion Training Programme. Journal of Child Psychology and Psychiatry. 2012;53(12):1268-76. [pmid: 22881991].
40 Young RL, Posselt M. Using the transporters DVD as a learning tool for children with Autism Spectrum Disorders (ASD). J Autism Dev Disord. Jun. 2012;42(6):984-91. [pmid: 21822764].
41 Begeer S, Gevers C, Clifford P, et al. Theory of mind training in children with autism: A randomized controlled trial. Journal of Autism and Developmental Disorders. 2011;41(8):997-1006. [pmid: 20976617].
42 Carter AS, Messinger DS, Stone WL, et al. A randomized controlled trial of Hanen's ‘More Than Words’ in toddlers with early autism symptoms. J Child Psychol Psychiatry. Jul. 2011;52(7):741-52. [pmid: 21418212].
43 Castorina LL, Negri LM. The inclusion of siblings in social skills training groups for boys with Asperger syndrome. J Autism Dev Disord. Jan. 2011;41(1):73-81. [pmid: 20461452].
44 DeRosier ME, Swick DC, Davis NO, et al. The efficacy of a Social Skills Group Intervention for improving social behaviors in children with High Functioning Autism Spectrum disorders. J Autism Dev Disord. Aug. 2011;41(8):1033-43. [pmid: 21042870].
45 Landa RJ, Holman KC, O'Neill AH, et al. Intervention targeting development of socially synchronous engagement in toddlers with autism spectrum disorder: a randomized controlled trial. J Child Psychol Psychiatry. Jan. 2011;52(1):13-21. [pmid: 21126245].
46 Landa RJ, Kalb LG. Long-term outcomes of toddlers with autism spectrum disorders exposed to short-term intervention. Pediatrics. Nov. Suppl 2. 2012;130:S186-90. [pmid: 23118250].
47 Murdock LC, Hobbs JQ. Picture Me Playing: Increasing Pretend Play Dialogue of Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2011;41(7):870-8. [pmid: 20872061].
48 Pajareya K, Nopmaneejumruslers K. A pilot randomized controlled trial of DIR/Floortime parent training intervention for pre-school children with autistic spectrum disorders. Autism. Sep. 2011;15(5):563-77. [pmid: 21690083].
49 Roberts J, Williams K, Carter M, et al. A Randomised Controlled Trial of Two Early Intervention Programs for Young Children with Autism: Centre-Based with Parent Program and Home-Based. Research in Autism Spectrum Disorders. 2011;5(4):1553-66.
50 Scarpa A, Reyes NM. Improving emotion regulation with CBT in young children with high functioning autism spectrum disorders: a pilot study. Behav Cogn Psychother. Jul. 2011;39(4):495-500. [pmid: 21457605].
51 Strain PS, Bovey EH. Randomized, Controlled Trial of the Leap Model of Early Intervention for Young Children with Autism Spectrum Disorders. Topics in Early Childhood Special Education. 2011;31(3):133-54.
52 Sung M, Ooi YP, Goh TJ, et al. Effects of cognitive-behavioral therapy on anxiety in children with autism spectrum disorders: a randomized controlled trial. Child Psychiatry Hum Dev. Dec. 2011;42(6):634-49. [pmid: 21660428].
53 Drahota A, Wood JJ, Sze KM, et al. Effects of cognitive behavioral therapy on daily living skills in children with high-functioning autism and concurrent anxiety disorders. J Autism Dev Disord. Mar. 2011;41(3):257-65. [pmid: 20508979].
54 Wood JJ, Drahota A, Sze K, et al. Cognitive Behavioral Therapy for Anxiety in Children with Autism Spectrum Disorders: A Randomized, Controlled Trial. Journal of Child Psychology and Psychiatry. Mar. 2009;50(3):224-34. [pmid: 19309326].
55 Wood JJ, Drahota A, Sze K, et al. Brief Report: Effects of Cognitive Behavioral Therapy on Parent-Reported Autism Symptoms in School-Age Children with High-Functioning Autism. Journal of Autism and Developmental Disorders. Nov. 2009;39(11):1608-12. [pmid: 19562475].
56 Ingersoll B. Brief report: Pilot randomized controlled trial of reciprocal imitation training for teaching elicited and spontaneous imitation to children with autism. Journal of Autism and Developmental Disorders. 2010;40(9):1154-60. [pmid: 20155309].
57 Ingersoll B. Brief report: effect of a focused imitation intervention on social functioning in children with autism. J Autism Dev Disord. Aug. 2012;42(8):1768-73. [pmid: 22146934].
58 Itzchak EB, Zachor DA. Who Benefits from Early Intervention in Autism Spectrum Disorders?. Research in Autism Spectrum Disorders. 2011;5(1):345-50.
59 Zachor DA, Itzchak EB. Treatment Approach, Autism Severity and Intervention Outcomes in Young Children. Research in Autism Spectrum Disorders. 2010;4(3):425-32.
60 Kasari C, Gulsrud AC, Wong C, et al. Randomized controlled caregiver mediated joint engagement intervention for toddlers with autism. Journal of Autism and Developmental Disorders. 2010;40(9):1045-56. [pmid: 20145986].
61 Keen D, Couzens D, Muspratt S, et al. The effects of a parent-focused intervention for children with a recent diagnosis of autism spectrum disorder on parenting stress and competence. Research in Autism Spectrum Disorders. 2010;4(2):229-41.
62 Koenig K, White SW, Pachler M, et al. Promoting social skill development in children with pervasive developmental disorders: a feasibility and efficacy study. J Autism Dev Disord. Oct. 2010;40(10):1209-18. [pmid: 20204689].
63 Kouijzer MEJ, van Schie HT, de Moor JMH, et al. Neurofeedback treatment in autism. Preliminary findings in behavioral, cognitive, and neurophysiological functioning. Research in Autism Spectrum Disorders. 2010;4(3):386-99.
64 Lopata C, Thomeer ML, Volker MA, et al. RCT of a manualized social treatment for high-functioning autism spectrum disorders. J Autism Dev Disord. Nov. 2010;40(11):1297-310. [pmid: 20232240].
65 McConkey R, Truesdale-Kennedy M, Crawford H, et al. Preschoolers with Autism Spectrum Disorders: Evaluating the Impact of a Home-Based Intervention to Promote Their Communication. Early Child Development and Care. 2010;180(3):299-315.
66 Oosterling I, Visser J, Swinkels S, et al. Randomized controlled trial of the focus parent training for toddlers with autism: 1-year outcome. J Autism Dev Disord. Dec. 2010;40(12):1447-58. [pmid: 20440639].
67 Peters-Scheffer N, Didden R, Mulders M, et al. Low intensity behavioral treatment supplementing preschool services for young children with autism spectrum disorders and severe to mild intellectual disability. Res Dev Disabil. Nov-Dec. 2010;31(6):1678-84. [pmid: 20627451].
68 Reed P, Osborne L. Impact of Severity of Autism and Intervention Time-Input on Child Outcomes: Comparison across Several Early Interventions. British Journal of Special Education. 2012;39(3):130-6.
69 Siller M, Hutman T, Sigman M. A Parent-Mediated Intervention to Increase Responsive Parental Behaviors and Child Communication in Children with ASD: A Randomized Clinical Trial. Journal of Autism and Developmental Disorders. 2013;43(3):540-55. [pmid: 22825926].
70 Wong VCN, Kwan QK. Randomized controlled trial for early intervention for autism: A pilot study of the Autism 1–2–3 project. Journal of Autism and Developmental Disorders. 2010;40(6):677-88. [pmid: 20020319].
71 Dawson G, Jones EJ, Merkle K, et al. Early behavioral intervention is associated with normalized brain activity in young children with autism. J Am Acad Child Adolesc Psychiatry. Nov. 2012;51(11):1150-9. [pmid: 23101741].
72 Dawson G, Rogers S, Munson J, et al. Randomized, Controlled Trial of an Intervention for Toddlers With Autism: The Early Start Denver Model. Pediatrics. 2010. January. 2010.
73 Kouijzer MEJ, de Moor JMH, Gerrits BJL, et al. Neurofeedback Improves Executive Functioning in Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. Jan. 2009;3(1):145-62.
74 Kouijzer MEJ, de Moor JMH, Gerrits BJL, et al. Long-term effects of neurofeedback treatment in autism. Research in Autism Spectrum Disorders. 2009;3(2):496-501.
75 Arnold LE, Aman MG, Li X, et al. Research units of pediatric psychopharmacology (RUPP) autism network randomized clinical trial of parent training and medication: One-year follow-Up. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(11):1173-84. [pmid: 23101743].
76 Aman MG, McDougle CJ, Scahill L, et al. Medication and Parent Training in Children With Pervasive Developmental Disorders and Serious Behavior Problems: Results From a Randomized Clinical Trial. J Am Acad Child Adolesc Psychiatry. 2009. Oct. 23. [pmid: 19858761].
77 Farmer C, Lecavalier L, Yu S, et al. Predictors and moderators of parent training efficacy in a sample of children with autism spectrum disorders and serious behavioral problems. J Autism Dev Disord. Jun. 2012;42(6):1037-44. [pmid: 21822762].
78 Scahill L, McDougle CJ, Aman MG, et al. Effects of risperidone and parent training on adaptive functioning in children with pervasive developmental disorders and serious behavioral problems. J Am Acad Child Adolesc Psychiatry. Feb. 2012;51(2):136-46. [pmid: 22265360].
79 Kovshoff H, Hastings RP, Remington B. Two-year outcomes for children with autism after the cessation of early intensive behavioral intervention. Behav Modif. Sep. 2011;35(5):427-50. [pmid: 21586502].
80 Remington B, Hastings RP, Kovshoff H, et al. Early intensive behavioral intervention: outcomes for children with autism and their parents after two years. Am J Ment Retard. Nov. 2007;112(6):418-38. [pmid: 17963434].
81 Kasari C, Gulsrud A, Freeman S, et al. Longitudinal follow-up of children with autism receiving targeted interventions on joint attention and play. J Am Acad Child Adolesc Psychiatry. May. 2012;51(5):487-95. [pmid: 22525955].
82 Lawton K, Kasari C. Brief Report: Longitudinal Improvements in the Quality of Joint Attention in Preschool Children with Autism. Journal of Autism and Developmental Disorders. 2012;42(2):307-12. [pmid: 22187107].
83 Kasari C, Paparella T, Freeman S, et al. Language outcome in autism: randomized comparison of joint attention and play interventions. J Consult Clin Psychol. Feb. 2008;76(1):125-37. [pmid: 18229990].
84 Kasari C, Freeman S, Paparella T. Joint attention and symbolic play in young children with autism: a randomized controlled intervention study. J Child Psychol Psychiatry. Jun. 2006;47(6):611-20. [pmid: 16712638].
85 Aldred C, Green J, Emsley R, et al. Mediation of treatment effect in a communication intervention for pre-school children with autism. Journal of Autism and Developmental Disorders. 2012;42(3):447-54. [pmid: 21512834].
86 Aldred C, Green J, Adams C. A new social communication intervention for children with autism: pilot randomised controlled treatment study suggesting effectiveness. J Child Psychol Psychiatry. Nov. 2004;45(8):1420-30. [pmid: 15482502].