# Evidence Table

Table C-1 Evidence table

## Abbreviations in Evidence Table

ABA: Applied Behavioral Analysis
ABC: Aberrant Behavior Checklist
ABC-I: Aberrant Behavior Checklist - Irritability
ACS: Autism Characteristics and Severity
ADHD: Attention Deficit Hyperactivity Disorder
ADI-R: Autism Diagnostic Interview - Revised
ADIS: Anxiety Disorders Interview Schedule
ADIS-P: Anxiety Disorders Interview Schedule – Parent Rated
ADIS-C/P: Anxiety Disorders Interview Schedule – Child and Parent Rated Versions
ADL: Activities of daily living
ADOS: Autism Diagnostic Observation Schedule
ADOS-G: Autism Diagnostic Observation Schedule - Generic
AEPS: Assessment, Evaluation, and Programming System
ALQ: Achieved Learning Questionnaire
ANCOVA: Analysis of Covariance
ASD: Autism Spectrum Disorder
ASSQ: Autism Spectrum Screening Questionnaire (High-Functioning)
BAS-II: British Abilities Scale
BASC-2: Behavior Assessment System for Children
BASC-2-PRS: Behavior Assessment System for Children – Parent Rating Scale
BSID: Bayley Scales of Infant Development
CARS: Childhood Autism Rating Scale
CASL: Comprehensive Assessment of Spoken Language
CASI: Child and Adolescent Symptom Inventory
CASP: Child and Adolescent Social Perception Measure
CAST: Childhood Asperger Syndrome Test
CBCL: Child Behavioral Checklist
CBS-DP: Communication and Symbolic Behavior Scales – Developmental Profile
CBT: Cognitive Behavioral Therapy
CCC: Children's Communication Checklist
CDI: Communication developmental Inventories
CGI: Clinical Global Impression
CHAT: Checklist for Autism
CIS-P: Columbia Impairment Scale-Parent Rated
CSBS-DP: Communication and Symbolic Behavior Scales – Developmental Profile
CSBQ: Children's Social Behavior Questionnaire
CSHQ: Children's Sleep Habits Questionnaire
CSR: Clinician Severity Rating
CTM: Comparison Comprehensive Treatment Model
CYBOCS: Children's Yale-Brown Obsessive-Compulsive Scale
DANVA: Diagnostic Analysis of Non-Verbal Accuracy
DAS: Differential Abilities Scale
DBC: Developmental Behavior Checkllist
DIR: Developmental, Individual Differences, Relationship-based
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders – Fourth Edition
EEG: Electroencephalogram
EIBI: Early and Intensive Behavioral Intervention
EL: Expressive Language
ELC: Early Learning Composite
ESAT: Early Screening for Autistic Traits
ESCS: Early Social Communications Scale
ESDM: Early Start Denver Model
EVT: Expressive Vocabulary Test
FAF: Facing Your Fears
FEAS: Functional Emotional Assessment Scale
FEDQ: Functional Emotional Development Questionnaire
FPI: Focused Playtime Intervention
FSIQ: Full Scale Intelligence Quotient
GAD: Generalized Anxiety Disorder
GARS: Gilliam Autism Rating Scale
GCSE: General Certificate of Secondary Education
GHQ: General Health Questionnaire
GMDS-ER: Griffiths Mental Development Scale – Extended Revised
HFASD: High-Functioning Autism Spectrum Disorder
HSQ: Home Situations Questionnaire
IBI: Intensive Behavioral Intervention
ICD-10: International Statistical Classification of Diseases
ICQ: Infant Characteristics Questionnaire
ID: Intellectual Disabilities
IJA: Initiating Joint Attention
IS: Interpersonal Synchrony
ITT: Intention to Treat
IQ: Intelligence Quotient
JA: Joint Attention
JASP/ER: Joint Attention and Symbolic Play/Engagement and Regulation Intervention
JE: Joint Engagement
LEAP: Learning Experiences and Alternative Program for Preschoolers
LEAS-C: The Levels of Emotional Awareness Scale for Children
MASC-P: Multidimensional Anxiety Scale for Children- Parent Rated
MCDI: MacArthur-Bates Communicative Development Inventory
MSEL: Mullen Scales of Early Learning
MTW: More Than Words
NEPSY-II: A Developmental Neuropsychological Assessment
NR: Not Reported
NRCT: Nonrandomized controlled trial
NS: Not Statistically Significant
NCD-I: MacArthur Communicative Development Inventory (Dutch Version)
OCD: Obsessive-Compulsive Disorder
ODD: Oppositional Defiant Disorder
PARS: Pediatric Anxiety Rating Scale
PCFP: Parent child free play
PCIQ: Parent-Child Interaction Questionnaire
PDD-BI: Pervasive Development Disorder - Behavior Inventory
PDD-MRS: Pervasive Development Disorder in Mentally Retarded Persons
PDD-NOS: Pervasive Developmental Disorder- Not Otherwise Specified
PECS: Picture Exchange Communication System
PEP-R: Psycho-Educational Profile – Revised
P-ESDM: Parent Delivery – Early Start Denver Model
PIA-CV: Parent Interview for Autism – Clinical Version
PIQ: Performance Intelligence Quotient
PLS-4: Preschool Language Scale
PPVT-4: Peabody Picture Vocabulary Test
PSI: Parental Stress Index
PSOC: Parenting Sense of Competence
RCMAS: Revised Children's Manifest Anxiety Scale
RCT: Randomized, Controlled Trials
RDLS: Reynell Developmental Language Scale
RSI-T: Reciprocal Social Interaction – Teacher Rated
SACA: Service Assessment for Children and Adolescents—Service Use Scale
SAD: Separation Anxiety Disorder
SCARED: Screen for Childhood Anxiety Related Emotional Disorders
SCAS: Spence Children's Interview Scale
SCAS-C: Spence Child Anxiety Scale – Child Rated
SCAS-P: Spence Children's Interview Scale – Parent Rate (?)
SCL-90-R: Symptoms Checklist – 90 – Revised
SCQ: Social Communication Questionnaire
SD: Standard Deviation
SDARI: Sociodramatic Affective Relational Intervention
SE: Standard error
SEI: Socially Engage Imitation
SES: Socioeconomic Status
SIB-R: Scales of Independent Behavior – Revised
SIOS: Social Interaction Observation System
SKA: Skillstreaming Knowledge Assessment
SOL: Sleep Onset Latency
SON-2.5-7: Snijders-Oomen Non-verbal Intelligence Test
SPA: Shared Positive Affect
SR: Social Recreational
SRB-P: Sensory and Repetitive Behaviors – Parent Rated
SRB-T: Sensory and Repetitive Behaviors – Teacher Rated
SRS: Social Responsiveness Scale
S.S. GRIN-HFA: Social Skills Group Intervention – High Functioning Autism
SSRI: Selective Serotonin Reuptake Inhibitor
SSRS-P: Social Skills Rating System – Parent Rated
SSRS-T: Social Skills Rating System – Teacher Rated
STAT: Screening Tool for Autism
TOM: Theory of Mind
TPSS: Teacher Perceptions of Social Skills
VABS: Vineland Adaptive Behavior Scales
VIQ: Verbal Intelligence Quotient
VR: Visual reception
WASI: Wechsler Abbreviated Scale of Intelligence
WASO: Wake After Sleep Onset
WISC-IV: Wechsler Intelligence Scale IV
WPPSI: Wechsler Preschool and Primary Scale of Intelligence

## References

1 Boyd BA, Hume K, McBee MT, et al. Comparative Efficacy of LEAP, TEACCH and Non-Model-Specific Special Education Programs for Preschoolers with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jun. 28.
2 Casenhiser DM, Shanker SG, Stieben J. Learning through interaction in children with autism: preliminary data from asocial-communication-based intervention. Autism. Mar. 2013;17(2):220-41. [pmid: 21949005].
3 Goods KS, Ishijima E, Chang Y-C, et al. Preschool Based JASPER Intervention in Minimally Verbal Children with Autism: Pilot RCT. Journal of Autism and Developmental Disorders. May. 2013. 2013;43(5):1050-6. [pmid: 22965298].
4 Ichikawa K, Takahashi Y, Ando M, et al. TEACCH-based group social skills training for children with high-functioning autism: a pilot randomized controlled trial. Biopsychosoc Med. 2013;7(1):14. [pmid: 24083413].
5 Kenworthy L, Anthony LG, Naiman DQ, et al. Randomized controlled effectiveness trial of executive function intervention for children on the autism spectrum. J Child Psychol Psychiatry. 2013. Nov. 21. [pmid: 24256459].
6 Malow BA, Adkins KW, Reynolds A, et al. Parent-Based Sleep Education for Children with Autism Spectrum Disorders. J Autism Dev Disord. 2013. Jun. 11. [pmid: 23754339].
7 Mandelberg J, Frankel F, Cunningham T, et al. Long-term outcomes of parent-assisted social skills intervention for high-functioning children with autism spectrum disorders. Autism. 2013. Aug. 30. [pmid: 23996903].
8 Frankel F, Myatt R, Sugar C, et al. A Randomized Controlled Study of Parent-assisted Children's Friendship Training with Children having Autism Spectrum Disorders. J Autism Dev Disord. 2010. Jan. 8. [pmid: 20058059].
9 Warren Z, Veenstra-VanderWeele J, Stone W, Bruzek JL, Nahmias AS, Foss-Feig JH, Jerome RN, Krishnaswami S, Sathe NA, Glasser AM, Surawicz T, McPheeters ML. Therapies for Children With Autism Spectrum Disorders. Comparative Effectiveness Review No. 26. (Prepared by the Vanderbilt Evidence-based Practice Center under Contract No. 290-2007-10065-I.). AHRQ Publication No. 11-EHC029-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
10 McNally Keehn RH, Lincoln AJ, Brown MZ, et al. The Coping Cat program for children with anxiety and autism spectrum disorder: A pilot randomized controlled trial. Journal of Autism and Developmental Disorders. 2013;43(1):57-67. [pmid: 22588377].
11 Paynter J, Peterson CC. Further Evidence of Benefits of Thought-Bubble Training for Theory of Mind Development in Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. February. 2013. 2013;7(2):344-8.
12 Perry A, Blacklock K, Dunn Geier J. The relative importance of age and IQ as predictors of outcomes in Intensive Behavioral Intervention. Research in Autism Spectrum Disorders. 2013;7(9):1142-50.
13 Perry A, Cummings A, Geier JD, et al. Effectiveness of Intensive Behavioral Intervention in a Large, Community-Based Program. Research in Autism Spectrum Disorders. Oct. 2008;2(4):621-42.
14 Shine R, Perry A. The relationship between parental stress and intervention outcome of children with autism. Journal on Developmental Disabilities. 2010;16(2):64-6.
15 Freeman N, Perry A. Outcomes of intensive behavioural intervention in the Toronto Preschool Autism Service. Journal on Developmental Disabilities. 2010;16(2):17-32.
16 Perry A, Cummings A, Geier JD, et al. Predictors of Outcome for Children Receiving Intensive Behavioral Intervention in a Large, Community-Based Program. Research in Autism Spectrum Disorders. 2011;5(1):592-603.
17 Flanagan HE, Perry A, Freeman NL. Effectiveness of large-scale community-based intensive Behavioral Intervention: A waitlist comparison study exploring outcomes and predictors. Research in Autism Spectrum Disorders. 2012;6(2):673-82.
18 Peters-Scheffer N, Didden R, Mulders M, et al. Effectiveness of low intensity behavioral treatment for children with autism spectrum disorder and intellectual disability. Research in Autism Spectrum Disorders. 2013;7(9):1012-25.
19 Reed P, Osborne LA, Makrygianni M, et al. Evaluation of the Barnet Early Autism Model (BEAM) Teaching Intervention Programme in a “Real World” Setting. Research in Autism Spectrum Disorders. June. 2013. 2013;7(6):631-8.
20 Schertz HH, Odom SL, Baggett KM, et al. Effects of Joint Attention Mediated Learning for Toddlers with Autism Spectrum Disorders: An Initial Randomized Controlled Study. Early Childhood Research Quarterly. 2013. 2013;28(2):249-58.
21 Schreibman L, Stahmer AC. A Randomized Trial Comparison of the Effects of Verbal and Pictorial Naturalistic Communication Strategies on Spoken Language for Young Children with Autism. J Autism Dev Disord. 2013. Nov. 23. [pmid: 24272416].
22 Sharp WG, Burrell TL, Jaquess DL. The Autism MEAL Plan: A parent-training curriculum to manage eating aversions and low intake among children with autism. Autism. 2013. Oct. 7. [pmid: 24101716].
23 Siller M, Hutman T, Sigman M. A Parent-Mediated Intervention to Increase Responsive Parental Behaviors and Child Communication in Children with ASD: A Randomized Clinical Trial. Journal of Autism and Developmental Disorders. 2013;43(3):540-55. [pmid: 22825926].
24 Storch EA, Arnold EB, Lewin AB, et al. The effect of cognitive-behavioral therapy versus treatment as usual for anxiety in children with autism spectrum disorders: A randomized, controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2013;52(2):132-42. [pmid: 23357440].
25 Warreyn P, Roeyers H. See what I see, do as I do: Promoting joint attention and imitation in preschoolers with autism spectrum disorder. Autism. 2013. Oct. 8. [pmid: 24104513].
26 Wong CS. A play and joint attention intervention for teachers of young children with Autism: A randomized controlled pilot study. Autism. May. 2013. 2013;17(3):340-57. [pmid: 23610236].
27 Adkins KW, Molloy C, Weiss SK, et al. Effects of a standardized pamphlet on insomnia in children with autism spectrum disorders. Pediatrics. Nov. 2012;130(Suppl 2):S139-44. [pmid: 23118244].
28 Aldred C, Green J, Emsley R, et al. Mediation of treatment effect in a communication intervention for pre-school children with autism. Journal of Autism and Developmental Disorders. 2012;42(3):447-54. [pmid: 21512834].
29 Aldred C, Green J, Adams C. A new social communication intervention for children with autism: pilot randomised controlled treatment study suggesting effectiveness. J Child Psychol Psychiatry. Nov. 2004;45(8):1420-30. [pmid: 15482502].
30 Cortesi F, Giannotti F, Sebestiani T, et al. Controlled‐release melatonin, singly and combined with cognitive behavioural therapy, for persistent insomnia in children with autism spectrum disorders: A randomized placebo‐controlled trial. Journal of Sleep Research. 2012;21(6):700-9. [pmid: 22616853].
31 Dawson G, Jones EJ, Merkle K, et al. Early behavioral intervention is associated with normalized brain activity in young children with autism. J Am Acad Child Adolesc Psychiatry. Nov. 2012;51(11):1150-9. [pmid: 23101741].
32 Dawson G, Rogers S, Munson J, et al. Randomized, Controlled Trial of an Intervention for Toddlers With Autism: The Early Start Denver Model. Pediatrics. 2010. January. 2010.
33 Eikeseth S, Klintwall L, Jahr E, et al. Outcome for Children with Autism Receiving Early and Intensive Behavioral Intervention in Mainstream Preschool and Kindergarten Settings. Research in Autism Spectrum Disorders. 2012;6(2):829-35.
34 Eldevik S, Hastings RP, Jahr E, et al. Outcomes of behavioral intervention for children with autism in mainstream pre-school settings. J Autism Dev Disord. Feb. 2012;42(2):210-20. [pmid: 21472360].
35 Scahill L, McDougle CJ, Aman MG, et al. Effects of risperidone and parent training on adaptive functioning in children with pervasive developmental disorders and serious behavioral problems. J Am Acad Child Adolesc Psychiatry. Feb. 2012;51(2):136-46. [pmid: 22265360].
36 Farmer C, Lecavalier L, Yu S, et al. Predictors and moderators of parent training efficacy in a sample of children with autism spectrum disorders and serious behavioral problems. J Autism Dev Disord. Jun. 2012;42(6):1037-44. [pmid: 21822762].
37 Arnold LE, Aman MG, Li X, et al. Research units of pediatric psychopharmacology (RUPP) autism network randomized clinical trial of parent training and medication: One-year follow-Up. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(11):1173-84. [pmid: 23101743].
38 Handen BL, Johnson CR, Butter EM, et al. Use of a Direct Observational Measure in a Trial of Risperidone and Parent Training in Children with Pervasive Developmental Disorders. J Dev Phys Disabil. Jun. 1. 2013;25(3):355-71. [pmid: 23730123].
39 Ingersoll B. Brief report: effect of a focused imitation intervention on social functioning in children with autism. J Autism Dev Disord. Aug. 2012;42(8):1768-73. [pmid: 22146934].
40 Ingersoll B. Brief report: Pilot randomized controlled trial of reciprocal imitation training for teaching elicited and spontaneous imitation to children with autism. Journal of Autism and Developmental Disorders. 2010;40(9):1154-60. [pmid: 20155309].
41 Kaale A, Smith L, Sponheim E. A randomized controlled trial of preschool-based joint attention intervention for children with autism. J Child Psychol Psychiatry. Jan. 2012;53(1):97-105. [pmid: 21883204].
42 Kasari C, Gulsrud A, Freeman S, et al. Longitudinal follow-up of children with autism receiving targeted interventions on joint attention and play. J Am Acad Child Adolesc Psychiatry. May. 2012;51(5):487-95. [pmid: 22525955].
43 Lawton K, Kasari C. Brief Report: Longitudinal Improvements in the Quality of Joint Attention in Preschool Children with Autism. Journal of Autism and Developmental Disorders. 2012;42(2):307-12. [pmid: 22187107].
44 Kasari C, Freeman S, Paparella T. Joint attention and symbolic play in young children with autism: a randomized controlled intervention study. J Child Psychol Psychiatry. Jun. 2006;47(6):611-20. [pmid: 16712638].
45 Kasari C, Paparella T, Freeman S, et al. Language outcome in autism: randomized comparison of joint attention and play interventions. J Consult Clin Psychol. Feb. 2008;76(1):125-37. [pmid: 18229990].
46 Kasari C, Rotheram-Fuller E, Locke J, et al. Making the connection: randomized controlled trial of social skills at school for children with autism spectrum disorders. J Child Psychol Psychiatry. Apr. 2012;53(4):431-9. [pmid: 22118062].
47 Landa RJ, Holman KC, O'Neill AH, et al. Intervention targeting development of socially synchronous engagement in toddlers with autism spectrum disorder: a randomized controlled trial. J Child Psychol Psychiatry. Jan. 2011;52(1):13-21. [pmid: 21126245].
48 Landa RJ, Kalb LG. Long-term outcomes of toddlers with autism spectrum disorders exposed to short-term intervention. Pediatrics. Nov. 2012;130(Suppl 2):S186-90. [pmid: 23118250].
49 Lawton K, Kasari C. Teacher-implemented joint attention intervention: pilot randomized controlled study for preschoolers with autism. J Consult Clin Psychol. Aug. 2012;80(4):687-93. [pmid: 22582764].
50 Lerner MD, Mikami AY. A preliminary randomized controlled trial of two social skills interventions for youth with high-functioning autism spectrum disorders. Focus on Autism and Other Developmental Disabilities. 2012;27(3):147-57.
51 Reaven J, Blakeley-Smith A, Culhane-Shelburne K, et al. Group cognitive behavior therapy for children with high-functioning autism spectrum disorders and anxiety: a randomized trial. J Child Psychol Psychiatry. Apr. 2012;53(4):410-9. [pmid: 22435114].
52 Reed P, Osborne L. Impact of Severity of Autism and Intervention Time-Input on Child Outcomes: Comparison across Several Early Interventions. British Journal of Special Education. 2012;39(3):130-6.
53 Rogers SJ, Estes A, Lord C, et al. Effects of a brief Early Start Denver Model (ESDM)–based parent intervention on toddlers at risk for autism spectrum disorders: A randomized controlled trial. Journal of the American Academy of Child & Adolescent Psychiatry. 2012;51(10):1052-65. [pmid: 23021480].
54 Estes A, Vismara L, Mercado C, et al. The Impact of Parent-Delivered Intervention on Parents of Very Young Children with Autism. J Autism Dev Disord. 2013. Jul. 10. [pmid: 23838727].
55 Strauss K, Vicari S, Valeri G, et al. Parent inclusion in Early Intensive Behavioral Intervention: the influence of parental stress, parent treatment fidelity and parent-mediated generalization of behavior targets on child outcomes. Res Dev Disabil. Mar-Apr. 2012;33(2):688-703. [pmid: 22188793].
56 Fava L, Strauss K, Valeri G, et al. The Effectiveness of a Cross-Setting Complementary Staff- and Parent-Mediated Early Intensive Behavioral Intervention for Young Children with ASD. Research in Autism Spectrum Disorders. 2011;5(4):1479-92.
57 Thomeer ML, Lopata C, Volker MA, et al. Randomized clinical trial replication of a psychosocial treatment for children with high‐functioning autism spectrum disorders. Psychology in the Schools. 2012;49(10):942-54.
58 Venker CE, McDuffie A, Weismer SE, et al. Increasing Verbal Responsiveness in Parents of Children with Autism: A Pilot Study. Autism: The International Journal of Research and Practice. 2012;16(6):568-85. [pmid: 21846665].
59 Williams BT, Gray KM, Tonge BJ. Teaching Emotion Recognition Skills to Young Children with Autism: A Randomised Controlled Trial of an Emotion Training Programme. Journal of Child Psychology and Psychiatry. 2012;53(12):1268-76. [pmid: 22881991].
60 Young RL, Posselt M. Using the transporters DVD as a learning tool for children with Autism Spectrum Disorders (ASD). J Autism Dev Disord. Jun. 2012;42(6):984-91. [pmid: 21822764].
61 Begeer S, Gevers C, Clifford P, et al. Theory of mind training in children with autism: A randomized controlled trial. Journal of Autism and Developmental Disorders. 2011;41(8):997-1006. [pmid: 20976617].
62 Carter AS, Messinger DS, Stone WL, et al. A randomized controlled trial of Hanen's ‘More Than Words’ in toddlers with early autism symptoms. J Child Psychol Psychiatry. Jul. 2011;52(7):741-52. [pmid: 21418212].
63 Castorina LL, Negri LM. The inclusion of siblings in social skills training groups for boys with Asperger syndrome. J Autism Dev Disord. Jan. 2011;41(1):73-81. [pmid: 20461452].
64 DeRosier ME, Swick DC, Davis NO, et al. The efficacy of a Social Skills Group Intervention for improving social behaviors in children with High Functioning Autism Spectrum disorders. J Autism Dev Disord. Aug. 2011;41(8):1033-43. [pmid: 21042870].
65 Drahota A, Wood JJ, Sze KM, et al. Effects of cognitive behavioral therapy on daily living skills in children with high-functioning autism and concurrent anxiety disorders. J Autism Dev Disord. Mar. 2011;41(3):257-65. [pmid: 20508979].
66 Wood JJ, Drahota A, Sze K, et al. Brief Report: Effects of Cognitive Behavioral Therapy on Parent-Reported Autism Symptoms in School-Age Children with High-Functioning Autism. Journal of Autism and Developmental Disorders. Nov. 2009;39(11):1608-12. [pmid: 19562475].
67 Wood JJ, Drahota A, Sze K, et al. Cognitive Behavioral Therapy for Anxiety in Children with Autism Spectrum Disorders: A Randomized, Controlled Trial. Journal of Child Psychology and Psychiatry. Mar. 2009;50(3):224-34. [pmid: 19309326].
68 Zachor DA, Itzchak EB. Treatment Approach, Autism Severity and Intervention Outcomes in Young Children. Research in Autism Spectrum Disorders. 2010;4(3):425-32.
69 Itzchak EB, Zachor DA. Who Benefits from Early Intervention in Autism Spectrum Disorders?. Research in Autism Spectrum Disorders. 2011;5(1):345-50.
70 Kovshoff H, Hastings RP, Remington B. Two-year outcomes for children with autism after the cessation of early intensive behavioral intervention. Behav Modif. Sep. 2011;35(5):427-50. [pmid: 21586502].
71 Remington B, Hastings RP, Kovshoff H, et al. Early intensive behavioral intervention: outcomes for children with autism and their parents after two years. Am J Ment Retard. Nov. 2007;112(6):418-38. [pmid: 17963434].
72 Murdock LC, Hobbs JQ. Picture Me Playing: Increasing Pretend Play Dialogue of Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 2011;41(7):870-8. [pmid: 20872061].
73 Pajareya K, Nopmaneejumruslers K. A pilot randomized controlled trial of DIR/Floortime parent training intervention for pre-school children with autistic spectrum disorders. Autism. Sep. 2011;15(5):563-77. [pmid: 21690083].
74 Roberts J, Williams K, Carter M, et al. A Randomised Controlled Trial of Two Early Intervention Programs for Young Children with Autism: Centre-Based with Parent Program and Home-Based. Research in Autism Spectrum Disorders. 2011;5(4):1553-66.
75 Scarpa A, Reyes NM. Improving emotion regulation with CBT in young children with high functioning autism spectrum disorders: a pilot study. Behav Cogn Psychother. Jul. 2011;39(4):495-500. [pmid: 21457605].
76 Strain PS, Bovey EH. Randomized, Controlled Trial of the Leap Model of Early Intervention for Young Children with Autism Spectrum Disorders. Topics in Early Childhood Special Education. 2011;31(3):133-54.
77 Sung M, Ooi YP, Goh TJ, et al. Effects of cognitive-behavioral therapy on anxiety in children with autism spectrum disorders: a randomized controlled trial. Child Psychiatry Hum Dev. Dec. 2011;42(6):634-49. [pmid: 21660428].
78 Kasari C, Gulsrud AC, Wong C, et al. Randomized controlled caregiver mediated joint engagement intervention for toddlers with autism. Journal of Autism and Developmental Disorders. 2010;40(9):1045-56. [pmid: 20145986].
79 Keen D, Couzens D, Muspratt S, et al. The effects of a parent-focused intervention for children with a recent diagnosis of autism spectrum disorder on parenting stress and competence. Research in Autism Spectrum Disorders. 2010;4(2):229-41.
80 Koenig K, White SW, Pachler M, et al. Promoting social skill development in children with pervasive developmental disorders: a feasibility and efficacy study. J Autism Dev Disord. Oct. 2010;40(10):1209-18. [pmid: 20204689].
81 Kouijzer MEJ, van Schie HT, de Moor JMH, et al. Neurofeedback treatment in autism. Preliminary findings in behavioral, cognitive, and neurophysiological functioning. Research in Autism Spectrum Disorders. 2010;4(3):386-99.
82 Lopata C, Thomeer ML, Volker MA, et al. RCT of a manualized social treatment for high-functioning autism spectrum disorders. J Autism Dev Disord. Nov. 2010;40(11):1297-310. [pmid: 20232240].
83 McConkey R, Truesdale-Kennedy M, Crawford H, et al. Preschoolers with Autism Spectrum Disorders: Evaluating the Impact of a Home-Based Intervention to Promote Their Communication. Early Child Development and Care. 2010;180(3):299-315.
84 Oosterling I, Visser J, Swinkels S, et al. Randomized controlled trial of the focus parent training for toddlers with autism: 1-year outcome. J Autism Dev Disord. Dec. 2010;40(12):1447-58. [pmid: 20440639].
85 Peters-Scheffer N, Didden R, Mulders M, et al. Low intensity behavioral treatment supplementing preschool services for young children with autism spectrum disorders and severe to mild intellectual disability. Res Dev Disabil. Nov-Dec. 2010;31(6):1678-84. [pmid: 20627451].
86 Wong VCN, Kwan QK. Randomized controlled trial for early intervention for autism: A pilot study of the Autism 1-2-3 project. Journal of Autism and Developmental Disorders. 2010;40(6):677-88. [pmid: 20020319].
87 Aman MG, McDougle CJ, Scahill L, et al. Medication and Parent Training in Children With Pervasive Developmental Disorders and Serious Behavior Problems: Results From a Randomized Clinical Trial. J Am Acad Child Adolesc Psychiatry. 2009. Oct. 23. [pmid: 19858761].
88 Kouijzer MEJ, de Moor JMH, Gerrits BJL, et al. Neurofeedback Improves Executive Functioning in Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. Jan. 2009;3(1):145-62.
89 Kouijzer MEJ, de Moor JMH, Gerrits BJL, et al. Long-term effects of neurofeedback treatment in autism. Research in Autism Spectrum Disorders. 2009;3(2):496-501.