# Screening and Quality Assessment Forms

Abstract Review Form

Full Text Review Form

Quality/Risk of Bias Rating Form