# Search Strategies

Table A-1 PubMed search strategies

Search terms | | Search results
#1 | Autistic[tiab] OR autism[tiab] OR autistic disorder[mh] OR asperger syndrome[mh] OR child development disorders, pervasive[mh:noexp] OR asperger[tiab] OR asperger's[tiab] OR aspergers[tiab] OR pervasive development[tiab] OR pervasive developmental[tiab] OR pdd[tiab] | 26442
#2 | therapy[sh] OR therapeutics[mh] OR teaching[mh] OR psychotherapy[mh] OR treatment outcome[mh] | 6660534
#3 | #1 AND #2 AND eng[la] AND humans[mh] | 6377
#4 | newspaper article[pt] OR letter[pt] OR comment[pt] OR case reports[pt] OR review[pt] OR practice guideline[pt] OR news[pt] OR editorial[pt] OR historical article[pt] OR meta-analysis[pt] OR legal cases[pt] OR published erratum[pt] OR congresses[pt] | 4864950
#17 | #3 NOT #4 AND 2000:2013[dp] | 2505

Key: [mh] Medical Subject Heading; [tiab] title/abstract word; [pt] publication type; [sh] subheading; [dp] publication date; [la] language; [pt] publication type

Table A-2 PsycINFO search strategies (ProQuest interface)

Search terms | | Search results
#1 | SU.EXACT.EXPLODE(“pervasive developmental disorders” or “aspergers syndrome” or “autism”) | 24282
#2 | SU.EXACT.EXPLODE(“Treatment”) OR SU.EXACT.EXPLODE(“Medicinal Herbs and Plants”) OR SU.EXACT.EXPLODE(“Dietary Supplements”) OR SU.EXACT.EXPLODE(“Nutrition”) OR SU.EXACT.EXPLODE(“Vitamins”) | 562313
#3 | #1 and #2 and DTYPE(journal article) and (ME(empirical study) or ME(field study) or ME(followup study) or ME(longitudinal study) or ME(prospective study) or ME(qualitative study) or ME(quantitative study) or ME(retrospective study) or ME(treatment outcome/clinical trial)) and LA(English), limited to peer-reviewed journals and human population, limited to publication date 2000 to present | 1089**

Key: DE subject descriptor; PT publication type; ME methodology; AE age group

Table A-3 ERIC search strategies (ProQuest interface)

Search terms | | Search results
#1 | SU.EXACT.EXPLODE(“Autism”) OR SU.EXACT(“Pervasive Developmental Disorders”) OR SU.EXACT.EXPLODE(“Asperger Syndrome”) | 9380
#2 | SU.EXACT.EXPLODE(“Therapy”) OR SU.EXACT.EXPLODE(“Intervention”) OR SU.EXACT.EXPLODE(“Outcomes of Treatment”) OR SU.EXACT.EXPLODE(“Special Education”) OR SU.EXACT.EXPLODE(“Dietetics”) OR SU.EXACT.EXPLODE(“Nutrition”) OR SU.EXACT.EXPLODE(“Adapted Physical Education”) OR SU.EXACT.EXPLODE(“Therapeutic Environment”) OR SU.EXACT.EXPLODE(“Food”) | 80298
#3 | #1 and #2 and LA(English), limited to peer reviewed journals, 2000 to present | 1782**

Key: DE subject descriptor, KW keyword