# Abbreviations

ABA: Applied Behavior Analysis
ABC-H: Aberrant Behavior Checklist – Hyperactivity/Noncompliance
ADI-R: Autism Diagnostic Interview - Revised
ADOS: Autism Diagnostic Observation Schedule
AEPS: Assessment Evaluation and Programming System for Infants
AHRQ: Agency for Healthcare Research and Quality
ASD: Autism Spectrum Disorder
BASC: Behavioral Assessment System for Children
CAM: Complementary and Alternative Medicine
CARS: Childhood Autism Rating Scale
CBT: Cognitive Behavioral Therapy
CER: Comparative Effectiveness Review
CGI-I: Clinical Global Impression-Improvement
CGI-S: Clinical Global Impression-Severity
DIR: Developmental, Individual Differences, Relationship-based model
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, 4^th^ Edition
DSM-5: Diagnostic and Statistical Manual of Mental Disorders, 5^th^ Edition
DQ: Developmental Quotient
EEG: Electroencephalogram
EPC: Evidence-based Practice Center
ERIC: Educational Resources Information Clearinghouse
ESDM: Early Start Denver Model
GARS: Gilliam Autism Rating Scale
HSQ: Home Situations Questionnaire
IQ: Intelligence Quotient
KQ: Key Question
JASP/ER: Joint Attention and Symbolic Play/Engagement and Regulation Intervention
LEAP: Learning Experiences and Alternative Program for Preschoolers
M-CHAT: Modified Checklist for Autism in Toddlers
MEHRIT: Milton and Ethel Harris Research Initiative Treatment Program
NR: Not Reported
nRCT: Non-Randomized Controlled Trial
NS: Not Statistically Significant
PARS: Pediatric Anxiety Rating Scale
PDD-NOS: Pervasive Developmental Disorder- Not Otherwise Specified
PECS: Picture Exchange Communication System
PEER: Peer-Mediated Social Skills Training
PICOTS: Population, Intervention, Comparator, Outcomes, Timing, and Setting
RCT: Randomized Controlled Trial
SCARED: Screen for Childhood Anxiety Related Emotional Disorders
SDARI: Sociodramatic Affective Relational Intervention
SOE: Strength of the evidence
SS GRIN-HFA: Social Skills Group Intervention – High Functioning Autism
TEP: Technical Expert Panel
TOO: Task Order Officer
TEACCH: Treatment and Education of Autistic and Related Communication Handicapped Children
UCLA: University of California, Los Angeles