# References

1 American Thoracic Society, Infectious Diseases Society of America. Guidelines for the management of adults with hospital-acquired, ventilator-associated, and healthcare-associated pneumonia. Am J Respir Crit Care Med. Feb. 15. 2005;171(4):388-416. Epub: 2005/02/09. [pmid: 15699079].
2 Chawla R. Epidemiology, etiology, and diagnosis of hospital-acquired pneumonia and ventilator-associated pneumonia in Asian countries. Am J Infect Control. May. 2008;36(4 Suppl):S93-100. Epub: 2008/05/28. [pmid: 18468551].
3 Vincent JL, Rello J, Marshall J, et al. International study of the prevalence and outcomes of infection in intensive care units. JAMA. Dec. 2. 2009;302(21):2323-9. Epub: 2009/12/03. [pmid: 19952319].
4 Forel JM, Voillet F, Pulina D, et al. Ventilator-associated pneumonia and ICU mortality in severe ARDS patients ventilated according to a lung-protective strategy. Crit Care. 2012;16(2):R65. Epub: 2012/04/25. [pmid: 22524447].
5 Valles J, Peredo R, Burgueno MJ, et al. Efficacy of single-dose antibiotic against early-onset pneumonia in comatose patients who are ventilated. Chest. May. 2013;143(5):1219-25. Epub: 2013/05/30. [pmid: 23715136].
6 Chung DR, Song JH, Kim SH, et al. High prevalence of multidrug-resistant nonfermenters in hospital-acquired pneumonia in Asia. Am J Respir Crit Care Med. Dec. 15. 2011;184(12):1409-17. Epub: 2011/09/17. [pmid: 21920919].
7 Rello J, Ulldemolins M, Lisboa T, et al. Determinants of prescription and choice of empirical therapy for hospital-acquired and ventilator-associated pneumonia. Eur Respir J. Jun. 2011;37(6):1332-9. Epub: 2010/09/18. [pmid: 20847075].
8 Agrafiotis M, Siempos II, Ntaidou TK, et al. Attributable mortality of ventilator-associated pneumonia: a meta-analysis. Int J Tuberc Lung Dis. Sep. 2011;15(9):1154-63. i. v. Epub: 2011/06/15. [pmid: 21669028].
9 Timsit JF, Zahar JR, Chevret S. Attributable mortality of ventilator-associated pneumonia. Curr Opin Crit Care. Oct. 2011;17(5):464-71. Epub: 2011/08/17. [pmid: 21844801].
10 File TM. Risk factors and prevention of hospital-acquired, ventilator-associated, and healthcare-associated pneumonia in adults. UpToDate, Inc. June. 26. 2012;2012. http://www.uptodate.com/contents/risk-factors-and-prevention-of-hospital-acquired-ventilator-associated-and-healthcare-associated-pneumonia-in-adults. December 11, 2012.
11 Craven DE, Kunches LM, Kilinsky V, et al. Risk factors for pneumonia and fatality in patients receiving continuous mechanical ventilation. Am Rev Respir Dis. May. 1986;133(5):792-6. Epub: 1986/05/01. [pmid: 3706887].
12 Kollef MH. Prevention of hospital-associated pneumonia and ventilator-associated pneumonia. Crit Care Med. Jun. 2004;32(6):1396-405. Epub: 2004/06/10. [pmid: 15187525].
13 Bornstain C, Azoulay E, De Lassence A, et al. Sedation, sucralfate, and antibiotic use are potential means for protection against early-onset ventilator-associated pneumonia. Clin Infect Dis. May. 15. 2004;38(10):1401-8. Epub: 2004/05/25. [pmid: 15156478].
14 Celis R, Torres A, Gatell JM, et al. Nosocomial pneumonia. A multivariate analysis of risk and prognosis. Chest. Feb. 1988;93(2):318-24. Epub: 1988/02/01. [pmid: 3338299].
15 Kollef MH, Von Harz B, Prentice D, et al. Patient transport from intensive care increases the risk of developing ventilator-associated pneumonia. Chest. Sep. 1997;112(3):765-73. Epub: 1997/10/07. [pmid: 9315813].
16 Torres A, Gatell JM, Aznar E, et al. Re-intubation increases the risk of nosocomial pneumonia in patients needing mechanical ventilation. Am J Respir Crit Care Med. Jul. 1995;152(1):137-41. Epub: 1995/07/01. [pmid: 7599812].
17 Kollef MH. Ventilator-associated pneumonia. A multivariate analysis. JAMA. Oct. 27. 1993;270(16):1965-70. Epub: 1993/10/27. [pmid: 8411554].
18 Kollef MH, Vlasnik J, Sharpless L, et al. Scheduled change of antibiotic classes: a strategy to decrease the incidence of ventilator-associated pneumonia. Am J Respir Crit Care Med. Oct. 1997;156(4 Pt 1):1040-8. Epub: 1997/11/14. [pmid: 9351601].
19 Chastre J, Trouillet JL, Vuagnat A, et al. Nosocomial pneumonia in patients with acute respiratory distress syndrome. Am J Respir Crit Care Med. Apr. 1998;157(4 Pt 1):1165-72. Epub: 1998/05/01. [pmid: 9563735].
20 Coffin SE, Klompas M, Classen D, et al. Strategies to prevent ventilator-associated pneumonia in acute care hospitals. Infect Control Hosp Epidemiol. Oct. Suppl 1. 2008;29:S31-40. Epub: 2008/10/09. [pmid: 18840087].
21 Hortal J, Giannella M, Perez MJ, et al. Incidence and risk factors for ventilator-associated pneumonia after major heart surgery. Intensive Care Med. Sep. 2009;35(9):1518-25. Epub: 2009/06/27. [pmid: 19557389].
22 Seymann GB, Di Francesco L, Sharpe B, et al. The HCAP gap: differences between self-reported practice patterns and published guidelines for health care-associated pneumonia. Clin Infect Dis. Dec. 15. 2009;49(12):1868-74. Epub: 2009/11/17. [pmid: 19911940].
23 Zilberberg MD, Shorr AF, Micek ST, et al. Antimicrobial therapy escalation and hospital mortality among patients with health-care-associated pneumonia: a single-center experience. Chest. Nov. 2008;134(5):963-8. Epub: 2008/07/22. [pmid: 18641103].
24 Kollef MH, Sherman G, Ward S, et al. Inadequate antimicrobial treatment of infections: a risk factor for hospital mortality among critically ill patients. Chest. Feb. 1999;115(2):462-74. Epub: 1999/02/23. [pmid: 10027448].
25 Iregui M, Ward S, Sherman G, et al. Clinical importance of delays in the initiation of appropriate antibiotic treatment for ventilator-associated pneumonia. Chest. Jul. 2002;122(1):262-8. Epub: 2002/07/13. [pmid: 12114368].
26 McKinnon PS, Paladino JA, Schentag JJ. Evaluation of area under the inhibitory curve (AUIC) and time above the minimum inhibitory concentration (T>MIC) as predictors of outcome for cefepime and ceftazidime in serious bacterial infections. Int J Antimicrob Agents. Apr. 2008;31(4):345-51. Epub: 2008/03/04. [pmid: 18313273].
27 Olofsson SK, Cars O. Optimizing drug exposure to minimize selection of antibiotic resistance. Clin Infect Dis. Sep. 1. Suppl 2. 2007;45:S129-36. Epub: 2007/08/19. [pmid: 17683017].
28 Olofsson SK, Marcusson LL, Stromback A, et al. Dose-related selection of fluoroquinolone-resistant Escherichia coli. J Antimicrob Chemother. Oct. 2007;60(4):795-801. Epub: 2007/07/20. [pmid: 17635875].
29 Roberts JA, Kruger P, Paterson DL, et al. Antibiotic resistance--what's dosing got to do with it?. Crit Care Med. Aug. 2008;36(8):2433-40. Epub: 2008/07/04. [pmid: 18596628].
30 Drusano GL. Antimicrobial pharmacodynamics: critical interactions of ‘bug and drug’. Nat Rev Microbiol. Apr. 2004;2(4):289-300. Epub: 2004/03/20. [pmid: 15031728].
31 Lodise TP, Drusano GL, Butterfield JM, et al. Penetration of vancomycin into epithelial lining fluid in healthy volunteers. Antimicrob Agents Chemother. Dec. 2011;55(12):5507-11. Epub: 2011/09/14. [pmid: 21911567].
32 Conte JE Jr, Golden JA, Kipps J, et al. Intrapulmonary pharmacokinetics of linezolid. Antimicrob Agents Chemother. May. 2002;46(5):1475-80. Epub: 2002/04/18. [pmid: 11959585].
33 Boselli E, Breilh D, Rimmele T, et al. Pharmacokinetics and intrapulmonary concentrations of linezolid administered to critically ill patients with ventilator-associated pneumonia. Crit Care Med. Jul. 2005;33(7):1529-33. Epub: 2005/07/09. [pmid: 16003058].
34 Rodvold KA, George JM, Yoo L. Penetration of anti-infective agents into pulmonary epithelial lining fluid: focus on antibacterial agents. Clin Pharmacokinet. Oct. 2011;50(10):637-64. Epub: 2011/09/08. [pmid: 21895037].
35 Rybak M, Lomaestro B, Rotschafer JC, et al. Therapeutic monitoring of vancomycin in adult patients: a consensus review of the American Society of Health-System Pharmacists, the Infectious Diseases Society of America, and the Society of Infectious Diseases Pharmacists. Am J Health Syst Pharm. Jan. 1. 2009;66(1):82-98. Epub: 2008/12/25. [pmid: 19106348].
36 Peterson LR. Bad bugs, no drugs: no ESCAPE revisited. Clin Infect Dis. Sep. 15. 2009;49(6):992-3. Epub: 2009/08/22. [pmid: 19694542].
37 Centers for Disease Control and Prevention. Antibiotic Resistance Threats in the United States, 2013. Atlanta, GA. CDC. 2013. www.cdc.gov/drugresistance/threat-report-2013. September 16, 2013.
38 Kashuba AD, Nafziger AN, Drusano GL, et al. Optimizing aminoglycoside therapy for nosocomial pneumonia caused by gram-negative bacteria. Antimicrob Agents Chemother. Mar. 1999;43(3):623-9. Epub: 1999/02/27. [pmid: 10049277].
39 Moore RD, Lietman PS, Smith CR. Clinical response to aminoglycoside therapy: importance of the ratio of peak concentration to minimal inhibitory concentration. J Infect Dis. Jan. 1987;155(1):93-9. Epub: 1987/01/01. [pmid: 3540140].
40 Housman ST, Kuti JL, Nicolau DP. Optimizing antibiotic pharmacodynamics in hospital-acquired and ventilator-acquired bacterial pneumonia. Clin Chest Med. Sep. 2011;32(3):439-50. Epub: 2011/08/27. [pmid: 21867814].
41 Craig WA. Interrelationship between pharmacokinetics and pharmacodynamics in determining dosage regimens for broad-spectrum cephalosporins. Diagn Microbiol Infect Dis. May-Jun. 1995;22(1-2):89-96. Epub: 1995/05/01. [pmid: 7587056].
42 Vogelman B, Gudmundsson S, Leggett J, et al. Correlation of antimicrobial pharmacokinetic parameters with therapeutic efficacy in an animal model. J Infect Dis. Oct. 1988;158(4):831-47. Epub: 1988/10/01. [pmid: 3139779].
43 Leggett JE, Fantin B, Ebert S, et al. Comparative antibiotic dose-effect relations at several dosing intervals in murine pneumonitis and thigh-infection models. J Infect Dis. Feb. 1989;159(2):281-92. Epub: 1989/02/01. [pmid: 2644371].
44 Rybak MJ, Lomaestro BM, Rotschafer JC, et al. Vancomycin therapeutic guidelines: a summary of consensus recommendations from the infectious diseases Society of America, the American Society of Health-System Pharmacists, and the Society of Infectious Diseases Pharmacists. Clin Infect Dis. Aug. 1. 2009;49(3):325-7. Epub: 2009/07/03. [pmid: 19569969].
45 Moise-Broder PA, Forrest A, Birmingham MC, et al. Pharmacodynamics of vancomycin and other antimicrobials in patients with Staphylococcus aureus lower respiratory tract infections. Clin Pharmacokinet. 2004;43(13):925-42. Epub: 2004/10/29. [pmid: 15509186].
46 Ambrose PG, Bhavnani SM, Ellis-Grosse EJ, et al. Pharmacokinetic-pharmacodynamic considerations in the design of hospital-acquired or ventilator-associated bacterial pneumonia studies: look before you leap!. Clin Infect Dis. Aug. 1. Suppl 1. 2010;51:S103-10. Epub: 2010/07/06. [pmid: 20597657].
47 Ambrose PG, Bhavnani SM, Rubino CM, et al. Pharmacokinetics-pharmacodynamics of antimicrobial therapy: it's not just for mice anymore. Clin Infect Dis. Jan. 1. 2007;44(1):79-86. Epub: 2006/12/05. [pmid: 17143821].
48 Roberts DM, Roberts JA, Roberts MS, et al. Variability of antibiotic concentrations in critically ill patients receiving continuous renal replacement therapy: a multicentre pharmacokinetic study. Crit Care Med. May. 2012;40(5):1523-8. Epub: 2012/04/19. [pmid: 22511133].
49 Franzetti F, Antonelli M, Bassetti M, et al. Consensus document on controversial issues for the treatment of hospital-associated pneumonia. Int J Infect Dis. Oct. Suppl 4. 2010;14:S55-65. Epub: 2010/09/25. [pmid: 20863734].
50 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. Jul. 21. 2009;6(7):e1000097. Epub: 2009/07/22. [pmid: 19621072].
51 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. AHRQ Pub. No.12-EHC047-EF. Rockville MD. 2008.
52 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. Epub: 2009/07/15. [pmid: 19595577].
53 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. Epub: 2011/04/06. [pmid: 21463926].
54 Nicolau DP, Lacy MK, McNabb J, et al. Pharmacokinetics of continuous and intermittent ceftazidime in intensive care unit patients with nosocomial pneumonia. Infect Dis Clin Pract. 1999;8(1):45-9.
55 McNabb JJ, Nightingale CH, Quintiliani R, et al. Cost-effectiveness of ceftazidime by continuous infusion versus intermittent infusion for nosocomial pneumonia. Pharmacotherapy. May. 2001;21(5):549-55. Epub: 2001/05/15. [pmid: 11349744].
56 Sakka SG, Glauner AK, Bulitta JB, et al. Population pharmacokinetics and pharmacodynamics of continuous versus short-term infusion of imipenem-cilastatin in critically ill patients in a randomized, controlled trial. Antimicrob Agents Chemother. Sep. 2007;51(9):3304-10. Epub: 2007/07/11. [pmid: 17620371].
57 Nicolau DP, McNabb J, Lacy MK, et al. Continuous versus intermittent administration of ceftazidime in intensive care unit patients with nosocomial pneumonia. Int J Antimicrob Agents. Jun. 2001;17(6):497-504. Epub: 2001/06/09. [pmid: 11397621].
58 Nicolau DP, McNabb J, Lacy MK, et al. Pharmacokinetics and pharmacodynamics of continuous and intermittent ceftazidime during the treatment of nosocomial pneumonia. Clin Drug Invest. 1999;(2):133-9.
59 Hanes SD, Wood GC, Herring V, et al. Intermittent and continuous ceftazidime infusion for critically ill trauma patients. Am J Surg. Jun. 2000;179(6):436-40. Epub: 2000/09/27. [pmid: 11004326].
60 Jaruratanasirikul S, Wongpoowarak W, Kositpantawong N, et al. Pharmacodynamics of doripenem in critically ill patients with ventilator-associated Gram-negative bacilli pneumonia. Int J Antimicrob Agents. Nov. 2012;40(5):434-9. Epub: 2012/09/11. [pmid: 22959555].
61 Wang D. Experience with extended-infusion meropenem in the management of ventilator-associated pneumonia due to multidrugresistant Acinetobacter baumannii. Int J Antimicrob Agents. 2009;33:290-1. [pmid: 19091523].
62 Scaglione F, Esposito S, Leone S, et al. Feedback dose alteration significantly affects probability of pathogen eradication in nosocomial pneumonia. Eur Respir J. Aug. 2009;34(2):394-400. Epub: 2009/02/14. [pmid: 19213786].
63 Fahimi F, Ghafari S, Jamaati H, et al. Continuous versus intermittent administration of piperacillin-tazobactam in intensive care unit patients with ventilator-associated pneumonia. Indian J Crit Care Med. Jul. 2012;16(3):141-7. [pmid: 23188954].
64 Lorente L, Jimenez A, Martin MM, et al. Clinical cure of ventilator-associated pneumonia treated with piperacillin/tazobactam administered by continuous or intermittent infusion. Int J Antimicrob Agents. May. 2009;33(5):464-8. Epub: 2009/01/20. [pmid: 19150225].
65 Knaus WA, Wagner DP, Draper EA, et al. The APACHE III prognostic system. Risk prediction of hospital mortality for critically ill hospitalized adults. Chest. Dec. 1991;100(6):1619-36. Epub: 1991/12/01. [pmid: 1959406].
66 Mohd Hafiz AA, Staatz CE, Kirkpatrick CM, et al. Continuous infusion vs. bolus dosing: implications for beta-lactam antibiotics. Minerva Anestesiol. Jan. 2012;78(1):94-104. Epub: 2011/07/07. [pmid: 21730935].
67 Society for Healthcare Epidemiology of America, Infectious Diseases Society of America, Pediatric Infectious Diseases Society. Policy statement on antimicrobial stewardship by the Society for Healthcare Epidemiology of America (SHEA), the Infectious Diseases Society of America (IDSA), and the Pediatric Infectious Diseases Society (PIDS). Infect Control Hosp Epidemiol. Apr. 2012;33(4):322-7. Epub: 2012/03/16. [pmid: 22418625].
68 Goff DA, Nicolau DP. When pharmacodynamics trump costs: an antimicrobial stewardship program's approach to selecting optimal antimicrobial agents. Clin Ther. Jun. 2013;35(6):766-71. Epub: 2013/06/26. [pmid: 23795574].
69 Dellit TH, Owens RC, McGowan JE Jr, et al. Infectious Diseases Society of America and the Society for Healthcare Epidemiology of America guidelines for developing an institutional program to enhance antimicrobial stewardship. Clin Infect Dis. Jan. 15. 2007;44(2):159-77. Epub: 2006/12/19. [pmid: 17173212].
70 Holland TL, Fowler VG Jr. Vancomycin minimum inhibitory concentration and outcome in patients with Staphylococcus aureus bacteremia: pearl or pellet?. J Infect Dis. Aug. 1. 2011;204(3):329-31. Epub: 2011/07/12. [pmid: 21742827].
71 Holmes NE, Turnidge JD, Munckhof WJ, et al. Antibiotic choice may not explain poorer outcomes in patients with Staphylococcus aureus bacteremia and high vancomycin minimum inhibitory concentrations. J Infect Dis. Aug. 1. 2011;204(3):340-7. Epub: 2011/07/12. [pmid: 21742831].
72 Holmes NE, Turnidge JD, Munckhof WJ, et al. Vancomycin minimum inhibitory concentration, host comorbidities and mortality in Staphylococcus aureus bacteraemia. Clin Microbiol Infect. Dec. 2013;19(12):1163-8. Epub: 2013/02/28. [pmid: 23441652].