# Methods

The methods for this comparative effectiveness review follow the guidance provided in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (www.effectivehealthcare.ahrq.gov/methodsguide.cfm) for the Evidence-based Practice Center (EPC) program. The main sections in this chapter reflect the elements of the protocol established for this review. Certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.50 All methods and analyses were determined a priori.

A stakeholder panel, which was convened by the Blue Cross Blue Shield Technical Evaluation Center for the purpose of identifying relevant topics for systematic review, nominated this topic. The AHRQ Effective Health Care (EHC) program's Topic Triage group then developed and reviewed the topic; because this group deemed the topic sufficiently relevant, they moved it forward for the Topic Refinement phase. All topics are reviewed and assessed for appropriateness for systematic review (see EHC Web site for information on the process for selecting topics: http://www.effectivehealthcare.ahrq.gov/index.cfm/submit-a-suggestion-for-research/how-are-research-topics-chosen/). Once a topic is assessed and determined to be appropriate for further product development in the EHC program, AHRQ assigns it to a research team. Further development of the topic occurs with the input of Key Informants (KIs) and technical experts (see the EHC Web site for information on the research process: http://www.effectivehealthcare.ahrq.gov/index.cfm/submit-a-suggestion-for-research/what-is-the-research-process/).

## Topic Refinement and Review Protocol

During the topic development and refinement processes, we engaged in a public process to develop a draft and final protocol for the review. We generated an analytic framework, preliminary Key Questions (KQs), and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, settings). Information provided by the topic nominator helped guide our processes; similarly, other methods and content experts and KIs provided insights to help formulate our procedures. We also conducted a scan of the relevant literature. We carried out preliminary literature searches and discussions with KIs to develop appropriate KQs.

We worked with five KIs during the topic refinement; all five also served as members of our Technical Expert Panel (TEP) for this report. They represented critical care medicine, pulmonology, infectious disease, infectious disease pharmacy, and payers. TEP members participated in conference calls and discussions through email at several points: review the analytic framework, KQs, and PICOTS; discuss the preliminary assessment of the literature; provide input on the information and categories included in evidence tables; and comment on the data analysis plan.

Our KQs were posted for public comment on AHRQ's EHC program Web site (www.effectivehealthcare.ahrq.gov) from March 22, 2013, through April 18, 2013. We revised them as needed after reviewing the comments and discussing them with the TEP; specifically, we decided to include dose-monitoring studies, in which no therapeutic drug monitoring occurs during the studies but which apply PK/PD principles. We then drafted a protocol for the review that was posted on the same Web site. Its PROSPERO registration number is CRD42013005309.

## Literature Search Strategy

### Search Strategy

To identify articles relevant to each KQ, we searched MEDLINE^®^, the Cochrane Library, and the International Pharmaceutical Abstracts from January 1, 2004, through through May 15, 2013; we later updated the searches through June 7, 2014. (Appendix A presents the full search strategy.) We used either medical subject headings (MeSH) or major headings as search terms when available or key words when appropriate, focusing on terms to describe the relevant population and interventions of interest. We reviewed our search strategy with TEP members and incorporated their input into our search strategies. An experienced information scientist (our EPC librarian) ran the searches; another information scientist (EPC librarian) peer-reviewed the searches.

We limited the electronic searches to English-language and human-only studies. We did not limit searches by date. We manually searched reference lists of pertinent reviews, included trials, and background articles on this topic to identify any relevant citations that our searches might have missed. We imported all citations into an EndNote^®^ X4 electronic database.

We searched for unpublished studies relevant to this review using ClinicalTrials.gov and the World Health Organization's International Clinical Trials Registry Platform. In addition, the AHRQ Scientific Resource Center requested scientific information packets (SIPs) from relevant pharmaceutical and test manufacturing companies, asking for any unpublished studies or data relevant for this systematic review (SR). We received no SIPs.

### Inclusion and Exclusion Criteria

We developed eligibility (inclusion and exclusion) criteria with respect to PICOTS and study designs and durations for each KQ (Table 2). We required that studies measure and report at least one of our specified outcomes. For both intermediate outcomes and health outcomes, randomized controlled trials (RCTs), nonrandomized controlled trials, and prospective cohort studies were eligible. For adverse effects data, case-control and retrospective cohort studies were also eligible.

Table 2 Eligibility criteria for review of PK/PD measures for hospital-acquired pneumonia (HAP)

Criteria | Inclusion Criteria | Exclusion Criteria
Population | Adults (age 18 years or older) who have presumed or confirmed HAP, VAP, or HCAP and are being treated with intravenous antibiotics (listed in Table 1) | - Children and adolescents under 18 years of age; - Fungal pneumonia; - Other methods of administration (e.g., inhaled antibiotics)
Interventions | - KQ 1 and KQ 3: Use of PK/PD measures for dosing and monitoring intravenous antibiotics:; ○ Serum concentration; ○ Volume of distribution; ○ Protein binding; ○ Time above MIC; ○ Ratio of AUC to MIC; - KQ 2 and KQ 3: Prolonged or continuous infusion | - No intervention
Comparators | - KQ 1 and KQ 3; ○ No use of PK/PD measures; ○ Different targets of PK/PD measures; ○ Usual care (e.g., physician discretion or judgment, local epidemiology of bacteria and resistance); - KQ 2 and KQ 3: Bolus dosing | - No comparator; - Studies in which only serum concentration is measured, without targeting different serum concentration levels
Outcomes | - KQ 1a, KQ 2a, and KQ 3: Intermediate outcomes; ○ Clinical response; ○ Mechanical ventilation (occurrence or length); - KQ 1b, KQ 2b, and KQ 3: Health outcomes; ○ Mortality; – In hospital; – Within 30 days of discharge; – All-cause mortality; – Mortality due to pneumonia; ○ Morbidity; – Reinfection, or two episodes of pneumonia with different pathogens; – Relapse, or second episode of pneumonia with the same pathogen; – Superinfection, or infection with multiple pathogens; - KQ 1c, KQ 2c, and KQ 3: Antibiotic-related adverse events; ○ Organ toxicity (e.g., hepatotoxicity, nephrotoxicity); ○ Hematologic effects (e.g., anemia, thrombocytopenia); ○ Clostridium difficile infection; ○ Antibiotic resistance (reported at either the patient or the unit level) | - No outcomes of interest
Timing (length of followup) | No limits | Not applicable
Settings | - Treatment beginning in the hospital (emergency department, floor, or intensive care unit); - Treatment continuing in other settings (e.g., in the home or a skilled nursing facility) | - Treatment beginning in other settings, such as nursing homes
Admissible evidence (study design and other criteria) | - Original research; eligible study designs include:; - For all KQs: randomized controlled trials with masking of subjects and providers (i.e., double-blind), nonrandomized controlled trials, or prospective cohort studies with an eligible comparison group; - For KQ 1c, KQ 2c, and KQ 3 on adverse events: all the above plus case-control studies and retrospective cohorts | - Nonsystematic reviews; - Systematic reviews; - Editorials; - Letters to the editor; - Articles rated as having high risk of bias; - Case reports; - Case series; - Studies with historical, rather than concurrent, control groups
Publication language | English | All other languages
Geography | No limits | Not applicable
Time period | No date limit; searches were updated after the draft report was submitted for peer review | Not applicable

AUC = antibiotic area under the curve; HAP = hospital-acquired pneumonia; HCAP = health care–associated pneumonia; KQ = Key Question; MIC = minimum inhibitory concentration; PK/PD = pharmacokinetic/pharmacodynamic; VAP = ventilator-associated pneumonia.

We required studies to have a comparator to be included. Because of this requirement, studies lacking a comparator PK/PD target goal were not eligible; similarly, retrospective cohort studies without an appropriate comparator group were not eligible. Our goal was not to examine an individual drug's performance; rather, we focused on use of PK/PD measures to guide and optimize treatment.

Thus, many vancomycin dosing studies for S. aureus pneumonia using PK/PD measures would not be eligible if they did not prospectively compare two or more different dosing approaches, such as targeting two different troughs. Studies that retrospectively examined the peak or trough values that different patients achieved and related those data to the MIC of the organism would also not be included. Furthermore, studies evaluating extended interval aminoglycoside dosing were not included if they did not have a prospective comparator group.

We excluded studies of fungal pneumonia in this review because fungal infections would involve a different set of PICOTS from those found in the literature for bacterial lung infections. Because the report scope was limited to HAP, ventilator-acquired pneumonia (VAP), or health-care-acquired pneumonia (HCAP), we also did not include studies of community-acquired pneumonia or other pneumonias in which treatment began in a setting other than the hospital. Ventilator-associated tracheobronchitis (VAT) that has not become VAP would not meet the inclusion criteria for our review. PK/PD studies of VAT alone would need to be separate from VAP because the concentration of drug at the site of infection differs.

In addition, because of the report's focus on pneumonia, we did not include studies of shock, sepsis, or other infections that did not provide data for HAP patients. As stated in the introduction, the lung is a unique organ for drug penetration. Thus, serum concentrations for other conditions, such as sepsis, do not necessarily correlate with optimizing dosing for pneumonia.

Finally, we excluded studies in which serum concentration had been measured without comparing different serum concentration targets, because this type of intervention would be considered standard of care. For that reason, these practices do not constitute a study design for examining optimization of PK/PD measures to inform treatment decisions.

### Study Selection

Two trained members of the research team independently reviewed all titles and abstracts (identified through searches) for eligibility against our inclusion/exclusion criteria. Studies marked for possible inclusion by either reviewer underwent a full-text review. Titles and abstracts that lacked adequate information to determine inclusion or exclusion underwent a full-text review.

We retrieved the full text of all articles included during the title and abstract review phase. Two trained members of the research team independently reviewed each full-text article for inclusion or exclusion based on the eligibility criteria described above. If both reviewers agreed that a study did not meet the eligibility criteria, we excluded it. If the reviewers disagreed, they resolved conflicts by discussion and consensus or by consulting a third senior member of the review team.

All results in both review stages were tracked in an EndNote® database. We recorded the principal reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix C).

### Data Extraction

For studies that met our inclusion criteria, we extracted important information into evidence tables. We designed and used structured data extraction forms to gather pertinent information from each article, including characteristics of study populations, settings, interventions, comparators, study designs, methods, and results. We recorded intention-to-treat results if available.

Trained reviewers recorded the relevant data from each included article into the evidence tables. A second member of the team reviewed all data abstractions for completeness and accuracy. All data abstraction was performed using Microsoft Excel® software.

## Risk of Bias Assessment of Individual Studies

To assess the risk of bias (i.e., internal validity) of studies, we applied predefined criteria based on the AHRQ Methods Guide.51 This approach uses questions to assess selection bias, confounding, performance bias, detection bias, and attrition bias—that is, it addresses issues of adequacy of randomization, allocation concealment, similarity of groups at baseline, masking, attrition, whether intention-to-treat analysis was used, method of handling dropouts and missing data, validity and reliability of outcome measures, and treatment fidelity.

Two independent reviewers assessed risk of bias for each study. Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team.

Studies are rated as low, medium, or high risk of bias. In general terms, results from a study assessed as having low risk of bias are considered to be valid. A study with medium risk of bias is susceptible to some risk of bias but probably not enough to invalidate its results. A study assessed as high risk of bias has significant risk of bias (e.g., stemming from serious issues in design, conduct, or analysis) that may invalidate its results.

## Data Synthesis

We did not find multiple studies for any comparison of interest that reported similar outcomes; for that reason, we could not consider quantitative synthesis (i.e., meta-analysis) of the data from the included studies. All analyses in this review are, therefore, qualitative. We synthesized data from the included studies in tabular and narrative format. Synthesized evidence was organized by KQ.

## Strength of Evidence of the Body of Evidence

We graded the strength of evidence based on the guidance established for the EPC program.52 Developed to grade the overall strength of a body of evidence, this approach incorporates four required domains: risk of bias (including study design and aggregate quality), consistency, directness, and precision of the evidence. Reviewers can also consider other optional domains that may be relevant for some scenarios; these include dose-response association, plausible confounding that would decrease the observed effect, strength of association (i.e., magnitude of effect), and publication bias.

Table 3 defines the grades of evidence that we assigned. We graded the strength of the body of evidence for major outcomes and comparisons relating to the three KQs stated above. Two reviewers assessed each domain for each key outcome and resolved differences by consensus. For each assessment, one of the two reviewers was always an experienced, senior investigator. The overall grade was based on a qualitative decision taking into account the ratings for the four required domains, and, if relevant, ratings of the other domains.

Table 3 Definition of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Medium | Medium confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Source: Owens et al., 2010^52^

We graded the strength of evidence for the outcomes deemed to be of greatest importance to clinicians and other stakeholders. Tables showing our assessments for each domain and the resulting strength of evidence grades for each KQ, organized by intervention-comparison pair and outcome, appear in the results section.

## Applicability

We assessed the applicability of individual studies as well as the applicability of the body of evidence following guidance from the AHRQ Methods Guide.53 For individual studies, we examined factors that may limit applicability based on the PICOTS framework. Such factors may be associated with heterogeneity of treatment effect or the ability to generalize the effectiveness of an intervention to use in everyday practice. Some factors identified a priori that could limit the applicability of evidence for this review included the following: severity of illness, whether studies enrolled patients with chronic lung diseases, and settings.

## Peer Review and Public Commentary

The AHRQ Task Order Officer (TOO) and an AHRQ associate editor (a senior member of another EPC) reviewed the draft report before peer review and public comment. The draft report (revised as needed) was sent to invited peer reviewers and simultaneously uploaded to the AHRQ Web site where it was available for public comment for 28 days.

We collated all reviewer comments (both invited and from the public) and addressed them individually. We documented all our responses to these comments in a disposition of comments document, which will be posted on the AHRQ EHC program Web site about 3 months after Web publication of the evidence report. The authors of the report have final discretion as to how the report will be revised based on the reviewer comments, with oversight by the TOO and associate editor.