# Peer Reviewers

Before publication of the final evidence report, the RTI-UNC EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers for this report follows:

- Donald Craven, M.D., FIDSA, FRCP(C)
  Lahey Clinic Medical Center
  Burlington, MA
  Tufts University School of Medicine
  Boston, MA
- Nadia Haque, Pharm.D., M.H.S.A., B.C.P.S.
  Henry Ford Health System
  Detroit, MI
- Thomas Lodise, Pharm.D., Ph.D.
  Albany College of Pharmacy and Health Sciences
  Albany, NY
- Ayman Noreddin, Ph.D., R.Ph.
  Hampton University
  Hampton, VA
- Marya Zilberberg, M.D., M.P.H., FCCP
  University of Massachusetts
  Amherst, MA