# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- William Clarke, Ph.D., M.B.A., D.A.B.C.C.
  Johns Hopkins University School of Medicine
  Baltimore, MD
- Ivor S. Douglas, M.D., FRCP
  University of Colorado
  Denver, CO
- Andre C. Kalil, M.D.
  University of Nebraska Medical Center
  Omaha, NE
- Michael B. Kays, Pharm.D., B.C.P.S., FCCP
  Purdue University
  West Lafayette, IN
- Joseph Ming Wa Li, M.D., SFHM, FACP
  Harvard Medical School
  Boston, MA
- Johnalyn Lyles, Pharm.D.
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Andrew Masica, M.D., M.S.C.I.
  Baylor Scott & White Health
  Dallas, TX
- Mark Metersky, M.D.
  University of Connecticut
  Farmington, CT
- John Powers, M.D., FACP, FDSA
  George Washington University
  Washington, DC