# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Christine Chang, M.D., M.P.H. We thank Dr. Chang and our Associate Editor, Thomas Trikalinos, M.D., Ph.D., for their helpful comments on a draft version of the report.

The authors deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at the RTI–UNC EPC. We express our gratitude to the following individuals for their contributions to this project: Loraine Monroe and Sharon Barrell, M.A., of RTI, and Jennifer Middleton, Ph.D., of UNC.