# Discussion

This chapter summarizes the key findings and how they relate to published findings and current clinical practices and policies. We then briefly examine the applicability of our findings and their implications for decisionmaking. Limitations of both the review process and the entire evidence base are also examined as a segue into our discussion of research gaps in this field.

## Key Findings and Strength of Evidence

Comparative evidence is scarce on use of pharmacokinetic/pharmacodynamic (PK/PD) measures in dosing or monitoring. Similarly, little evidence is available on use of PK/PD strategies in adult patients with HAP who are being treated with intravenous (IV) antibiotics.

The strength of evidence is insufficient to conclude whether using measures to inform decisions about dosing or monitoring IV antibiotic treatment (Key Question [KQ] 1) improves either intermediate or health outcomes. We found only a single prospective cohort study (which we rated as high risk of bias) that used PK/PD measures to study the impact of different antibiotic dosing on clinical responses, such as time on mechanical ventilation, treatment failure, and mortality.

Evidence is also insufficient to draw conclusions about the effect of continuous infusions of beta-lactam antibiotics compared with the effect of intermittent infusions on outcomes related to clinical response, mechanical ventilation, morbidity, mortality, or rates of antibiotic-related adverse events (KQ 2). Pertinent studies found no significant differences in clinical response, duration of mechanical ventilation, superinfection, rates of antibiotic-related adverse events, or infusion-related adverse effects.

### Findings in Relation to What Is Already Known

In screening titles and abstracts identified by our searches, we determined that very little research has focused on the use of PK/PD measures in dosing or monitoring adult patients with hospital-acquired pneumonia (HAP) (including ventilator-associated pneumonia [VAP] and health-care-associated pneumonia [HCAP]) being treated with IV antibiotics. This dearth of studies suggests that the research conducted to date has been conducted in in vitro and animal studies. In what little is published relating to different PK/PD strategies, investigators have studied mixed populations, including patients with a variety of conditions (e.g., sepsis, bacteremia, community-acquired pneumonia, HAP) without reporting outcomes for patients with HAP separately. Our review focused solely on HAP and explicitly omitted community-acquired pneumonia.

Two previous reviews had found limited evidence on patients with HAP. A 2010 review by Franzetti and colleagues focused narrowly on treatment (primarily vancomycin) for Gram-positive pathogens.49 Of the seven studies in their final analysis, only three retrospective cohorts (published between 2004 and 2007) included HAP; of these, two involved the same patient group with HCAP caused by methicillin-resistant S. aureus. These studies were limited by their small sample sizes and retrospective design. Moreover, they were not focused on using PK/PD measures to adjust dosing. Rather, the investigators used set targets and reported on patient outcomes using those targets, not on monitoring the PK/PD measures and adjusting doses to improve outcomes and reduce harms.

One study (published in 2000) compared continuous and intermittent infusion of ceftazidime in critically ill trauma patients with VAP; it found no significant differences in duration of mechanical ventilation.59 Recently, Mohd Hafiz and colleagues evaluated the methodological shortcomings of clinical studies comparing intermittent dosing and continuous infusion of beta-lactam antibiotics in critically ill patients. Some of these shortcomings included inconsistent antibiotic doses and endpoints, heterogeneous patient groups, and small sample sizes.66

Emerging microbial resistance concerns motivate clinicians and policymakers alike. These changes have led to efforts to develop more effective strategies for using current therapies. For example, the Agency for Healthcare Research and Quality (AHRQ) has made investments in patient safety, with specific attention to health care-associated infections and antibiotic resistance. In addition, the National Institutes of Health has issued new funding opportunities to encourage development of new antibiotics.

Many national and international organizations have recognized the growing global problem of antibiotic resistance and have made efforts to raise public awareness and coordinate actions to address problems related to resistance. For example, the Centers for Disease Control and Prevention has launched the Get Smart Campaign to encourage the judicious use of antibiotics. Strategies often employed include infection control and prevention techniques such as hand-washing, development of rapid, point-of-care diagnostic tests to diagnose infection more rapidly and accurately, public policies to support development and approval of new drugs to treat resistant infections, and implementation of coordinated efforts to optimize antibiotic use through practices referred to as antibiotic stewardship.

Antibiotic stewardship programs have several goals. Among them are improving appropriate use of antibiotics by promoting antibiotic use only when indicated and selection of optimal antimicrobial drug regimens to improve clinical outcomes. Minimizing toxicity and other adverse events, including limiting the emergence of antibiotic-resistant strains of bacteria, are related goals. Such programs often focus on streamlining antimicrobial therapy, de-escalating or targeting antibiotics based on microbiological data, minimizing excessive durations of antibiotic courses, and optimizing antibiotic doses.

The Infectious Diseases Society of America (IDSA), the Society for Healthcare Epidemiology of America, and the Pediatric Infectious Diseases Society have all made recommendations to the Centers for Medicare & Medicaid Services to require antibiotic stewardship programs in all acute care hospitals in the United States.67 Pharmacodynamic dose optimization has been suggested as a strategy that antibiotic stewardship programs can employ to improve antibiotic use.68 In fact, the IDSA guidelines for developing an institutional program to enhance antimicrobial stewardship refer to PK and PD considerations as important parts of antimicrobial stewardship.69

### Applicability

Based on the guidelines from the AHRQ Methods Guide, we found no robust studies addressing the applicability of PK/PD in relation to our PICOTS (populations, interventions, comparators, outcomes, timing, settings) structure. Studies instead evaluated heterogeneous treatment effects and diverse patient populations.

## Implications for Clinical and Policy Decisionmaking

Given the dearth of findings in this review, the evidence base provides little guidance for either clinical or policy decisionmaking. We comment here on two key issues that warrant attention by health professionals, policymakers, and society at large; we offer specific recommendations about filling these research gaps below.

First, as antimicrobial resistance becomes a global problem, appropriate use of antibiotics is of paramount importance. Appropriate use encompasses optimal dosing strategies that are cost-effective, can improve patient outcomes, and can combat further development of resistance. These matters are relevant to clinicians, hospital administrators, insurers, patients, and public-sector agencies. With respect specifically to PK/PD approaches, of particular interest are exposure-response relationships of antibiotics, antibiotic use in “real-world” clinical settings (all types of hospitals and intensive care units [ICUs]), and a broad range of patient-centered outcomes (clinical response, morbidity, mortality, and adverse events) as well as costs of care.

Second, almost a decade ago, the American Thoracic Society (ATS) redefined its dosing guidelines based on PK/PD principles and clinical trial efficacy data.1 Nevertheless, the effectiveness of the dosing strategies described in these guidelines remains unclear. Clinicians and policymakers alike would benefit from updated information that will point to more effective strategies for using current therapies that are now widely available.

In summary, despite the theoretical advantages of optimizing IV antibiotic dosing using PK/PD principles in patients with HAP, major gaps in the available evidence preclude our drawing conclusions or examining clinical or policy implications. The near-absence of strong evidence, particularly related to clinical applications, has severely limited the broad adoption of PK/PD dosing optimization in the clinical arena. Below we address the gaps in evidence that might point to additional needed research and to the methods shortcomings in the studies we were able to use.

## Limitations of the Systematic Review Process

This review focused on the comparative effectiveness of using PK/PD measures to monitor and adjust dosing of IV antibiotics for HAP in comparison with no care, usual care, or different targets of PK/PD measures. Because our focus was only HAP (including VAP and HCAP), we omitted any study that included community-acquired pneumonia or involved only healthy volunteers. In addition, we addressed use of PK/PD measures only for IV antibiotics; therefore, studies using oral antibiotics or aerosols were excluded. Also, our focus was on patient-oriented and clinical outcomes.

We did not address cost outcomes in this review. While screening studies for inclusion, we did observe some drug comparison studies reporting on the cost-effectiveness of IV antibiotics in HAP, but these studies did not meet the eligibility criteria for this systematic review. No studies directly reported on the cost-effectiveness of using PK/PD measures in dosing or monitoring IV antibiotics in treating patients with HAP. One study included in this review, comparing continuous infusion with intermittent infusion of ceftazidime in ICU patients with HAP, found continuous infusions were significantly lower in cost than intermittent infusion.55

Evidence-based Practice Center (EPC) reviewers consider the applicability of the evidence to key populations, major outcomes, and the like, to help stakeholders determine the applicability of the evidence to their own circumstances. As discussed above, the lack of studies precluded any in depth discussion in regard to applicability of this evidence base.

## Limitations of the Evidence Base

Our review highlights the considerable limitations of the available evidence. Despite our efforts to cast a wide net for usable studies, only six studies met criteria for inclusion. Our review addressed the use of PK/PD measures or strategies to dose and monitor IV antibiotics in treating patients with HAP. Therefore, our focus was on the lung, a unique organ for drug penetration. Serum concentrations for other conditions, such as sepsis, do not necessarily correlate with optimizing dosing for pneumonia, and thus we did not include such studies in this review.

Systematic review methods require rating the risk of bias of all included studies; applying internationally accepted methods to do this led to ratings of “high” risk of bias for half of the six studies that we could include. We opted to retain these three studies in our evidence base. Although EPCs that adopt a “best evidence” approach for certain clinical topics with large numbers of trials or observational studies might have excluded high risk-of-bias studies from their main analyses, doing so here would have reduced the evidence base to even lower levels (e.g., three studies for KQ 2) and eliminated even suggestive information from consideration.

Review procedures also require grading strength of the bodies of evidence. Again, following accepted EPC procedures, we determined that evidence was uniformly insufficient to allow any conclusions to be drawn about the two main KQs. The main problems were small numbers of patients, lack of reporting of clinical or patient-centered outcomes, aggregate risk of bias, unknown consistency for most outcomes (typically with just one small study reporting most outcomes that had any evidence), and overall lack of precision in measurements.

We did exclude several studies from our analysis because of mixed patient populations, lack of an intervention group, or inadequate clinical outcome reporting. The limitations of such studies stemmed from several problems. First, although many studies involved patients with HAP, the overall study population in these investigations tended to be mixed. Typically, analysts did not report findings specifically for patients with HAP. For example, studies comparing continuous with intermittent infusions of beta-lactams (KQ 2) often do not focus solely on subjects with HAP; neither do they present analyses in ways that would have permitted us to extract data on outcomes for HAP patients.

Second, other studies that do focus on patients with HAP do not compare different PK/PD strategies; instead, they compare different antibiotics. Some do not address clinical outcomes at all. Results from these types of studies do not provide comparative evidence addressing our KQs. At best, such studies could provide only hypothesis-generating evidence for the KQs we addressed in this CER.

Third, several methodological limitations in these studies restricted our review. In general, the trials were small and not powered to demonstrate any significant differences between groups. As noted above, we rated three studies as high risk of bias (three medium risk of bias and none low risk of bias). The two main problems were high risk of selection bias and confounding (i.e., researchers did not rule out any impact from a concurrent intervention or an unintended exposure).

## Research Gaps

Review procedures call for identifying specific and important gaps in the evidence base. We offer here some specific suggestions for improving future investigations, considering both study design and conduct as well as choice of topics for research.

First, whether use of PK/PD measures for informing dosing decisions for patients with HAP influences clinical outcomes remains unknown, largely because of both the absence of studies and the questionable quality of many of those studies (leading to imprecise findings). As noted, half of the included studies were rated as high risk of bias because of numerous problems with their design or conduct. Moreover, the available studies were sufficiently diverse that they cannot be expected to produce “consistent” findings (and in fact did not).

Second, two key topics were not addressed in most investigations: (1) use of targeted and monitored antibiotic concentrations to tailor antibiotic doses of individual patients and (2) broad applications of PK/PD concepts such as using extended or prolonged infusions of time-dependent antibiotics. Although several studies have reported PK endpoints and findings from Monte Carlo simulated data sets, few in vivo studies have yet been designed to evaluate clinical endpoints. Such endpoints might include the types of intermediate outcomes we sought, such as immediate clinical response or days on a ventilator, but the preferable endpoints would be patient-centered health outcomes, especially disease or death. In this review, only one RCT evaluated clinical outcomes for patients with HAP receiving continuous versus intermittent ceftazidime infusions.57

Third, the effect of optimizing antibiotic dosing based on PK/PD principles for patients with HAP who fall into various clinical or sociodemographic subgroups is not known. This is a critical deficiency in the evidence base that future research needs to address directly. Specifically, pharmacokinetic variability based on patient-specific factors such as critical illness, body weight, renal function, or age may influence the magnitude of the effect of PK/PD dose optimization (assuming an effect exists). Furthermore, the infecting pathogen and the mimimum inhibitory concentration (MIC) of the pathogen are factors that are likely to influence the magnitude of any effect. Certain populations of patients may be more likely to benefit from dose optimizations based on these factors.

The gaps in understanding the links among patient-specific factors, organism MIC, antibiotic dose, and clinical outcomes reflect the difficulty in isolating these variables and establishing cause-effect relationships. Elevated organism MICs and, thus, antibiotic regimen and dosing choices may be correlated with disease severity without having a causal effect. Furthermore, unmeasured organism factors such as virulence determinants, which may be associated with elevated MICs, may play a role in patient outcomes. These potential confounding variables should be considered when drawing conclusions about the effects of antibiotic dose optimization on patient outcomes.70-72

Finally, another hole in the evidence is whether optimizing PK in dosing strategies in the clinical setting can delay the development of antimicrobial resistance. Resistant organisms are a persistent and increasing problem, with methicillin-resistant S. aureus infections now accounting for more deaths than AIDS in the United States. Resistance among Gram-negative organisms is particularly concerning because of the scarcity of new drugs in development with activity against these pathogens. A possible contributor to this emerging resistance is today's approach to dosing antibiotics that is based on the assumptions outlined above for PK/PD. Because present dosing recommendations derive largely from PK/PD studies in healthy volunteers, the recommendations may lead to suboptimal clinical outcomes in patients with HAP (or VAP or HCAP). Furthermore, subtherapeutic concentrations of antibiotics may further contribute to the survival and growth of resistant organisms.

Future investigations could be conducted in large-scale blinded prospective designs intended to compare different PK/PD strategies in patients with HAP. The two primary goals of such investigations are (1) to document the impact of different dosing strategies on meaningful clinical and patient-centered endpoints, such as survival in different patient populations, and (2) to determine their effects on the development of antibiotic resistance in bacteria. In addition, such studies can provide important data on other outcomes of interest to both clinicians and patients; these include ventilator days, rates of relapse, rates of reinfection, mortality risk, and timeliness of laboratory results in terms of being clinically useful in managing treatment. Measuring microbiological outcomes such as eradication of bacteria, microbiologic relapse, decrease in colony counts of culture, and development of antibiotic resistance can also yield information useful for developing dosing guidelines and recommendations. For certain patient-centered outcomes, such as clinical response and treatment failure not otherwise explained, clearly identifying how the investigators defined those outcomes (e.g., clinician judgment of patient signs and symptoms, laboratory values, quality of life assessed through patient self-reports, or mortality as measured at specific points in time) will improve interpretation of the findings. We believe research teams should be precise in delineating their conceptualization of all such outcomes.

Although antibiotic resistance clearly can arise during or from antibiotic treatment, less is known about the relationships among drug dosage, PK/PD optimization, and the development of resistance. Evaluating either the development or the prevention of resistance is a difficult research endeavor. Nevertheless, investigators can institute several approaches such as monitoring resistance trends in individual patients or tracking changes in hospital or local susceptibility patterns over time. Metrics for evaluating the development of resistance should be tested and validated in relationship to meaningful clinical and ultimate health outcomes. Researchers mounting PK/PD studies would then have more reliable and valid ways to examine this very important public health concern.