# Evidence Tables

Table D-1 Characteristics of included studies

Table D-2 Characteristics of samples from included studies

Table D-3 Intervention and comparator components from included studies

Table D-4 Clinical response and mechanical ventilation outcomes

Table D-5 Morbidity and mortality outcomes

Table D-6 Antibiotic-related adverse events

## References for Appendix D

1 Fahimi F, Ghafari S, Jamaati H, et al. Continuous versus intermittent administration of piperacillin-tazobactam in intensive care unit patients with ventilator-associated pneumonia. Indian J Crit Care Med. Jul. 2012;16(3):141-7. [pmid: 23188954].
2 Hanes SD, Wood GC, Herring V, et al. Intermittent and continuous ceftazidime infusion for critically ill trauma patients. Am J Surg. Jun. 2000;179(6):436-40. Epub: 2000/09/27. [pmid: 11004326].
3 Jaruratanasirikul S, Wongpoowarak W, Kositpantawong N, et al. Pharmacodynamics of doripenem in critically ill patients with ventilator-associated Gram-negative bacilli pneumonia. Int J Antimicrob Agents. Nov. 2012;40(5):434-9. Epub: 2012/09/11. [pmid: 22959555].
4 Lorente L, Jimenez A, Martin MM, et al. Clinical cure of ventilator-associated pneumonia treated with piperacillin/tazobactam administered by continuous or intermittent infusion. Int J Antimicrob Agents. May. 2009;33(5):464-8. Epub: 2009/01/20. [pmid: 19150225].
5 Nicolau DP, McNabb J, Lacy MK, et al. Pharmacokinetics and pharmacodynamics of continuous and intermittent ceftazidime during the treatment of nosocomial pneumonia. Clin Drug Invest. 1999;(2):133-9.
6 Nicolau DP, Lacy MK, McNabb J, et al. Pharmacokinetics of continuous and intermittent ceftazidime in intensive care unit patients with nosocomial pneumonia. Infect Dis Clin Pract. 1999;8(1):45-9.
7 Nicolau DP, McNabb J, Lacy MK, et al. Continuous versus intermittent administration of ceftazidime in intensive care unit patients with nosocomial pneumonia. Int J Antimicrob Agents. Jun. 2001;17(6):497-504. Epub: 2001/06/09. [pmid: 11397621].
8 McNabb JJ, Nightingale CH, Quintiliani R, et al. Cost-effectiveness of ceftazidime by continuous infusion versus intermittent infusion for nosocomial pneumonia. Pharmacotherapy. May. 2001;21(5):549-55. Epub: 2001/05/15. [pmid: 11349744].
9 Sakka SG, Glauner AK, Bulitta JB, et al. Population pharmacokinetics and pharmacodynamics of continuous versus short-term infusion of imipenem-cilastatin in critically ill patients in a randomized, controlled trial. Antimicrob Agents Chemother. Sep. 2007;51(9):3304-10. Epub: 2007/07/11. [pmid: 17620371].
10 Scaglione F, Esposito S, Leone S, et al. Feedback dose alteration significantly affects probability of pathogen eradication in nosocomial pneumonia. Eur Respir J. Aug. 2009;34(2):394-400. Epub: 2009/02/14. [pmid: 19213786].
11 Wang D. Experience with extended-infusion meropenem in the management of ventilator-associated pneumonia due to multidrugresistant Acinetobacter baumannii. Int J Antimicrob Agents. 2009;33:290-1. [pmid: 19091523].
12 Knaus WA, Wagner DP, Draper EA, et al. The APACHE III prognostic system. Risk prediction of hospital mortality for critically ill hospitalized adults. Chest. Dec. 1991;100(6):1619-36. Epub: 1991/12/01. [pmid: 1959406].