# Excluded Studies

Exclusion Codes
1. - Not available in English
2. - Wrong Outcome(s)
3. - Wrong or No Intervention
4. - Wrong Population
5. - Wrong Publication Type
6. - Wrong Study Design
7. - Wrong Comparison or No Comparison
8. - Does Not Answer a KQ

1 Pneumonia: 3 days of antibiotics for uncomplicated course. Journal of hospital medicine : an official publication of the Society of Hospital Medicine. 2006;(6):387. PMID: CN-00574952. Exclusion Code: 4. [pmid: 17219539].
2 Abbas AM, Taylor MC, Newby D, et al. Ceftazidime: a new approach in the treatment of moderate and severe infections. J Antimicrob Chemother. Jul. Suppl A. 1983;12:147-52. Exclusion Code: 3. [pmid: 6352615].
3 Alvarez-Lerma F, Insausti-Ordeñana J, Jordá-Marcos R, et al. Efficacy and tolerability of piperacillin/tazobactam versus ceftazidime in association with amikacin for treating nosocomial pneumonia in intensive care patients: a prospective randomized multicenter trial. Intensive Care Med. 2001;(3):493-502. PMID: CN-00355757. Exclusion Code: 3. [pmid: 11355117].
4 Andrews R, Fasoli R, Scoggins WG, et al. Combined aztreonam and gentamicin therapy for pseudomonal lower respiratory tract infections. Clin Ther. Mar-Apr. 1994;16(2):236-52. Exclusion Code: 4. [pmid: 8062319].
5 Bagg R. Antibiotic treatment of staphylococcal pneumonia in adults. J Antimicrob Chemother. Jul. 1978;4(4):297-9. Exclusion Code: 5. [pmid: 308503].
6 Balderson BJ, Yates ME, Patil NP, et al. Evaluation of doripenem utilization and susceptibilities at a large urban hospital. Int J Clin Pharm. Dec. 2011;33(6):958-63. Exclusion Code: 4. [pmid: 21984226].
7 Bartel K, Habash T, Lugauer S, et al. Optimal tobramycin dosage in patients with cystic fibrosis--evidence for predictability based on previous drug monitoring. Infection. 1999;27(4-5):268-71. Exclusion Code: 4. [pmid: 10885841].
8 Bassetti M, Righi E, Fasce R, et al. Efficacy of ertapenem in the treatment of early ventilator-associated pneumonia caused by extended-spectrum beta-lactamase-producing organisms in an intensive care unit. J Antimicrob Chemother. Aug. 2007;60(2):433-5. Exclusion Code: 2. [pmid: 17540673].
9 Bauer KA, West JE, O'Brien JM, et al. Extended-infusion cefepime reduces mortality in patients with Pseudomonas aeruginosa infections. Antimicrob Agents Chemother. Jul. 2013;57(7):2907-12. Exclusion Code: 4. [pmid: 23571547].
10 Beaucaire G, Leroy O, Beuscart C, et al. Clinical and bacteriological efficacy, and practical aspects of amikacin given once daily for severe infections. J Antimicrob Chemother. May. Suppl C. 1991;27:91-103. Exclusion Code: 4. [pmid: 1856149].
11 Belliveau PP, Freeman CD, Nicolau DP, et al. Serum bactericidal activity of ceftizoxime and ceftriaxone against pathogens associated with community-acquired and nosocomial pneumonias. Am J Health Syst Pharm. May. 1. 1996;53(9):1024-7. Exclusion Code: 4. [pmid: 8744464].
12 Benko AS, Cappelletty DM, Kruse JA, et al. Continuous infusion versus intermittent administration of ceftazidime in critically ill patients with suspected gram-negative infections. Antimicrob Agents Chemother. Mar. 1996;40(3):691-5. Exclusion Code: 4. [pmid: 8851594].
13 Benko R, Matuz M, Doro P, et al. Pharmacokinetics and pharmacodynamics of levofloxacin in critically ill patients with ventilator-associated pneumonia. Int J Antimicrob Agents. Aug. 2007;30(2):162-8. Exclusion Code: 7. [pmid: 17570646].
14 Bernhardt LL. Cefadroxil in the treatment of lobar pneumonia. J Int Med Res. 1980;8(Suppl 1):98-100. Exclusion Code: 3. [pmid: 7439514].
15 Betrosian AP, Frantzeskaki F, Xanthaki A, et al. Efficacy and safety of high-dose ampicillin/sulbactam vs. colistin as monotherapy for the treatment of multidrug resistant Acinetobacter baumannii ventilator-associated pneumonia. J Infect. Jun. 2008;56(6):432-6. Exclusion Code: 2. [pmid: 18501431].
16 Betrosian AP, Frantzeskaki F, Xanthaki A, et al. High-dose ampicillin-sulbactam as an alternative treatment of late-onset VAP from multidrug-resistant Acinetobacter baumannii. Scand J Infect Dis. 2007;39(1):38-43. Exclusion Code: 4. [pmid: 17366011].
17 Bhavnani SM, Rubino CM, Hammel JP, et al. Pharmacological and patient-specific response determinants in patients with hospital-acquired pneumonia treated with tigecycline. Antimicrob Agents Chemother. Feb. 2012;56(2):1065-72. Exclusion Code: 2. [pmid: 22143524].
18 Boccazzi A, Langer M, Mandelli M, et al. The pharmacokinetics of aztreonam and penetration into the bronchial secretions of critically ill patients. J Antimicrob Chemother. Mar. 1989;23(3):401-7. Exclusion Code: 7. [pmid: 2732121].
19 Bolivar R, Fainstein V, Elting L, et al. Cefoperazone for the treatment of infections in patients with cancer. Rev Infect Dis. Mar-Apr. Suppl 1. 1983;5:S181-7. Exclusion Code: 3. [pmid: 6221389].
20 Boselli E, Breilh D, Caillault-Sergent A, et al. Alveolar diffusion and pharmacokinetics of linezolid administered in continuous infusion to critically ill patients with ventilator-associated pneumonia. J Antimicrob Chemother. May. 2012;67(5):1207-10. Exclusion Code: 2. [pmid: 22351682].
21 Boselli E, Breilh D, Djabarouti S, et al. Reliability of mini-bronchoalveolar lavage for the measurement of epithelial lining fluid concentrations of tobramycin in critically ill patients. Intensive Care Med. Sep. 2007;33(9):1519-23. Exclusion Code: 7. [pmid: 17530217].
22 Boselli E, Breilh D, Rimmele T, et al. Alveolar concentrations of piperacillin/tazobactam administered in continuous infusion to patients with ventilator-associated pneumonia. Crit Care Med. May. 2008;36(5):1500-6. Exclusion Code: 7. [pmid: 18434883].
23 Boselli E, Breilh D, Saux MC, et al. Pharmacokinetics and lung concentrations of ertapenem in patients with ventilator-associated pneumonia. Intensive Care Med. Dec. 2006;32(12):2059-62. Exclusion Code: 7. [pmid: 17039351].
24 Bradsher RW. Ceftriaxone (Ro 13-9904) therapy of serious infection. Antimicrob Agents Chemother. Jul. 1982;22(1):36-42. Exclusion Code: 3. [pmid: 6289739].
25 Bruch HP, Kujath P. Study of cefotaxime twice daily for the therapy of postoperative pneumonia. The German Cefotaxime Study Group. Diagn Microbiol Infect Dis. May-Jun. 1995;22(1-2):203-7. Exclusion Code: 2. [pmid: 7587041].
26 Buck C, Bertram N, Ackermann T, et al. Pharmacokinetics of piperacillin-tazobactam: intermittent dosing versus continuous infusion. Int J Antimicrob Agents. Jan. 2005;25(1):62-7. Exclusion Code: 4. [pmid: 15620828].
27 Buising KL, O'Reilly MA, Paull AE, et al. Legionella pneumophila: not just pneumonia. Med J Aust. May. 7. 2001;174(9):476-7. Exclusion Code: 6. [pmid: 11386595].
28 Burgess DS. Curbing Resistance Development: Maximizing the Utility of Available Agents. J Manag Care Pharm. 2009;15:S5. Exclusion Code: 5. [pmid: 19505173].
29 Burkhardt O, Kumar V, Katterwe D, et al. Ertapenem in critically ill patients with early-onset ventilator-associated pneumonia: pharmacokinetics with special consideration of free-drug concentration. J Antimicrob Chemother. Feb. 2007;59(2):277-84. Exclusion Code: 7. [pmid: 17185298].
30 Calbo E, Alsina M, Rodriguez-Carballeira M, et al. Systemic expression of cytokine production in patients with severe pneumococcal pneumonia: effects of treatment with a beta-lactam versus a fluoroquinolone. Antimicrob Agents Chemother. Jul. 2008;52(7):2395-402. Exclusion Code: 4. [pmid: 18426893].
31 Cano EL, Haque NZ, Welch VL, et al. Incidence of nephrotoxicity and association with vancomycin use in intensive care unit patients with pneumonia: retrospective analysis of the IMPACT-HAP Database. Clin Ther. Jan. 2012;34(1):149-57. Exclusion Code: 3. [pmid: 22284995].
32 Carbon C. Prospective randomized phase II study of intravenous cefpirome 1g or 2g bd in the treatment of hospitalized patients with different infections. Cefpirome Study Group. J Antimicrob Chemother. Apr. Suppl A. 1992;29:87-94. Exclusion Code: 3. [pmid: 1601764].
33 Chan JD, Pham TN, Wong J, et al. Clinical outcomes of linezolid vs vancomycin in methicillin-resistant Staphylococcus aureus ventilator-associated pneumonia: retrospective analysis. J Intensive Care Med. Nov-Dec. 2011;26(6):385-91. Exclusion Code: 6. [pmid: 21606058].
34 Chandorkar G, Huntington JA, Gotfried MH, et al. Intrapulmonary penetration of ceftolozane/tazobactam and piperacillin/tazobactam in healthy adult subjects. J Antimicrob Chemother. Oct. 2012;67(10):2463-9. Exclusion Code: 4. [pmid: 22773741].
35 Chapuis TM, Giannoni E, Majcherczyk PA, et al. Prospective monitoring of cefepime in intensive care unit adult patients. Crit Care. 2010;14(2):R51. Exclusion Code: 4. [pmid: 20359352].
36 Chastre J, Wunderink R, Prokocimer P, et al. Efficacy and safety of intravenous infusion of doripenem versus imipenem in ventilator-associated pneumonia: a multicenter, randomized study. Crit Care Med. Apr. 2008;36(4):1089-96. Exclusion Code: 7. [pmid: 18379232].
37 Choi EY, Huh JW, Lim CM, et al. Relationship between the MIC of vancomycin and clinical outcome in patients with MRSA nosocomial pneumonia. Intensive Care Med. Apr. 2011;37(4):639-47. Exclusion Code: 2. [pmid: 21253703].
38 Chung J, Oh JM, Cho EM, et al. Optimal dose of vancomycin for treating methicillin-resistant Staphylococcus aureus pneumonia in critically ill patients. Anaesth Intensive Care. Nov. 2011;39(6):1030-7. Exclusion Code: 3. [pmid: 22165354].
39 Cies JJ, Shankar V. Nephrotoxicity in Patients with Vancomycin Trough Concentrations of 1520g/ml in a Pediatric Intensive Care Unit. 33:392. Exclusion Code: 4.
40 Cipolle RJ, Seifert RD, Zaske DE, et al. Hospital acquired gram-negative pneumonias: response rate and dosage requirements with individualized tobramycin therapy. Ther Drug Monit. 1980;2(4):359-63. Exclusion Code: 3. [pmid: 7222190].
41 Combes A, Luyt CE, Fagon JY, et al. Impact of piperacillin resistance on the outcome of Pseudomonas ventilator-associated pneumonia. Intensive Care Med. 2006;(12):1970-8. PMID: CN-00585884. Exclusion Code: 3. [pmid: 16957901].
42 Combes A, Luyt CE, Fagon JY, et al. Impact of methicillin resistance on outcome of Staphylococcus aureus ventilator-associated pneumonia. Am J Respir Crit Care Med. Oct. 1. 2004;170(7):786-92. Exclusion Code: 6. [pmid: 15242840].
43 Correa Lima MB, Louro E, Netto AR, et al. Multicentre trial with cephacetrile in the treatment of severe infections. Arzneimittelforschung. Sep. 1974;24(9b):1515-23. Exclusion Code: 3. [pmid: 4479817].
44 Crandon JL, Bulik CC, Kuti JL, et al. Clinical pharmacodynamics of cefepime in patients infected with Pseudomonas aeruginosa. Antimicrob Agents Chemother. Mar. 2010;54(3):1111-6. Exclusion Code: 4. [pmid: 20038614].
45 Croce MA, Fabian TC, Stewart RM, et al. Empiric monotherapy versus combination therapy of nosocomial pneumonia in trauma patients. J Trauma. Aug. 1993;35(2):303-9. discussion 9-11. Exclusion Code: 2. [pmid: 8355313].
46 Dalfino L, Puntillo F, Mosca A, et al. High-dose, extended-interval colistin administration in critically ill patients: is this the right dosing strategy? A preliminary study. Clin Infect Dis. Jun. 2012;54(12):1720-6. Exclusion Code: 4. [pmid: 22423120].
47 Dallas J, Brown SM, Hock K, et al. Diagnostic utility of plasma procalcitonin for nosocomial pneumonia in the intensive care unit setting. Respir Care. Apr. 2011;56(4):412-9. Exclusion Code: 2. [pmid: 21255510].
48 Damas P, Garweg C, Monchi M, et al. Combination therapy versus monotherapy: a randomised pilot study on the evolution of inflammatory parameters after ventilator associated pneumonia [ISRCTN31976779]. Crit Care. 2006;10(2):R52. Exclusion Code: 2. [pmid: 16569261].
49 Dartois N, Castaing N, Gandjini H, et al. Tigecycline versus levofloxacin for the treatment of community-acquired pneumonia: European experience. Journal of chemotherapy (Florence, Italy). 2008:28-35. PMID: CN-00680424. Exclusion Code: 4.
50 Davidson R, Cavalcanti R, Brunton JL, et al. Resistance to levofloxacin and failure of treatment of pneumococcal pneumonia. N Engl J Med. Mar. 7. 2002;346(10):747-50. Exclusion Code: 6. [pmid: 11882730].
51 Davies BI, Maesen FP, Teengs JP. Aztreonam in patients with acute purulent exacerbations of chronic bronchitis: failure to prevent emergence of pneumococcal infections. J Antimicrob Chemother. Mar. 1985;15(3):375-84. Exclusion Code: 3. [pmid: 3922936].
52 De Jongh R, Hens R, Basma V, et al. Continuous versus intermittent infusion of temocillin, a directed spectrum penicillin for intensive care patients with nosocomial pneumonia: stability, compatibility, population pharmacokinetic studies and breakpoint selection. J Antimicrob Chemother. Feb. 2008;61(2):382-8. Exclusion Code: 3. [pmid: 18070831].
53 Debon R, Breilh D, Boselli E, et al. Pharmacokinetic parameters of ciprofloxacin (500 mg/5 mL) oral suspension in critically ill patients with severe bacterial pneumonia: a comparison of two dosages. J Chemother. Apr. 2002;14(2):175-80. Exclusion Code: 4. [pmid: 12017373].
54 Dimopoulos G, Poulakou G, Pneumatikos IA, et al. Short- vs long-duration antibiotic regimens for ventilator-associated pneumonia: a systematic review and meta-analysis. Chest. Dec. 2013;144(6):1759-67. Exclusion Code: 6. [pmid: 23788274].
55 Drusano GL, Preston SL, Fowler C, et al. Relationship between fluoroquinolone area under the curve: minimum inhibitory concentration ratio and the probability of eradication of the infecting pathogen, in patients with nosocomial pneumonia. J Infect Dis. May. 1. 2004;189(9):1590-7. Exclusion Code: 3. [pmid: 15116294].
56 Dulhunty JM, Roberts JA, Davis JS, et al. Continuous infusion of beta-lactam antibiotics in severe sepsis: A multicenter double-blind, randomized controlled trial. Clin Infect Dis. 2013;56(2):236-44. PMID: CN-00913082. Exclusion Code: 4. [pmid: 23074313].
57 Duszynska W, Taccone FS, Switala M, et al. Continuous infusion of piperacillin/tazobactam in ventilator-associated pneumonia: a pilot study on efficacy and costs. Int J Antimicrob Agents. Feb. 2012;39(2):153-8. Exclusion Code: 7. [pmid: 22154855].
58 Eachempati SR, Hydo LJ, Shou J, et al. Does de-escalation of antibiotic therapy for ventilator-associated pneumonia affect the likelihood of recurrent pneumonia or mortality in critically ill surgical patients?. J Trauma. May. 2009;66(5):1343-8. Exclusion Code: 2. [pmid: 19430237].
59 El Solh AA, Choi G, Schultz MJ, et al. Clinical and hemostatic responses to treatment in ventilator-associated pneumonia: role of bacterial pathogens. Crit Care Med. Feb. 2007;35(2):490-6. Exclusion Code: 4. [pmid: 17205031].
60 Erard V, Lamy O, Bochud PY, et al. Full-course oral levofloxacin for treatment of hospitalized patients with community-acquired pneumonia. European journal of clinical microbiology & infectious diseases : official publication of the European Society of Clinical Microbiology. 2004;(2):82-8. PMID: CN-00471723. Exclusion Code: 4.
61 Erttmann M, Ullmann U, Koch EM. Results of a clinical and pharmacokinetic study of ceftazidime in patients with postoperative pneumonia on assisted ventilation. J Hosp Infect. Apr. Suppl A. 1990;15:55-9. Exclusion Code: 7. [pmid: 1971646].
62 Fainstein V, Bolivar R, Elting L, et al. Ceftizoxime in the treatment of infections in patients with cancer. J Antimicrob Chemother. Nov. Suppl C. 1982;10:167-73. Exclusion Code: 3. [pmid: 6296002].
63 Falagas ME, Kasiakou SK. Colistin: The revival of polymyxins for the management of multidrug-resistant gram-negative bacterial infections. Clin Infect Dis. 2005;40(Sep):1333-41. Exclusion Code: 5. [pmid: 15825037].
64 Falagas ME, Tansarli GS, Ikawa K, et al. Clinical outcomes with extended or continuous versus short-term intravenous infusion of carbapenems and piperacillin/tazobactam: a systematic review and meta-analysis. Clin Infect Dis. Jan. 2013;56(2):272-82. Exclusion Code: 6. [pmid: 23074314].
65 Fass RJ. Treatment of mixed bacterial infections with clindamycin and gentamicin. J Infect Dis. Mar. Suppl. 1977;135:S74-9. Exclusion Code: 3. [pmid: 403243].
66 Feld R, Valdivieso M, Bodey GP, et al. A comparative trial of sisomicin therapy by intermittent versus continuous infusion. Am J Med Sci. Sep-Oct. 1977;274(2):179-88. Exclusion Code: 3. [pmid: 602958].
67 Fernandez de Gatta MM, Mendez ME, Romano S, et al. Pharmacokinetics of amikacin in intensive care unit patients. J Clin Pharm Ther. Dec. 1996;21(6):417-21. Exclusion Code: 4. [pmid: 9201569].
68 Fiala M, Chatterjee SN. Antibiotic blood concentrations in patients successfully treated with tobramycin. Postgrad Med J. Sep. 1981;57(671):548-51. Exclusion Code: 4. [pmid: 7329892].
69 Fink MP, Snydman DR, Niederman MS, et al. Treatment of severe pneumonia in hospitalized patients: results of a multicenter, randomized, double-blind trial comparing intravenous ciprofloxacin with imipenem-cilastatin. The Severe Pneumonia Study Group. Antimicrob Agents Chemother. 1994;(3):547-57. PMID: CN-00101939. Exclusion Code: 3. [pmid: 8203853].
70 Flint LM, Gott J, Short L, et al. Serum level monitoring of aminoglycoside antibiotics. Limitations in intensive care unit-related bacterial pneumonia. Arch Surg. Jan. 1985;120(1):99-103. Exclusion Code: 3. [pmid: 3966875].
71 Follath F, Bindschedler M, Wenk M, et al. Use of ciprofloxacin in the treatment of Pseudomonas aeruginosa infections. Eur J Clin Microbiol. Apr. 1986;5(2):236-40. Exclusion Code: 3. [pmid: 2941289].
72 Fong IW, Vandenbroucke A, Simbul M. Penetration of enoxacin into bronchial secretions. Antimicrob Agents Chemother. 1987;(5):748-51. PMID: CN-00048984. Exclusion Code: 3. [pmid: 3475036].
73 Furtado GH, Gales AC, Perdiz LB, et al. Prevalence and clinical outcomes of episodes of ventilator-associated pneumonia caused by SPM-1-producing and non-producing imipenem-resistant Pseudomonas aeruginosa. Rev Soc Bras Med Trop. Oct. 2011;44(5):604-6. Exclusion Code: 2. [pmid: 22031077].
74 Georges B, Conil JM, Cougot P, et al. Cefepime in critically ill patients: continuous infusion vs. an intermittent dosing regimen. Int J Clin Pharmacol Ther. Aug. 2005;43(8):360-9. Exclusion Code: 4. [pmid: 16119511].
75 Georges B, Conil JM, Ruiz S, et al. Ceftazidime dosage regimen in intensive care unit patients: from a population pharmacokinetic approach to clinical practice via Monte Carlo simulations. Br J Clin Pharmacol. 2012;(4):588-96. PMID: CN-00832394. Exclusion Code: 4. [pmid: 21988468].
76 Georges B, Conil JM, Ruiz S, et al. Ceftazidime dosage regimen in intensive care unit patients: from a population pharmacokinetic approach to clinical practice via Monte Carlo simulations. 73:588. Exclusion Code: 6.
77 Giamarellou H, Galanakis N, Dendrinos C, et al. Evaluation of ciprofloxacin in the treatment of Pseudomonas aeruginosa infections. Eur J Clin Microbiol. Apr. 1986;5(2):232-5. Exclusion Code: 3. [pmid: 2941288].
78 Greenberg RN, Martin E. Pneumococcal pneumonia in adults treated at University of Kentucky Medical Center, 1995-1998: implications of pathogen resistance. Clin Infect Dis. May. 1999;28(5):1160-2. Exclusion Code: 3. [pmid: 10452654].
79 Greenberg RN, Reilly PM, Luppen KL, et al. Treatment of serious gram-negative infections with aztreonam. J Infect Dis. Nov. 1984;150(5):623-30. Exclusion Code: 3. [pmid: 6541672].
80 Gryglicka B, Wegrzyn-Szkutnik I, Michnar M, et al. Evaluation of an anti-chlamydial antibiotic therapy influence on asthma patients. Ann Univ Mariae Curie Sklodowska Med. 2003;58(1):444-51. Exclusion Code: 4. [pmid: 15315030].
81 Hamilton LA, Christopher Wood G, Magnotti LJ, et al. Treatment of methicillin-resistant Staphylococcus aureus ventilator-associated pneumonia with high-dose vancomycin or linezolid. J Trauma Acute Care Surg. Jun. 2012;72(6):1478-83. Exclusion Code: 2. [pmid: 22695410].
82 Hammer GS, Ribner BS, Meyers BR, et al. Clinical studies with cefazolin: a new cephalosporin antibiotic. Mt Sinai J Med. Mar-Apr. 1975;42(2):142-9. Exclusion Code: 3. [pmid: 1079566].
83 Hansman D, Glasgow H, Sturt J, et al. Increased resistance to penicillin of pneumococci isolated from man. N Engl J Med. Jan. 28. 1971;284(4):175-7. Exclusion Code: 3. [pmid: 4395334].
84 Hansmann Y, Doyle A, Remy V, et al. An outbreak of Pneumococcal pneumonia among residents of a retirement home in France during October 2003. Infect Control Hosp Epidemiol. Nov. 2006;27(11):1252-4. Exclusion Code: 6. [pmid: 17080386].
85 Haque NZ, Arshad S, Peyrani P, et al. Analysis of pathogen and host factors related to clinical outcomes in patients with hospital-acquired pneumonia due to methicillin-resistant Staphylococcus aureus. J Clin Microbiol. May. 2012;50(5):1640-4. Exclusion Code: 6. [pmid: 22337980].
86 Haque NZ, Zuniga LC, Peyrani P, et al. Relationship of vancomycin minimum inhibitory concentration to mortality in patients with methicillin-resistant Staphylococcus aureus hospital-acquired, ventilator-associated, or health-care-associated pneumonia. Chest. Dec. 2010;138(6):1356-62. Exclusion Code: 3. [pmid: 20558550].
87 Haranaga S, Tateyama M, Higa F, et al. Intravenous ciprofloxacin versus erythromycin in the treatment of Legionella pneumonia. Intern Med. 2007;46(7):353-7. Exclusion Code: 6. [pmid: 17409596].
88 Hermsen ED, Hanson M, Sankaranarayanan J, et al. Clinical outcomes and nephrotoxicity associated with vancomycin trough concentrations during treatment of deep-seated infections. Expert Opin Drug Saf. Jan. 2010;9(1):9-14. Exclusion Code: 4. [pmid: 20021290].
89 Hidayat LK, Hsu DI, Quist R, et al. High-dose vancomycin therapy for methicillin-resistant Staphylococcus aureus infections: efficacy and toxicity. Arch Intern Med. Oct. 23. 2006;166(19):2138-44. Exclusion Code: 4. [pmid: 17060545].
90 Hiraki Y, Tsuji Y, Matsumoto K, et al. Influence of linezolid clearance on the induction of thrombocytopenia and reduction of hemoglobin. Am J Med Sci. Dec. 2011;342(6):456-60. Exclusion Code: 4. [pmid: 21681075].
91 Hirata-Dulas CA, Stein DJ, Guay DR, et al. A randomized study of ciprofloxacin versus ceftriaxone in the treatment of nursing home-acquired lower respiratory tract infections. J Am Geriatr Soc. Oct. 1991;39(10):979-85. Exclusion Code: 7. [pmid: 1918785].
92 Hodges GR, Saslaw S. Experiences with cefazolin: a new cephalosporin antibiotic. Am J Med Sci. Jan. 1973;265(1):23-32. Exclusion Code: 3. [pmid: 4692994].
93 Holmes NE, Turnidge JD, Munckhof WJ, et al. Vancomycin AUC/MIC ratio and 30-day mortality in patients with Staphylococcus aureus bacteremia. Antimicrob Agents Chemother. Apr. 2013;57(4):1654-63. Exclusion Code: 7. [pmid: 23335735].
94 Hsaiky L, Murray KP, Kokoska L, et al. Standard versus prolonged doripenem infusion for treatment of gram-negative infections. Ann Pharmacother. Jul-Aug. 2013;47(7-8):999-1006. Exclusion Code: 3. [pmid: 23821611].
95 Hutschala D, Skhirtladze K, Zuckermann A, et al. In vivo measurement of levofloxacin penetration into lung tissue after cardiac surgery. Antimicrob Agents Chemother. Dec. 2005;49(12):5107-11. Exclusion Code: 6. [pmid: 16304179].
96 Ikegame S, Wakamatsu K, Kumazoe H, et al. A retrospective analysis of 111 cases of pneumococcal pneumonia: clinical features and prognostic factors. Intern Med. 2012;51(1):37-43. Exclusion Code: 4. [pmid: 22214621].
97 Imberti R, Cusato M, Villani P, et al. Steady-state pharmacokinetics and BAL concentration of colistin in critically Ill patients after IV colistin methanesulfonate administration. Chest. Dec. 2010;138(6):1333-9. Exclusion Code: 2. [pmid: 20558557].
98 Iwamoto T, Kagawa Y, Kojima M. Clinical efficacy of therapeutic drug monitoring in patients receiving vancomycin. Biol Pharm Bull. Jun. 2003;26(6):876-9. Exclusion Code: 6. [pmid: 12808304].
99 Japoni A, Vazin A, Davarpanah MA, et al. Ventilator-associated pneumonia in Iranian intensive care units. J Infect Dev Ctries. Apr. 2011;5(4):286-93. Exclusion Code: 2. [pmid: 21537070].
100 Jaruratanasirikul S, Aeinlang N, Jullangkoon M, et al. Pharmacodynamics of imipenem in critically ill patients with ventilator-associated pneumonia. J Med Assoc Thai. May. 2013;96(5):551-7. Exclusion Code: 2. [pmid: 23745309].
101 Jaruratanasirikul S, Sriwiriyajan S, Punyo J. Comparison of the pharmacodynamics of meropenem in patients with ventilator-associated pneumonia following administration by 3-hour infusion or bolus injection. Antimicrob Agents Chemother. Apr. 2005;49(4):1337-9. Exclusion Code: 2. [pmid: 15793108].
102 Jaruratanasirikul S, Sudsai T. Comparison of the pharmacodynamics of imipenem in patients with ventilator-associated pneumonia following administration by 2 or 0.5 h infusion. J Antimicrob Chemother. Mar. 2009;63(3):560-3. Exclusion Code: 2. [pmid: 19153079].
103 Jaruratanasirikul S, Wongpoowarak W, Kositpantawong N, et al. Pharmacodynamics of doripenem in critically ill patients with ventilator-associated Gram-negative bacilli pneumonia. Int J Antimicrob Agents. Nov. 2012;40(5):434-9. Exclusion Code: 2. [pmid: 22959555].
104 Jeffres MN, Isakow W, Doherty JA, et al. Predictors of mortality for methicillin-resistant Staphylococcus aureus health-care-associated pneumonia: specific evaluation of vancomycin pharmacokinetic indices. Chest. Oct. 2006;130(4):947-55. Exclusion Code: 6. [pmid: 17035423].
105 Jeffres MN, Isakow W, Doherty JA, et al. A retrospective analysis of possible renal toxicity associated with vancomycin in patients with health care-associated methicillin-resistant Staphylococcus aureus pneumonia. Clin Ther. Jun. 2007;29(6):1107-15. Exclusion Code: 6. [pmid: 17692725].
106 Jehl F, Muller-Serieys C, de Larminat V, et al. Penetration of piperacillin-tazobactam into bronchial secretions after multiple doses to intensive care patients. Antimicrob Agents Chemother. Dec. 1994;38(12):2780-4. Exclusion Code: 7. [pmid: 7695262].
107 Jonsson M, Walder M. Pharmacokinetics of intravenous antibiotics in acutely ill elderly patients. Eur J Clin Microbiol. Dec. 1986;5(6):629-33. Exclusion Code: 7. [pmid: 3803375].
108 Kashuba AD, Bertino JS Jr, Nafziger AN. Dosing of aminoglycosides to rapidly attain pharmacodynamic goals and hasten therapeutic response by using individualized pharmacokinetic monitoring of patients with pneumonia caused by gram-negative organisms. Antimicrob Agents Chemother. Jul. 1998;42(7):1842-4. Exclusion Code: 4. [pmid: 9661031].
109 Kashuba AD, Nafziger AN, Drusano GL, et al. Optimizing aminoglycoside therapy for nosocomial pneumonia caused by gram-negative bacteria. Antimicrob Agents Chemother. Mar. 1999;43(3):623-9. Exclusion Code: 2. [pmid: 10049277].
110 Kim A, Kuti JL, Nicolau DP. Probability of Pharmacodynamic Target Attainment With Standard and Prolonged-Infusion Antibiotic Regimens for Empiric Therapy in Adults With Hospital-Acquired Pneumonia. Clin Ther. 31:2765. Exclusion Code: 3. [pmid: 20110018].
111 Klekner A, Bagyi K, Bognar L, et al. Effectiveness of cephalosporins in the sputum of patients with nosocomial bronchopneumonia. J Clin Microbiol. Sep. 2006;44(9):3418-21. Exclusion Code: 2. [pmid: 16954290].
112 Koch-Weser J, Sidel VW, Federman EB, et al. Adverse effects of sodium colistimethate. Manifestations and specific reaction rates during 317 courses of therapy. Ann Intern Med. Jun. 1970;72(6):857-68. Exclusion Code: 3. [pmid: 5448745].
113 Krobot CH, Smith PS. Infections in the elderly. Part 2. Therapeutic considerations. Hosp. Ther. 1988;13(Jan):27-41. Exclusion Code: 5.
114 Langgartner J, Lehn N, Gluck T, et al. Comparison of the pharmacokinetics of piperacillin and sulbactam during intermittent and continuous intravenous infusion. Chemotherapy. 2007;53(5):370-7. Exclusion Code: 2. [pmid: 17785973].
115 Le Bris-Tomczak A, Bedos JP, Billon C, et al. Antibiotic strategy in severe community-acquired pneumococcal pneumonia. Med Mal Infect. May. 2012;42(5):226-34. Exclusion Code: 4. [pmid: 22583782].
116 Leblebicioglu H, Cakir N, Celen M, et al. Comparative activity of carbapenem testing (the COMPACT study) in Turkey. BMC Infect Dis. 2012;12:42. Exclusion Code: 6. [pmid: 22340940].
117 Lechi A, Arosio E, Montesi G, et al. Ceftazidime in patients with severe Pseudomonas infections. Int J Clin Pharmacol Ther Toxicol. Mar. 1986;24(3):159-64. Exclusion Code: 3. [pmid: 3516892].
118 Lerner PI, Smith H, Weinstein L. Penicillin neurotoxicity. Ann N Y Acad Sci. Sep. 27. 1967;145(2):310-8. Exclusion Code: 3. [pmid: 4998180].
119 Li C, Kuti JL, Nightingale CH, et al. Population pharmacokinetic analysis and dosing regimen optimization of meropenem in adult patients. J Clin Pharmacol. Oct. 2006;46(10):1171-8. Exclusion Code: 4. [pmid: 16988206].
120 Linssen CF, Jacobs JA, Schouten JS, et al. Influence of antibiotic therapy on the cytological diagnosis of ventilator-associated pneumonia. Intensive Care Med. May. 2008;34(5):865-72. Exclusion Code: 2. [pmid: 18251009].
121 Lodise TP, Drusano GL, Butterfield JM, et al. Penetration of vancomycin into epithelial lining fluid in healthy volunteers. Antimicrob Agents Chemother. Dec. 2011;55(12):5507-11. Exclusion Code: 4. [pmid: 21911567].
122 Lodise TP Jr, Lomaestro B, Drusano GL. Piperacillin-tazobactam for Pseudomonas aeruginosa infection: clinical implications of an extended-infusion dosing strategy. Clin Infect Dis. Feb. 1. 2007;44(3):357-63. Exclusion Code: 6. [pmid: 17205441].
123 Lodise TP, Patel N, Lomaestro BM, et al. Relationship between initial vancomycin concentration-time profile and nephrotoxicity among hospitalized patients. Clin Infect Dis. Aug. 15. 2009;49(4):507-14. Exclusion Code: 4. [pmid: 19586413].
124 Lodise TP Jr, Pypstra R, Kahn JB, et al. Probability of target attainment for ceftobiprole as derived from a population pharmacokinetic analysis of 150 subjects. Antimicrob Agents Chemother. Jul. 2007;51(7):2378-87. Exclusion Code: 3. [pmid: 17387149].
125 Lodise TP, Sorgel F, Melnick D, et al. Penetration of meropenem into epithelial lining fluid of patients with ventilator-associated pneumonia. Antimicrob Agents Chemother. Apr. 2011;55(4):1606-10. Exclusion Code: 6. [pmid: 21300830].
126 Lorente L, Jimenez A, Palmero S, et al. Comparison of clinical cure rates in adults with ventilator-associated pneumonia treated with intravenous ceftazidime administered by continuous or intermittent infusion: a retrospective, nonrandomized, open-label, historical chart review. Clin Ther. Nov. 2007;29(11):2433-9. Exclusion Code: 6. [pmid: 18158083].
127 Lorente L, Lorenzo L, Martin MM, et al. Meropenem by continuous versus intermittent infusion in ventilator-associated pneumonia due to gram-negative bacilli. Ann Pharmacother. Feb. 2006;40(2):219-23. Exclusion Code: 6. [pmid: 16449546].
128 Lu Q, Yang J, Liu Z, et al. Nebulized ceftazidime and amikacin in ventilator-associated pneumonia caused by Pseudomonas aeruginosa. Am J Respir Crit Care Med. Jul. 1. 2011;184(1):106-15. Exclusion Code: 2. [pmid: 21474643].
129 Luna CM, Vujacich P, Niederman MS, et al. Impact of BAL data on the therapy and outcome of ventilator-associated pneumonia. Chest. Mar. 1997;111(3):676-85. Exclusion Code: 6. [pmid: 9118708].
130 Luque S, Grau S, Valle M, et al. Differences in pharmacokinetics and pharmacodynamics of colistimethate sodium (CMS) and colistin between three different CMS dosage regimens in a critically ill patient infected by a multidrug-resistant Acinetobacter baumannii. Int J Antimicrob Agents. Aug. 2013;42(2):178-81. Exclusion Code: 3. [pmid: 23769664].
131 Maeda Y, Omoda K, Fukuhara S, et al. Evaluation of clinical efficacy of Maeda's nomogram for vancomycin dosage adjustment in adult Japanese MRSA pneumonia patients. Drug Metab Pharmacokinet. Feb. 2006;21(1):54-60. Exclusion Code: 3. [pmid: 16547394].
132 Mah GT, Mabasa VH, Chow I, et al. Evaluating Outcomes Associated with Alternative Dosing Strategies for Piperacillin/Tazobactam: A Qualitative Systematic Review. Ann Pharmacother. 2012;117:265. Exclusion Code: 5. [pmid: 22274145].
133 Mandigers CM, Diepersloot RJ, Dessens M, et al. A hospital outbreak of penicillin-resistant pneumococci in The Netherlands. Eur Respir J. Sep. 1994;7(9):1635-9. Exclusion Code: 6. [pmid: 7995393].
134 Mann HJ, Canafax DM, Cipolle RJ, et al. Increased dosage requirements of tobramycin and gentamicin for treating Pseudomonas pneumonia in patients with cystic fibrosis. Pediatr Pulmonol. Sep-Oct. 1985;1(5):238-43. Exclusion Code: 4. [pmid: 4069813].
135 Matsumoto T, Hanaki H, Kimura T, et al. Clinical efficacy and safety of arbekacin sulfate in patients with MRSA sepsis or pneumonia: a multi-institutional study. J Infect Chemother. Feb. 2013;19(1):128-37. Exclusion Code: 3. [pmid: 23263188].
136 Mazzei JA, Mazzei CM, Palermo ME. Amoxicillin in the treatment of respiratory infections. J Infect Dis. Jun. suppl. 1974;129(0):S200-1. Exclusion Code: 3. [pmid: 4152075].
137 McKindley DS, Boucher BA, Hess MM, et al. Pharmacokinetics of aztreonam and imipenem in critically ill patients with pneumonia. Pharmacotherapy. Sep-Oct. 1996;16(5):924-31. Exclusion Code: 3. [pmid: 8888088].
138 McMillian WD, Bednarik JL, Aloi JJ, et al. Utility of ampicillin-sulbactam for empiric treatment of ventilator-associated pneumonia in a trauma population. J Trauma. Oct. 2010;69(4):861-5. Exclusion Code: 2. [pmid: 20938272].
139 Medell M, Hart M, Duquesne A, et al. Nosocomial ventilator-associated pneumonia in Cuban intensive care units: bacterial species and antibiotic resistance. MEDICC Rev. Apr. 2013;15(2):26-9. Exclusion Code: 3. [pmid: 23686252].
140 Merchant S, Gast C, Nathwani D, et al. Hospital resource utilization with doripenem versus imipenem in the treatment of ventilator-associated pneumonia. Clin Ther. Apr. 2008;30(4):717-33. Exclusion Code: 7. [pmid: 18498921].
141 Michel F, Franceschini B, Berger P, et al. Early antibiotic treatment for BAL-confirmed ventilator-associated pneumonia: a role for routine endotracheal aspirate cultures. Chest. Feb. 2005;127(2):589-97. Exclusion Code: 6. [pmid: 15706001].
142 Miyagawa CI, Andrle AM, Healy DP. Continuous ceftazidime infusions in critically ill surgical patients. Journal of Infectious Disease Pharmacotherapy (USA). 1999;4(Jan):25-34. Exclusion Code: 7.
143 Mizokami F, Shibasaki M, Yoshizue Y, et al. Pharmacodynamics of vancomycin in elderly patients aged 75 years or older with methicillin-resistant Staphylococcus aureus hospital-acquired pneumonia. Clin Interv Aging. 2013;8:1015-21. Exclusion Code: 3. [pmid: 23966773].
144 Moise-Broder PA, Forrest A, Birmingham MC, et al. Pharmacodynamics of vancomycin and other antimicrobials in patients with Staphylococcus aureus lower respiratory tract infections. Clin Pharmacokinet. 2004;43(13):925-42. Exclusion Code: 4. [pmid: 15509186].
145 Montgomery MJ, Beringer PM, Aminimanizani A, et al. Population pharmacokinetics and use of Monte Carlo simulation to evaluate currently recommended dosing regimens of ciprofloxacin in adult patients with cystic fibrosis. Antimicrob Agents Chemother. Dec. 2001;45(12):3468-73. Exclusion Code: 6. [pmid: 11709326].
146 Moriyama B, Henning SA, Childs R, et al. High-dose continuous infusion beta-lactam antibiotics for the treatment of resistant Pseudomonas aeruginosa infections in immunocompromised patients. Ann Pharmacother. May. 2010;44(5):929-35. Exclusion Code: 6. [pmid: 20371747].
147 Mulligan T, Kolb KW. Ceftriaxone pharmacokinetics in infected nursing home residents. Journal of Geriatric Drug Therapy (USA). 1991;6(Feb):45-64. Exclusion Code: 3.
148 Nandy P, Samtani MN, Lin R. Population pharmacokinetics of doripenem based on data from phase 1 studies with healthy volunteers and phase 2 and 3 studies with critically ill patients. Antimicrob Agents Chemother. Jun. 2010;54(6):2354-9. Exclusion Code: 4. [pmid: 20385854].
149 Nicasio AM, Ariano RE, Zelenitsky SA, et al. Population pharmacokinetics of high-dose, prolonged-infusion cefepime in adult critically ill patients with ventilator-associated pneumonia. Antimicrob Agents Chemother. Apr. 2009;53(4):1476-81. Exclusion Code: 6. [pmid: 19188394].
150 Nicasio AM, Eagye KJ, Nicolau DP, et al. Pharmacodynamic-based clinical pathway for empiric antibiotic choice in patients with ventilator-associated pneumonia. J Crit Care. Mar. 2010;25(1):69-77. Exclusion Code: 6. [pmid: 19427167].
151 Nicholls AC, Pease PE, Green ID. A study of the agglutinin response in 40 cases of bacterial pneumonia. J Clin Pathol. Jun. 1975;28(6):453-6. Exclusion Code: 3. [pmid: 806611].
152 Nichols L, Gudmundsson S, Maki DG. Experience with cefsulodin therapy for lower respiratory tract infections caused by Pseudomonas aeruginosa in adults without cystic fibrosis or granulocytopenia. Rev Infect Dis. Sep-Oct. Suppl 3. 1984;6:S711-20. Exclusion Code: 7. [pmid: 6443772].
153 Nicoletti G, Schito G, Fadda G, et al. Bacterial isolates from severe infections and their antibiotic susceptibility patterns in Italy: a nationwide study in the hospital setting. J Chemother. Dec. 2006;18(6):589-602. Exclusion Code: 4. [pmid: 17267336].
154 Niederman MS, Chastre J, Corkery K, et al. BAY41-6551 achieves bactericidal tracheal aspirate amikacin concentrations in mechanically ventilated patients with Gram-negative pneumonia. Intensive Care Med. Feb. 2012;38(2):263-71. Exclusion Code: 2. [pmid: 22147112].
155 Noone P, Parsons TM, Pattison JR, et al. Experience in monitoring gentamicin therapy during treatment of serious gram-negative sepsis. Br Med J. Mar. 16. 1974;1(5906):477-81. Exclusion Code: 4. [pmid: 4206128].
156 Noreddin AM, Marras TK, Sanders K, et al. Pharmacodynamic target attainment analysis against Streptococcus pneumoniae using levofloxacin 500 mg, 750 mg and 1000 mg once daily in plasma (P) and epithelial lining fluid (ELF) of hospitalized patients with community acquired pneumonia (CAP). Int J Antimicrob Agents. Nov. 2004;24(5):479-84. Exclusion Code: 4. [pmid: 15519481].
157 Ohmichi M, Hiraga Y. The efficacy, safety and pharmacokinetics of intravenous ciprofloxacin in patients with lower respiratory tract infections. J Int Med Res. 1999;27(6):297-304. Exclusion Code: 4. [pmid: 10726239].
158 Okimoto N, Yamato K, Honda Y, et al. Clinical effect of intravenous ciprofloxacin on hospital-acquired pneumonia. J Infect Chemother. Feb. 2005;11(1):52-4. Exclusion Code: 2. [pmid: 15729490].
159 Padrones S, Garcia-Vidal C, Fernandez-Serrano S, et al. Impact of antibiotic therapy on systemic cytokine expression in pneumococcal pneumonia. Eur J Clin Microbiol Infect Dis. Oct. 2010;29(10):1243-51. Exclusion Code: 2. [pmid: 20567869].
160 Paladino JA, Eubanks DA, Adelman MH, et al. Once-daily cefepime versus ceftriaxone for nursing home-acquired pneumonia. J Am Geriatr Soc. May. 2007;55(5):651-7. Exclusion Code: 2. [pmid: 17493183].
161 Panidis D, Markantonis SL, Boutzouka E, et al. Penetration of gentamicin into the alveolar lining fluid of critically ill patients with ventilator-associated pneumonia. Chest. Aug. 2005;128(2):545-52. Exclusion Code: 7. [pmid: 16100136].
162 Park SC, Kim EY, Kang YA, et al. Validation of a scoring tool to predict drug-resistant pathogens in hospitalised pneumonia patients. Int J Tuberc Lung Dis. May. 2013;17(5):704-9. Exclusion Code: 3. [pmid: 23575340].
163 Patanwala AE, Norris CJ, Nix DE, et al. Vancomycin dosing for pneumonia in critically ill trauma patients. J Trauma. Oct. 2009;67(4):802-4. Exclusion Code: 6. [pmid: 19820588].
164 Patel N, Scheetz MH, Drusano GL, et al. Identification of optimal renal dosage adjustments for traditional and extended-infusion piperacillin-tazobactam dosing regimens in hospitalized patients. Antimicrob Agents Chemother. Jan. 2010;54(1):460-5. Exclusion Code: 2. [pmid: 19858253].
165 Pea F, Furlanut M, Cojutti P, et al. Therapeutic drug monitoring of linezolid: a retrospective monocentric analysis. Antimicrob Agents Chemother. Nov. 2010;54(11):4605-10. Exclusion Code: 4. [pmid: 20733043].
166 Pedersen SS, Pressler T, Jensen T, et al. Combined imipenem/cilastatin and tobramycin therapy of multiresistant Pseudomonas aeruginosa in cystic fibrosis. J Antimicrob Chemother. Jan. 1987;19(1):101-7. Exclusion Code: 3. [pmid: 3104273].
167 Perry TR, Schentag JJ. Clinical use of ceftriaxone: a pharmacokinetic-pharmacodynamic perspective on the impact of minimum inhibitory concentration and serum protein binding. Clin Pharmacokinet. 2001;40(9):685-94. Exclusion Code: 6. [pmid: 11605716].
168 Poon H, Chang MH, Fung HB. Ceftaroline Fosamil: A Cephalosporin With Activity Against Methicillin-Resistant Staphylococcus Aureus;. Clin Ther. 2012;34:743. Exclusion Code: 5. [pmid: 22444785].
169 Potgieter PD, Linton DM, Forder AA, et al. Ceftriaxone therapy in adults with severe lower respiratory tract infections. S Afr Med J. Apr. 12. 1986;69(8):495-7. Exclusion Code: 3. [pmid: 3961646].
170 Potgieter PD, Linton DM, Forder AA, et al. Imipenem/cilastatin in the treatment of severe nosocomial pneumonia. S Afr Med J. Oct. 15. 1988;74(8):390-2. Exclusion Code: 3. [pmid: 3187816].
171 Radigan EA, Gilchrist NA, Miller MA. Management of aminoglycosides in the intensive care unit. J Intensive Care Med. Nov-Dec. 2010;25(6):327-42. Exclusion Code: 6. [pmid: 20837630].
172 Raff MJ, Rogers JH, Barnwell PA, et al. Cefazolin in the treatment of pneumonia. Int J Clin Pharmacol Biopharm. Feb. 1978;16(2):78-82. Exclusion Code: 7. [pmid: 24596].
173 Ramirez J, Dartois N, Gandjini H, et al. Randomized Phase 2 Trial To Evaluate the Clinical Efficacy of Two High-Dosage Tigecycline Regimens versus Imipenem-Cilastatin for Treatment of Hospital-Acquired Pneumonia. Antimicrob Agents Chemother. 2013;57:1756. Exclusion Code: 7. [pmid: 23357775].
174 Rea-Neto A, Niederman M, Lobo SM, et al. Efficacy and safety of doripenem versus piperacillin/tazobactam in nosocomial pneumonia: a randomized, open-label, multicenter study. Curr Med Res Opin. Jul. 2008;24(7):2113-26. Exclusion Code: 2. [pmid: 18549664].
175 Reina R, Estenssoro E, Sáenz G, et al. Safety and efficacy of colistin in Acinetobacter and Pseudomonas infections: a prospective cohort study. Intensive Care Med. 2005;(8):1058-65. PMID: CN-00528693. Exclusion Code: 3. [pmid: 15983759].
176 Richards F, McCall C, Cox C. Gentamicin treatment of staphylococcal infections. JAMA. Feb. 22. 1971;215(8):1297-300. Exclusion Code: 3. [pmid: 5107559].
177 Rizzato G, Montemurro L, Fanti D, et al. Meropenem versus imipenem: Relationship between microbiological parameters and clinical outcome in lower respiratory tract infections. Curr Ther Res Clin Exp. 1993;(6):731-52. PMID: CN-00179823. Exclusion Code: 3.
178 Roberts JA, Lipman J. Optimal doripenem dosing simulations in critically ill nosocomial pneumonia patients with obesity, augmented renal clearance, and decreased bacterial susceptibility. Crit Care Med. Feb. 2013;41(2):489-95. Exclusion Code: 6. [pmid: 23263583].
179 Rouzic N, Janvier F, Libert N, et al. Prompt and successful toxin-targeting treatment of three patients with necrotizing pneumonia due to Staphylococcus aureus strains carrying the Panton-Valentine leukocidin genes. J Clin Microbiol. May. 2010;48(5):1952-5. Exclusion Code: 6. [pmid: 20129956].
180 Rubino CM, Forrest A, Bhavnani SM, et al. Tigecycline population pharmacokinetics in patients with community- or hospital-acquired pneumonia. Antimicrob Agents Chemother. Dec. 2010;54(12):5180-6. Exclusion Code: 4. [pmid: 20921315].
181 Rubinstein E, Vaughan D. Tigiecycline - A novel glycylcycline. Drugs (New Zealand). 2005;65(Oct):1317-36. Exclusion Code: 5.
182 Sandiumenge A, Diaz E, Rodriguez A, et al. Impact of diversity of antibiotic use on the development of antimicrobial resistance. J Antimicrob Chemother. Jun. 2006;57(6):1197-204. Exclusion Code: 2. [pmid: 16565158].
183 Santré C, Georges H, Jacquier JM, et al. Amikacin levels in bronchial secretions of 10 pneumonia patients with respiratory support treated once daily versus twice daily. Antimicrob Agents Chemother. 1995;(1):264-7. PMID: CN-00112321. Exclusion Code: 4. [pmid: 7695320].
184 Satia I, Bashagha S, Anwar N, et al. Not your typical pneumonia. Clin Med. Apr. 2013;13(2):206-10. Exclusion Code: 2. [pmid: 23681877].
185 Sato M, Chida K, Suda T, et al. Recommended initial loading dose of teicoplanin, established by therapeutic drug monitoring, and outcome in terms of optimal trough level. J Infect Chemother. Aug. 2006;12(4):185-9. Exclusion Code: 3. [pmid: 16944256].
186 Schafer JJ, Goff DA, Stevenson KB, et al. Early experience with tigecycline for ventilator-associated pneumonia and bacteremia caused by multidrug-resistant Acinetobacter baumannii. Pharmacotherapy. Jul. 2007;27(7):980-7. Exclusion Code: 6. [pmid: 17594203].
187 Scheetz MH, Wunderink RG, Postelnick MJ. Potential impact of vancomycin pulmonary distribution on treatment outcomes in patients with methicillin-resistant <it>Staphylococcus aureus</it> pneumonia. Pharmacotherapy (USA). 2006;26(Apr):539-50. Exclusion Code: 5.
188 Schentag JJ. Correlation of pharmacokinetic parameters to efficacy of antibiotics: relationships between serum concentrations, MIC values, and bacterial eradication in patients with gram-negative pneumonia. Scand J Infect Dis Suppl. 1990;74:218-34. Exclusion Code: 7. [pmid: 2097710].
189 Schentag JJ, Reitberg DP, Cumbo TJ. Cefmenoxime efficacy, safety, and pharmacokinetics in critical care patients with nosocomial pneumonia. Am J Med. Dec. 21. 1984;77(6A):34-42. Exclusion Code: 3. [pmid: 6097122].
190 Schentag JJ, Smith IL, Swanson DJ, et al. Role for dual individualization with cefmenoxime. Am J Med. Dec. 21. 1984;77(6A):43-50. Exclusion Code: 3. [pmid: 6097124].
191 Schmelzer TM, Christmas AB, Norton HJ, et al. Vancomycin intermittent dosing versus continuous infusion for treatment of ventilator-associated pneumonia in trauma patients. Am Surg. 2013;79(11):1185-90. PMID: CN-00962463. Exclusion Code: 3. [pmid: 24165255].
192 Schuetz P, Christ-Crain M, Wolbers M, et al. Procalcitonin guided antibiotic therapy and hospitalization in patients with lower respiratory tract infections: a prospective, multicenter, randomized controlled trial. BMC Health Serv Res. 2007;7:102. Exclusion Code: 2. [pmid: 17615073].
193 Shea KM, Cheatham SC, Smith DW, et al. Comparative Pharmacodynamics of Intermittent and Prolonged Infusions of Piperacillin/Tazobactam Using Monte Carlo Simulations and Steady-State Pharmacokinetic Data from Hospitalized Patients. Ann Pharmacother. 2009;43:1747. Exclusion Code: 3. [pmid: 19809009].
194 Shiba K, Hori S, Shimada J, et al. Fundamental and clinical studies on tazobactam/piperacillin. Chemotherapy. 1994;(Suppl. 2):369-80. PMID: CN-00398771. Exclusion Code: 1. [pmid: 7842819].
195 Shimazaki N, Hayashi H, Umeda K, et al. Clinical factors affecting the efficacy of vancomycin in methicillin-resistant Staphylococcus aureus pneumonia. Int J Clin Pharmacol Ther. Aug. 2010;48(8):534-41. Exclusion Code: 6. [pmid: 20650045].
196 Shiu Jennifer R, Wang E, Tejani Aaron M, et al. Continuous versus intermittent infusions of antibiotics for the treatment of severe acute infections. Cochrane Database of Systematic Reviews. 2013;(3). PMID: CD008481. Exclusion Code: 6.
197 Shorr AF, Cook D, Jiang X, et al. Correlates of clinical failure in ventilator-associated pneumonia: insights from a large, randomized trial. J Crit Care. 2008;(1):64-73. PMID: CN-00647918. Exclusion Code: 3. [pmid: 18359423].
198 Simon C, Gatzemeier U. Serum and sputum levels of cefaclor. Postgrad Med J. 1979:30-4. PMID: CN-00023058. Exclusion Code: 3. [pmid: 548940].
199 Sloan RW. Monitoring antimicrobial therapy. Am Fam Physician. Apr. 1982;25(4):136-42. Exclusion Code: 5. [pmid: 6461233].
200 Solberg CO, Matsen JM. Infections with Providence bacilli. A clinical and bacteriologic study. Am J Med. Feb. 1971;50(2):241-6. Exclusion Code: 3. [pmid: 5545459].
201 Stein GE, Wells EM. The importance of tissue penetration in achieving successful antimicrobial treatment of nosocomial pneumonia and complicated skin and soft-tissue infections caused by methicillin-resistant Staphylococcus aureus: vancomycin and linezolid. Curr Med Res Opin. Mar. 2010;26(3):571-88. Exclusion Code: 6. [pmid: 20055750].
202 Stolz D, Smyrnios N, Eggimann P, et al. Procalcitonin for reduced antibiotic exposure in ventilator-associated pneumonia: a randomised study. Eur Respir J. Dec. 2009;34(6):1364-75. Exclusion Code: 2. [pmid: 19797133].
203 Suzuki Y, Kawasaki K, Sato Y, et al. Is peak concentration needed in therapeutic drug monitoring of vancomycin? A pharmacokinetic-pharmacodynamic analysis in patients with methicillin-resistant staphylococcus aureus pneumonia. Chemotherapy. 2012;58(4):308-12. Exclusion Code: 4. [pmid: 23147106].
204 Sveska KJ, Roffe BD, Solomon DK, et al. Outcome of patients treated by an aminoglycoside pharmacokinetic dosing service. Am J Hosp Pharm. Nov. 1985;42(11):2472-8. Exclusion Code: 4. [pmid: 4073064].
205 Talaie H, Sabeti S, Mahdavinejad A, et al. A survey on microorganisms and their sensitivity by E-test in ventilator-associated pneumonia at Toxicological-Intensive Care Unit of Loghman-Hakim Hospital. Acta Biomed. Dec. 2010;81(3):210-6. Exclusion Code: 2. [pmid: 22530459].
206 Tayab ZR, Hochhaus G, Kaufmann S, et al. Do intensive care patients need an individualized dosing regimen for levofloxacin?. Int J Clin Pharmacol Ther. Jun. 2006;44(6):262-9. Exclusion Code: 4. [pmid: 16800098].
207 Thalhammer F, Traunmuller F, El Menyawi I, et al. Continuous infusion versus intermittent administration of meropenem in critically ill patients. J Antimicrob Chemother. Apr. 1999;43(4):523-7. Exclusion Code: 4. [pmid: 10350382].
208 Tod M, Minozzi C, Beaucaire G, et al. Isepamicin in intensive care unit patients with nosocomial pneumonia: population pharmacokinetic-pharmacodynamic study. J Antimicrob Chemother. Jul. 1999;44(1):99-108. Exclusion Code: 3. [pmid: 10459816].
209 Torres A, Bauer TT, León-Gil C, et al. Treatment of severe nosocomial pneumonia: a prospective randomised comparison of intravenous ciprofloxacin with imipenem/cilastatin. Thorax. 2000;(12):1033-9. PMID: CN-00329657. Exclusion Code: 3. [pmid: 11083889].
210 Uvizl R, Hanulik V, Husickova V, et al. Hospital-acquired pneumonia in ICU patients. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Dec. 2011;155(4):373-8. Exclusion Code: 2. [pmid: 22336651].
211 Valdivieso M, Feld R, Rodriguez V, et al. Amikacin therapy of infections in neutropenic patients. Am J Med Sci. Nov-Dec. 1975;270(3):453-63. Exclusion Code: 4. [pmid: 1108649].
212 Van der Auwera P, Clumeck N, Van Laethem Y, et al. Moxalactam therapy of serious infections. Infection. Jul-Aug. 1983;11(4):212-8. Exclusion Code: 7. [pmid: 6618677].
213 van Ingen J, Egelund EF, Levin A, et al. The pharmacokinetics and pharmacodynamics of pulmonary Mycobacterium avium complex disease treatment. Am J Respir Crit Care Med. Sep. 15. 2012;186(6):559-65. Exclusion Code: 4. [pmid: 22744719].
214 Vic P, Ategbo S, Turck D, et al. Tolerance, pharmacokinetics and efficacy of once daily amikacin for treatment of Pseudomonas aeruginosa pulmonary exacerbations in cystic fibrosis patients. Eur J Pediatr. Nov. 1996;155(11):948-53. Exclusion Code: 4. [pmid: 8911895].
215 Wade WE, McCall CY. Pharmacist-managed aminoglycoside therapy in combination with a beta-lactam agent in the treatment of nosocomial pneumonia in critically ill patients. Pharmacotherapy. Mar-Apr. 1995;15(2):216-9. Exclusion Code: 7. [pmid: 7624269].
216 Wallace RJ Jr, Steele LC, Brooks DL, et al. Amoxicillin-clavulanic acid in the treatment of lower respiratory tract infections caused by beta-lactamase-positive Haemophilus influenzae and Branhamella catarrhalis. Antimicrob Agents Chemother. Jun. 1985;27(6):912-5. Exclusion Code: 3. [pmid: 3875310].
217 Walraven CJ, North MS, Marr-Lyon L, et al. Site of infection rather than vancomycin MIC predicts vancomycin treatment failure in methicillin-resistant Staphylococcus aureus bacteraemia. J Antimicrob Chemother. Oct. 2011;66(10):2386-92. Exclusion Code: 4. [pmid: 21775337].
218 Warns H, Lode H, Harnoss CM, et al. Multiple dose pharmacokinetics and therapeutic results with ceftazidime. J Antimicrob Chemother. Jul. Suppl A. 1983;12:235-40. Exclusion Code: 3. [pmid: 6352625].
219 Watling SM, Kisor DF. Population pharmacokinetics: development of a medical intensive care unit-specific gentamicin dosing nomogram. Ann Pharmacother. Feb. 1993;27(2):151-4. Exclusion Code: 4. [pmid: 8439687].
220 Wesner AR, Brackbill ML, Coyle LL, et al. Prospective trial of a novel nomogram to achieve updated vancomycin trough concentrations. Interdisciplinary perspectives on infectious diseases. 2013. PMID: CN-00913801. Exclusion Code: 3.
221 Wysocki M, Delatour F, Faurisson F, et al. Continuous versus intermittent infusion of vancomycin in severe Staphylococcal infections: prospective multicenter randomized study. Antimicrob Agents Chemother. Sep. 2001;45(9):2460-7. Exclusion Code: 4. [pmid: 11502515].
222 Yamamoto M, Kuzuya T, Baba H, et al. Population pharmacokinetic analysis of vancomycin in patients with gram-positive infections and the influence of infectious disease type. J Clin Pharm Ther. Aug. 2009;34(4):473-83. Exclusion Code: 4. [pmid: 19583681].
223 Yamamoto Y, Izumikawa K, Hashiguchi K, et al. The efficacy and safety of high-dose arbekacin sulfate therapy (once-daily treatment) in patients with MRSA infection. J Infect Chemother. Apr. 2012;18(2):241-6. Exclusion Code: 3. [pmid: 22398881].
224 Yoshida K, Okimoto N, Kishimoto M, et al. Efficacy and safety of moxifloxacin for community-acquired bacterial pneumonia based on pharmacokinetic analysis. J Infect Chemother. Oct. 2011;17(5):678-85. Exclusion Code: 4. [pmid: 21847518].
225 Yoshida M, Yasuda N, Nishikata M, et al. New recommendations for vancomycin dosage for patients with MRSA pneumonia with various degrees of renal function impairment. J Infect Chemother. Aug. 2005;11(4):182-8. Exclusion Code: 6. [pmid: 16133709].
226 Young RJ, Lipman J, Gin T, et al. Intermittent bolus dosing of ceftazidime in critically ill patients. J Antimicrob Chemother. Aug. 1997;40(2):269-73. Exclusion Code: 4. [pmid: 9301994].
227 Zarowitz BJ, Robert S, Peterson EL. Prediction of glomerular filtration rate using aminoglycoside clearance in critically ill medical patients. Ann Pharmacother. Oct. 1992;26(10):1205-10. Exclusion Code: 4. [pmid: 1421639].
228 Zhanel GG, Sniezek G, Schweizer F, et al. Ceftaroline A Novel Broad-Spectrum Cephalosporin with Activity against Meticillin-Resistant Staphylococcus aureus. 69-809. Exclusion Code: 5.
229 Zhang J, Xu JF, Liu YB, et al. Population pharmacokinetics of oral levofloxacin 500 mg once-daily dosage in community-acquired lower respiratory tract infections: results of a prospective multicenter study in China. J Infect Chemother. Oct. 2009;15(5):293-300. Exclusion Code: 4. [pmid: 19856067].