# Risk of Bias Assessment

In general terms, a “low” risk of bias study has the least risk of bias and its results are considered to be valid. A “medium” risk of bias study is susceptible to some bias but probably not sufficient to invalidate its results. A “high” risk of bias study has significant risk of bias (e.g., stemming from serious errors in design, conduct, or analysis) that may invalidate its results.

For this systematic review (SR), two independent reviewers assigned risk of bias ratings for each study. For each article, one of the two reviewers was always an experienced investigator. Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team.

The most common methodologic shortcomings contributing to high risk of bias ratings were high rates of attrition or differential attrition, inadequate methods used to handle missing data, and lack of intention-to-treat analysis.

Below we list the 15 questions used to assess risk of bias for randomized controlled trials and the 10 questions used to assess risk of bias for observational studies. Then, Tables B-1 and B-2 (respectively) provide the answers to these questions for each study.

Table B-1 Risk of bias ratings for randomized controlled trials

Table B-1 Risk of bias ratings for randomized controlled trials, part 1

Author, Year Trial Name | Method of randomization adequate? | Allocation of treatment adequately concealed? | Did strategy for recruiting participants into study differ across study groups? | Baseline characteristics similar between groups? If not, did analysis control for differences? | Were the outcome assessors blinded to the intervention or exposure status of participants? | Were the care providers blinded to the intervention or exposure status of participants? | Were the patients blinded to their intervention or exposure status?
Hanes et al., 2000^1^ | Unclear or not reported | No | No | Yes | No | No | Unclear or not reported
Jaruratanasirikul, 2012^2^ | Yes | No | No | Only 11 pts, mostly male, varying renal function | No | No | Yes
Nicolau, 1999^3^ | Unclear or NR | No | No | Yes | No | Single blinded (unclear who was blinded and who was not) | Unclear who was blinded and who was not
Nicolau, 1999^4^ | Unclear or NR | No | No | Yes | No | No mention of blinding | No mention of blinding
Nicolau, 2001^5^ McNabb, 2001^6^ | Unclear or NR | No | No | Yes | No | Not blinded (open label) | Not blinded (open label)
Sakka, 2007^7^ | Yes | Unclear or NR | Unclear or NR | Yes | Unclear or NR | Not blinded | Not blinded
Wang, 2009^8^ | Unclear or not reported | No | No | Yes, but very few baseline characteristics reported | No | No | Unclear or not reported

Table B-1 Risk of bias ratings for randomized controlled trials, part 2

Author, Year Trial Name | Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results? | Did variation from the study protocol compromise the conclusions of the study? | Was there a high rate of differential or overall attrition? (i.e., ≥20% for overall attrition or ≥15% for differential attrition) | Did attrition result in a difference in group characteristics between baseline (or randomization) and follow-up? | Is the analysis conducted on an intention-to-treat (ITT) basis? | Are the inclusion/exclusion criteria measured using valid and reliable measures, implemented consistently across all study participants?
Hanes et al., 2000^1^ | Unclear or not reported | No | No | No | Unclear or not reported | Yes
Jaruratanasirikul, 2012^2^ | No | No | No | No | No | Yes
Nicolau, 1999^3^ | Unclear or NR | No | No | Yes | No | Yes
Nicolau, 1999^4^ | Unclear or NR | Unclear or NR | Unclear or NR | Unclear or NR | Unclear or NR | Yes
Nicolau, 2001^5^ McNabb, 2001^6^ | Yes | No | No | No | No | Yes
Sakka, 2007^7^ | No | Unclear or NR | No | No | No | Yes
Wang, 2009^8^ | Unclear or not reported | Unclear or not reported | Unclear or not reported | | Unclear or not reported | Yes

Table B-1 Risk of bias ratings for randomized controlled trials, part 3

Author, Year Trial Name | Intermediate outcomes assessed using valid and reliable measures, implemented consistently across all study participants? | Mortality and morbidity outcomes assessed using valid and reliable measures, implemented consistently across all study participants? | Antibiotic-related adverse events assessed using valid and reliable measures, implemented consistently across all study participants? | Potential outcomes pre-specified by researchers? Are all pre-specified outcomes reported? | Risk of Bias | Comments
Hanes et al., 2000^1^ | Yes | Yes | Unclear or not reported | Yes | Medium
Jaruratanasirikul, 2012^2^ | Not evaluated | Not evaluated | Unclear or not reported | Yes | High | Very small number of patients. High risk of selection, measurement bias, and confounding.
Nicolau, 1999^3^ | NA | NA | Unclear or NR | Yes | Medium
Nicolau, 1999^4^ | NA | NA | Unclear or NR | Yes | Medium
Nicolau, 2001^5^ McNabb, 2001^6^ | Yes | Yes | Yes | Yes | Medium
Sakka, 2007^7^ | Yes | Yes | Unclear or NR | No | High | High risk of selection bias, measurement bias, and confounding. Not blinded. It is unclear how patients were recruited and if this was different for the two different groups. It does not appear that the researchers ruled out any potential impact from a concurrent intervention or unintended exposure (several patients received various other antibiotics before receiving the treatment drug). Also all potential outcomes were not prespecified in the methods.
Wang, 2009^8^ | Yes | Yes | Unclear or not reported | Yes | Medium

Table B-2 Risk of bias ratings for observational studies

Table B-2 Risk of bias ratings for observational studies, part 1

Author, Year Trial Name | Did strategy for recruiting participants into study differ across study groups? | Baseline characteristics similar between groups? If not, did analysis control for differences? | Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results? | Was there a high rate of differential or overall attrition? (i.e., ≥20% for overall attrition or ≥15% for differential attrition) | Did attrition result in a difference in group characteristics between baseline (or randomization) and follow-up? | Is the analysis conducted on an intention-to-treat (ITT) basis? | Are the inclusion/exclusion criteria measured using valid and reliable measures, implemented consistently across all study participants?
Fahimi et al., 2012^9^ | Unclear or not reported | Yes | Unclear or not reported | No | No | Not applicable | Yes
Lorente, 2009^10^ | No | Yes | Unclear or NR | NA | NA | NA | Yes
Scaglione, 2009^11^ | Unclear or NR | No | No | Unclear or NR | Unclear or NR | Unclear or NR | Yes

Table B-2 Risk of bias ratings for observational studies, part 2

Author, Year Trial Name | Intermediate outcomes assessed using valid and reliable measures, implemented consistently across all study participants? | Mortality and morbidity outcomes assessed using valid and reliable measures, implemented consistently across all study participants? | Antibiotic-related adverse events assessed using valid and reliable measures, implemented consistently across all study participants? | Potential outcomes pre-specified by researchers? Are all pre-specified outcomes reported? | Important confounding and modifying variables taken into account in the design and/or analysis? | Risk of Bias | Comments
Fahimi et al., 2012^9^ | Yes | Yes | Not reported | Yes | No | Medium
Lorente, 2009^10^ | Yes | Yes | NA | Yes | Yes | High | High risk of selection bias and confounding. It does not appear that the researchers ruled out any impact from a concurrent intervention or unintended exposure. Study was retrospective, not randomized, not blinded.
Scaglione, 2009^11^ | Yes | Yes | Yes | Yes | No (Not accounted for or not identified) | High | High risk of selection bias, measurement bias, and confounding. Significant differences between groups at baseline, methods unclear, potential confounding not accounted for, outcomes reported do not map to the definitions; combined “leaving against medical advice” with mortality.

## Randomized Controlled Trials

### Criteria

- Was randomization adequate?
- Was allocation concealment adequate?
- Did strategy for recruiting participants into study differ across study groups?
- Were groups similar at baseline?
- Were outcome assessors masked?
- Were care providers masked?
- Were patients masked?
- Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
- Did variation from the study protocol compromise the conclusions of the study?
- Was overall attrition 20% or higher or was differential attrition 15% or higher?
- Did attrition result in a difference in group characteristics between baseline (or randomization) and follow-up?
- Did the study use intention-to-treat analysis?
- Are the inclusion/exclusion criteria measured using valid and reliable measures, implemented consistently across all study participants?
- Were outcome measures equal, valid, and reliable?
- Were potential outcomes pre-specified by researchers and were all pre-specified outcomes reported?

## Observational Studies

### Criteria

- Did the strategy for recruiting participants into the study differ across study groups?
- Were groups similar at baseline?
- Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
- Was overall attrition 20% or higher or was differential attrition 15% or higher?
- Did attrition result in a difference in group characteristics between baseline (or randomization) and follow-up?
- Did the study use intention-to-treat analysis?
- Were the inclusion/ exclusion criteria measured using valid and reliable measures, implemented consistently across all study participants?
- Were outcome measures equal, valid, and reliable?
- Were potential outcomes pre-specified by researchers and were all pre-specified outcomes reported?
- Were important confounding and modifying variables taken into account in the design and/or analysis?

## References for Appendix B

1 Hanes SD, Wood GC, Herring V, et al. Intermittent and continuous ceftazidime infusion for critically ill trauma patients. Am J Surg. Jun. 2000;179(6):436-40. Epub: 2000/09/27. [pmid: 11004326].
2 Jaruratanasirikul S, Wongpoowarak W, Kositpantawong N, et al. Pharmacodynamics of doripenem in critically ill patients with ventilator-associated Gram-negative bacilli pneumonia. Int J Antimicrob Agents. Nov. 2012;40(5):434-9. Epub: 2012/09/11. [pmid: 22959555].
3 Nicolau DP, McNabb J, Lacy MK, et al. Pharmacokinetics and pharmacodynamics of continuous and intermittent ceftazidime during the treatment of nosocomial pneumonia. Clin Drug Invest. 1999;(2):133-9.
4 Nicolau DP, Lacy MK, McNabb J, et al. Pharmacokinetics of continuous and intermittent ceftazidime in intensive care unit patients with nosocomial pneumonia. Infect Dis Clin Pract. 1999;8(1):45-9.
5 Nicolau DP, McNabb J, Lacy MK, et al. Continuous versus intermittent administration of ceftazidime in intensive care unit patients with nosocomial pneumonia. Int J Antimicrob Agents. Jun. 2001;17(6):497-504. Epub: 2001/06/09. [pmid: 11397621].
6 McNabb JJ, Nightingale CH, Quintiliani R, et al. Cost-effectiveness of ceftazidime by continuous infusion versus intermittent infusion for nosocomial pneumonia. Pharmacotherapy. May. 2001;21(5):549-55. Epub: 2001/05/15. [pmid: 11349744].
7 Sakka SG, Glauner AK, Bulitta JB, et al. Population pharmacokinetics and pharmacodynamics of continuous versus short-term infusion of imipenem-cilastatin in critically ill patients in a randomized, controlled trial. Antimicrob Agents Chemother. Sep. 2007;51(9):3304-10. Epub: 2007/07/11. [pmid: 17620371].
8 Wang D. Experience with extended-infusion meropenem in the management of ventilator-associated pneumonia due to multidrugresistant Acinetobacter baumannii. Int J Antimicrob Agents. 2009;33:290-1. [pmid: 19091523].
9 Fahimi F, Ghafari S, Jamaati H, et al. Continuous versus intermittent administration of piperacillin-tazobactam in intensive care unit patients with ventilator-associated pneumonia. Indian J Crit Care Med. Jul. 2012;16(3):141-7. [pmid: 23188954].
10 Lorente L, Jimenez A, Martin MM, et al. Clinical cure of ventilator-associated pneumonia treated with piperacillin/tazobactam administered by continuous or intermittent infusion. Int J Antimicrob Agents. May. 2009;33(5):464-8. Epub: 2009/01/20. [pmid: 19150225].
11 Scaglione F, Esposito S, Leone S, et al. Feedback dose alteration significantly affects probability of pathogen eradication in nosocomial pneumonia. Eur Respir J. Aug. 2009;34(2):394-400. Epub: 2009/02/14. [pmid: 19213786].