# Exact Search Strings

## Medline^®^ Search Update June 7, 2014

Search | Query | Items found
#1 | Search (pneumonia[all fields] OR pneumonia[mesh] OR “pneumonia, bacterial”[mesh] OR “lung inflammation”[all fields] OR “pulmonary inflammation”[all fields] OR “pneumonias”[all fields] OR “pneumonitis”[all fields] OR “pneumonitides”[all fields] OR “HCAP”[all fields] OR “healthcare associated pneumonia”[all fields] OR “VAP”[all fields] OR “ventilator associated pneumonia” OR “HAP”[all fields] OR “hospital-acquired pneumonia”[all fields] OR “Pneumonia, Ventilator-Associated”[mesh]) | 132945
#2 | Search (“nosocomial”[all fields] OR “hospital acquired”[all fields] OR “healthcare associated”[all fields] OR “ventilator associated”[all fields] OR “cross infection”[mesh] OR “cross infection”[all fields] OR “nursing home”[all fields] OR “nursing homes”[all fields] OR “intermediate care facililty”[all fields] OR “intermediate care facilities”[all fields] OR “skilled nursing facility”[all fields] OR “skilled nursing facility”[all fields] OR “nursing home”[MeSH] OR “intermediate care facilities”[MeSH] OR “skilled nursing facilities”[MeSH] OR ((Heteroresistant OR resistant) AND (VISA[all fields] OR “vancomycin intermediate staphylococcus aureus”[all fields])) OR “Staphylococcus aureus”[all fields] OR “Staphylococcus aureus”[mesh] OR Susceptibility[all fields] OR Resistance[all fields] OR “drug resistance”[mesh] OR “drug resistance”[all fields] OR “drug resistance, bacterial”[mesh] OR “Critical care”[mesh] OR “critical care”[all fields] OR “care, critical”[all fields] OR “intensive care”[mesh] OR “Gram-Negative Bacterial Infections”[mesh] OR “Gram-Negative Bacterial Infection”[all fields] OR “Gram-Positive Bacterial Infections”[mesh] OR “Gram-Positive Bacterial Infections”[all fields]) | 1576325
#3 | Search (Sepsis[MeSH] OR Sepsis[tw] OR Pyemia[tw] OR Pyemias[tw] OR Pyohemia[tw] OR Pyohemias[tw] OR Pyaemia[tw] OR Pyaemias[tw] OR Septicemia[tw] OR Septicemias[tw] OR “Blood Poisoning” [tw] OR “Blood Poisonings” [tw] OR Severe Sepsis[tw] OR Bacteremia[MeSH] OR Bacteremia[tw] OR Bacteremias[tw] OR Endotoxemia[MeSH] OR Endotoxemia[tw] OR Endotoxemias[tw] OR “Hemorrhagic Septicemia”[MeSH] OR “Hemorrhagic Septicemia”[tw] OR “Haemorrhagic Septicaemia”[tw] OR “Hemorrhagic Septicaemia”[tw] OR “Haemorrhagic Septicemia”[tw] OR “Hemorrhagic Bacteremia”[tw] OR “Haemorrhagic Bacteremia”[tw] OR “Shock, Septic”[MeSH] OR “Septic Shock”[tw] OR “Toxic Shock”[tw] OR “Toxic Shock Syndrome”[tw] OR “Toxic Shock Syndromes”[tw] OR “Endotoxic Shock”[tw]) | 149630
#4 | Search (#1 AND (#2 OR #3)) | 48199
#5 | Search (pharmacokinetic*[all fields] OR “pharmacokinetics”[mesh] OR “pharmacokinetics”[sh] OR “Area Under Curves”[all fields] OR “Curve, Area Under”[all fields] OR “Curves, Area Under”[all fields] OR “Under Curve, Area”[all fields] OR “Under Curves, Area”[all fields] OR AUC[all fields] OR “Biological Availability”[mesh] OR “biological availability”[all fields] OR “bioavailability”[all fields] OR “Metabolic Clearance Rate”[mesh] OR “metabolic clearance rate”[all fields] OR “Therapeutic Equivalency”[mesh] OR “therapeutic equivalency”[all fields] OR “bioequivalence”[all fields] OR “Tissue Distribution”[mesh] OR “tissue distribution”[all fields] OR “adme”[all fields] OR “admet”[all fields] OR “Absorption/drug effects”[mesh] OR “metabolism/drug effects”[all fields] OR “metabolism”[sh] OR “creatinine clearance”[all fields] OR “metabolic clearance rate”[mesh] OR “volume of distribution”[all fields] OR “apparent volume of distribution”[all fields] OR “rate of infusion”[all fields] OR “dosing rate”[all fields] OR “body fluid compartments”[mesh] OR “onset of action”[all fields] OR “biological half-life”[all fields] OR “Protein binding”[mesh] OR “protein binding”[all fields] OR “Plasma Protein Binding”[all fields] OR “therapeutic index”[all fields] OR “therapeutic ratio”[all fields] OR “Trough level”[all fields] OR “peak level”[all fields] OR “therapeutic drug monitoring”[all fields] OR “drug monitoring”[MeSH]) | 5862674
#6 | Search (pharmacodynamic*[all fields] OR “dose-response relationship, drug”[mesh] OR “drug dose-response relationship”[all fields] OR “dose response relationship, drug”[all fields] OR “antimicrobial pharmacodynamics”[all fields] OR “MIC”[all fields] OR “minimum inhibitory concentration”[all fields] OR “AUC”[all fields] OR “AUIC”[all fields] OR “area under the curve”[all fields] OR “area under the inhibitory curve” OR “microbial sensitivity tests”[mesh] OR “time kill curve”[all fields] OR “time kill”[all fields] OR “time killing curves”[all fields] OR “time killing”[all fields]) | 499130
#7 | Search (Vancomycin[mesh] OR vancomycin[all fields] OR Carbapenems[all fields] OR Thienamycins[all fields] OR Cephalosporins[all fields] OR Cefamandole[all fields] OR Cefazolin[all fields] OR Cefonicid[all fields] OR Cefsulodin[all fields] OR Cephacetrile[all fields] OR Cephalexin[all fields] OR Cephaloridine[all fields] OR Cephamycins[all fields] OR “Clavulanic Acids”[all fields] OR “Clavulanic Acid”[all fields] OR Monobactams[all fields] OR Aztreonam[all fields] OR Moxalactam[all fields] OR Penicillin[all fields] OR penicillins[all fields] OR Amdinocillin[all fields] OR Cyclacillin[all fields] OR Methicillin[all fields] OR Nafcillin[all fields] OR Oxacillin[all fields] OR “Penicillanic Acid”[all fields] OR “Penicillin G”[all fields] OR “Penicillin V”[all fields] OR Sulbactam[all fields] OR Ticarcillin[all fields] OR Aminoglycosides[all fields] OR Anthracyclines[all fields] OR Aclarubicin[all fields] OR Daunorubicin[all fields] OR Plicamycin[all fields] OR “Butirosin Sulfate”[all fields] OR Gentamicins[all fields] OR Sisomicin[all fields] OR “Hygromycin B”[all fields] OR Kanamycin[all fields] OR Amikacin[all fields] OR Dibekacin[all fields] OR Nebramycin[all fields] OR Metrizamide[all fields] OR Neomycin[all fields] OR Framycetin[all fields] OR Paromomycin[all fields] OR Ribostamycin[all fields] OR Puromycin[all fields] OR “Puromycin Aminonucleoside”[all fields] OR Spectinomycin[all fields] OR Streptomycin[all fields] OR “Dihydrostreptomycin Sulfate”[all fields] OR Streptothricins[all fields] OR Streptozocin[all fields] OR Fluoroquinolones[all fields] OR Ciprofloxacin[all fields] OR Fleroxacin[all fields] OR Enoxacin[all fields] OR Norfloxacin[all fields] OR Ofloxacin[all fields] OR Pefloxacin[all fields] OR Ampicillin[MeSH] OR ampicillin[all fields] OR Piperacillin[MeSH] OR piperacillin[all fields] OR Tazobactam[Supplementary Concept] OR tazobactam[all fields] OR Ceftriaxone[MeSH] OR Ceftriaxone[all fields] OR Cefotaxime[MeSH] OR cefotaxime[all fields] OR Ceftazidime[MeSH] OR Ceftazidime[all fields] OR Cefepime[supplementary concept] OR cefepime[all fields] OR Ceftaroline[all fields] OR “T 91825”[supplementary concept] OR Doripenem[supplementary concept] OR doripenem[all fields] OR Ertapenem[supplementary concept] OR ertapenem[all fields] OR Imipenem[MeSH] OR imipenem[all fields] OR Meropenem[supplementary concept] OR meropenem[all fields] OR ofloxacine[MeSH] OR Levofloxacin[all fields] OR Moxifloxacin[supplementary concept] OR moxifloxacin[all fields] OR Tobramycin[MeSH] OR tobramycin[all fields] OR Linezolid[supplementary concept] OR linezolid[all fields] OR Colistin[MeSH] or colistin[all fields] OR colistimethate[supplementary concept] OR “colistimethate sodium”[all fields] OR rifamycins[MeSH] OR rifampin[MeSH] OR rifampin[all fields] OR rifampicin[all fields] OR tetracyclines[MeSH] OR doxycycline[MeSH] OR doxycycline[all fields] OR minocycline[MeSH] OR minocycline[all fields] OR tigecycline[supplementary concept] OR tigecycline[all fields]) | 386774
#8 | Search (“anti-bacterial agent”[all fields] OR “anti-bacterial agents”[all fields] OR “antibacterial agent”[all fields] OR “antibacterial agents”[all fields] OR antibiotic*[all fields] OR “Anti-Bacterial Agents”[mesh]) | 655101
#9 | Search (“Editorial”[publication type] OR “Letter”[publication type] OR “Addresses”[publication type] OR “Autobiography”[publication type] OR “Bibliography”[publication type] OR “Biography”[publication type] OR “comment”[publication type] OR “Congresses”[publication type] OR “Consensus Development Conference, NIH”[publication type] OR “Dictionary”[publication type] OR “Directory”[publication type] OR “Festschrift”[publication type] OR “Interactive Tutorial”[publication type] OR “Interview”[publication type] OR “Lectures”[publication type] OR “Legal Cases”[publication type] OR “Legislation”[publication type] OR “Patient Education Handout”[publication type] OR “Periodical Index”[publication type] OR “Portraits”[publication type] OR “Scientific Integrity Review”[publication type] OR “Video-Audio Media”[publication type] OR “Webcasts”[publication type]) | 1623787
#10 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields]) | 128163
#11 | Search (#4 AND (#5 OR #6) AND (#7 OR #8))) | 4540
#12 | Search (#11 NOT (#9 OR #10)) | 4340
#13 | Search (#11 NOT (#9 OR #10)) Filters: Humans | 3558
#14 | Search (#11 NOT (#9 OR #10)) Filters: Other Animals | 921
#15 | Search (#14 NOT #13) | 586
#16 | Search (#12 NOT #15) | 3754
#17 | Search (#12 NOT #15) Filters: English | 2864
#18 | Search (#12 NOT #15) Filters: English; Adult: 19+ years | 1298
#19 | Search (#12 NOT #15) Filters: Publication date from 2012/10/30; English; Adult: 19+ years | 94
#20 | Search ((#11 AND (“retraction”[All Fields] OR “Retracted Publication”[pt]) | 1

## Cochrane Search Update 6/8/14

63 results – 62 imported

ID | Search | Hits
#1 | [mh Pneumonia] | 2562
#2 | [mh “Pneumonia, Bacterial”] | 682
#3 | [mh “Pneumonia, Ventilator-Associated”] | 200
#4 | ‘pneumonia’ or ‘pneumonia bacterial’ or ‘lung inflammation’ or ‘pulmonary inflammation’ or ‘pneumonias’ or ‘pneumonitis’ or ‘pneumonitides’ | 8925
#5 | #1 or #2 or #3 or #4 | 8965
#6 | [mh “Nursing Homes”] | 1018
#7 | [mh “Skilled Nursing Facilities”] | 53
#8 | [mh “Intermediate Care Facilities”] | 15
#9 | [mh “Drug Resistance, Bacterial”] | 800
#10 | [mh “Critical Care”] | 1844
#11 | [mh “[Intensive Care”] | 1151
#12 | [mh “Gram-Positive Bacterial Infections”] | 4904
#13 | [mh “Gram-Negative Bacterial Infections”] | 5762
#14 | ‘hcap’ or ‘healthcare associated pneumonia’ or ‘vap’ or ‘ventilator associated pneumonia’ or ‘hap’ or ‘hospital-acquired pneumonia’ or ‘pneumonia ventilator-associated’ or ‘nosocomial’ or ‘hospital acquired’ or ‘healthcare associated’ or ‘ventilator associated’ or ‘cross infection’ or ‘nursing home’ or ‘nursing homes’ or ‘intermediate care facililty’ or ‘intermediate care facilities’ or ‘skilled nursing facility’ or ‘skilled nursing facilities’ or heteroresistant or resistant or visa or ‘vancomycin intermediate staphylococcus aureus’ or ‘staphylococcus aureus’ or susceptibility or resistance or ‘drug resistance’ or ‘drug resistance bacterial’ or ‘critical care’ or ‘care critical’ or ‘intensive care’ or ‘gram-negative bacterial infections’ or ‘gram-negative bacterial infection’ or ‘gram-positive bacterial infections’ | 84802
#15 | #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 | 91608
#16 | [mh Sepsis] | 3046
#17 | [mh Bacteremia] | 748
#18 | [mh Endotoxemia] | 133
#19 | [mh “Hemorrhagic Septicemia”] | 0
#20 | [mh “Shock, Septic”] | 429
#21 | Sepsis or Pyemia* or Pyohemia* or Pyaemia* or Septicemia* or ‘Blood Poisoning’ or ‘Blood Poisonings’ or Bacteremia* or Endotoxemia* or ‘Hemorrhagic Septicemia’ or ‘Haemorrhagic Septicaemia’ or ‘Hemorrhagic Septicaemia’ or ‘Haemorrhagic Septicemia’ or ‘Hemorrhagic Bacteremia’ or ‘Haemorrhagic Bacteremia’ or ‘Septic Shock’ or ‘Toxic Shock’ or ‘Endotoxic Shock’ or ‘Severe Sepsis’ | 7733
#22 | #16 or #17 or #18 or #19 or #20 or #21 | 8312
#23 | #5 and (#15 or #22) | 4887
#24 | [mh Pharmacokinetics] | 10527
#25 | [mh “Drug Monitoring”] | 1095
#26 | pharmacokinetic* or ‘pharmacokinetics’ or ‘pharmacokinetic’ or ‘area under curves’ or ‘area under curve’ or ‘curve, area under’ or ‘curves, area under’ or ‘under curve, area’ or ‘under curves, area’ or ‘auc’ or ‘biological availability’ or ‘bioavailability’ or ‘therapeutic equivalency’ or ‘bioequivalence’ or ‘tissue distribution’ or ‘adme’ or ‘admet’ or ‘absorption’ or ‘metabolism’ or ‘creatinine clearance’ or ‘metabolic clearance rate’ or ‘volume of distribution’ or ‘apparent volume of distribution’ or ‘rate of infusion’ or ‘dosing rate’ or ‘body fluid compartments’ or ‘onset of action’ or ‘biological half-life’ or ‘protein binding’ or ‘plasma protein binding’ or ‘therapeutic index’ or ‘therapeutic ratio’ or ‘trough level’ or ‘peak level’ | 192588
#27 | #24 or #25 or #26 | 192979
#28 | [mh “Dose-Response Relationship, Drug”] | 24746
#29 | pharmacodynamic* or ‘dose-response relationship, drug’ or ‘drug dose-response relationship’ or ‘antimicrobial pharmacodynamics’ or ‘mic’ or ‘minimum inhibitory concentration’ or ‘auc’ or ‘auic’ or ‘area under the curve’ or ‘area under the inhibitory curve’ or ‘microbial sensitivity tests’ or ‘microbial sensitivity test’ or ‘time kill curve’ or ‘time kill’ or ‘time killing curves’ or ‘time killing’ | 48751
#30 | #28 or #29 | 48751
#31 | ‘vancomycin’ or ‘carbapenems’ or ‘thienamycins’ or ‘cephalosporins’ or ‘cefamandole’ or ‘cefazolin’ or ‘cefonicid’ or ‘cefsulodin’ or ‘cephacetrile’ or ‘cephalexin’ or ‘cephaloridine’ or ‘cephamycins’ or ‘clavulanic acids’ or ‘clavulanic acid’ or ‘monobactams’ or ‘aztreonam’ or ‘moxalactam’ or ‘penicillin’ or ‘penicillins’ or ‘amdinocillin’ or ‘cyclacillin’ or ‘methicillin’ or ‘nafcillin’ or ‘oxacillin’ or ‘penicillanic acid’ or ‘penicillin g’ or ‘penicillin v’ or ‘sulbactam’ or ‘ticarcillin’ or ‘aminoglycosides’ or ‘anthracyclines’ or ‘aclarubicin’ or ‘daunorubicin’ or ‘plicamycin’ or ‘butirosin sulfate’ or ‘gentamicins’ or ‘sisomicin’ or ‘hygromycin b’ or ‘kanamycin’ or ‘amikacin’ or ‘dibekacin’ or ‘nebramycin’ or ‘metrizamide’ or ‘neomycin’ or ‘framycetin’ or ‘paromomycin’ or ‘ribostamycin’ or ‘puromycin’ or ‘puromycin aminonucleoside’ or ‘spectinomycin’ or ‘streptomycin’ or ‘dihydrostreptomycin sulfate’ or ‘streptothricins’ or ‘streptozocin’ or ‘fluoroquinolones’ or ‘ciprofloxacin’ or ‘fleroxacin’ or ‘enoxacin’ or ‘norfloxacin’ or ‘ofloxacin’ or ‘pefloxacin’ or ‘ampicillin’ or ‘piperacillin’ or ‘tazobactam’ or ‘ceftriaxone’ or ‘cefotaxime’ or ‘ceftazidime’ or ‘cefepime’ or ‘ceftaroline’ or ‘t 91825’ or ‘doripenem’ or ‘ertapenem’ or ‘imipenem’ or ‘meropenem’ or ofloxacine or ‘levofloxacin’ or ‘moxifloxacin’ or ‘tobramycin’ or ‘linezolid’ or ‘colistin’ or ‘colistimethate’ or ‘colistimethate sodium’ or ‘rifamycins’ or ‘rifampin’ or ‘rifampicin’ or ‘tetracyclines’ or ‘doxycycline’ or ‘minocycline’ or ‘tigecycline’ | 21899
#32 | [mh “Anti-Bacterial Agents”] | 9205
#33 | ‘anti-bacterial agent’ or ‘anti-bacterial agents’ or ‘antibacterial agent’ or ‘antibacterial agents’ or antibiotic* | 22025
#34 | #31 or #32 or #33 | 34313
#35 | #23 and (#27 or #30) and #34 | 1205
#36 | #35 Publication Year from 2012 to 2014, in Trials | 63

## IPA Search Update 6/8/14 (15 retrieved – all imported)

# | Query | Limiters/Expanders | Last Run Via | Results
S36 | S35 | Limiters - Published Date: 20121001-20141231 Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 15
S35 | S23 and (S27 OR S30) and S34 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 289
S34 | S31 OR S32 OR S33 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 42,296
S33 | TX “anti-bacterial agent” OR “anti-bacterial agents” OR “antibacterial agent” OR “antibacterial agents” OR antibiotic* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 27,509
S32 | SU AntiBacterial Agents | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 1,026
S31 | TX “vancomycin” OR “carbapenems” OR “thienamycins” OR “cephalosporins” OR “cefamandole” OR “cefazolin” OR “cefonicid” OR “cefsulodin” OR “cephacetrile” OR “cephalexin” OR “cephaloridine” OR “cephamycins” OR “clavulanic acids” OR “clavulanic acid” OR “monobactams” OR “aztreonam” OR “moxalactam” OR “penicillin” OR “penicillins” OR “amdinocillin” OR “cyclacillin” OR “methicillin” OR “nafcillin” OR “oxacillin” OR “penicillanic acid” OR “penicillin g” OR “penicillin v” OR “sulbactam” OR “ticarcillin” OR “aminoglycosides” OR “anthracyclines” OR “aclarubicin” OR “daunorubicin” OR “plicamycin” OR “butirosin sulfate” OR “gentamicins” OR “sisomicin” OR “hygromycin b” OR “kanamycin” OR “amikacin” OR “dibekacin” OR “nebramycin” OR “metrizamide” OR “neomycin” OR “framycetin” OR “paromomycin” OR “ribostamycin” OR “puromycin” OR “puromycin aminonucleoside” OR “spectinomycin” OR “streptomycin” OR “dihydrostreptomycin sulfate” OR “streptothricins” OR “streptozocin” OR “fluoroquinolones” OR “ciprofloxacin” OR “fleroxacin” OR “enoxacin” OR “norfloxacin” OR “ofloxacin” OR “pefloxacin” OR “ampicillin” OR “piperacillin” OR “tazobactam” OR “ceftriaxone” OR “cefotaxime” OR “ceftazidime” OR “cefepime” OR “ceftaroline” OR “t 91825” OR “doripenem” OR “ertapenem” OR “imipenem” OR “meropenem” OR ofloxacine OR “levofloxacin” OR “moxifloxacin” OR “tobramycin” OR “linezolid” OR “colistin” OR “colistimethate” OR “colistimethate sodium” OR “rifamycins” OR “rifampin” OR “rifampicin” OR “tetracyclines” OR “doxycycline” OR “minocycline” OR “tigecycline” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 26,994
S30 | S28 OR S29 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 22,451
S29 | pharmacodynamic* OR “dose-response relationship, drug” OR “drug dose-response relationship” OR “antimicrobial pharmacodynamics” OR “mic” OR “minimum inhibitory concentration” OR “auc” OR “auic” OR “area under the curve” OR “area under the inhibitory curve” OR “microbial sensitivity tests” OR “microbial sensitivity test” OR “time kill curve” OR “time kill” OR “time killing curves” OR “time killing” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 22,442
S28 | SU Dose-Response Relationship | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 9
S27 | S24 OR S25 OR S26 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 87,860
S26 | TX pharmacokinetic* OR “pharmacokinetics” OR “pharmacokinetic” OR “area under curves” OR “area under curve” OR “curve, area under” OR “curves, area under” OR “under curve, area” OR “under curves, area” OR “auc” OR “biological availability” OR “bioavailability” OR “therapeutic equivalency” OR “bioequivalence” OR “tissue distribution” OR “adme” OR “admet” OR “absorption” OR “metabolism” OR “creatinine clearance” OR “metabolic clearance rate” OR “volume of distribution” OR “apparent volume of distribution” OR “rate of infusion” OR “dosing rate” OR “body fluid compartments” OR “onset of action” OR “biological half-life” OR “protein binding” OR “plasma protein binding” OR “therapeutic index” OR “therapeutic ratio” OR “trough level” OR “peak level” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 87,061
S25 | SU Drug Monitoring | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 1,017
S24 | SU Pharmacokinetics | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 46,035
S23 | S5 AND (S15 OR S22) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 1,439
S22 | S16 OR S17 OR S18 OR S19 OR S20 OR S21 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 3,300
S21 | TX Sepsis OR Pyemia* OR Pyohemia* OR Pyaemia* OR Septicemia* OR “Blood Poisoning” OR “Blood Poisonings” OR Bacteremia* OR Endotoxemia* OR “Hemorrhagic Septicemia” OR “Haemorrhagic Septicaemia” OR “Hemorrhagic Septicaemia” OR “Haemorrhagic Septicemia” OR “Hemorrhagic Bacteremia” OR “Haemorrhagic Bacteremia” OR “Septic Shock” OR “Toxic Shock” OR “Endotoxic Shock” OR “Severe Sepsis” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 3,293
S20 | SU Septic Shock | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 98
S19 | SU Hemorrhagic Shock | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 7
S18 | SU Endotoxemia | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 34
S17 | SU Bacteremia | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 329
S16 | SU Sepsis | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 834
S15 | S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 29,558
S14 | TX “hcap” OR “healthcare associated pneumonia” OR “vap” OR “ventilator associated pneumonia” OR “hap” OR “hospital-acquired pneumonia” OR “pneumonia ventilator-associated” OR “nosocomial” OR “hospital acquired” OR “healthcare associated” OR “ventilator associated” OR “cross infection” OR “nursing home” OR “nursing homes” OR “intermediate care facililty” OR “intermediate care facilities” OR “skilled nursing facility” OR “skilled nursing facilities” OR heteroresistant OR resistant OR visa OR “vancomycin intermediate staphylococcus aureus” OR “staphylococcus aureus” OR susceptibility OR resistance OR “drug resistance” OR “drug resistance bacterial” OR “critical care” OR “care critical” OR “intensive care” OR “gram-negative bacterial infections” OR “gram-negative bacterial infection” OR “gram-positive bacterial infections” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 29,510
S13 | SU Gram-Negative Bacterial Infections | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 157
S12 | SU Gram-Positive Bacterial Infections | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 215
S11 | SU Intensive Care Unit | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 1,824
S10 | SU Critical Care | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 2,062
S9 | SU Drug Resistance | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 241
S8 | SU Intermediate Care Facilities | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 17
S7 | SU Skilled Nursing Facilities | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 125
S6 | SU Nursing Homes | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 925
S5 | S1 OR S2 OR S3 OR S4 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 4,000
S4 | TX “pneumonia” OR “pneumonia bacterial” OR “lung inflammation” OR “pulmonary inflammation” OR “pneumonias” OR “pneumonitis” OR “pneumonitides” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 4,000
S3 | SU Ventilator-Associated Pneumonia | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 2
S2 | SU Bacterial Pneumonia | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 18
S1 | SU Pneumonia | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - International Pharmaceutical Abstracts | 2,274

## Medline^®^ Search Update 10/30/13

Search | Most Recent Queries | Result
#1 | Search ((pneumonia[all fields] OR pneumonia[mesh] OR “pneumonia, bacterial”[mesh] OR “lung inflammation”[all fields] OR “pulmonary inflammation”[all fields] OR “pneumonias”[all fields] OR “pneumonitis”[all fields] OR “pneumonitides”[all fields] OR “HCAP”[all fields] OR “healthcare associated pneumonia”[all fields] OR “VAP”[all fields] OR “ventilator associated pneumonia” OR “HAP”[all fields] OR “hospital-acquired pneumonia”[all fields] OR “Pneumonia, Ventilator-Associated”[mesh])) | 128,649
#2 | Search (“nosocomial”[all fields] OR “hospital acquired”[all fields] OR “healthcare associated”[all fields] OR “ventilator associated”[all fields] OR “cross infection”[mesh] OR “cross infection”[all fields] OR “nursing home”[all fields] OR “nursing homes”[all fields] OR “intermediate care facility”[all fields] OR “intermediate care facilities”[all fields] OR “skilled nursing facility”[all fields] OR “skilled nursing facility”[all fields] OR “nursing home”[MeSH] OR “intermediate care facilities”[MeSH] OR “skilled nursing facilities”[MeSH] OR ((Heteroresistant OR resistant) AND (VISA[all fields] OR “vancomycin intermediate staphylococcus aureus”[all fields])) OR “Staphylococcus aureus”[all fields] OR “Staphylococcus aureus”[mesh] OR Susceptibility[all fields] OR Resistance[all fields] OR “drug resistance”[mesh] OR “drug resistance”[all fields] OR “drug resistance, bacterial”[mesh] OR “Critical care”[mesh] OR “critical care”[all fields] OR “care, critical”[all fields] OR “intensive care”[mesh] OR “Gram-Negative Bacterial Infections”[mesh] OR “Gram-Negative Bacterial Infection”[all fields] OR “Gram-Positive Bacterial Infections”[mesh] OR “Gram-Positive Bacterial Infections”[all fields]) | 1,523,261
#3 | Search (Sepsis[MeSH] OR Sepsis[tw] OR Pyemia[tw] OR Pyemias[tw] OR Pyohemia[tw] OR Pyohemias[tw] OR Pyaemia[tw] OR Pyaemias[tw] OR Septicemia[tw] OR Septicemias[tw] OR “Blood Poisoning” [tw] OR “Blood Poisonings” [tw] OR Severe Sepsis[tw] OR Bacteremia[MeSH] OR Bacteremia[tw] OR Bacteremias[tw] OR Endotoxemia[MeSH] OR Endotoxemia[tw] OR Endotoxemias[tw] OR “Hemorrhagic Septicemia”[MeSH] OR “Hemorrhagic Septicemia”[tw] OR “Haemorrhagic Septicaemia”[tw] OR “Hemorrhagic Septicaemia”[tw] OR “Haemorrhagic Septicemia”[tw] OR “Hemorrhagic Bacteremia”[tw] OR “Haemorrhagic Bacteremia”[tw] OR “Shock, Septic”[MeSH] OR “Septic Shock”[tw] OR “Toxic Shock”[tw] OR “Toxic Shock Syndrome”[tw] OR “Toxic Shock Syndromes”[tw] OR “Endotoxic Shock”[tw]) | 144,734
#4 | Search (#1 AND (#2 OR #3)) | 46,515
#5 | Search ((pharmacokinetic*[all fields] OR “pharmacokinetics”[mesh] OR “pharmacokinetics”[sh] OR “Area Under Curves”[all fields] OR “Curve, Area Under”[all fields] OR “Curves, Area Under”[all fields] OR “Under Curve, Area”[all fields] OR “Under Curves, Area”[all fields] OR AUC[all fields] OR “Biological Availability”[mesh] OR “biological availability”[all fields] OR “bioavailability”[all fields] OR “Metabolic Clearance Rate”[mesh] OR “metabolic clearance rate”[all fields] OR “Therapeutic Equivalency”[mesh] OR “therapeutic equivalency”[all fields] OR “bioequivalence”[all fields] OR “Tissue Distribution”[mesh] OR “tissue distribution”[all fields] OR “adme”[all fields] OR “admet”[all fields] OR “Absorption/drug effects”[mesh] OR “metabolism/drug effects”[all fields] OR “metabolism”[sh] OR “creatinine clearance”[all fields] OR “metabolic clearance rate”[mesh] OR “volume of distribution”[all fields] OR “apparent volume of distribution”[all fields] OR “rate of infusion”[all fields] OR “dosing rate”[all fields] OR “body fluid compartments”[mesh] OR “onset of action”[all fields] OR “biological half-life”[all fields] OR “Protein binding”[mesh] OR “protein binding”[all fields] OR “Plasma Protein Binding”[all fields] OR “therapeutic index”[all fields] OR “therapeutic ratio”[all fields] OR “Trough level”[all fields] OR “peak level”[all fields] OR “therapeutic drug monitoring”[all fields] OR “drug monitoring”[MeSH])) | 5,713,972
#6 | Search ((pharmacodynamic*[all fields] OR “dose-response relationship, drug”[mesh] OR “drug dose-response relationship”[all fields] OR “dose response relationship, drug”[all fields] OR “antimicrobial pharmacodynamics”[all fields] OR “MIC”[all fields] OR “minimum inhibitory concentration”[all fields] OR “AUC”[all fields] OR “AUIC”[all fields] OR “area under the curve”[all fields] OR “area under the inhibitory curve” OR “microbial sensitivity tests”[mesh] OR “time kill curve”[all fields] OR “time kill”[all fields] OR “time killing curves”[all fields] OR “time killing”[all fields])) | 485,405
#7 | Search ((Vancomycin[mesh] OR vancomycin[all fields] OR Carbapenems[all fields] OR Thienamycins[all fields] OR Cephalosporins[all fields] OR Cefamandole[all fields] OR Cefazolin[all fields] OR Cefonicid[all fields] OR Cefsulodin[all fields] OR Cephacetrile[all fields] OR Cephalexin[all fields] OR Cephaloridine[all fields] OR Cephamycins[all fields] OR “Clavulanic Acids”[all fields] OR “Clavulanic Acid”[all fields] OR Monobactams[all fields] OR Aztreonam[all fields] OR Moxalactam[all fields] OR Penicillin[all fields] OR penicillins[all fields] OR Amdinocillin[all fields] OR Cyclacillin[all fields] OR Methicillin[all fields] OR Nafcillin[all fields] OR Oxacillin[all fields] OR “Penicillanic Acid”[all fields] OR “Penicillin G”[all fields] OR “Penicillin V”[all fields] OR Sulbactam[all fields] OR Ticarcillin[all fields] OR Aminoglycosides[all fields] OR Anthracyclines[all fields] OR Aclarubicin[all fields] OR Daunorubicin[all fields] OR Plicamycin[all fields] OR “Butirosin Sulfate”[all fields] OR Gentamicins[all fields] OR Sisomicin[all fields] OR “Hygromycin B”[all fields] OR Kanamycin[all fields] OR Amikacin[all fields] OR Dibekacin[all fields] OR Nebramycin[all fields] OR Metrizamide[all fields] OR Neomycin[all fields] OR Framycetin[all fields] OR Paromomycin[all fields] OR Ribostamycin[all fields] OR Puromycin[all fields] OR “Puromycin Aminonucleoside”[all fields] OR Spectinomycin[all fields] OR Streptomycin[all fields] OR “Dihydrostreptomycin Sulfate”[all fields] OR Streptothricins[all fields] OR Streptozocin[all fields] OR Fluoroquinolones[all fields] OR Ciprofloxacin[all fields] OR Fleroxacin[all fields] OR Enoxacin[all fields] OR Norfloxacin[all fields] OR Ofloxacin[all fields] OR Pefloxacin[all fields] OR Ampicillin[MeSH] OR ampicillin[all fields] OR Piperacillin[MeSH] OR piperacillin[all fields] OR Tazobactam[Supplementary Concept] OR tazobactam[all fields] OR Ceftriaxone[MeSH] OR Ceftriaxone[all fields] OR Cefotaxime[MeSH] OR cefotaxime[all fields] OR Ceftazidime[MeSH] OR Ceftazidime[all fields] OR Cefepime[supplementary concept] OR cefepime[all fields] OR Ceftaroline[all fields] OR “T 91825”[supplementary concept] OR Doripenem[supplementary concept] OR doripenem[all fields] OR Ertapenem[supplementary concept] OR ertapenem[all fields] OR Imipenem[MeSH] OR imipenem[all fields] OR Meropenem[supplementary concept] OR meropenem[all fields] OR ofloxacine[MeSH] OR Levofloxacin[all fields] OR Moxifloxacin[supplementary concept] OR moxifloxacin[all fields] OR Tobramycin[MeSH] OR tobramycin[all fields] OR Linezolid[supplementary concept] OR linezolid[all fields] OR Colistin[MeSH] or colistin[all fields] OR colistimethate[supplementary concept] OR “colistimethate sodium”[all fields] OR rifamycins[MeSH] OR rifampin[MeSH] OR rifampin[all fields] OR rifampicin[all fields] OR tetracyclines[MeSH] OR doxycycline[MeSH] OR doxycycline[all fields] OR minocycline[MeSH] OR minocycline[all fields] OR tigecycline[supplementary concept] OR tigecycline[all fields])) | 377,175
#8 | Search ((“anti-bacterial agent”[all fields] OR “anti-bacterial agents”[all fields] OR “antibacterial agent”[all fields] OR “antibacterial agents”[all fields] OR antibiotic*[all fields] OR “Anti-Bacterial Agents”[mesh])) | 634,169
#9 | Search ((“Editorial”[publication type] OR “Letter”[publication type] OR “Addresses”[publication type] OR “Autobiography”[publication type] OR “Bibliography”[publication type] OR “Biography”[publication type] OR “comment”[publication type] OR “Congresses”[publication type] OR “Consensus Development Conference, NIH”[publication type] OR “Dictionary”[publication type] OR “Directory”[publication type] OR “Festschrift”[publication type] OR “Interactive Tutorial”[publication type] OR “Interview”[publication type] OR “Lectures”[publication type] OR “Legal Cases”[publication type] OR “Legislation”[publication type] OR “Patient Education Handout”[publication type] OR “Periodical Index”[publication type] OR “Portraits”[publication type] OR “Scientific Integrity Review”[publication type] OR “Video-Audio Media”[publication type] OR “Webcasts”[publication type])) | 1,565,573
#10 | Search (((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields])) | 115,455
#11 | Search (#4 AND (#5 OR #6) AND (#7 OR #8)) | 4,349
#12 | Search (#11 NOT (#9 OR #10)) | 4,157
#13 | Search (#11 NOT (#9 OR #10)) Filters: Humans | 3,437
#14 | Search (#11 NOT (#9 OR #10)) Filters: Other Animals | 878
#15 | Search (#14 NOT #13) | 562
#16 | Search (#12 NOT #15) | 3,595
#17 | Search (#12 NOT #15) Filters: English | 2,722
#18 | Search (#12 NOT #15) Filters: English; Adult: 19+ years | 1,247
#19 | Search (#12 NOT #15) Filters: Publication date from 2012/05/15 to 2013/12/31; English; Adult: 19+ years | 75
#20 | Search (#11 AND (“retraction”[All Fields] OR “Retracted Publication”[pt] )) | 1

## Cochrane Search Update 10/30/13

ID | Search | Hits
#1 | MeSH descriptor: [Pneumonia] explode all trees | 2,450
#2 | MeSH descriptor: [Pneumonia, Bacterial] explode all trees | 654
#3 | MeSH descriptor: [Pneumonia, Ventilator-Associated] explode all trees | 170
#4 | ‘pneumonia’ or ‘pneumonia bacterial’ or ‘lung inflammation’ or ‘pulmonary inflammation’ or ‘pneumonias’ or ‘pneumonitis’ or ‘pneumonitides’ | 7,677
#5 | #1 or #2 or #3 or #4 | 7,717
#6 | MeSH descriptor: [Nursing Homes] explode all trees | 915
#7 | MeSH descriptor: [Skilled Nursing Facilities] explode all trees | 52
#8 | MeSH descriptor: [Intermediate Care Facilities] explode all trees | 14
#9 | MeSH descriptor: [Drug Resistance, Bacterial] explode all trees | 749
#10 | MeSH descriptor: [Critical Care] explode all trees | 1,693
#11 | MeSH descriptor: [Intensive Care] explode all trees | 1,047
#12 | MeSH descriptor: [Gram-Positive Bacterial Infections] explode all trees | 4,608
#13 | MeSH descriptor: [Gram-Negative Bacterial Infections] explode all trees | 5,532
#14 | ‘hcap’ or ‘healthcare associated pneumonia’ or ‘vap’ or ‘ventilator associated pneumonia’ or ‘hap’ or ‘hospital-acquired pneumonia’ or ‘pneumonia ventilator-associated’ or ‘nosocomial’ or ‘hospital acquired’ or ‘healthcare associated’ or ‘ventilator associated’ or ‘cross infection’ or ‘nursing home’ or ‘nursing homes’ or ‘intermediate care facility’ or ‘intermediate care facilities’ or ‘skilled nursing facility’ or ‘skilled nursing facilities’ or heteroresistant or resistant or visa or ‘vancomycin intermediate staphylococcus aureus’ or ‘staphylococcus aureus’ or susceptibility or resistance or ‘drug resistance’ or ‘drug resistance bacterial’ or ‘critical care’ or ‘care critical’ or ‘intensive care’ or ‘gram-negative bacterial infections’ or ‘gram-negative bacterial infection’ or ‘gram-positive bacterial infections’ | 74,453
#15 | #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 | 80,926
#16 | MeSH descriptor: [Sepsis] explode all trees | 2,832
#17 | MeSH descriptor: [Bacteremia] explode all trees | 700
#18 | MeSH descriptor: [Endotoxemia] explode all trees | 125
#19 | MeSH descriptor: [Hemorrhagic Septicemia] explode all trees | 0
#20 | MeSH descriptor: [Shock, Septic] explode all trees | 389
#21 | Sepsis or Pyemia* or Pyohemia* or Pyaemia* or Septicemia* or ‘Blood Poisoning’ or ‘Blood Poisonings’ or Bacteremia* or Endotoxemia* or ‘Hemorrhagic Septicemia’ or ‘Haemorrhagic Septicaemia’ or ‘Hemorrhagic Septicaemia’ or ‘Haemorrhagic Septicemia’ or ‘Hemorrhagic Bacteremia’ or ‘Haemorrhagic Bacteremia’ or ‘Septic Shock’ or ‘Toxic Shock’ or ‘Endotoxic Shock’ or ‘Severe Sepsis’ | 6,835
#22 | #16 or #17 or #18 or #19 or #20 or #21 | 7,382
#23 | #5 and (#15 or #22) | 4,263
#24 | MeSH descriptor: [Pharmacokinetics] explode all trees | 9,833
#25 | MeSH descriptor: [Drug Monitoring] explode all trees | 958
#26 | pharmacokinetic* or ‘pharmacokinetics’ or ‘pharmacokinetic’ or ‘area under curves’ or ‘area under curve’ or ‘curve, area under’ or ‘curves, area under’ or ‘under curve, area’ or ‘under curves, area’ or ‘auc’ or ‘biological availability’ or ‘bioavailability’ or ‘therapeutic equivalency’ or ‘bioequivalence’ or ‘tissue distribution’ or ‘adme’ or ‘admet’ or ‘absorption’ or ‘metabolism’ or ‘creatinine clearance’ or ‘metabolic clearance rate’ or ‘volume of distribution’ or ‘apparent volume of distribution’ or ‘rate of infusion’ or ‘dosing rate’ or ‘body fluid compartments’ or ‘onset of action’ or ‘biological half-life’ or ‘protein binding’ or ‘plasma protein binding’ or ‘therapeutic index’ or ‘therapeutic ratio’ or ‘trough level’ or ‘peak level’ | 173,487
#27 | #24 or #25 or #26 | 173,838
#28 | MeSH descriptor: [Dose-Response Relationship, Drug] explode all trees | 23,367
#29 | pharmacodynamic* or ‘dose-response relationship, drug’ or ‘drug dose-response relationship’ or ‘antimicrobial pharmacodynamics’ or ‘mic’ or ‘minimum inhibitory concentration’ or ‘auc’ or ‘auic’ or ‘area under the curve’ or ‘area under the inhibitory curve’ or ‘microbial sensitivity tests’ or ‘microbial sensitivity test’ or ‘time kill curve’ or ‘time kill’ or ‘time killing curves’ or ‘time killing’ | 44,156
#30 | #28 or #29 | 44,156
#31 | ‘vancomycin’ or ‘carbapenems’ or ‘thienamycins’ or ‘cephalosporins’ or ‘cefamandole’ or ‘cefazolin’ or ‘cefonicid’ or ‘cefsulodin’ or ‘cephacetrile’ or ‘cephalexin’ or ‘cephaloridine’ or ‘cephamycins’ or ‘clavulanic acids’ or ‘clavulanic acid’ or ‘monobactams’ or ‘aztreonam’ or ‘moxalactam’ or ‘penicillin’ or ‘penicillins’ or ‘amdinocillin’ or ‘cyclacillin’ or ‘methicillin’ or ‘nafcillin’ or ‘oxacillin’ or ‘penicillanic acid’ or ‘penicillin g’ or ‘penicillin v’ or ‘sulbactam’ or ‘ticarcillin’ or ‘aminoglycosides’ or ‘anthracyclines’ or ‘aclarubicin’ or ‘daunorubicin’ or ‘plicamycin’ or ‘butirosin sulfate’ or ‘gentamicins’ or ‘sisomicin’ or ‘hygromycin b’ or ‘kanamycin’ or ‘amikacin’ or ‘dibekacin’ or ‘nebramycin’ or ‘metrizamide’ or ‘neomycin’ or ‘framycetin’ or ‘paromomycin’ or ‘ribostamycin’ or ‘puromycin’ or ‘puromycin aminonucleoside’ or ‘spectinomycin’ or ‘streptomycin’ or ‘dihydrostreptomycin sulfate’ or ‘streptothricins’ or ‘streptozocin’ or ‘fluoroquinolones’ or ‘ciprofloxacin’ or ‘fleroxacin’ or ‘enoxacin’ or ‘norfloxacin’ or ‘ofloxacin’ or ‘pefloxacin’ or ‘ampicillin’ or ‘piperacillin’ or ‘tazobactam’ or ‘ceftriaxone’ or ‘cefotaxime’ or ‘ceftazidime’ or ‘cefepime’ or ‘ceftaroline’ or ‘t 91825’ or ‘doripenem’ or ‘ertapenem’ or ‘imipenem’ or ‘meropenem’ or ofloxacine or ‘levofloxacin’ or ‘moxifloxacin’ or ‘tobramycin’ or ‘linezolid’ or ‘colistin’ or ‘colistimethate’ or ‘colistimethate sodium’ or ‘rifamycins’ or ‘rifampin’ or ‘rifampicin’ or ‘tetracyclines’ or ‘doxycycline’ or ‘minocycline’ or ‘tigecycline’ | 20,769
#32 | MeSH descriptor: [Anti-Bacterial Agents] explode all trees | 8,537
#33 | ‘anti-bacterial agent’ or ‘anti-bacterial agents’ or ‘antibacterial agent’ or ‘antibacterial agents’ or antibiotic* | 20,299
#34 | #31 or #32 or #33 | 31,927
#35 | #23 and (#27 or #30) and #34 Limit: from 2012, in Trials | 21

## IPA Search Update 10/30/13

# | Query | Results
S1 | SU Pneumonia | 2,231
S2 | SU Bacterial Pneumonia | 18
S3 | SU Ventilator-Associated Pneumonia | 2
S4 | TX “pneumonia” OR “pneumonia bacterial” OR “lung inflammation” OR “pulmonary inflammation” OR “pneumonias” OR “pneumonitis” OR “pneumonitides” | 3,918
S5 | S1 OR S2 OR S3 OR S4 | 3,918
S6 | SU Nursing Homes | 919
S7 | SU Skilled Nursing Facilities | 125
S8 | SU Intermediate Care Facilities | 17
S9 | SU Drug Resistance | 237
S10 | SU Critical Care | 2,032
S11 | SU Intensive Care Unit | 1,783
S12 | SU Gram-Positive Bacterial Infections | 210
S13 | SU Gram-Negative Bacterial Infections | 150
S14 | TX “hcap” OR “healthcare associated pneumonia” OR “vap” OR “ventilator associated pneumonia” OR “hap” OR “hospital-acquired pneumonia” OR “pneumonia ventilator-associated” OR “nosocomial” OR “hospital acquired” OR “healthcare associated” OR “ventilator associated” OR “cross infection” OR “nursing home” OR “nursing homes” OR “intermediate care facililty” OR “intermediate care facilities” OR “skilled nursing facility” OR “skilled nursing facilities” OR heteroresistant OR resistant OR visa OR “vancomycin intermediate staphylococcus aureus” OR “staphylococcus aureus” OR susceptibility OR resistance OR “drug resistance” OR “drug resistance bacterial” OR “critical care” OR “care critical” OR “intensive care” OR “gram-negative bacterial infections” OR “gram-negative bacterial infection” OR “gram-positive bacterial infections” | 28,805
S15 | S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 | 28,853
S16 | SU Sepsis | 807
S17 | SU Bacteremia | 312
S18 | SU Endotoxemia | 33
S19 | SU Hemorrhagic Shock | 7
S20 | SU Septic Shock | 98
S21 | TX Sepsis OR Pyemia* OR Pyohemia* OR Pyaemia* OR Septicemia* OR “Blood Poisoning” OR “Blood Poisonings” OR Bacteremia* OR Endotoxemia* OR “Hemorrhagic Septicemia” OR “Haemorrhagic Septicaemia” OR “Hemorrhagic Septicaemia” OR “Haemorrhagic Septicemia” OR “Hemorrhagic Bacteremia” OR “Haemorrhagic Bacteremia” OR “Septic Shock” OR “Toxic Shock” OR “Endotoxic Shock” OR “Severe Sepsis” | 3,221
S22 | S16 OR S17 OR S18 OR S19 OR S20 OR S21 | 3,228
S23 | S5 AND (S15 OR S22) | 1,401
S24 | SU Pharmacokinetics | 45,001
S25 | SU Drug Monitoring | 1,014
S26 | TX pharmacokinetic* OR “pharmacokinetics” OR “pharmacokinetic” OR “area under curves” OR “area under curve” OR “curve, area under” OR “curves, area under” OR “under curve, area” OR “under curves, area” OR “auc” OR “biological availability” OR “bioavailability” OR “therapeutic equivalency” OR “bioequivalence” OR “tissue distribution” OR “adme” OR “admet” OR “absorption” OR “metabolism” OR “creatinine clearance” OR “metabolic clearance rate” OR “volume of distribution” OR “apparent volume of distribution” OR “rate of infusion” OR “dosing rate” OR “body fluid compartments” OR “onset of action” OR “biological half-life” OR “protein binding” OR “plasma protein binding” OR “therapeutic index” OR “therapeutic ratio” OR “trough level” OR “peak level” | 93,595
S27 | S24 OR S25 OR S26 | 94,350
S28 | SU Dose-Response Relationship | 9
S29 | pharmacodynamic* OR “dose-response relationship, drug” OR “drug dose-response relationship” OR “antimicrobial pharmacodynamics” OR “mic” OR “minimum inhibitory concentration” OR “auc” OR “auic” OR “area under the curve” OR “area under the inhibitory curve” OR “microbial sensitivity tests” OR “microbial sensitivity test” OR “time kill curve” OR “time kill” OR “time killing curves” OR “time killing” | 21,920
S30 | S28 OR S29 | 21,929
S31 | TX “vancomycin” OR “carbapenems” OR “thienamycins” OR “cephalosporins” OR “cefamandole” OR “cefazolin” OR “cefonicid” OR “cefsulodin” OR “cephacetrile” OR “cephalexin” OR “cephaloridine” OR “cephamycins” OR “clavulanic acids” OR “clavulanic acid” OR “monobactams” OR “aztreonam” OR “moxalactam” OR “penicillin” OR “penicillins” OR “amdinocillin” OR “cyclacillin” OR “methicillin” OR “nafcillin” OR “oxacillin” OR “penicillanic acid” OR “penicillin g” OR “penicillin v” OR “sulbactam” OR “ticarcillin” OR “aminoglycosides” OR “anthracyclines” OR “aclarubicin” OR “daunorubicin” OR “plicamycin” OR “butirosin sulfate” OR “gentamicins” OR “sisomicin” OR “hygromycin b” OR “kanamycin” OR “amikacin” OR “dibekacin” OR “nebramycin” OR “metrizamide” OR “neomycin” OR “framycetin” OR “paromomycin” OR “ribostamycin” OR “puromycin” OR “puromycin aminonucleoside” OR “spectinomycin” OR “streptomycin” OR “dihydrostreptomycin sulfate” OR “streptothricins” OR “streptozocin” OR “fluoroquinolones” OR “ciprofloxacin” OR “fleroxacin” OR “enoxacin” OR “norfloxacin” OR “ofloxacin” OR “pefloxacin” OR “ampicillin” OR “piperacillin” OR “tazobactam” OR “ceftriaxone” OR “cefotaxime” OR “ceftazidime” OR “cefepime” OR “ceftaroline” OR “t 91825” OR “doripenem” OR “ertapenem” OR “imipenem” OR “meropenem” OR ofloxacine OR “levofloxacin” OR “moxifloxacin” OR “tobramycin” OR “linezolid” OR “colistin” OR “colistimethate” OR “colistimethate sodium” OR “rifamycins” OR “rifampin” OR “rifampicin” OR “tetracyclines” OR “doxycycline” OR “minocycline” OR “tigecycline” | 26,609
S32 | SU AntiBacterial Agents | 1,026
S33 | TX “anti-bacterial agent” OR “anti-bacterial agents” OR “antibacterial agent” OR “antibacterial agents” OR antibiotic* | 27,023
S34 | S31 OR S32 OR S33 | 41,641
S35 | S23 and (S27 OR S30) and S34 | 284
S36 | S35 Limiters – Published Date 20090101-20131231 | 78
S37 | S35 Limiters – Published Date 20120101-20131231 | 7

## Original Searches 5/15/2013

### MEDLINE^®^

Search | Most Recent Queries | Result
#1 | Search (pneumonia[all fields] OR pneumonia[mesh] OR “pneumonia, bacterial”[mesh] OR “lung inflammation”[all fields] OR “pulmonary inflammation”[all fields] OR “pneumonias”[all fields] OR “pneumonitis”[all fields] OR “pneumonitides”[all fields] OR “HCAP”[all fields] OR “healthcare associated pneumonia”[all fields] OR “VAP”[all fields] OR “ventilator associated pneumonia” OR “HAP”[all fields] OR “hospital-acquired pneumonia”[all fields] OR “Pneumonia, Ventilator-Associated”[mesh]) | 125,685
#2 | Search “nosocomial”[all fields] OR “hospital acquired”[all fields] OR “healthcare associated”[all fields] OR “ventilator associated”[all fields] OR “cross infection”[mesh] OR “cross infection”[all fields] OR “nursing home”[all fields] OR “nursing homes”[all fields] OR “intermediate care facililty”[all fields] OR “intermediate care facilities”[all fields] OR “skilled nursing facility”[all fields] OR “skilled nursing facility”[all fields] OR “nursing home”[MeSH] OR “intermediate care facilities”[MeSH] OR “skilled nursing facilities”[MeSH] OR ((Heteroresistant OR resistant) AND (VISA[all fields] OR “vancomycin intermediate staphylococcus aureus”[all fields])) OR “Staphylococcus aureus”[all fields] OR “Staphylococcus aureus”[mesh] OR Susceptibility[all fields] OR Resistance[all fields] OR “drug resistance”[mesh] OR “drug resistance”[all fields] OR “drug resistance, bacterial”[mesh] OR “Critical care”[mesh] OR “critical care”[all fields] OR “care, critical”[all fields] OR “intensive care”[mesh] OR “Gram-Negative Bacterial Infections”[mesh] OR “Gram-Negative Bacterial Infection”[all fields] OR “Gram-Positive Bacterial Infections”[mesh] OR “Gram-Positive Bacterial Infections”[all fields] | 1,487,227
#3 | Search Sepsis[MeSH] OR Sepsis[tw] OR Pyemia[tw] OR Pyemias[tw] OR Pyohemia[tw] OR Pyohemias[tw] OR Pyaemia[tw] OR Pyaemias[tw] OR Septicemia[tw] OR Septicemias[tw] OR “Blood Poisoning” [tw] OR “Blood Poisonings” [tw] OR Severe Sepsis[tw] OR Bacteremia[MeSH] OR Bacteremia[tw] OR Bacteremias[tw] OR Endotoxemia[MeSH] OR Endotoxemia[tw] OR Endotoxemias[tw] OR “Hemorrhagic Septicemia”[MeSH] OR “Hemorrhagic Septicemia”[tw] OR “Haemorrhagic Septicaemia”[tw] OR “Hemorrhagic Septicaemia”[tw] OR “Haemorrhagic Septicemia”[tw] OR “Hemorrhagic Bacteremia”[tw] OR “Haemorrhagic Bacteremia”[tw] OR “Shock, Septic”[MeSH] OR “Septic Shock”[tw] OR “Toxic Shock”[tw] OR “Toxic Shock Syndrome”[tw] OR “Toxic Shock Syndromes”[tw] OR “Endotoxic Shock”[tw] | 141,016
#4 | Search (#1 AND (#2 OR #3)) | 45,371
#5 | Search (pharmacokinetic*[all fields] OR “pharmacokinetics”[mesh] OR “pharmacokinetics”[sh] OR “Area Under Curves”[all fields] OR “Curve, Area Under”[all fields] OR “Curves, Area Under”[all fields] OR “Under Curve, Area”[all fields] OR “Under Curves, Area”[all fields] OR AUC[all fields] OR “Biological Availability”[mesh] OR “biological availability”[all fields] OR “bioavailability”[all fields] OR “Metabolic Clearance Rate”[mesh] OR “metabolic clearance rate”[all fields] OR “Therapeutic Equivalency”[mesh] OR “therapeutic equivalency”[all fields] OR “bioequivalence”[all fields] OR “Tissue Distribution”[mesh] OR “tissue distribution”[all fields] OR “adme”[all fields] OR “admet”[all fields] OR “Absorption/drug effects”[mesh] OR “metabolism/drug effects”[all fields] OR “metabolism”[sh] OR “creatinine clearance”[all fields] OR “metabolic clearance rate”[mesh] OR “volume of distribution”[all fields] OR “apparent volume of distribution”[all fields] OR “rate of infusion”[all fields] OR “dosing rate”[all fields] OR “body fluid compartments”[mesh] OR “onset of action”[all fields] OR “biological half-life”[all fields] OR “Protein binding”[mesh] OR “protein binding”[all fields] OR “Plasma Protein Binding”[all fields] OR “therapeutic index”[all fields] OR “therapeutic ratio”[all fields] OR “Trough level”[all fields] OR “peak level”[all fields] OR “therapeutic drug monitoring”[all fields] OR “drug monitoring”[MeSH]) | 5,605,147
#6 | Search (pharmacodynamic*[all fields] OR “dose-response relationship, drug”[mesh] OR “drug dose-response relationship”[all fields] OR “dose response relationship, drug”[all fields] OR “antimicrobial pharmacodynamics”[all fields] OR “MIC”[all fields] OR “minimum inhibitory concentration”[all fields] OR “AUC”[all fields] OR “AUIC”[all fields] OR “area under the curve”[all fields] OR “area under the inhibitory curve” OR “microbial sensitivity tests”[mesh] OR “time kill curve”[all fields] OR “time kill”[all fields] OR “time killing curves”[all fields] OR “time killing”[all fields]) | 475,113
#7 | Search (Vancomycin[mesh] OR vancomycin[all fields] OR Carbapenems[all fields] OR Thienamycins[all fields] OR Cephalosporins[all fields] OR Cefamandole[all fields] OR Cefazolin[all fields] OR Cefonicid[all fields] OR Cefsulodin[all fields] OR Cephacetrile[all fields] OR Cephalexin[all fields] OR Cephaloridine[all fields] OR Cephamycins[all fields] OR “Clavulanic Acids”[all fields] OR “Clavulanic Acid”[all fields] OR Monobactams[all fields] OR Aztreonam[all fields] OR Moxalactam[all fields] OR Penicillin[all fields] OR penicillins[all fields] OR Amdinocillin[all fields] OR Cyclacillin[all fields] OR Methicillin[all fields] OR Nafcillin[all fields] OR Oxacillin[all fields] OR “Penicillanic Acid”[all fields] OR “Penicillin G”[all fields] OR “Penicillin V”[all fields] OR Sulbactam[all fields] OR Ticarcillin[all fields] OR Aminoglycosides[all fields] OR Anthracyclines[all fields] OR Aclarubicin[all fields] OR Daunorubicin[all fields] OR Plicamycin[all fields] OR “Butirosin Sulfate”[all fields] OR Gentamicins[all fields] OR Sisomicin[all fields] OR “Hygromycin B”[all fields] OR Kanamycin[all fields] OR Amikacin[all fields] OR Dibekacin[all fields] OR Nebramycin[all fields] OR Metrizamide[all fields] OR Neomycin[all fields] OR Framycetin[all fields] OR Paromomycin[all fields] OR Ribostamycin[all fields] OR Puromycin[all fields] OR “Puromycin Aminonucleoside”[all fields] OR Spectinomycin[all fields] OR Streptomycin[all fields] OR “Dihydrostreptomycin Sulfate”[all fields] OR Streptothricins[all fields] OR Streptozocin[all fields] OR Fluoroquinolones[all fields] OR Ciprofloxacin[all fields] OR Fleroxacin[all fields] OR Enoxacin[all fields] OR Norfloxacin[all fields] OR Ofloxacin[all fields] OR Pefloxacin[all fields] OR Ampicillin[MeSH] OR ampicillin[all fields] OR Piperacillin[MeSH] OR piperacillin[all fields] OR Tazobactam[Supplementary Concept] OR tazobactam[all fields] OR Ceftriaxone[MeSH] OR Ceftriaxone[all fields] OR Cefotaxime[MeSH] OR cefotaxime[all fields] OR Ceftazidime[MeSH] OR Ceftazidime[all fields] OR Cefepime[supplementary concept] OR cefepime[all fields] OR Ceftaroline[all fields] OR “T 91825”[supplementary concept] OR Doripenem[supplementary concept] OR doripenem[all fields] OR Ertapenem[supplementary concept] OR ertapenem[all fields] OR Imipenem[MeSH] OR imipenem[all fields] OR Meropenem[supplementary concept] OR meropenem[all fields] OR ofloxacine[MeSH] OR Levofloxacin[all fields] OR Moxifloxacin[supplementary concept] OR moxifloxacin[all fields] OR Tobramycin[MeSH] OR tobramycin[all fields] OR Linezolid[supplementary concept] OR linezolid[all fields] OR Colistin[MeSH] or colistin[all fields] OR colistimethate[supplementary concept] OR “colistimethate sodium”[all fields] OR rifamycins[MeSH] OR rifampin[MeSH] OR rifampin[all fields] OR rifampicin[all fields] OR tetracyclines[MeSH] OR doxycycline[MeSH] OR doxycycline[all fields] OR minocycline[MeSH] OR minocycline[all fields] OR tigecycline[supplementary concept] OR tigecycline[all fields]) | 370,705
#8 | Search (“anti-bacterial agent”[all fields] OR “anti-bacterial agents”[all fields] OR “antibacterial agent”[all fields] OR “antibacterial agents”[all fields] OR antibiotic*[all fields] OR “Anti-Bacterial Agents”[mesh]) | 621,086
#9 | Search (“Editorial”[publication type] OR “Letter”[publication type] OR “Addresses”[publication type] OR “Autobiography”[publication type] OR “Bibliography”[publication type] OR “Biography”[publication type] OR “comment”[publication type] OR “Congresses”[publication type] OR “Consensus Development Conference, NIH”[publication type] OR “Dictionary”[publication type] OR “Directory”[publication type] OR “Festschrift”[publication type] OR “Interactive Tutorial”[publication type] OR “Interview”[publication type] OR “Lectures”[publication type] OR “Legal Cases”[publication type] OR “Legislation”[publication type] OR “Patient Education Handout”[publication type] OR “Periodical Index”[publication type] OR “Portraits”[publication type] OR “Scientific Integrity Review”[publication type] OR “Video-Audio Media”[publication type] OR “Webcasts”[publication type]) | 1,527,036
#10 | Search ((“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields]) | 107,278
#11 | Search (#4 AND (#5 OR #6) AND (#7 OR #8)) | 4,233
#12 | Search (#11 NOT (#9 OR #10)) | 4,048
#13 | Search (#11 NOT (#9 OR #10)) Filters: Humans | 3,356
#14 | Search (#11 NOT (#9 OR #10)) Filters: Other Animals | 850
#15 | Search (#14 NOT #13) | 547
#16 | Search (#12 NOT #15) | 3,501
#17 | Search (#16) Filters: English | 2,636
#18 | Search (#16) Filters: English; Adult: 19+ years | 1,213

### Cochrane

ID | Search | Hits
#1 | MeSH descriptor: [Pneumonia] explode all trees | 2,406
#2 | MeSH descriptor: [Pneumonia, Bacterial] explode all trees | 643
#3 | MeSH descriptor: [Pneumonia, Ventilator-Associated] explode all trees | 159
#4 | ‘pneumonia’ or ‘pneumonia bacterial’ or ‘lung inflammation’ or ‘pulmonary inflammation’ or ‘pneumonias’ or ‘pneumonitis’ or ‘pneumonitides’ | 7,518
#5 | #1 or #2 or #3 or #4 | 7,588
#6 | MeSH descriptor: [Nursing Homes] explode all trees | 882
#7 | MeSH descriptor: [Skilled Nursing Facilities] explode all trees | 51
#8 | MeSH descriptor: [Intermediate Care Facilities] explode all trees | 13
#9 | MeSH descriptor: [Drug Resistance, Bacterial] explode all trees | 739
#10 | MeSH descriptor: [Critical Care] explode all trees | 1,668
#11 | MeSH descriptor: [Intensive Care] explode all trees | 1,029
#12 | MeSH descriptor: [Gram-Positive Bacterial Infections] explode all trees | 4,508
#13 | MeSH descriptor: [Gram-Negative Bacterial Infections] explode all trees | 5,475
#14 | ‘hcap’ or ‘healthcare associated pneumonia’ or ‘vap’ or ‘ventilator associated pneumonia’ or ‘hap’ or ‘hospital-acquired pneumonia’ or ‘pneumonia ventilator-associated’ or ‘nosocomial’ or ‘hospital acquired’ or ‘healthcare associated’ or ‘ventilator associated’ or ‘cross infection’ or ‘nursing home’ or ‘nursing homes’ or ‘intermediate care facililty’ or ‘intermediate care facilities’ or ‘skilled nursing facility’ or ‘skilled nursing facilities’ or heteroresistant or resistant or visa or ‘vancomycin intermediate staphylococcus aureus’ or ‘staphylococcus aureus’ or susceptibility or resistance or ‘drug resistance’ or ‘drug resistance bacterial’ or ‘critical care’ or ‘care critical’ or ‘intensive care’ or ‘gram-negative bacterial infections’ or ‘gram-negative bacterial infection’ or ‘gram-positive bacterial infections’ | 72,654
#15 | #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 | 79,030
#16 | MeSH descriptor: [Sepsis] explode all trees | 2,788
#17 | MeSH descriptor: [Bacteremia] explode all trees | 687
#18 | MeSH descriptor: [Endotoxemia] explode all trees | 122
#19 | MeSH descriptor: [Hemorrhagic Septicemia] explode all trees | 0
#20 | MeSH descriptor: [Shock, Septic] explode all trees | 382
#21 | Sepsis or Pyemia* or Pyohemia* or Pyaemia* or Septicemia* or ‘Blood Poisoning’ or ‘Blood Poisonings’ or Bacteremia* or Endotoxemia* or ‘Hemorrhagic Septicemia’ or ‘Haemorrhagic Septicaemia’ or ‘Hemorrhagic Septicaemia’ or ‘Haemorrhagic Septicemia’ or ‘Hemorrhagic Bacteremia’ or ‘Haemorrhagic Bacteremia’ or ‘Septic Shock’ or ‘Toxic Shock’ or ‘Endotoxic Shock’ or ‘Severe Sepsis’ | 6,717
#22 | #16 or #17 or #18 or #19 or #20 or #21 | 7,257
#23 | #5 and (#15 or #22) | 4,159
#24 | MeSH descriptor: [Pharmacokinetics] explode all trees | 9,715
#25 | MeSH descriptor: [Drug Monitoring] explode all trees | 933
#26 | pharmacokinetic* or ‘pharmacokinetics’ or ‘pharmacokinetic’ or ‘area under curves’ or ‘area under curve’ or ‘curve, area under’ or ‘curves, area under’ or ‘under curve, area’ or ‘under curves, area’ or ‘auc’ or ‘biological availability’ or ‘bioavailability’ or ‘therapeutic equivalency’ or ‘bioequivalence’ or ‘tissue distribution’ or ‘adme’ or ‘admet’ or ‘absorption’ or ‘metabolism’ or ‘creatinine clearance’ or ‘metabolic clearance rate’ or ‘volume of distribution’ or ‘apparent volume of distribution’ or ‘rate of infusion’ or ‘dosing rate’ or ‘body fluid compartments’ or ‘onset of action’ or ‘biological half-life’ or ‘protein binding’ or ‘plasma protein binding’ or ‘therapeutic index’ or ‘therapeutic ratio’ or ‘trough level’ or ‘peak level’ | 170,788
#27 | #24 or #25 or #26 | 171,127
#28 | MeSH descriptor: [Dose-Response Relationship, Drug] explode all trees | 23,091
#29 | pharmacodynamic* or ‘dose-response relationship, drug’ or ‘drug dose-response relationship’ or ‘antimicrobial pharmacodynamics’ or ‘mic’ or ‘minimum inhibitory concentration’ or ‘auc’ or ‘auic’ or ‘area under the curve’ or ‘area under the inhibitory curve’ or ‘microbial sensitivity tests’ or ‘microbial sensitivity test’ or ‘time kill curve’ or ‘time kill’ or ‘time killing curves’ or ‘time killing’ | 43,464
#30 | #28 or #29 | 43,464
#31 | ‘vancomycin’ or ‘carbapenems’ or ‘thienamycins’ or ‘cephalosporins’ or ‘cefamandole’ or ‘cefazolin’ or ‘cefonicid’ or ‘cefsulodin’ or ‘cephacetrile’ or ‘cephalexin’ or ‘cephaloridine’ or ‘cephamycins’ or ‘clavulanic acids’ or ‘clavulanic acid’ or ‘monobactams’ or ‘aztreonam’ or ‘moxalactam’ or ‘penicillin’ or ‘penicillins’ or ‘amdinocillin’ or ‘cyclacillin’ or ‘methicillin’ or ‘nafcillin’ or ‘oxacillin’ or ‘penicillanic acid’ or ‘penicillin g’ or ‘penicillin v’ or ‘sulbactam’ or ‘ticarcillin’ or ‘aminoglycosides’ or ‘anthracyclines’ or ‘aclarubicin’ or ‘daunorubicin’ or ‘plicamycin’ or ‘butirosin sulfate’ or ‘gentamicins’ or ‘sisomicin’ or ‘hygromycin b’ or ‘kanamycin’ or ‘amikacin’ or ‘dibekacin’ or ‘nebramycin’ or ‘metrizamide’ or ‘neomycin’ or ‘framycetin’ or ‘paromomycin’ or ‘ribostamycin’ or ‘puromycin’ or ‘puromycin aminonucleoside’ or ‘spectinomycin’ or ‘streptomycin’ or ‘dihydrostreptomycin sulfate’ or ‘streptothricins’ or ‘streptozocin’ or ‘fluoroquinolones’ or ‘ciprofloxacin’ or ‘fleroxacin’ or ‘enoxacin’ or ‘norfloxacin’ or ‘ofloxacin’ or ‘pefloxacin’ or ‘ampicillin’ or ‘piperacillin’ or ‘tazobactam’ or ‘ceftriaxone’ or ‘cefotaxime’ or ‘ceftazidime’ or ‘cefepime’ or ‘ceftaroline’ or ‘t 91825’ or ‘doripenem’ or ‘ertapenem’ or ‘imipenem’ or ‘meropenem’ or ofloxacine or ‘levofloxacin’ or ‘moxifloxacin’ or ‘tobramycin’ or ‘linezolid’ or ‘colistin’ or ‘colistimethate’ or ‘colistimethate sodium’ or ‘rifamycins’ or ‘rifampin’ or ‘rifampicin’ or ‘tetracyclines’ or ‘doxycycline’ or ‘minocycline’ or ‘tigecycline’ | 20,530
#32 | MeSH descriptor: [Anti-Bacterial Agents] explode all trees | 8,388
#33 | ‘anti-bacterial agent’ or ‘anti-bacterial agents’ or ‘antibacterial agent’ or ‘antibacterial agents’ or antibiotic* | 19,974
#34 | #31 or #32 or #33 | 31,453
#35 | #23 and (#27 or #30) and #34 | 1,080
#36 | #23 and (#27 or #30) and #34 Limit: Trials | 411

### IPA

# | Query | Results
S1 | SU Pneumonia | 2,205
S2 | SU Bacterial Pneumonia | 18
S3 | SU Ventilator-Associated Pneumonia | 2
S4 | TX “pneumonia” OR “pneumonia bacterial” OR “lung inflammation” OR “pulmonary inflammation” OR “pneumonias” OR “pneumonitis” OR “pneumonitides” | 3,859
S5 | S1 OR S2 OR S3 OR S4 | 3,859
S6 | SU Nursing Homes | 914
S7 | SU Skilled Nursing Facilities | 124
S8 | SU Intermediate Care Facilities | 17
S9 | SU Drug Resistance | 235
S10 | SU Critical Care | 2,009
S11 | SU Intensive Care Unit | 1,748
S12 | SU Gram-Positive Bacterial Infections | 206
S13 | SU Gram-Negative Bacterial Infections | 147
S14 | TX “hcap” OR “healthcare associated pneumonia” OR “vap” OR “ventilator associated pneumonia” OR “hap” OR “hospital-acquired pneumonia” OR “pneumonia ventilator-associated” OR “nosocomial” OR “hospital acquired” OR “healthcare associated” OR “ventilator associated” OR “cross infection” OR “nursing home” OR “nursing homes” OR “intermediate care facililty” OR “intermediate care facilities” OR “skilled nursing facility” OR “skilled nursing facilities” OR heteroresistant OR resistant OR visa OR “vancomycin intermediate staphylococcus aureus” OR “staphylococcus aureus” OR susceptibility OR resistance OR “drug resistance” OR “drug resistance bacterial” OR “critical care” OR “care critical” OR “intensive care” OR “gram-negative bacterial infections” OR “gram-negative bacterial infection” OR “gram-positive bacterial infections” | 28,294
S15 | S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 | 28,339
S16 | SU Sepsis | 792
S17 | SU Bacteremia | 306
S18 | SU Endotoxemia | 33
S19 | SU Hemorrhagic Shock | 7
S20 | SU Septic Shock | 98
S21 | TX Sepsis OR Pyemia* OR Pyohemia* OR Pyaemia* OR Septicemia* OR “Blood Poisoning” OR “Blood Poisonings” OR Bacteremia* OR Endotoxemia* OR “Hemorrhagic Septicemia” OR “Haemorrhagic Septicaemia” OR “Hemorrhagic Septicaemia” OR “Haemorrhagic Septicemia” OR “Hemorrhagic Bacteremia” OR “Haemorrhagic Bacteremia” OR “Septic Shock” OR “Toxic Shock” OR “Endotoxic Shock” OR “Severe Sepsis” | 3,178
S22 | S16 OR S17 OR S18 OR S19 OR S20 OR S21 | 3,185
S23 | S5 AND (S15 OR S22) | 1,385
S24 | SU Pharmacokinetics | 44,211
S25 | SU Drug Monitoring | 1,009
S26 | TX pharmacokinetic* OR “pharmacokinetics” OR “pharmacokinetic” OR “area under curves” OR “area under curve” OR “curve, area under” OR “curves, area under” OR “under curve, area” OR “under curves, area” OR “auc” OR “biological availability” OR “bioavailability” OR “therapeutic equivalency” OR “bioequivalence” OR “tissue distribution” OR “adme” OR “admet” OR “absorption” OR “metabolism” OR “creatinine clearance” OR “metabolic clearance rate” OR “volume of distribution” OR “apparent volume of distribution” OR “rate of infusion” OR “dosing rate” OR “body fluid compartments” OR “onset of action” OR “biological half-life” OR “protein binding” OR “plasma protein binding” OR “therapeutic index” OR “therapeutic ratio” OR “trough level” OR “peak level” | 92,393
S27 | S24 OR S25 OR S26 | 93,144
S28 | SU Dose-Response Relationship | 9
S29 | pharmacodynamic* OR “dose-response relationship, drug” OR “drug dose-response relationship” OR “antimicrobial pharmacodynamics” OR “mic” OR “minimum inhibitory concentration” OR “auc” OR “auic” OR “area under the curve” OR “area under the inhibitory curve” OR “microbial sensitivity tests” OR “microbial sensitivity test” OR “time kill curve” OR “time kill” OR “time killing curves” OR “time killing” | 21,472
S30 | S28 OR S29 | 21,481
S31 | TX “vancomycin” OR “carbapenems” OR “thienamycins” OR “cephalosporins” OR “cefamandole” OR “cefazolin” OR “cefonicid” OR “cefsulodin” OR “cephacetrile” OR “cephalexin” OR “cephaloridine” OR “cephamycins” OR “clavulanic acids” OR “clavulanic acid” OR “monobactams” OR “aztreonam” OR “moxalactam” OR “penicillin” OR “penicillins” OR “amdinocillin” OR “cyclacillin” OR “methicillin” OR “nafcillin” OR “oxacillin” OR “penicillanic acid” OR “penicillin g” OR “penicillin v” OR “sulbactam” OR “ticarcillin” OR “aminoglycosides” OR “anthracyclines” OR “aclarubicin” OR “daunorubicin” OR “plicamycin” OR “butirosin sulfate” OR “gentamicins” OR “sisomicin” OR “hygromycin b” OR “kanamycin” OR “amikacin” OR “dibekacin” OR “nebramycin” OR “metrizamide” OR “neomycin” OR “framycetin” OR “paromomycin” OR “ribostamycin” OR “puromycin” OR “puromycin aminonucleoside” OR “spectinomycin” OR “streptomycin” OR “dihydrostreptomycin sulfate” OR “streptothricins” OR “streptozocin” OR “fluoroquinolones” OR “ciprofloxacin” OR “fleroxacin” OR “enoxacin” OR “norfloxacin” OR “ofloxacin” OR “pefloxacin” OR “ampicillin” OR “piperacillin” OR “tazobactam” OR “ceftriaxone” OR “cefotaxime” OR “ceftazidime” OR “cefepime” OR “ceftaroline” OR “t 91825” OR “doripenem” OR “ertapenem” OR “imipenem” OR “meropenem” OR ofloxacine OR “levofloxacin” OR “moxifloxacin” OR “tobramycin” OR “linezolid” OR “colistin” OR “colistimethate” OR “colistimethate sodium” OR “rifamycins” OR “rifampin” OR “rifampicin” OR “tetracyclines” OR “doxycycline” OR “minocycline” OR “tigecycline” | 26,345
S32 | SU Anti-Bacterial Agents | 19,600
S33 | TX “anti-bacterial agent” OR “anti-bacterial agents” OR “antibacterial agent” OR “antibacterial agents” OR antibiotic* | 26,571
S34 | S31 OR S32 OR S33 | 41,069
S35 | S23 and (S27 OR S30) and S34 | 220

Total references identified by the main searches = 1844

Total references from main and hand searches, minus duplicates = 1696