# Results

## Search Results

After removing duplicate citations from our searches, we retrieved 6,809 unique citations (Figure 3). After reviewing titles, abstracts, and full articles, we included 126 studies (in 130 publications). We included 14 studies that evaluated the diagnostic accuracy of a troponin elevation in the diagnosis of acute coronary syndrome (ACS) in patients with chronic kidney disease (CKD) (Key Question [KQ] 1).37-50 We did not find any studies that directly assessed how troponin levels affect management strategies of ACS in patients with CKD (KQ 2). However, we discuss one study that reported troponin levels by management strategies in patients with CKD and symptoms of ACS.51 We found 12 studies in 14 publications that addressed short- and long-term prognosis in patients with CKD after presentation with ACS by troponin levels (KQ 3).40, 52-64 We included 98 studies (in 105 publications) that evaluated use of troponin levels for risk stratification among patients with CKD without ACS symptoms (KQ 4).9, 11, 25, 26, 47, 65-163 One study reported on both KQ 1 and KQ 3.^40^ One study reported on both KQ 3 and KQ 4.^47^

Figure 3 Summary of the literature search

* Total may exceed number in corresponding box, as articles could be excluded for more than one reason at this level.

** One study indirectly addressed this Key Question

CKD = chronic kidney disease; KQ = Key Question

The figure shows the literature search via a vertical search flow diagram. The first box shows the Electronic databases that were searched, PubMed, Embase, and Cochrane, and how many returns from the search. The next box has total retrieved titles. Then there is a box to the right with duplicates that were removed, then title review, then a box to the right with excluded titles, then abstract review, a box to the right with excluded titles than another box to the right with reasons for exclusion. Then below, article review, with a box to the right with excluded articles and another box to the right with reasons for exclusion at article review level. Finally, there is a box summarizing the included studies broken down by key question.

## KQ 1 Use of Troponin for Diagnosis of Acute Coronary Syndrome Among Chronic Kidney Disease Patients

### Study Design Characteristics

We included 14 studies for this KQ. Of these, six used a prospective cohort design, five used a retrospective design, two used a cross-sectional design, and one used a prospective case-control design. All studies took place in the acute care setting, and all but two took place in the hospital setting. Of these two, one took place in a mixed setting, including the emergency department, intensive care unit, and internal medicine wards;40 and the setting for the second was unknown.42 Five studies took place in the United States,41, 43, 45-47 six in Europe,37, 40, 42, 48-50 two in Asia,38, 44 and one in the Middle East.39

Seven studies did not explicitly give dates of enrollment. For those seven studies which did report enrollment, start dates ranged from 1999 to 2009 and end dates ranged from 1999 to 2010.^37-40, 43, 49, 50^ Seven studies did not report mean length of followup. For those studies that did report length of followup, it ranged from 30 days to 2 years.37, 41-43, 47, 49

Of the 14 studies included for this KQ, different numbers of studies addressed various operating characteristics; some studies addressed more than one type of operating characteristic. Table 4, below, presents the number of unique studies addressing each type of operating characteristic, and the relevant KQ to which they apply.

Table 4 Number of unique studies addressing each type of operating characteristic

Key Question | Type of Operating Characteristic Presented | Number of Unique Studies
1.1 | Sensitivity and specificity | 11
1.1a | Negative and positive predictive value | 6
1.1b | Change in troponin values vs. single value | 1
1.2 | Operating characteristic by subgroup | 3
1.4 | Direct comparison of troponin assays | 1
All of Key Question 1 | | 14 unique studies

### Study Population Characteristics

The total number of patients enrolled ranged from 31 to 1,601. Five studies reported explicit adjudication of an acute coronary syndrome (ACS) diagnosis, all with panels; two included cardiologists;39, 43 and three did not include cardiologists.46, 48, 49 Table 5 summarizes the adjudication criteria the studies used.

Table 5 Adjudication criteria researchers used to define acute coronary syndromes in studies that evaluated the use of troponin to diagnosis acute coronary syndromes among patients with chronic kidney disease

Author, Year | ACS Definition | Adjudication
Flores-Solis, 2012^37^ | European Society of Cardiology 164 | No
Sukonthasarn, 2007^38^ | European Society of Cardiology164 | No
Alcalai, 2007^39^ | Not explicitly reported | Yes (including cardiologist)
Flores, 2006^40^ | European Society of Cardiology/American College of Cardiology “AMI definition of 2000”165 | No
Noeller, 2003^41^ | STEMI: ECG changes plus chest pain or CK-MB increase; NSTEMI: ECG changes and either chest pain or ECG changes; UA: anginal change/at rest/ECG changes [no reference given] | No
Fehr, 2003^42^ | “MI: angiography; UA: typical symptoms, ECG changes and positive cTnT test” [no reference given] | No
McCullough, 2002^43^ | Not explicitly reported | Yes (including cardiologist)
Ikeda, 2002^44^ | Not explicitly reported | No
Apple, 1999^45^ | Not explicitly reported | Yes
Bhagavan, 1998^46^ | “WHO criteria were used for diagnosing MI, which included presenting symptoms, ECG, and cardiac enzymes. Physical exam findings and various diagnostic imaging studies were also taken into consideration.” [no reference] | No
Martin, 1998^47^ | “History, physical examination, ECG, and CK-MB measurements” [no reference] | No
Chenevier-Gobeaux, 2013^48^ | Global Consensus on MI | Yes (including cardiologist)
Haaf, 2013^49^ | Global Consensus on MI | Yes (including cardiologist)
Pfortmueller, 2013^50^ | Patint history, physical examination, electrocardiogram, and laboratory values [no reference given] | No

AMI = acute myocardial infarction; CK-MB = creatine kinase-MB; cTnT = cardiac troponin T; ECG = electrocardiogram; MI = myocardial infarction; NSTEMI = non-ST-segment elevation myocardial infarction; STEMI = ST-segment elevation myocardial infarction; UA = unstable angina; WHO = World Health Organization

The studies included patients with various stages of CKD. Four studies included patients on dialysis.38, 42-44 One study included patients in stages 1-4 of CKD.40 Another study included patients in stages 1-5 of chronic kidney disease (CKD) but did not include patients on dialysis.48 No studies exclusively included patients in stage 1 or 2. Two studies included only patients in stage 3 or 4.^37, 50^

The mean age of those enrolled ranged from 48 to 80 years. Three studies did not provide this information.44-46 The percentage of men among those enrolled ranged from 35 to 76; three studies did not report gender distribution.44-46 Five of the studies reported distribution of race or ethnicity. The percentage of African American patients ranged from 48 to 86, and the percentage of White patients ranged from 12 to 65.^41, 43, 47^

### Study Quality

The quality of the included studies varied. Three studies were of good quality.37-39 One study was of poor quality.40 The remainder of the studies were of fair quality.

### KQ 1.1 Operating Characteristics of a Troponin Elevation (Sensitivity, Specificity, Positive Predictive Value, and Negative Predictive Value)

Key Points
- In six studies, the sensitivity of the troponin T assay for ACS in patients with CKD ranged from 71 to 100 percent, and its specificity ranged from 31 to 86 percent. Three studies reported a positive predictive value (PPV) and negative predictive value (NPV) for troponin T for the diagnosis of ACS. The PPV for troponin T ranged from 66 to 77; the NPV ranged from 71 to 98. In one study, the assay was associated with a greater PPV and NPV for the subgroup of patients with age less than 65 years (strength of evidence: low).
- In eight studies, the sensitivity of the troponin I assay for ACS ranged from 43 to 94 percent, and its specificity ranged from 48 to 100 percent. In five studies, that reported PPV and NPV, PPV ranged from 74 to 100; the NPV ranged from 93 to 98 percent. The broad range of these findings can be attributed to heterogeneity in regard to study populations, definitions of ACS, assays used, and assay cutoffs used (strength of evidence: low).
- One study found that the magnitude of change in the troponin T assay did not differ between patients with ACS and a control group, during 24 hours after admission. The rate of change did differ but this rate displayed marked variability during the 24 hours. This was a single study with a small sample size and imprecise results, and thus not conclusive (strength of evidence: insufficient).
- One study, which included details of ACS adjudication, reported sensitivity and specificity for troponin I elevation which appeared roughly comparable to that of other studies, though direct comparison is impossible.

#### Results

Ten unique studies reported on the sensitivity or specificity of a troponin assay to diagnose ACS.37, 38, 40, 42, 44-47, 49, 50 Three studies reported explicit adjudication of an ACS diagnosis, all included panels, two including cardiologists,39, 43 and three did not include cardiologists.46, 48, 49 Two studies reported other diagnostic criteria of ACS; two used criteria from the European Society of Cardiology,37, 38 and two electrocardiogram and clinical criteria.41, 50 We were unable to conduct a meta-analysis because the number of studies was too small, and thus we do not have an aggregate estimate of the sensitivity and specificity. We presented the results for troponin T and troponin I separately below.

##### Troponin T

Six studies examined the operating characteristics of the troponin T assay in their entire study population (Table 6).38, 42, 44, 48-50 Two studies used a cutoff of 0.1 mcg/L, both used the Roche Elecsys assay.38, 42 One study used a cutoff of 0.16 mcg/L and did not specify the manufacture or assay.44 Another study used multiple cutoffs, including 0.014 mcg/L and 0.0358 mcg/L and the high-sensitivity Roche Elecsys assay.48 One study reported a cutoff of 0.009 mcg/L for the Roche Elecsys assay, and a cutoff of 0.0194 mcg/L for the high-sensitivity Roche Elecsys assay.49 One study used a cutoff of 0.014 mcg/L for the Roche Modular E170 assay.50 The sample size of those studies using the troponin T assay ranged from 31 to 382. The sensitivity in these studies ranged from 71 to 100 percent, and the specificity ranged from 31 to 86 percent (Figure 4). The heterogeneity of these results using the same cutoff and assay can potentially be understood in the light of the different geographic settings of the studies; moreover, while one study adjudicated ACS according to the standards of the European Society of Cardiology;38 and two others did so with cardiologist adjudication, according to the criteria of the Global Consensus on MI;48, 49 two other studies did not explicitly report adjudication standards.42, 44

Table 6 Operating characteristics of elevated troponin in the diagnosis of acute coronary syndrome among patients with chronic kidney disease

Author, Year | Troponin Assay | Cutoff (mcg/L) | ACS Diagnosis | Total N | Sensitivity | Specificity
Flores-Solis, 2012^37^ | Troponin I, Beckman | 0.5 | Adjudication according to European Society for Cardiology 2007 standards | 484 | 0.43 | 0.94
Flores, 2006^40^ | Troponin I, Beckman Access AccuTnI | 0.5 | European Society of Cardiology/American College of Cardiology 2000 standards | 467 | 0.70 (95% CI, 0.57 to 0.83) | 0.92 (95% CI 0.90 to 0.95)
Flores-Solis, 2012^37^ | Troponin I, Vidas | 0.11 | Adjudication according to European Society for Cardiology 2007 standards | 484 | 0.64 | 0.87
Apple, 1999^45^ | Troponin I, BioSite | 0.4 | Modified WHO criteria | 1,601 | >0.89 | 0.95 to 1.00
Bhagavan, 1998^46^ | Troponin I, Baxter | 0.6 | WHO criteria | 155 | 0.90 | 0.81
Martin, 1998^47^ | Troponin I, Dade Stratus | 0.8 | None given | 56 | 0.94 (95% CI, 0.82 to 1.06) | 1.00
Ikeda, 2002^44^ | Troponin I, manufacturer not given | 0.8 | None given | 173 | 0.83 | 0.91
Fehr, 2003^42^ | Troponin I, DPC Immulite | 1.0 | None given | 31 | 0.45 | 1.00
Haaf, 2013^49^ | High-sensitivity troponin I, Siemens | 0.0063 | Global Consensus on MI (JACC) | 1,117 | 0.73 | 0.53
Haaf, 2013^49^ | High-sensitivity troponin I, Beckman Access | 0.0099 | Global Consensus on MI (JACC) | 1,117 | 0.81 | 0.48
Sukonthasarn, 2007^38^ | Troponin T, Roche | 0.1 | Adjudication according to European Society of Cardiology standards | 46 | 0.91 | 0.85
Fehr, 2003^42^ | Troponin T, Roche Elecsys | 0.1 | None given | 31 | 1.00 | 0.42
Ikeda, 2002^44^ | Troponin T, manufacturer not given | 0.16 | None given | 173 | 0.85 | 0.81
Chenevier-Gobeaux, 2013^48^ | High sensitivity troponin T, Roche Elecsys | 0.014 | Global Consensus on MI (JACC) | 375 | 1.00 (95% CI, 0.76 to 1.00) | 0.54 (95% CI 0.40 to 0.67)
Chenevier-Gobeaux, 2013^48^ | High sensitivity troponin T, Roche Elecsys | 0.0358 | Global Consensus on MI (JACC) | 375 | 0.94 (95% CI, 0.68 to 1.00) | 0.86 (95% CI 0.74 to 0.94)
Haaf, 2013^49^ | Troponin T Roche Elecsys | 0.009 | Global Consensus on MI (JACC) | 1,117 | 0.75 | 0.37
Haaf, 2013^49^ | High sensitivity troponin T Roche Elecsys | 0.0194 | Global Consensus on MI (JACC) | 1,117 | 0.71 | 0.58
Pfortmueller, 2013^50^ | High sensitivity troponin T, Roche Modular E170 | 0.014 | Patient history, signs and symptoms, electrocardiogram changes, positive TnT test | 382 | 0.74 (95% CI, 0.60 to 0.88) | 0.31 (95% CI, 0.21 to 0.41)

ACS = acute coronary syndrome; CI = confidence interval; JACC = Journal of the American College of Cardiology; mcg/L = micrograms per liter; WHO = World Health Organization

Figure 4 Sensitivity and specificity of elevated troponin T in the diagnosis of acute coronary syndrome among patients with chronic kidney disease

Closed markers represent studies that adjudicated acute coronary syndrome, open markers represent studies that either did not adjudicate or did not report adjudicating acute coronary syndrome. Diamond markers indicate a troponin T cutoff of less than 0.1 mcg/L. Round markers indicate a troponin T cutoff of 0.1 mcg/L or higher.

* Indicates a dialysis population.

† Indicates a non-dialysis population.

‡ Indicates a mixed population

§ Does not specify if the population is on dialysis or not.

This figure is a scatter plot graph with specificity on the x axis and sensitivity on the y axis. Studies included: Chenevier-Gobeaux, 2013; Fehr, 2003; Haaf, 2013; Ikeda, 2002; Sukonthasarn, 2007; Pfortmueller, 2013. The Information presented shows adjudication of acute coronary syndrome and troponin cutoff level by varying the shapes, and opening or closing the markers. Footnotes indicate whether the population was on dialysis or not. The scale on x axis goes from 1 to 0 and on the y axis from 0 to 1. The points are clustered between 0.3 and 0.9 on the x axis and 0.7 and 1 on the y axis.

##### Troponin I

Eight studies examined the operating characteristics of the troponin I assay in their entire study population (Table 6).37, 40, 42, 44-47, 49 The cutoff values they used for the diagnosis of ACS differed (with some studies evaluating multiple different cutoffs). One study used a cutoff of 0.11 mcg/L,37 one study used 0.4 mcg/L,45 two studies used 0.5 mcg/L,37, 40 one study used 0.6 mcg/L,46one study used 1.0 mcg/L42 and two studies used 0.8 mcg/L.44, 47 One study used two cutoffs, 0.0063 mcg/L and 0.0099 mcg/L.49 The sample size of these studies ranged from 31 to 1,601.

The troponin I assays in these studies were of a variety of types from a range of manufacturers. Three studies used an assay from the same manufacturer, Beckman.37, 40, 49 Other studies used the manufacturers Vidas, Biosite, Baxter, Dade, DPC, and Siemens. One study did not report a manufacturer.44

One study46 that reported details of ACS adjudication, showed values of sensitivity and specificity, which did not appear to differ markedly from those of the other studies using troponin I; however, we can make no conclusions due to the heterogeneity of cutpoints.

The sensitivity in these studies ranged from 43 to 94 percent, and the specificity ranged from 48 to 100 percent (Figure 5).

Figure 5 Sensitivity and specificity of elevated troponin I in the diagnosis of acute coronary syndrome among patients with chronic kidney disease

Closed markers represent studies that adjudicated acute coronary syndrome, open markers represent studies that either did not adjudicate or did not report adjudicating acute coronary syndrome. Diamond markers indicate a troponin I cutoff of less than 0.1 mcg/L. Round markers indicate a troponin I cutoff between 0.1 mcg/L and 0.5 mcg/L. Square markers indicate a troponin I cutoff between 0.5 and 1.0 mcg/L. Triangular markers indicate a troponin I cutoff greater than or equal to 1.0 mcg/L.

* Indicates a dialysis population.

† Indicates a non-dialysis population.

‡ Indicates a mixed population

§ Does not specify if the population is on dialysis or not.

This figure is a scatter plot graph with specificity on the x axis and sensitivity on the y axis . Studies include: Martin, 1998; Bhagavan, 1998; Apple, 1999; Ikeda,2002; Flores, 2006, Flores-Solis, 2012; Fehr, 2003; Haaf, 2013.The Information presented shows adjudication of acute coronary syndrome and troponin cutoff level by varying the shapes, and opening or closing the markers. Footnotes indicate whether the population was on dialysis or not. The scale on x axis goes from 1 to 0 and on the y axis from 0 to 1. The points are clustered between 0.5 and 1 on the x axis and 0.4 and 0.94 on the y axis.

#### KQ 1.1.a Positive and Negative Predictive Values

##### Results

Five studies estimated the positive and negative predictive values for troponin I in the assessment of ACS in their entire study population.37, 40, 46, 47, 49 They used multiple cutoffs. One used 0.11 mcg/L,37 two used 0.5 mcg/L,37, 40 one used 0.6 mcg/L,46 one used 0.8 mcg/L,47 and one used two cutoffs, 0.0063 mcg/L and 0.0099 mcg/L. For troponin I in the diagnosis of ACS, the PPV ranged from 7 to 100 percent; the NPV ranged from 93 to 98 percent. Given the heterogeneity of the cutoffs and manufacturers used in these studies, it was not possible to identify a trend relating the cutoff value to NPV or PPV. We were unable to conduct a meta-analysis because the studies were insufficient in number, and thus cannot provide an aggregate estimate of PPV or NPV.

One study estimated the NPV or PPV of troponin T for the diagnosis of ACS for two subgroups41 (Table 7); two studies did so for the entire study population.48, 49 The PPV for troponin T ranged from 6 to 77 percent; the NPV ranged from 71 to 98 percent. In one study, the assay was associated with a greater PPV and NPV for the subgroup of patients with age less than 65 years.

Table 7 Operating characteristics of elevated troponin in the diagnosis of acute coronary syndrome among patients with chronic kidney disease

Author, Year | Troponin Assay | Cutoff (mcg/L) | PPV | NPV
Flores-Solis, 2012^37^ | Troponin I, Vidas | 0.1 | 40 | 95
Flores-Solis, 2012^37^ | Troponin I, Beckman | 0.5 | 50 | 93
Flores, 2006^40^ | Troponin I, Beckman Access AccuTnI | 0.5 | 51 (95% CI, 39 to 63) | 97 (95% CI, 95 to 98)
Bhagavan, 1998^46^ | Troponin I, manufacturer and assay not given | 0.6 | | 98
Martin, 1998^47^ | Troponin I, Dade International Stratus | 0.8 | 100 | 94
Haaf, 2013^49^ | High-sensitivity troponin I, Siemens | 0.0063 | 7 | 98
Haaf, 2013^49^ | High-sensitivity troponin I, Beckman Access | 0.0099 | 7 | 98
Noeller, 2003^41^ Age < 65 years | Troponin T, Roche-Boehringer-Mannheim CARDIAC-T ELISA | 0.1 | 77 | 78
Noeller, 2003^41^ Age > 65 years | Troponin T, Roche-Boehringer-Mannheim CARDIAC-T ELISA | 0.1 | 62 | 71
Chenevier-Gobeaux, 2013^48^ | High-sensitivity troponin T, Roche Elecsys | 0.014 | 37 (95% CI, 23 to 53) | 100 (95% CI, 96 to 100)
Chenevier-Gobeaux, 2013^48^ | High-sensitivity troponin T, Roche Elecsys | 0.0358 | 65 (95% CI, 43 to 83) | 98 (95% CI, 89 to 100)
Haaf, 2013^49^ | Troponin T, Roche Elecsys | 0.009 | 6 | 97
Haaf, 2013^49^ | High-sensitivity troponin T, Roche Elecsys | 0.0194 | 8 | 98

CI = confidence interval; mcg/L = micrograms per liter; NPV = negative predictive value; PPV = positive predictive value

#### KQ 1.1.b Change in Troponin Values Versus Single Troponin Elevation

##### Results

One study addressed this KQ, with a total sample size of 46.^38^ This study was performed in CKD patients in stages 3, 4, and 5, including nine patients on hemodialysis. The authors found that the magnitude of change in the troponin T assay in the first 24 hours after admission did not significantly differ between the control group and the group with ACS; neither did the rate of change from 0 to 6, or 6 to 12 hours after admission. While the rate of change from 0 to 24 hours after admission was greater in the group with ACS, there was great variability in this rate of change.

#### Strength of Evidence

The strength of evidence for the body of literature addressing KQ1.1, 1.1a, and 1.1b is explained in Tables 8 and 9.

Table 8 Elevated troponin T or I versus nonelevated troponin T or I in terms of diagnostic accuracy among patients with chronic kidney disease: Strength of evidence domains for KQ 1.1, 1.1a, and 1.1b

Comparison | Number of Studies (subjects) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Diagnostic accuracy of troponin T elevation | 6 (2,738) | Medium | Consistent | Direct | Imprecise | Low
Diagnostic accuracy of troponin I elevation | 8 (5,008) | Medium | Consistent | Direct | Imprecise | Low
Change in troponin T values | 1 (46) | High | NA (single study) | Direct | Imprecise | Insufficient

NA = not applicable

Table 9 Elevated troponin T or I versus nonelevated troponin T or I in terms of diagnostic accuracy among patients with chronic kidney disease: Details regarding strength of evidence domains

Outcome | Risk of Bias Details | Reasons for Downgrading Domains Comments About How Overall Strength of Evidence Derived
Diagnostic accuracy of troponin T elevation | 1 study poor quality, 5 fair quality, and 1 good quality | Some studies did not provide complete information on adjudication of outcomes, and assessors were generally not blinded to the results of troponin assays on adjudicating ACS diagnoses. Some results were imprecise.
Diagnostic accuracy of troponin I elevation | 4 studies poor quality, and 5 fair quality | One study did not report information on assay type and reported incomplete operating characteristics. Two studies provided no information on adjudication of ACS. Other studies did not provide complete information on adjudication of outcomes, and generally did not blind assessors to the results of troponin assays on adjudicating ACS diagnoses. Some results were imprecise.
Change in troponin T values | 1 study fair quality | There was one study of fair quality. The study was too small to provide precise estimates.

ACS = acute coronary syndrome

### KQ 1.2 Operating Characteristics of a Troponin Elevation by Subgroups

Key Points
- Although a few studies have looked at how age and CKD stage affect the operating characteristics of troponin, they are small, of poor quality, and use different cutoffs for different categories. Therefore we were unable to draw any conclusions.
- There were no studies of troponin operating characteristics for ACS diagnosis in CKD patients with regard to history of coronary artery disease, electrocardiogram abnormalities, other comorbidities, or race and ethnicity.

#### Results

Two studies reported the operating characteristics of elevated troponin in diagnosing ACS among subgroups of patients with CKD. These studies reported one or more of sensitivity, specificity, PPV, or NPV by subgroups of age or CKD.39, 41

While these studies both examined the operating characteristics of the troponin T assay, they did so using different values of age and creatinine in their subgroups; thus their results cannot be directly compared except to say that the operating characteristics of troponin T appeared to vary by age and creatinine level (Table 10). Another study reported values of the area under the curve for subgroups (Table 11).43

Table 10 Operating characteristics of elevated troponin in the diagnosis of acute coronary syndrome among subgroups of patients with chronic kidney disease

Author, Year | Subpopulation | Troponin Assay | Cutoff (mcg/L) | Sensitivity | Specificity | PPV | NPV
Alcalai, 2007^39^ | Age < 70 years and creatinine < 1.13 mg/dL | Troponin T | Any positive result | NR | NR | 78 (95% CI, 72 to 84) | NR
Alcalai, 2007^39^ | Age < 70 years and creatinine < 1.13 mg/dL | Troponin T | 0.1 to 1.0 | NR | NR | 73 (95% CI, 65 to 80) | NR
Alcalai, 2007^39^ | Age < 70 years and creatinine < 1.13 mg/dL | Troponin T | > 1.0 | NR | NR | 89 (95% CI, 79 to 95) | NR
Alcalai, 2007^39^ | Age < 70 years and creatinine > 1.13 mg/dL | Troponin T | Any positive result | NR | NR | 44 (95% CI, 35 to 55) | NR
Alcalai, 2007^39^ | Age < 70 years and creatinine > 1.13 mg/dL | Troponin T | 0.1 to 1.0 | NR | NR | 73 (95% CI, 65 to 80) | NR
Alcalai, 2007^39^ | Age < 70 years and creatinine > 1.13 mg/dL | Troponin T | > 1.0 | NR | NR | 59 (95% CI, 36 to 79) | NR
Alcalai, 2007^39^ | Age > 70 years and creatinine < 1.13 mg/dL | Troponin T | Any positive result | NR | NR | 52 (95% CI, 42 to 63) | NR
Alcalai, 2007^39^ | Age > 70 years and creatinine < 1.13 mg/dL | Troponin T | 0.1 to 1.0 | NR | NR | 42 (95% CI 31 to 54) | NR
Alcalai, 2007^39^ | Age > 70 years and creatinine < 1.13 mg/dL | Troponin T | > 1.0 | NR | NR | 90 (95% CI, 68 to 99) | NR
Alcalai, 2007^39^ | Age > 70 years and creatinine > 1.13 mg/dL | Troponin T | Any positive result | NR | NR | 37 (95% CI, 29 to 45) | NR
Alcalai, 2007^39^ | Age > 70 years and creatinine > 1.13 mg/dL | Troponin T | 0.1 to 1.0 | NR | NR | 73 (95% CI, 65 to 80) | NR
Alcalai, 2007^39^ | Age > 70 years and creatinine > 1.13 mg/dL | Troponin T | > 1.0 | NR | NR | 59 (95% CI, 43 to 73) | NR
Noeller, 2003^41^ | Age < 65 years | Troponin T | > 0.1 | 45 | 94 | 77 | 78
Noeller, 2003^41^ | Age > 65 years | Troponin T | > 0.1 | 44 | 83 | 62 | 71
Noeller, 2003^41^ | Age < 65 years, creatinine < 1.5 mg/dL | Troponin T | > 0.1 | 45 | 96 | 78 | 83
Noeller, 2003^41^ | Age > 65 years, creatinine < 1.5 mg/dL | Troponin T | > 0.1 | 41 | 89 | 69 | 71
Noeller, 2003^41^ | Age < 65 years, creatinine > 1.5 mg/dL | Troponin T | > 0.1 | 43 | 69 | 38 | 73
Noeller, 2003^41^ | Age > 65 years, creatinine > 1.5 mg/dL | Troponin T | > 0.1 | 52 | 66 | 48 | 69

CI = confidence interval; mcg/L = micrograms per liter; mg/dL = miligrams per deciliter; NPV = negative predictive value; NR = not reported; PPV = positive predictive value

Table 11 Area under the curve for elevated troponin in the diagnosis of acute coronary syndrome among subgroups of patients with chronic kidney disease

Author, Year | Creatinine clearance or ESRD | Troponin Assay | Cut point (mcg/L) | AUC
McCullough, 2002^43^ | >99.4 mL/min/72 kg | Troponin I, Biosite Incorporated | 0.4 | 1
McCullough, 2002^43^ | 99.3-72.7 mL/min/72 kg | Troponin I, Biosite Incorporated | 0.4 | 0.94 (SD 0.02)
McCullough, 2002^43^ | 72.8-47.0 mL/min/72 kg | Troponin I, Biosite Incorporated | 0.4 | 0.97 (SD 0.01)
McCullough, 2002^43^ | ESRD, on dialysis | Troponin I, Biosite Incorporated | 0.4 | 0.99 (SD 0 .01)

AUC = area under the curve; ESRD = end-stage renal disease; mcg/L = micrograms per liter; mL/min/72 kg = milliliters per minute per 72 kilograms; SD = standard deviation

Two of the studies reporting results for subgroups39, 43 reported details of ACS adjudication, in contrast to other studies in this KQ. However, we can draw no conclusions about the operating characteristics of troponin assays in these studies compared with others, owing to heterogeneity in the type of operating characteristics reported.

This literature did not report many other subgroup characteristics that might be relevant to understanding the operating characteristics of a troponin assay in diagnosing ACS, including history of coronary artery disease, presence or absence of ischemic or other electrocardiogram changes, diabetes or other comorbidities, or race or ethnicity.

#### Strength of Evidence

We described the strength of the evidence addressing KQ1.2 in Tables 12 and 13.

Table 12 Numbers of studies and subjects, strength of evidence domains, magnitude of effect, and strength of evidence for the operating characteristics of elevated troponin among subgroups of patients with chronic kidney disease

Comparison | Number of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Operating characteristics in subgroups | 3 | Medium | Inconsistent | Direct | Imprecise | Insufficient

Table 13 Elevated troponin T versus nonelevated troponin T in terms of diagnostic accuracy in subgroups of age and chronic kidney disease stage among patients with chronic kidney disease: Details regarding strength of evidence domains

Outcome | Risk of Bias Details | Reasons for Downgrading Domains Comments About How Overall Strength of Evidence Derived
Operating characteristics in subgroups | 3 studies fair quality | Studies did not provide complete information on adjudication of outcomes, and generally did not blind assessors to the results of troponin assays on adjudicating ACS diagnoses. Some results were imprecise. In addition, the direction of the relationship between the operating characteristics and subgroups of age and CKD stage was inconsistent.

ACS = acute coronary syndrome; CKD = chronic kidney disease

### KQ 1.3 Harms Associated with a False-Positive Diagnosis

#### Results

We found no studies addressing this KQ.

### KQ 1.4 Direct Comparisons Between Troponin Assays

#### Results

##### Troponin T Versus Troponin I

One study addressed this question.42 The troponin T, Roche Elecsys assay using a cutoff of 0.1 mcg/L, was associated with a 100 percent sensitivity for ACS and a 42 percent specificity. By contrast, the Troponin I, DPC Immulite assay, using a cutoff of 1.0 mcg/L, had a sensitivity of 45 percent and a specificity of 100 percent. Both troponin assays predicted an increased risk of ACS, with area under the curve ranging from 0.7 to 0.8. We found no studies performing direct comparisons between troponin assays from the same manufacturer or using the same cutoff for the assay to diagnose ACS.

##### Troponin T Versus High-Sensitivity Troponin T

We found no studies addressing this comparison.

##### Troponin I Versus High-Sensitivity Troponin I

We found no studies addressing this comparison.

#### Strength of Evidence

The strength of evidence for KQ1.4 is insufficient given that it is based on one study of poor quality that is indirect, imprecise, and lacks consistency (since it is a single study).

### KQ 1.5 Direct Comparisons of Troponin Testing in Patients with Chronic Kidney Disease Versus Patients with Normal Renal Function

#### Results

Although the studies reviewed in the previous section did include patients with normal renal function, we were not able to draw conclusions because of the size and quality of the studies. We found no studies that carried out direct a priori comparisons of troponin testing in patients with CKD versus patients with normal renal function.

## KQ 2 Management of Acute Coronary Syndrome by Troponin Levels

We did not find any study that directly addressed the question of whether troponin levels can affect management strategies in chronic kidney disease (CKD) patients with acute coronary syndrome (ACS) symptoms. We identified one study by Barthelemy et al. that did not directly address this question since the study did not treat patients according to troponin levels, but they reported on troponin levels.51 This study did not answer KQ 2 as we defined it, but we discussed it here since it is the only study found that addressed troponin levels and management options in CKD patients with ACS symptoms.

Barthelemy et al. included patients with non-ST elevation ACS (diagnosis based on symptoms, ECG changes, and elevated troponin) scheduled for percutaneous coronary intervention and divided them according to those with and without renal failure. The study randomized ACS patients presenting to the emergency department to receive immediate or next working-day invasive management. In patients with a creatinine clearance less than 60 mL/min (n = 75), the peak cardiac troponin I level during hospitalization was not significantly different between those receiving immediate or next-day ACS management (P = 0.36). The study did not present a composite outcome of death, acute myocardial infarction (MI), urgent revascularization, or recurrent ischemia at 1 month separately based on elevated cardiac troponin I in the reported results; however, the authors stated in the discussion that “there was no increase in MI as evaluated by troponin I release.”51

We did not identify any additional studies meeting the criteria for KQ2.

### KQ 2.1 Modification of a Troponin Elevation on Comparative Effectiveness of Interventions or Management Strategies for Acute Coronary Syndrome

Key Points
- The one study evaluating management of ACS in CKD patients did not find a significant difference in peak cardiac troponin I between the management groups (immediate vs. delayed invasive strategy) (strength of evidence: insufficient).

### KQ 2.2 Modification of a Troponin Elevation on Comparative Effectiveness of Interventions or Management Strategies for Acute Coronary Syndrome by Subgroups

Barthelemy et al. did not do any subgroup analysis.

## KQ 3 Short- and Long-Term Prognosis After Presentation with Acute Coronary Syndrome by Troponin Levels

### Study Design Characteristics

We found 12 unique studies in 14 publications assessing the value of troponin in establishing prognosis for patients with CKD who presented with signs/symptoms of suspected ACS.40, 52-64

These studies included seven prospective studies,54, 56, 58, 59, 62-64 four retrospective studies,40, 53, 57, 60 and three post hoc analyses52, 55, 61 of previously published large randomized controlled trials (RCTs). The studies were published between 1999 and 2012 and enrolled patients from 1994 to 2008 with followups ranging from 1 month to 2 years. Three of the studies did not report the dates of enrollment52, 56, 63 and four of the studies did not specify the length of followup.40, 53, 55, 59 Studies did not report relevant details of study design uniformly.

The studies originated from the United States (nine studies),52, 54-56, 58-60, 62, 64 Europe (two studies, one from Germany63 and one from Spain40), one from Canada,57 one from Asia (Singapore)53), and one was a multinational study that recruited patients from 24 countries.61 Six studies enrolled the patients from the hospital,52-55, 61, 62 four from the emergency department,56, 57, 60, 64 two from the coronary care unit,58, 59 one from the dialysis unit,63 and one from two outpatient clinics as well as patients from the emergency department and the intensive care unit40 (Tables 14 through 17).

Table 14 Study design characteristics of studies evaluating the short- or long-term prognosis of patients with chronic kidney disease after presentation of acute coronary syndrome by troponin T levels

Author, Year | Enrollment | Followup | Study Design | Setting | Inclusion Diagnosis | Outcomes Measured | Populations Compared
Chew, 2008^53^ Asia (Singapore) | 2002 - 2005 | NR | Retrospective cross sectional | Hospital | CKD + chest pain (unstable angina, STEMI, non-STEMI) | Death | Normal vs. abnormal Tn levels in CKD patients
Han, 2005^60^ U.S. | 1999 - 2003 | 6 months | Retrospective | ED | Patients presenting to the ED with chest pain | Cardiac events at 6 months (acute MI, unstable angina, revascularization, cardiac dysrhythmias, all-cause mortality, congestive heart failure exacerbation) | ACS vs. No ACS
Aviles, 2002^61^ Multinational | 1998 - 2000 | 1 month | Post hoc analysis sub study GUSTO IV | Hospital | Patients with high risk ACS with no revascularization | Death MI | Normal vs. abnormal CrCl with Normal vs. abnormal Tn levels

ACS = acute coronary syndrome; CKD = chronic kidney disease; CrCl = creatinine clearance; ED = emergency department; GUSTO IV = Global Use of Strategies to Open Occluded Coronary Arteries IV in Acute Coronary Syndromes; MI= myocardial infarction; STEMI = ST-elevation myocardial infarction; Tn = troponin; U.S. = United States

Table 15 Study design characteristics of studies evaluating the short- or long-term prognosis of patients with chronic kidney disease after presentation of acute coronary syndrome by troponin I levels

Author, Year | Enrollment | Followup | Study Design | Setting | Inclusion Diagnosis | Outcomes Measured | Populations Compared
Melloni, 2008^55^ U.S. | 2003 - 2005 | NR | Post hoc analysis sub-study CRUSADE | Hospital | Patients with high risk NSTE-ACS admitted for exclusion of MI | Short-term mortality | Normal vs. abnormal Tn levels
Flores, 2006^40^ Europe (Spain) | 2004 - 2004 | NR | Retrospective | ED-ICU- Outpatient | Patients with CKD and chest pain | Cardiac events (MI) Death | AMI vs. Angina vs. Other chest pain
Bueti, 2006^57^ | 2001 - 2002 | 1 month | Retrospective cohort | ED | Dialysis patients presenting to the ED with chest pain | MACE (cardiovascular death, MI, coronary revascularization, de novo congestive heart failure) within 30 days | Chest pain followup at 30 days
Kontos, 2008^54^ U.S. | 1996 - 2000 | 1 year | Prospective | Hospital | Patients with chest pain | 30 day and 1 year mortality | Cockcroft-Gault (C-G) vs. Modification of Diet in Renal Disease (MDRD) equation
Kontos, 2005^58^ U.S. | 1996 - 2000 | 1 year | Prospective | Hospital (CCU) | Patients with chest pain admitted for exclusion of MI | Cardiac mortality All-cause mortality Revascularization | Severe renal failure Moderate renal failure Normal renal function
Kontos, 2005^59^ U.S. | 1996 - 2000 | NR | Prospective | Hospital (CCU) | Patients with chest pain admitted for exclusion of MI | 30 day and 1 year: Cardiac mortality All-cause mortality | Severe renal failure Moderate renal failure Normal renal function
Gruberg, 2002^62^ U.S. | 1994 - 1999 | 1 year | Prospective | Hospital | CKD patients post PCI | In-hospital and 1 year: MI, Cardiac mortality All-cause mortality Repeat revascularization | Normal vs. abnormal Tn levels

ACS = acute coronary syndrome; CCU = critical care unit; CKD = chronic kidney disease; CrCl = creatinine clearance; CRUSADE = Can Rapid Risk Stratification of Unstable Angina Patients Suppress Adverse Outcomes with Early Implementation of the American College of Cardiology/American Heart Association Guidelines Initiative; ED = emergency department; ICU = intensive care unit; MACE = major adverse cardiovascular events; MI= myocardial infarction; NR = not reported; NSTE-ACS = non-ST-segment elevation acute coronary syndrome; PCI = percutaneous coronary intervention; Tn = troponin; U.S. = United States

Table 16 Study design characteristics of studies evaluating the short- or long-term prognosis of patients with chronic kidney disease after presentation of acute coronary syndrome by troponin T and I levels

Author, Year | Enrollment | Followup | Study Design | Setting | Inclusion Diagnosis | Outcomes Measured | Populations Compared
Apple, 2007^56^ U.S. | NR | 6 months | Prospective | ED | Patients presenting to the ED with symptoms suggestive of ACS | Cardiac events (MI) Death | Dade cTnI Roche cTnT Beckman cTnI Tosoh cTnI
Wayand, 2000^63^ Europe (Germany) | NR | 2 year | Prospective | Dialysis center | Dialysis patients | Cardiac events (MI) Death | ACS vs. No ACS
Van Lente, 1999^64^ U.S. | 1995 - 1997 | 6 months | Prospective | ED | CKD patients presenting to the ED with chest pain | In-hospital and 6 months: MI All-cause mortality Recurrent ischemia Revascularization/Bypass surgery Congestive heart failure Stroke | Troponin T and I in renal and nonrenal patients

ACS = acute coronary syndrome; CKD = chronic kidney disease; CrCl = creatinine clearance; ED = emergency department; MI= myocardial infarction; Tn = troponin; U.S. = United States

Table 17 Study design characteristics of studies evaluating the short- or long-term prognosis of patients with chronic kidney disease after presentation of acute coronary syndrome by unspecified troponin levels

Author, Year | Enrollment | Followup | Study Design | Setting | Inclusion Diagnosis | Outcomes Measured | Populations compared
Acharji, 2012^52^ U.S. | NR | 1 year | Post hoc analysis Substudy ACUITY | Hospital | CKD patients with ACS | MACE Death MI Revascularization Major bleeding | Positive vs. negative Tn

ACS = acute coronary syndrome; ACUITY = Acute Catheterization and Urgent Intervention Triage strategy; CKD = chronic kidney disease; MACE = major adverse cardiovascular events; MI= myocardial infarction; NR = not reported; Tn = troponin; U.S. = United States

### Study Population Characteristics

These 12 studies included 46,988 subjects and varied widely in size. Two studies included less than 100 patients,60, 63 six studies included between 100 and 1,000 patients,40, 53, 56, 57, 62, 64 five studies included between 1,000 and 10,000 patients,52, 54, 58, 59, 61 and one study included 31,586 patients.55

Three studies by Kontos et al.54, 58, 59 recruited patients during the same time period, in the same institution, and under the same protocol, but aimed to predict mortality in patients admitted for exclusion of myocardial ischemia in different ways; Cockcroft-Gault equation versus Modification of Diet in Renal Disease equation,54 specific short-term and long-term prognostic value of troponin I for patients with and without CKD,58 and short-term and long-term outcomes and prognostic value of multiple variables (troponin, ejection fraction, and renal function).59 Even if the total population for these studies is not the same, some of the patients may recur from study to study.

All the studies included patients older than 40 years, with means ranging between 56 and 71 and medians ranging between 63 and 80. All studies included similar proportions of men and women. One study included many more men (72 percent) than women62 and one study did not report gender of participants.63 Only five studies reported race.53-56, 60 Han et al.60 recruited 83 percent African Americans, Melloni et al.55 recruited 82 percent Whites, Apple et al.56 and Kontos et al.54 recruited a more balanced population, and Chew et al.53 recruited a prevalently Chinese population (Singapore).

We included studies with very heterogeneous baseline diagnosis, comparators, and aims. All studies had the presentation of suspected ACS at enrollment, but the definition of ACS varied among them. Apple et al., defined its patients only by the presence of clinical symptoms.56 While other studies required the presence of symptoms and ECG and enzymatic changes,53, 55, 59, 61, 64 two studies categorized the patients as low, moderate, or high risk ACS,52, 54 one based it on medical records,60 and five studies did not specify any criteria for diagnosis.40, 57, 58, 62, 63 Only three studies reported how the diagnosis was adjudicated52, 53, 64 and whether there was a cardiologist involved.53 Only 50 percent of studies reported presence of CAD, which ranged from 14 to 68 percent in those studies that did report this variable.40, 53, 54, 57, 60-62

All studies included patients with renal failure but again, the definition of renal failure varied amongst them. Seven studies defined renal failure as a creatinine clearance less than 60 mL/min,40, 52, 54-56, 58, 59 three studies used serum creatinine to set the cutoff,60, 62, 64 one study classified patients per quartiles of creatinine clearance,61 and three studies did not specify definition or cutoffs.53, 57, 63 Four studies used the Cockcroft-Gault equation to calculate glomerular filtration rate,52, 58, 59, 62 three studies used the Modification of Diet in Renal Disease equation,40, 55, 56 one used both since its purpose was to compare them,54 and six studies did not specify the equation used.53, 57, 60, 61, 63, 64 Three studies included patients in all renal failure stages including end-stage patients requiring dialysis.53, 55, 64 Two studies included patients in all renal failure stages but excluded patients on dialysis54, 62 and four studies included patients in all CKD stages and did not specify if dialysis patients were included or not.56, 58, 59, 166 Two studies included only dialysis patients,57, 63 one study included only patients with severe stage patients (including patients both in medical treatment and dialysis),60 and one study included only patients with moderate renal failure.52

Seven studies evaluated troponin I,40, 54, 55, 57-59, 62 three studies evaluated troponin T,53, 60, 61 and three studies evaluated both types of troponin assay.56, 63, 64 One study did not specify which troponin it measured (Table 18 and Table 19).52

Table 18 Study population characteristics of studies evaluating the short- or long-term prognosis of patients with chronic kidney disease after presentation of acute coronary syndrome by troponin levels

Author, Year | Patients Enrolled | Exclusion Criteria | Age (Years) | Male % | Race %
Acharji, 2012^52^ | 2179 | Patients with CrCl <30 mL/min | Median 76 | 53 | NR
Chew, 2008^53^ | 227 | NR | Median 66 | 54 | Chinese 75 Malay 23 Indian 2
Kontos, 2008^54^ | 4343 | STEMI, missing data (8-hour troponin, weight) | 58 | 51 | AA 64 W 36
Melloni, 2008^55^ | 31586 | Patients transferred, missing data (troponin and data needed to calculate eGFR) | Median 70 | 59 | W 82 Other 18
Apple, 2007^56^ | 510 | NR | 58 | 57 | W 48 AA 35 Native Am 8 Other 9
Flores, 2006^40^ | 467 | Patients transferred, missing data | Median 80 | 67 | NR
Bueti, 2006^57^ | 149 | NR | Median 63 | 49 | NR
Kontos, 2005^58^ | 3774 | ST-segment elevation that met criteria for fibrinolytic therapy, missing data (8-hour cardiac troponin I) | 58 | 50 | NR
Kontos, 2005^59^ | 3074 | ST-segment elevation, missing data (8-hour troponin I, ejection fraction) | 62 | 50 | NR
Han, 2005^60^ | 64 | Kidney transplant, trauma, terminal cancer | 56 | 52 | W 16 AA 83 Unknown 1
Aviles, 2002^61^ | 7033 | Early revascularization | 53% over age 65 years | 62 | NR
Gruberg, 2002^62^ | 116 | Patients on dialysis, baseline cardiac troponin I > 0.15 mcg/L, AMI within 72 hours (NSTEMI/STEMI) | 71 | 72 | NR
Wayand, 2000^63^ | 59 | NR | Range 40-77 | NR | NR
Van Lente, 1999^64^ | 255 | Cardiopulmonary resuscitation within 7 days, angiography or thrombolytic therapy within 3 weeks patients on vasopressors | 65 | 58 | NR

AA = African American; AMI = acute myocardial infarction; CrCl = creatinine clearance; eGFR = estimated glomerular filtration rate; mcg/L = micrograms per liter; Native Am = Native American; NR = not reported; NSTEMI = non-ST-segment elevation myocardial infarction; STEMI = ST-segment elevation myocardial infarction; W = White

Table 19 Definitions used to define cardiac and renal populations in studies evaluating the short- or long-term prognosis of patients with chronic kidney disease after presentation of acute coronary syndrome by troponin levels

Author, Year | ACS Diagnosis Parameters | ACS Diagnosis Adjudicated | % Population With Known CAD | CKD Definition | Formula Used for eGFR | CKD Stage Included /Dialysis | GFR Mean ml/min/m^2^
Acharji, 2012^52^ | Patients with moderate- and high-risk NSTE ACS | Panel adjudicated | NR | CrCl <60 ml/min | C-G | Included patients with and without impaired renal function CrCl 30-59 mL/min | 48.1
Chew, 2008^53^ | Symptoms, serial ECG, cardiac enzymes, and cardiac catheterization, or noninvasive cardiac imaging | Panel adjudicated with cardiologist | 63% | NR | NR | CKD patients Medical therapy (52%) Hemodialysis (32%) Peritoneal dialysis (16%) | NR
Kontos, 2008^54^ | High risk: Ischemic ECG changes or known coronary disease and typical symptoms Low risk: confirmed with markers and perfusion imaging | NR | 14-22% | eGFR <60 ml/min/1.73m^2^ | MDRD and C-G | All stages (No dialysis) Percentages vary depending of the formula used >60 ml/min/1.73m2 (73% C-G – 77% MDRD) 30-69 ml/min/1.73m2 (18% C-G – 15% MDRD) <30 ml/min/1.73m2 (8.9% C-G – 8.2% MDRD) | C-G 85 MDRD 82
Melloni, 2008^55^ | High-risk NSTE ACS: ACS Symptoms ST depression or elevation Positive cardiac markers | NR | NR | eGFR <60 ml/min/1.73m^2^ | MDRD | 1-2- eGFR >60 ml/min/1.73m2 (56%) 3- 30-60 ml/min/1.73m2 (32%) 4-5- <30 ml/min/1.73m2 (15%) Dialysis (2.8%) | NR
Apple, 2007^56^ | Clinical features considered indicative of ACS | NR | NR | eGFR<60 ml/min/1.73m^2^ | MDRD | eGFR ≥60 ml/min/1.73m2 (68%) 41-59 ml/min/1.73m2 (17%) ≤40 ml/min/1.73m2 (12%) | 77
Flores, 2006^40^ | Patients with ACS; 1. AMI; 2. Angina; 3. Other diagnosis | NR | 19% | eGFR <60 ml/min/1.73m^2^ | MDRD | eGFR <60 ml/min/1.73m2 30-59 (34%) 15-29 (50%) <15 (16%) | NR
Bueti, 2006^57^ | NR | NR | 43% | NR | NR | All dialysis patients | NR
Kontos, 2005^58^ | NR | NR | NR | CrCl <60 ml/min | C-G | CrCl >60 ml/min (71%) 30-59 (20%) <30 (8%) | NR
Kontos, 2005^59^ | ECG changes, known coronary disease with typical symptoms, or MPI with positive results | NR | NR | CrCl <60 ml/min | C-G | CrCl >60 ml/min (73%) 30-59 (19%) <30 (8%) | CrCl >60; 92 CrCl 30-59; 47 CrCl <30; 16
Han, 2005^60^ | Medical record and social security death index | NR | 40.6% | Serum creatinine >2.0 mg/dL | NR | CKD-Estimated CrCl <30 mL/min Medical therapy (60%) Hemodialysis (37%) Peritoneal dialysis (3%) | NR
Aviles, 2002^61^ | One or more episodes of angina, new ST-segment depression, abnormal result on a cardiac troponin | NR | Up to 68% (% given by features; MI-angina, previous interventions) | CrCl NS Patients grouped by quartiles | NR | Median CrCl 76 ml/min Severe <10 (11 patients) | 76 (median)
Gruberg, 2002^62^ | All patients post PCI—this was not exclusively an ACS population—could include patients with stable angina | NR | 100% | Serum creatinine ≥ 1.8 mg/dL | C-G | All stages but dialysis | NR
Wayand, 2000^63^ | ACS criteria not specified, Included patients with stable cardiac disease | NR | NR | NR | NR | All dialysis patients | NR
Van Lente, 1999^64^ | WHO criteria at least 2 of the following: chest pain, ECG changes or changes in CK and CK-MB | Single adjudicator | NR | Serum creatinine > 2 mg/dL | NR | Non CKD CKD all stages (9% in dialysis) | NR

ACS = acute coronary syndrome; AMI = acute myocardial infarction; CAD = coronary artery disease; C-G = Cockroft-Gault formula; CK = creatine kinase; CKD = chronic kidney disease; CK-MB = creatine kinase MB; CrCl = creatinine clearance; ECG = electrocardiogram; GFR = glomerular filtration rate; MDRD = Modification of Diet in Renal Disease; mL/min/m2 = millimeters per minute per meters squared; MPI = myocardial perfusion imaging; NR = not reported; NSTE ACS = non-ST-segment elevation acute coronary syndrome; PCI = percutaneous coronary intervention; WHO = World Health Organization

### Study Quality

The overall quality in the 14 studies evaluating the value of troponin in establishing prognosis for patients with renal failure who presented with signs/symptoms of suspected ACS was generally fair (three were good,52, 55, 57 eight were of fair quality,54, 56, 58-62, 64 and three were poor).40, 53, 63 All studies appropriately described their objective, interventions, outcomes and findings. Only one study did not describe the characteristics of the patients included.64 We felt that the included populations were representative of the general population in nine studies52, 55-58, 60-62, 64 and the setting (staff and facilities) was representative of a normal setting in eight studies.55, 57-59, 61-64 All the studies recruited their intervention groups from the same population and at the same time.

All the studies described the statistical methods used; none of the studies reported calculation of power (we found the power calculation for one study in the original RCT but not in the study we included52), seven studies reported on withdrawals,40, 57, 60-64 but all the studies took into account the losses to followup for the analyses. The authors described an adequate adjustment for confounding in the analyses in six studies,52, 55, 57, 58, 60, 64 only 21 percent of the studies (n=3)61, 63, 64 reported blinding the personnel who measured outcomes—43 percent (n=6)54-57, 59, 62 did not blind, and in 43 percent (n=6)40, 52, 53, 58, 60 blinding was not feasible due to the study design. Only one study did not do data dredging.62 All the studies reported accurate outcomes measures. Three studies did not report random variability estimates,40, 53, 55 and four studies did not report actual probability values.40, 54, 55, 60

In regard to funding, industry sponsored four studies52, 55, 61, 64 and government sponsored one.56 One study reported having no sponsorship57 and in eight studies this information was unclear.40, 53, 54, 58-60, 62, 63

### KQ 3.1 Troponin Associations With Long-Term and Short-Term Outcomes

Key Points
- Elevated troponin I or T were associated with higher risk of short-term mortality (<1 year) and cardiac outcomes (strength of evidence: low).
- A similar trend was observed for long-term mortality (≥1 year) with troponin I (strength of evidence: low), but less evidence was found for long-term cardiac events for troponin I and long-term outcomes for troponin T (strength of evidence: insufficient).
- Patients with advanced stages of CKD tend to have worse prognosis with elevated troponin I than those without elevation (strength of evidence: moderate).

#### All-Cause Mortality

##### Troponin T

Four studies evaluated all-cause mortality, following a presentation for suspected ACS, in the context of troponin T levels: one with a long-term followup period (greater than 1 year),63 one with an unreported followup period,53 and two with short-term followup periods (Table 20).52, 55 The long-term study and one short-term study used a troponin T cutoff of 0.1 mcg/L, while the others did not specify the upper limits of normal.

Table 20 Association of an elevated troponin T level with all-cause mortality among patients with chronic kidney disease presenting with symptoms of acute coronary syndrome

Author, Year | Troponin Manufacturer; Cutoff | Followup | n with Elevated Troponin | n (%) with Outcome (death) | n with Nonelevated Troponin | n (%) with Outcome (death) | Quality | Summary of Results
Chew, 2008^53^ | NR; 0.1 mcg/L | NR | 121 | NR | 106 | NR | Poor | P = 0.614
Wayand, 2000^*,63^ | Roche Enzymum; 0.1 mcg/L | 2 years | 9 | 3 (33.3%) | 19 | 1 (5.3%) | Poor | OR, 6.3; 95% CI, 0.6 to 69.7; P=0.13
Melloni 2008^55^ | NR 1, 2 and 3x ULN | In-hospital | NR | NR | NR | NR | Good | Incidence of death increased with severity of renal damage but relationship disappeared after adjustment
Acharji 2012^52^ | Unspecified troponin defined as positive or negative | 30 days 1 year | 1,291 | 60 (4.7%) 127 (10.7%) | 888 | 9 (1%) 51 (6.8%) | Good | P <0.0001 P =0.0005

CI = confidence interval; mcg/L = micrograms per liter; NR = Not reported; OR = odds ratio; ULN = upper limit of normal

* Not exclusively a population presenting with symptoms of acute coronary syndrome.

Wayand et al. conducted a small prospective cohort study that followed dialysis patients for 2 years and included 28 patients with myocardial discomfort or evidence of myocardial injury. The study analyzed both cardiac troponin T and I. Three patients with elevated cardiac troponin T values (>0.1 mcg/L) (n = 9) and one patient with a nonelevated cardiac troponin T died during followup (odds ratio [OR], 6.3; 95% confidence interval [CI], 0.6 to 69.7; P = 0.13). The study did not report the timing of these deaths.63

In the second study, Chew et al. found no significant difference in all-cause mortality between those with elevated (≥ 0.1 mcg/L) and nonelevated troponin T levels (P = 0.614). This was a retrospective study of 227 CKD patients with unstable angina pectoris, although the study did not report the number of patients in each group. Additionally, it did not give the duration of followup.53

The largest study of troponin T with an all-cause mortality outcome used data from an observational registry of patients admitted with ACS. A total of 13,843 patients had an estimated glomerular filtration rate less than 60 mL/min/1.73 m^2^ based on creatinine clearance. The study analyzed patients with mild CKD and normal kidney function jointly, so we did not consider data for stages 1 and 2 CKD for this review. Melloni et al. found an association between increases in troponin levels and death during initial hospitalization, though the study did not report the durations of hospital stays. The study grouped cardiac troponin T measurements by multiples of the assay's upper limits of normal. The study saw a trend toward death in those with higher troponin values assays. In those with an estimated GFR of 30-60 mL/min/1.73m^2^, the study saw mortality in 3.7, 5.3, and 7.3 percent of those with a troponin T value less than 1, 1 to 3, and greater than 3 times the upper limit of normal, respectively. For those with more severe CKD, these percentages were 7, 5.7, and 14 percent, respectively. However, after adjustment, troponin T elevation did not remain a significant predictor of mortality.55

Acharji et al. evaluated both cardiac troponin T and I, but did not distinguish between the two in the results or analysis, and therefore we did not include it in the strength of evidence analysis. This was a post hoc analysis of a large RCT reporting all-cause mortality in patients that had troponin measured prior to undergoing cardiac catheterization and revascularization after presenting with ACS. They analyzed data from the subjects in the RCT who had both CKD and baseline troponin T or I levels. The study did not list cutoff values for an elevated versus nonelevated test. They evaluated all-cause mortality at both 30 days and 1 year after presentation with ACS. Death within 30 days occurred in 4.7 percent (n = 60) of those with an elevated troponin versus only 1.0 percent (n = 9) with a non-elevated troponin (P < 0.0001). Similarly, 10.7 percent (n = 127) of those with an elevated troponin were dead at 1 year compared with 6.8 percent (n = 51) of those with non-elevated troponins (P = 0.0005). The study did not perform adjustment for this individual outcome.52

##### Troponin I

Seven studies investigated cardiac troponin I with an outcome of all-cause mortality.52, 54, 55, 58, 59, 62, 63 Because of overlap in patient cohorts and populations that were not exclusively ACS patients, we could not perform a pooled analysis (Table 21). The troponin I cutoff values ranged from 0.15 mcg/L to 1 mcg/L; two studies did not report a threshold.

Table 21 Association of an elevated troponin I level with all-cause mortality among patients with chronic kidney disease presenting with symptoms of acute coronary syndrome

Author, Year | Troponin Manufacturer; Cutoff | Followup | n with Elevated Troponin | n (%) with Outcome (death) | n with Nonelevated Troponin | n (%) with Outcome (death) | Quality | Summary of Results
Wayand, 2000^*,63^ | Dade Stratus; 0.4 mcg/L | 2 years | 14 | 4 (28.6%) | 14 | 0 (0%) | Poor | OR, 9.0; 95% CI, 0.4 to 182.8; P = 0.15
Melloni, 2008^55^ | NR; 3 x ULN | In-hospital | NR | NR | NR | NR | Good | Incidence of death increased with severity of renal damage but after adjustment was significant only for moderate CKD and TnI 3XULN OR, 1.8; 95% CI, 1.3 to 2.5 (adjusted)
Gruberg, 2002^*,62^ | Beckman Chemiluscent; 0.15 mcg/L | 1 year | 50 | 14 | 66 | 7 | Fair | OR, 2.3; 95% CI, 1.1 to 4.8, adjusted for age, diabetes, CAD
Kontos, 2005a58 | Behring Opus Magnum and Bayer ImmunoOne; 1.0 mcg/L | 1 year | 494 | 62 (12.6%) | 2951 | 200 (6.8%) | Fair | OR, 1.9; 95% CI, 1.4 to 2.5; P = 0.0001
Acharji 2012^52^ | Unspecified troponin Defined as positive or negative | 30 days 1 year | 1291 | 60 (4.7%) 127 (10.7%) | 888 | 9 (1%) 51 (6.8%) | Good | P <0.0001 P =0.0005

CAD = coronary artery disease; CI = confidence interval; CKD = chronic kidney disease; mcg/L = micrograms per liter; NR = Not reported; OR = odds ratio; ULN = upper limit of normal

* Not exclusively a population presenting with symptoms of acute coronary syndrome.

The only study we identified that reported on troponin I with a long-term outcome was the same study identified for troponin T that we described above. Out of a total of 28 patients, 14 had elevated cardiac troponin I values (≥ 0.4 mcg/L), and four of these patients died, whereas no patients with non-elevated cardiac troponin I died (OR, 9.0; 95% CI, 0.44 to 182.8; P = 0.15).63

A large study by Melloni et al., that used both troponin T and I (described above), grouped troponin values by multiples of the upper limit of normal, but do not specify the number of patients studied for each marker. After adjusting for patient characteristics and clinical factors, the only remaining significant association they found was between in-hospital mortality and elevated troponin I greater than 3-times the upper limit of normal in patients with an estimated GFR of 30-60 mL/min/1.73m^2^ (OR, 1.8; 95% CI, 1.3 to 2.5).55

Kontos et al. evaluated all-cause mortality in patients admitted to a large hospital after presenting to the emergency department with chest pain. This included 1,084 patients with creatinine clearance less than 60 mL/min; however, those with mild kidney dysfunction (creatinine clearance greater than 60 mL/min) and patients with normal kidney function were analyzed as a single group and therefore not appropriate for evaluation in this review. A significantly larger number of patients with creatinine clearance less than 60 mL/min who presented with elevated troponin levels died within 1 year, (12.6 percent) compared with those with non-elevated troponin I levels (6.8 percent; OR, 1.9; 95% CI, 1.4 to 2.5; P = 0.0001). Notably, this population excluded patients with ST elevation acute MI and was not exclusively ACS, as it may have included those with stable angina.58

Two additional studies by the same author meeting inclusion criteria for this review also included all-cause mortality as an outcome in ACS patients with CKD.54, 59

Acharji et al. evaluated both cardiac troponin T and I, but did not distinguish between the two in the results or analysis. We described the results above.52

#### Major Adverse Cardiovascular Events

##### Troponin T

In addition to the outcome of all-cause mortality, we also considered composite cardiac mortality, acute MI, cardiac ischemia, revascularization, dysrhythmia, and congestive heart failure exacerbation, as well as various composites of these endpoints. We did not identify any studies of cardiac troponin T that met inclusion criteria and evaluated MACE with a followup period of greater than 1 year.

We identified four studies of troponin T using short-term MACE outcomes following a presentation of suspected ACS (Table 22).52, 56, 60, 61 Troponin T cutoff values ranged from 0.01 mcg/L to 0.1 mcg/L. One report justified using a 0.1 mcg/L threshold by noting that the 99^th^ percentile in the reference population was below the lower limit of detection of 0.01 mcg/L.61

Table 22 Association of elevated troponin T with major adverse cardiac events among patients with chronic kidney disease presenting with symptoms of acute coronary syndrome

Author, Year | Troponin Manufacturer; Cutoff | Outcome | Followup | n with Elevated Troponin | n (%) with Outcome | n with Nonelevated Troponin | n (%) with Outcome | Quality | Summary of Results
Apple, 2007^56^ | Roche Elecsys; 0.01 mcg/L | Death or MI | 6 months | 69 | 18 (26.1%) | 66 | 7 (10.6%) | Fair | OR, 2.5, 95% CI, 1.0 to 6.3; P = 0.06
Aviles, 2002^61^ | Roche Elecsys; 0.1 mcg/L | Death or MI | 30 days | 2715 | 338 (12.4%) | 2583 | 177 (6.9%) | Fair | By quartile of CrCl: 1^st^; OR, 2.5; 95% CI, 1.8 to 3.3; 2^nd^; OR, 1.8; 95% CI, 1.3 to 2.6; 3^rd^; OR, 1.4; 95% CI, 0.9 to 2.1; 4^th^; OR, 2.3, 95% CI, 1.3 to 4.1; adjusted for sex, age, CAD
Han, 2005^60^ | Roche Elecsys; 0.1 mcg/L | MI, Angina, Revascularization, cardiac disrrhythmia, death | In-Hospital 30 days 6 months | NR | NR | NR | NR | Fair | AUC for changes in TnT and ACE at timepoints 0.63 (95% CI 0.48-0.78), 0.58 (95% CI 0.43-0.73) 0.60 (95% CI0.45-0.74)
Acharji, 2012^52^ | Unspecified troponin, defined as positive or negative | Cardiac death, MI Revascularization, | 30 days 1 year 30 days 1 year 30 days 1 year | 1291 | 51 (4.0%) 79 (6.8%) 106 (8.3%) 165 (13.3%) 45 (3.6%) 117 (10.0%) | 888 | 6 (0.7%) 23 (2.7%) 44 (5.0%) 63 (7.3%) 25 (2.8%) 89 (11.2%) | Good | P <0.0001 P =0.0001 P =0.003 P <0.0001 P =0.33 P =0.65

CI = confidence interval; CrCl = creatinine clearance; mcg/L = micrograms per liter; MI = myocardial infarction; NR = not reported; OR = odds ratio; TnT = troponin T

A post hoc analysis of an RCT with a composite outcome of 30-day acute MI or death found significant differences between patients with elevated and nonelevated troponin T. This study included patients with and without kidney dysfunction and presented results by quartile of creatinine clearance. There was a higher percentage of events in those with an elevated versus nonelevated troponin T when using a cutoff value of either 0.1 mcg/L (12.4 percent vs. 6.9 percent, respectively) or 0.03 mcg/L (12.2 percent vs. 5.3 percent). We presented results of the higher cutoff in Table 22. The results of the first two quartiles were significant after adjusting for sex, older age, ST-segment depression, and a history of angina, acute MI, stroke, diabetes, bypass surgery, and angioplasty. We provide an analysis of the quartiles separately below.61

Apple et al. reported a 6-month composite outcome of acute MI or death in 135 CKD patients with estimated glomerular filtration rates of less than 60 mL/min/1.73m^2^. The difference in event rate in those with elevated versus nonelevated troponin T was not statistically significant. (OR, 2.5; 95% CI, 1.0 to 6.3; P = 0.06).56

The study by Acharji et al. (described above) presented several outcomes for patients with measured troponin T or I, although the analysis did not distinguished the type of troponin. These outcomes included rate of cardiac death, which was significantly higher in the elevated troponin group than in the nonelevated troponin group at 30 days (P < 0.001) and 1 year (P = 0.0001). At both 30 days and 1 year, rates of ischemia and acute MI were higher in those with elevated troponin values than non-elevated troponin values (P < 0.05 for both). Differences in rates of unplanned revascularization were not significant. The only outcome presented as adjusted data was composite death or acute MI. Death or MI remained statistically significant after adjusting for baseline clinical characteristics and ECG and laboratory findings. This was true at 30 days (HR, 2.1; 95% CI, 1.5 to 2.8; P < 0.0001) and 1 year (HR, 1.7; 95% CI, 1.4 to 2.2; P < 0.0001).52

A study of 90 CKD patients presenting to the emergency department with symptoms of ACS by Han et al. used a composite endpoint of acute MI, unstable angina, revascularization, cardiac dysrhythmias, all-cause mortality, or congestive heart failure exacerbation. Using receiver operating curve analysis, the authors found that an increase in troponin T of 0.11 mcg/L compared with a prior non-ACS measure had a sensitivity of 27 percent and a specificity of 96 percent for the composite outcome at 6 months (positive likelihood ratio 7.2). The study did not provide the rate of events in groups with and without an elevated troponin T.60

##### Troponin I

Three of the studies reporting on short-term MACE outcomes for troponin I by the same author included substantial overlap in patient populations;54, 58, 59 therefore, we presented the most relevant results here. We identified five additional studies of troponin I.40, 52, 56, 57, 62 These included a wide range of troponin I cutoff values, from 0.0001 mcg/L to 1 mcg/L, although one study did not specify the threshold used (Table 23).

Table 23 Association of an elevated troponin I level with major adverse cardiac events among patients with chronic kidney disease presenting with symptoms of acute coronary syndrome

Author, Year | Troponin Manufacturer; Cutoff | Outcome | Followup | n with Elevated Troponin | n (%) with Outcome | n with Nonelevated Troponin | n (%) with Outcome | Quality | Summary of Results
Apple, 2007^56^ | Dade Dimension; 0.06 mcg/L | Death or MI | 6 months | 41 | 14 (34.1%) | 113 | 13 (11.5%) | Fair | OR, 3.0, 95% CI, 1.3 to 6.8, P = 0.01
Apple, 2007^56^ | Beckman Access; 0.1 mcg/L male, 0.04 mcg/L female | Death or MI | 6 months | 31 | 12 (38.7%) | 107 | 14 (13.1%) | Fair | OR, 3.0; 95% CI, 1.2 to 7.1, P = 0.01
Apple, 2007^56^ | Tosoh AIA; 0.07 mcg/L males, 0.06 females | Death or MI | 6 months | 35 | 10 (28.6%) | 63 | 5 (7.9%) | Fair | OR, 3.6; 95% CI, 1.1 to 11.4; P = 0.03
Bueti, 2006^57^ | Bayer ImmunoOne; 0.0001 mcg/L | Cardiac death, MI, revascularization, de novo CHF | 30 days | NR | NR | NR | NR | Good | OR, 15.2; 95% CI, 5.3 to 43.6
Flores, 2006^40^ | Beckman Access; 0.05 mcg/L | MI | In-hospital | 233 | 47 (20.2%) | 234 | 0 (0%) | Poor | OR, 95.4; 95% CI, 5.9 to 1556.9; P = 0.001
Kontos, 2005a58 | Behring Opus Magnum 1.0 mcg/L and Bayer ImmunoOne; 0.3 mcg/L | Cardiac mortality | 1 year | 494 | 46 (9.3%) | 2951 | 95 (3.2%) | Fair | OR, 2.9; 95% CI, 2.0 to 4.2; P < 0.0001
Gruberg, 2002^*,62^ | Beckman Chemiluscent; 0.15 mcg/L | Death, MI, or revascularization | 1 year | 50 | 20 | 66 | 20 | Fair | P = 0.16
Acharji, 2012^52^ Unspecified cTn | NR, defined as positive or negative | Cardiac death MI Revascularization | 30 days 1 year 30 days 1 year 30 days 1 year | 1291 | 51 (4.0%) 79 (6.8%) 106 (8.3%) 165 (13.3%) 45 (3.6%) 117 (10.0%) | 888 | 6 (0.7%) 23 (2.7%) 44 (5.0%) 63 (7.3%) 25 (2.8%) 89 (11.2%) | Good | P <0.0001 P =0.0001 P =0.003 P <0.0001 P =0.33 P =0.65

CHF = congestive heart failure; CI = confidence interval; mcg/L = micrograms per liter; MI = myocardial infarction; NR = not reported; OR = odds ratio

* Not exclusively a population presenting with symptoms of acute coronary syndrome.

Apple et al. reported a 6-month composite outcome of acute MI or death in CKD patients with estimated glomerular filtration rates less than 60 mL/min/1.73m^2^ for three troponin I assays. All assays resulted in a statistically significant higher event rate in those with elevated troponin levels (Dade: OR, 3.0; 95% CI, 1.3 to 6.8, P = 0.01; Beckman: OR, 3.0; 95% CI, 1.2 to 7.1, P = 0.01; Tosoh: OR, 3.6; 95% CI, 1.1 to 11.4; P = 0.03); however, there was some variation between assays. In the Tosoh and Beckman studies, respectively, event rates ranged from 9.6 to 15.6 percent in those with non-elevated troponin levels, and from 34.4 to 42.6 percent in those with elevated troponin values.56

Kontos et al. recruited patients who presented to an emergency department with chest pain, although the study excluded those with ST-segment elevation. The study defined cardiac death as death caused by acute MI, CAD, or arrhythmia. In 1,084 patients with creatinine clearance less than 60 mL/min, there were significantly fewer cardiac deaths in those with non-elevated troponin I levels (3.2%) than in those with elevated troponin I levels (9.3%).58

Flores et al. presented results of a retrospective study of 467 patients with creatinine clearance less than 60 mL/min and with suspected myocardial injury. They found an increased incidence of acute MI as primary diagnosis on discharge in those with troponin I between 0.05 and 0.5 mcg/L (8.3 percent, n = 14) and over 0.5 mcg/L (50.8 percent, n = 33) compared with those with a non-elevated troponin I (n = 0).40

A study of 149 chronic dialysis patients used a composite endpoint that included cardiac death, acute MI, revascularization, or de novo congestive heart failure within 30 days of presentation. Bueti et al. found that a troponin I greater than 0.0001 mcg/L had a strong association with the outcome (OR, 15.2; 95% CI, 5.3 to 43.6; P = 0.0000004). This remained strongly significant when adjusting separately for sex, blood pressure, and prior cardiovascular disease. This study included patients presenting to the emergency department for any reason who had a troponin I value recorded: 29 percent presented with chest pain and 20 percent presented with symptoms that were noted to be clearly non-cardiac. The association between clinical presentation and troponin I was not significant (P = 0.7), suggesting that the ability of troponin I to predict the outcome was similar in those presenting with cardiac and non-cardiac complaints.57

Although Gruberg et al. found 1-year all-cause mortality different between those with elevated versus non-elevated troponin I (as described above), there were no significant differences between troponin I groups for 1-year acute MI (P = 0.06), revascularization (P = 0.88), or composite MACE (death, acute MI, or revascularization) (P = 0.16).62

We presented results above of a study by Acharji et al., which did not distinguish between troponin T and I values.52

##### Strength of Evidence

We list the strength of evidence for the body of literature addressing KQ3.1 in Tables 24 and 25.

Table 24 Association of elevated troponin T or I versus nonelevated troponin T or I in terms of prognosis after acute coronary syndrome among patients with chronic kidney disease: Strength of evidence domains

Outcome | Troponin Assay | Number of Studies | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Strength of Evidence
All-cause mortality (≥ 1 year) | Troponin T | 1 | High | NA (single study) | Direct | Imprecise | OR 6.3 | Insufficient
All-cause mortality (≥ 1 year) | Troponin I | 3 | Medium | Consistent | Indirect | Precise | OR range 1.9 to 9.0 | Low
All-cause mortality (< 1 year) | Troponin T | 1 | Low | NA (single study) | Direct | Imprecise | NA | Low
All-cause mortality (< 1 year) | Troponin I | 1 | Low | NA (single study) | Direct | Precise | OR 1.8 | Low
MACE (≥1 year) | Troponin I | 2 | Medium | Inconsistent | Direct | Imprecise | OR 2.9 1 study NR | Insufficient
MACE (< 1 year) | Troponin T | 3 | Medium | Consistent | Direct | Imprecise | OR range 1.4 to 2.5 AUC 0.60 | Low
MACE (<1 year) | Troponin I | 3 | Medium | Consistent | Direct | Imprecise | OR range 3.6 to 95 | Low

AUC = area under the curve; HR = hazard ratio; MACE = major adverse cardiac event; NA = not applicable; NR = not reported; OR = odds ratio

Table 25 Association of elevated troponin T or I versus nonelevated troponin T or I in terms of prognosis after acute coronary syndrome among patients with chronic kidney disease: Details regarding strength of evidence domains

Outcome | Troponin Assay | Study Design | Risk of Bias Details | Reasons for Downgrading Domains- Comments About How Overall Strength of Evidence Derived
All-cause mortality (≥ 1 year) | Troponin T | Prospective cohort | 1 observational study of poor quality that was not adjusted for confounders | We were unable to draw conclusions based on one study with poor description of patient characteristics and imprecise estimates.
All-cause mortality (≥ 1 year) | Troponin I | Prospective cohorts | 3 observational studies, 1 of poor quality and 2 with fair quality, only 1 study adjusted for confounders | All the studies suggested an increased risk of mortality associated with elevated troponin, although one of the studies did not meet statistical significance. However, the results are indirect because two studies included asymptomatic patients.
All-cause mortality (< 1 year) | Troponin T and Troponin I | Prospective cohort | 1 observational study of good quality that adjusted for confounders, number with elevated values in each group not reported | The study suggested Troponin T and I were both associated with in-hospital mortality but the association disappeared when adjusted to confounders.
MACE (≥1 year) | Troponin I | 2 prospective | 2 studies of fair quality, 1 adjusted for confounders. | The results were inconsistent and imprecise. One study found significant results for TnI and the other found no significant difference.
MACE (< 1 year) | Troponin T | 1 prospective, 1 post hoc and 1 retrospective | 3 observational studies of fair quality, 1 study adjusted for confounders, another study blinded outcome assessors | Differences in study design limit our ability to combine data. Effect estimates suggested an association, but were imprecise with wide confidence intervals crossing 1.
MACE (<1 year) | Troponin I | 1 prospective, and 2 retrospective | 3 observational studies of fair quality, 1 study adjusted for confounders | Effect estimates consistently suggested an association, but were imprecise with wide confidence intervals crossing 1.

ACS = acute coronary syndrome; CKD = chronic kidney disease; MACE = major adverse cardiac events; OR = odds ratio; TnI = troponin I; TnT = troponin T

### KQ 3.2 Troponin Associations with Long-Term and Short-Term Outcomes by Subgroups

Key Points
- Patients with more advanced stages of CKD and elevated troponin I seem to be at higher risk of adverse outcomes than those with nonelevated troponin I (strength of evidence: moderate).
- Elevated troponin was associated with a higher risk of adverse cardiac outcome in dialysis patients with ACS compared with normal troponin levels, although the quality and heterogeneity of study designs limits the strength of this finding (strength of evidence: low).
- We did not find any studies that reported on the ability of elevated troponin to estimate prognosis after ACS in subgroups of CKD patients based on sex, age, status after renal transplant, presence of previously elevated troponin, ECG changes, comorbidities, smoking status, 10-year CAD risk, or history of CAD (strength of evidence: insufficient).

#### Results

The only subgroups presented in the studies meeting criteria for KQ3 were extent of kidney disease and utilization of dialysis.

##### Stage of Chronic Kidney Disease or Creatinine Clearance

###### Troponin T

Aviles et al. presented their study results by quartile of creatinine clearance, rather than standard stage of CKD. The authors found a significantly higher rate of death or MI in those with a troponin T greater than 0.1 mcg/L in creatinine clearance groups less than 58.4 mL/min and 58.4 to 76.9 mL/min (P < 0.001 for both). The difference for creatinine clearance 77.0 to 98.6 mL/min was insignificant (P = 0.16); however, this result became significant when they used a lower troponin T cutoff value of 0.03 mcg/L for analysis (P < 0.001).61

Melloni et al. did not find a significant difference in in-hospital mortality between those with elevated and nonelevated troponin T based on the hospital's upper limit of normal value when they considered stages of CKD separately.55

In a post hoc analysis of an RCT, Acharji et al. considered patients with creatinine clearance less than 30 mL/min separately from those with creatinine clearance 30 to 60 mL/min. Types of troponin included both T and I (threshold not specified) but they did not distinguish between the two in the analysis. The only statistically significant difference in outcomes between troponin groups that the study saw were in the creatinine clearance 30 to 60 mL/min subgroup. These included all-cause mortality, cardiac death, acute MI, and composite death or acute MI (P ≤ 0.001 for all) at both 30 days and 1 year.52

###### Troponin I

In their large analysis of registry data, Melloni et al. grouped patients by estimated glomerular filtration calculated via the Modification of Diet in Renal Failure method. After adjusting for patient characteristics and other factors known to be associated with in-hospital mortality, the only association that remained statistically significant was death in stage 3 CKD patients with elevated troponin I at more than 3-times the hospital-specified upper limit of normal (OR, 1.8; 95% CI, 1.3 to 2.5; P < 0.0012). They did not report ORs for insignificant adjusted analyses.55

One multivariate analysis, Kontos et al., that adjusted for age, sex, hypertension, prior revascularization or acute MI, left ventricular hypertrophy, and ischemic ECG changes, reported that an elevated troponin I (>1 mcg/L for Opus assay and >0.3 mcg/L for Bayer assay) was a predictor of 1-year all-cause mortality in patients with creatinine clearance 30 to 60 mL/min (HR, 1.7; 95% CI, 1.1 to 2.6) and creatinine clearance less than 30 mL/min (HR, 3.0; 95% CI, 1.8 to 5.0). Additionally, elevated troponin I was a predictor of 1-year cardiac mortality in patients with creatinine clearance 30 to 60 mL/min (HR, 2.2; 95% CI, 1.3 to 3.8) and with creatinine clearance less than 30 mL/min (HR, 3.3; 95% CI, 1.8 to 6.1). Thirty-day all-cause mortality was higher in those with an elevated versus nonelevated troponin I by CKD subgroup (10 vs. 3.8 percent in those with creatinine clearance 30 to 60 mL/min and 26 vs. 9.7 percent in those with creatinine clearance less than 30 mL/min).58

We presented the results of a CKD subgroup analysis for a study considering troponins T and I jointly above.52

##### Dialysis Status

Melloni et al. analyzed a nondialysis subgroup from a large cohort of CKD patients and did not demonstrate a significant difference from the results for the entire population of CKD patients. The study saw a trend toward death in those with higher troponin values for both troponin T and I in those with CKD not undergoing dialysis.55

Two studies only included those undergoing chronic dialysis (described above), and these have limitations.57, 63 The former was a small cohort of 28 patients and, although it reported long-term mortality as an outcome, it did not report timing of patient deaths. The latter study found an elevated troponin I had a strong association with a composite 30-day outcome including cardiac death, acute MI, revascularization, or de novo congestive heart failure (OR, 15.2; 95 percent CI, 5.3 to 43.6; P = 0.0000004). Limitations of this study included a low cutoff value for elevated troponin I (0.0001 mcg/L) and that it included all dialysis patients presenting to the emergency department (i.e., not strictly an ACS population).

#### Strength of Evidence

We listed the strength of evidence for the body of literature addressing KQ3.2 in Tables 26 and 27.

Table 26 Association of elevated troponin T or I versus nonelevated troponin T or I in terms of prognosis after acute coronary syndrome by subgroups of patients with chronic kidney disease: Strength of evidence domains^*^

Subgroup | Troponin Assay | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Strength of Evidence
Stage of CKD or creatinine clearance | Troponin T | 2 (40798)55, 61 | Medium | Inconsistent | Direct | Imprecise | OR Not given | Insufficient
Stage of CKD or creatinine clearance | Troponin I | 2 (37539)55, 58 | Medium | Consistent | Direct | Precise | OR 1.8 HR range 1.7 to 3.0 | Moderate
Dialysis status | Troponin T or I | 3 (31794)55, 57, 63 | Medium | Consistent | Indirect | Precise | OR range 1.8 to 15.2 | Low

CKD = chronic kidney disease; HR = hazards ratio; OR = odds ratio.

* None of the studies included high-sensitivity troponin T or I

Table 27 Association of elevated troponin T or I versus nonelevated troponin T or I in terms of prognosis after acute coronary syndrome by subgroups of patients with chronic kidney disease: Details regarding strength of evidence domains^*^

Outcome | Troponin Assay | Study Design | Risk of Bias Details | Reasons for Downgrading Domains- Comments About How Overall Strength of Evidence Derived
Stage of CKD or creatinine clearance | Troponin T | 2 post hoc analyses | 2 observational studies, 1 of fair and 1 of good quality | The effect of association was inconsistent and imprecise. One study did not find an association, while the other one found an association when using a higher cutoff. Magnitude of effect was not given as OR or HR in any study.
Stage of CKD or creatinine clearance | Troponin I | 1 post hoc and 1 prospective | 2 observational studies, 1 of fair and 1 of good quality | Effect estimates were consistent, direct, and precise for an association of troponin with the outcome. While one of the studies found the association in all stages, the other one found it only for severe CKD.
Dialysis status | Troponin T or I | 1 post hoc, 1 prospective, 1 retrospective | 3 observational studies, 1 of poor and 2 of good quality | One study included only nondialysis patients while the other two studies included dialysis patients only. Effect estimates consistently and precisely suggested an association of Tn with the outcome, but directness is lost due to inclusion of non-ACS patients in one of the studies.

ACS = acute coronary syndrome; CKD = chronic kidney disease; CrCl = creatinine clearance; HR = hazards ratio; OR = odds ratio; TnI = troponin I; TnT = troponin T

* None of the studies included high-sensitivity troponin T or I

### KQ 3.3 Direct Comparisons Between Troponin Assays to Estimate Prognosis After Acute Coronary Syndrome

Key Points
- We are unable to determine if there is a difference in the performance of troponin assays to estimate prognosis after ACS in patients with kidney disease based on three very heterogeneous studies with indirect and imprecise estimates (strength of evidence: insufficient).
- We did not identify any studies that included high sensitivity troponin I or T.

#### Results

##### Troponin T Versus Troponin I

Two studies directly compared troponin T and I by measuring performance in the prediction of composite cardiac ischemic endpoints; however they used different cutoff values and there were differences in the cardiac events comprising the outcome (Table 28).63, 64 From these results, it is difficult to determine the extent to which differences in predicting prognosis are due to the type of troponin or to the cutoff the studies used. One of these studies also compared receiver operating curve characteristics and found the difference between the area under the curve for troponin T and I to be insignificant (P = 0.213).63

Table 28 Results from studies directly comparing troponin T with troponin I to estimate prognosis after acute coronary syndrome

Troponin T Cutoff | Sensitivity | Specificity
0.01^*^ | 57% | 88%
0.02^†^ | 75% | 44%
0.10^†^ | 45% | 72%
Troponin I Cutoff | Sensitivity | Specificity
0.35^†^ | 33% | 78%
0.4^*^ | 57% | 67%
0.6^†^ | 27% | 83%
1.0^†^ | 21% | 89%

* Results from Wayand, 2000^63^

† Results from Van Lente, 1999^64^

A study by Apple et al. compared four troponin assays in ACS patients with an estimated glomerular filtration rate less than 60 mL/min/1.73m^2^ for a composite outcome of acute MI or death. These included troponin I by Beckman, Dade, and Tosoh, and troponin T by Roche. Six-month event rates were significantly different in elevated versus nonelevated troponin groups for all assays (P < 0.05 for all). Although there were differences in exact event rates between the assays, the study reported no measures of significance for these differences.56

##### Troponin T Versus High-Sensitivity Troponin T

We did not identify any studies that met inclusion criteria and evaluated troponin T versus high-sensitivity troponin T.

##### Troponin I Versus High-Sensitivity Troponin I

We did not identify any studies that met inclusion criteria and evaluated troponin I versus high-sensitivity troponin I.

#### Strength of Evidence

We listed the strength of evidence for the body of literature addressing KQ3.3 in Tables 29 and 30. The strength of evidence is insufficient to compare the performance of troponin subclasses because the effects were not consistent; the precision could not be determined; the magnitude of effect was weak; and the rating is limited by the heterogeneity of the overall risk of bias of the assays the studies used, and the populations the studies included.

Table 29 Comparisons between troponin assays to estimate prognosis after acute coronary syndrome among patients with chronic kidney disease: Strength of evidence domains

Troponin Assay | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | Strength of Association | Strength of Evidence
Troponin T vs. troponin I | 3 (824) | Medium | Consistent | Indirect | Imprecise | ROC 0.56 vs. 0.54 (p=0.7) 0.73 vs. 0.47 (p=0.2) | Insufficient

ROC = receiver operator curve

Table 30 Comparisons between troponin assays to estimate prognosis after acute coronary syndrome among patients with chronic kidney disease: Details regarding strength of evidence domains

Outcome | Troponin Assay | Study Design | Risk of Bias Details | Reasons for Downgrading Domains- Comments About How Overall Strength of Evidence Derived
All-cause mortality | Troponin T vs. troponin I | 3 prospective | 1 poor quality, 1 fair quality, and 1 good quality study | Two studies directly compared TnT with TnI and found no significant difference, however, they used different assays and cutoffs and measured different endpoints.

TnI = troponin I; TnT = troponin T

## KQ 4 Use of Troponin for Risk Stratification Among Chronic Kidney Disease Patients Without Acute Coronary Syndrome

### Study Design Characteristics

We included 98 studies (in 105 publications) that evaluated the use of troponin levels for risk stratification among patients with chronic kidney disease (CKD) without acute coronary syndrome (ACS) symptoms, KQ 4.^9, 11, 25, 26, 47, 65-163^

The studies took place in diverse countries, including 18 in the United States, 8 in Canada, 60 in Europe, 10 in Asia, 3 in Middle-East, 1 in Mexico, 6 in Australia, and 1 in multiple countries.

Studies varied in their sources of support. Twenty-four received industry funding, 26 reported no industry support, and the remainder did not report on support.

All studies were observational cohort studies. Enrollment into 21 studies started and ended before or in 2000,^26, 89, 94, 98, 100, 104, 114, 118, 121, 122, 124, 127, 133, 138, 140, 142-144, 151, 152, 167^ while 45 studies did not report the dates of enrollment period.11, 47, 69, 70, 75-77, 79, 81, 82, 87, 91, 93, 102, 103, 106, 110-113, 116, 117, 120, 123, 125, 126, 128-132, 134-137, 139, 141, 145-150, 153, 155

The median study followup time ranged from 30 days to 5 years.

Forty-six studies recruited patients in the outpatient setting, 50 took place in hospital setting, and 36 in dialysis centers.

### Study Population Characteristics

The characteristics of studies included in KQ4 are outlined in Table 31. The study sample size ranged from 16^151^ to 8,121.^69^ Five studies did not report the age distributions.65, 70, 76, 121, 140 Among others, the mean/median age of study populations ranged from 32^115^ to 77 years.25 Six studies did not report gender distribution.65, 76, 116, 126, 129, 146 Two studies included only men.93, 148 Among other studies, the percentage of men ranged from 14 percent154 to about 80 percent.121

Table 31 Population characteristics of studies evaluating the use of troponin levels in risk stratification among patients with chronic kidney disease without symptoms of acute coronary syndrome

Author, Year | Dialysis Population | Sample Size | Location | Mean Age in Years | Race, % | % Male | % CAD
Mockel, 1999^147^ | Both | 40 | Europe | Range: 28 to 78 | NR | 55 | NR
Musso, 1999^148^ | Both | Total: 166 CKD: 49 | Europe | NR | NR | NR | 0
Farshid, 2013^160^ | Both | 153 | Australia | 66 | NR | 58 | NR
Hickman, 2009^77^ | Dialysis | 143 | Australia | 60 | W, 89 AA, 4 Other, 7 | 63 | NR
McGill, 2010^76^ | Dialysis | 143 | Australia | NR | NR | NR | NR
Roberts, 2009^85^ | Dialysis | 81 | Australia | NR | NR | 55 | NR
Choy, 2003^126^ | Dialysis | 113 | Canada | Median: 63 | NR | NR | NR
Holden, 2012^72^ | Dialysis | 103 | Canada | 63 | NR | 69 | 47
Morton, 1998^150^ | Dialysis | 112 | Canada | 61 | NR | 62 | 47
Ooi, 2001^140^ | Dialysis | 244 | Canada | NR | NR | 60 | 33
Troyanov, 2005^109^ | Dialysis | 101 | Canada | 66 | NR | 57 | 37
Scott, 2003^130^ | Dialysis | 71 | Europe | 69 | NR | 51 | NR
Artunc, 2012^66^ | Dialysis | 239 | Europe | Median: 70 | NR | 64 | 74
Beciani, 2003^129^ | Dialysis | 101 | Europe | 64 | NR | 68 | NR
Boulier, 2004^119^ | Dialysis | 191 | Europe | Median: 67 | NR | 51 | 33
Brunet, 2008^96^ | Dialysis | 105 | Europe | 65.5 | NR | 59 | 31
Codognotto, 2010^75^ | Dialysis | 50 | Europe | 68 | NR | 72 | NR
Conway, 2005^107^ | Dialysis | 75 | Europe | Median: 64 | NR | 60 | 33
Deegan, 2001^137^ | Dialysis | 73 | Europe | Median: 64 | NR | 58 | 25
Dierkes, 2000^141^ | Dialysis | 102 | Europe | 64 | NR | 49 | 28
Fernandez-Reyes, 2004^114^ | Dialysis | 58 | Europe | 70 | NR | 50 | 22
Geerse, 2012^65^ | Dialysis | 206 | Europe | 65 | NR | 52 | 40
Hallen, 2011^74^ | Dialysis | 107 | Europe | 62 | NR | 75 | 27
Helleskov Madsen, 2008^92^ | Dialysis | 109 | Europe | 62 | NR | 75 | 27
Hocher, 2008^89^ | Dialysis | 230 | Europe | 66 | NR | 49 | 27
Hojs, 2005^111^ | Dialysis | 90 | Europe | 56 | NR | 61 | NR
Ie, 2004^116^ | Dialysis | 49 | Europe | 57 | NR | NR | NR
Iliou, 2003^26^ | Dialysis | 258 | Europe | 60 | W, 72 AA, 16 Other, 13 | 58 | 23
Katerinis, 2008^93^ | Dialysis | 50 | Europe | 63 | NR | 64 | 40
Lang, 2001^139^ | Dialysis | 100 | Europe | 57 | NR | 62 | NR
Le Goff, 2007^155^ | Dialysis | 86 | Europe | 60 | NR | 53 | 53
Mallamaci, 2002^136^ | Dialysis | 199 | Europe | 59 | NR | 56 | NR
Petrovic, 2009^81^ | Dialysis | 115 | Europe | 53 | NR | 62 | NR
Sahinarslan, 2008^87^ | Dialysis | 78 | Europe | 53 | NR | 69 | NR
Sharma, 2006^106^ | Dialysis | 126 | Europe | 52 | W, 50 AA, 25 Other, 25 | 63 | 38
Stolear, 1999^145^ | Dialysis | 94 | Europe | 63 | NR | 59 | NR
Svensson, 2009^153^ | Dialysis | 206 | Europe | 67 | NR | 65 | 100
Trape, 2008^86^ | Dialysis | 52 | Europe | Median: 74 | NR | 48 | 46
Sommerer, 2007^97^ | Dialysis | 134 | Germany | Median: 66 | NR | 60 | 21
Wang 2007^98^ | Dialysis | 238 | Hong Kong | 56 | NR | 51 | 20
Bagheri,2009^83^ | Dialysis | 138 | Iran | 65 | NR | 52 | NR
Ishii, 2001^138^ | Dialysis | 100 | Japan | 54 | NR | 61 | NR
Havekes, 2006^104^ | Dialysis | 847 | Netherlands | 59 | NR | 60 | NR
Hussein, 2004^117^ | Dialysis | 93 | Saudi Arabia | 50 | NR | 49 | 20
Han, 2009^91^ | Dialysis | 107 | South Korea | 52 | NR | 46 | NR
Kang, 2009^88^ | Dialysis | 121 | South Korea | 66 | NR | 44 | 27
Kalaji, 2012^67^ | Dialysis | 145 | Syria | Median: 45 | NR | 55 | 9
Hung, 2004^120^ | Dialysis | 70 | Taiwan | NR | NR | 38 | NR
Vichairuangthum, 2006^103^ | Dialysis | 63 | Thailand | NR | NR | 47 | NR
Abaci, 2004^113^ | Dialysis | 129 | Turkey | 44 | NR | 55 | NR
Duman, 2005 112 | Dialysis | 65 | Turkey | 56 | NR | 55 | 15
Yakupoglu, 2002^135^ | Dialysis | 38 | Turkey | 56 | NR | 42 | NR
Apple, 1997^151^ | Dialysis | 16 | U.S. | 46 | NR | 44 | 9
Apple, 2002^133^ | Dialysis | 733 | U.S. | 62 | W, 60 AA, 23 H, 3 | 56 | 29
deFilippi, 2003^127^ | Dialysis | 224 | U.S. | Median: 62 | W, 38 AA, 38 H, 21 | 54 | 36
Farkouh, 2003^131^ | Dialysis | 137 | U.S. | NR | NR | NR | NR
Gaiki, 2012^70^ | Dialysis | 51 | U.S. | 62 | W, 18 AA, 61 Hi, 14 Other, 8 | 53 | 31
Kanwar, 2006^101^ | Dialysis | 173 | U.S. | 62 | W, 57 | 53 | NR
Khan, 2001^11^ | Dialysis | 126 | U.S. | NR | NR | 61 | NR
Porter, 1998^149^ | Dialysis | 30 | U.S. | 66 | NR | 40 | 100
Porter, 2000^142^ | Dialysis | 27 | U.S. | 48 | NR | 41 | 15
Roppolo, 1999^146^ | Dialysis | 49 | U.S. | 59 | NR | NR | NR
Satyan, 2007^95^ | Dialysis | 150 | U.S. | 56 | AA, 90 | NR | NR
Wolley, 2013 158 | Dialysis | 239 | New Zealand | Median; 63 | W, 28% Asian 8% Pacific 49% African 0.5% | 51 | 33
Assa, 2013 157 | Dialysis | 90 | Europe | Median; 67 | NR | 52 | 40
Artunc, 2012 66 | Dialysis | 239 | Europe | Median; 70 | NR | 64 | 31
Gaiki, 2012 70 | Dialysis | 51 | U.S. | 62 | W, 18 AA, 61 Asian 8 H, 14 | 53 | 31
Alam, 2013^162^ | Dialysis | 133 | Canada | 65^*^ | NR | 72^*^ | 28^*^
Hassan, 2014^163^ | Dialysis | 431 | Australia | 64 | NR | 59 | NR
Lamb, 2007^99^ | No | 227 | England | 67 | W, 100 | 65 | 41
Scheven, 2012^69^ | No | 8121 | Europe | 49 | NR | 50 | NR
Abbas, 2005^108^ | No | Total: 227 CKD: 222 | Europe | 67 | NR | 65 | NR
Claes, 2010^78^ | No | 331 | Europe | Median: 53 | NR | NR | 24
Connolly, 2008^94^ | No | 372 | Europe | 47 | NR | 64 | NR
Feringa, 2006^100^ | No | Total: 558 CKD: 240 | Europe | 67 | NR | 77 | 43
Goicoechea, 2004^25^ | No | 176 | Europe | Median: 68 | NR | 62 | 18
Ilva, 2008^154^ | No | Total: 364 CKD: 163 | Europe | 75 | NR | 14 | 30
Kertai, 2004^121^ | No | 393 | Europe | NR | NR | 80 | NR
Lowbeer, 2002^134^ | No | 26 | Europe | 58 | NR | 50 | 19
Lowbeer, 2003^132^ | No | 115 | Europe | 52 | NR | 62 | 29
Sharma, 2006^105^ | No | 114 | Europe | 52 | W, 45 AA, 29 Other, 1 | 67 | 30
Wood, 2003^125^ | No | 96 | Europe | 52 | NR | 67 | 24
Hasegawa, 2012^68^ | No | 442 | Japan | 69 | NR | 63 | NR
Orea-Tejada, 2010^79^ | No | 152 | Mexico | 64 | NR | 54 | NR
Bozbas, 2004^115^ | No | 34 | Turkey | 31.8 | NR | 68 | 12
Hickson, 2008^90^ | No | 644 | U.S. | 51 | W, 98 | 56 | 34
Hickson, 2009^84^ | No | 603 | U.S. | 51 | W, 98 | 57 | 29
Shroff, 2012^71^ | No | 376 | U.S. | NR | W, 86 AA, 5 | 59 | 23
McMurray, 2011^73^ | No | 3857 | Worldwide | NR | NR | NR | NR
Quiroga 2013 156 | No | 218 | Europe | Median: 69 | NR | 62 | 38
Levin, 2014^159^ | No | 2402 | Canada | 68 | W, 89 | 63 | NR
Bayes-Genis, 2013^161^ | No | Total: 879 CKD: 542 | Europe | Median: 70 | W, 100 | 72 | NR

AA = African American; CAD = coronary artery disease; CKD = chronic kidney disease; H = Hispanic; NR = not reported; U.S. = United States; W = white

* Among patients with troponin I ≥ 0.06 mcg/L.

Sixty-five studies specifically excluded ACS patients, while 38 studies did not report ACS inclusion/exclusions. Seven studies included patients with CKD stage 1 to 4; one included patients with CKD stage 3 to 4; eight included patients with CKD stage 5; 75 included dialysis patients; and six studies included kidney transplant patients. Eight used the Modification of Diet in Renal Disease equation; two used the CKD-Epi equation; and five used the Cockcroft-Gault formula.

### Study Quality

Table 32 describes the quality of studies for KQ4. We rated the overall study quality fair to good as described in methods section. Although the adjustment of confounders was one of the factors considered in study quality assessment, it was not the only factor (i.e., a study could still have fair or good quality even without confounder adjustment if it was otherwise a well-done study with clear cutpoints, clear reporting of outcome ascertainment, and appropriate statistical methods, etc). Industry funding was not factored into the overall quality assessment, but we listed it here for reference.

Table 32 Select quality scores for studies evaluating the risk associated with elevated troponin among patients with chronic kidney disease

Author, Year | Blinding Those Measuring Outcomes | Adjust For Different Followup Length | Adequate Adjustment For Confounding In Analyses | Losses To Followup Taken Into Account | Industry Support | Overall Quality
Abaci, 2004^113^ | No | Yes | Yes some | Yes | NR | Fair
Abbas, 2005^108^ | UTD | Yes | Yes | Yes | Yes | Fair
Alam, 2013^162^ | Yes | Yes | Yes | Yes | No | Good
Apple, 1997^151^ | UTD | Yes | No | Yes | Yes | Fair
Apple, 2002^133^ | No | Yes | Yes some | Yes | Yes | Fair
Apple, 2004^118^ | UTD | Yes | Yes some | Yes | Yes | Good
Artunc, 2012^66^ | UTD | Yes | UTD | Yes | NR | Fair
Assa, 2013 157 | UTD | Yes | Yes | UTD | NR | Fair
Bagheri, 2009^83^ | No | Yes | No | Yes | NR | Fair
Bayes-Genis, 2013^161^ | UTD | Yes | Yes | Yes | NR | Good
Boulier, 2004^119^ | UTD | Yes | Yes | Yes | Yes | Good
Bozbas, 2004^115^ | UTD | Yes | No | Yes | NR | Poor
Brunet, 2008^96^ | No | Yes | No | Yes | Yes | Good
Choy, 2003^126^ | Yes | Yes | Yes | Yes | Yes | Good
Chrysochou, 2009^82^ | UTD | Yes | Yes | Yes | NR | Fair
Claes, 2010^78^ | UTD | Yes | Yes | Yes | NR | Good
Codognotto, 2010^75^ | No | Yes | No | Yes | No | Fair
Connolly, 2008^94^ | No | Yes | Yes | Yes | No | Good
Conway, 2005^107^ | UTD | Yes | No | Yes | NR | Fair
Deegan, 2001^137^ | Yes | Yes | Yes some | Yes | NR | Fair
deFilippi, 2003^127^ | UTD | Yes | Yes | Yes | Yes | Fair
Dierkes, 2000^141^ | Yes | Yes | Yes some | Yes | NR | Good
Duman, 2005^112^ | Yes | Yes | Yes | Yes | No | Fair
Farkouh, 2003^131^ | UTD | Yes | Yes | Yes | NR | Fair
Farshid, 2013^160^ | No | Yes | Yes | Yes | No | Good
Feringa, 2006^100^ | No | Yes | No | Yes | NR | Good
Fernandez-Reyes, 2004^114^ | UTD | UTD | No | UTD | NR | Fair
Gaiki, 2012^70^ | No | Yes | No | Yes | NR | Fair
Geerse, 2012^65^ | UTD | Yes | Yes some | Yes | NR | Fair
Goicoechea, 2004^25^ | Yes | Yes | Yes | Yes | NR | Good
Hallen, 2011^74^ | No | Yes | Yes | Yes | NR | Fair
Han, 2009^91^ | Yes | Yes | Yes some | Yes | NR | Fair
Hasegawa, 2012^68^ | Yes | Yes | Yes | Yes | NR | Fair
Hassan, 2014^163^ | UTD | Yes | Yes | Yes | No | Good
Havekes, 2006^104^ | UTD | Yes | Yes | Yes | No | Fair
Helleskov Madsen, 2008^92^ | Yes | Yes | Yes some | Yes | No | Good
Hickman, 2009^77^ | No | Yes | Yes | Yes | NR | Good
Hickson, 2008^90^ | UTD | Yes | Yes | Yes | No | Good
Hickson, 2009^84^ | UTD | Yes | Yes | Yes | No | Good
Hocher, 2003^124^ | UTD | Yes | Yes | Yes | No | Good
Hocher, 2004^122^ | UTD | Yes | Yes | Yes | No | Good
Hocher, 2008^89^ | UTD | Yes | Yes | Yes | No | Good
Hojs, 2005^111^ | UTD | Yes | No | Yes | NR | Poor
Holden, 2012^72^ | UTD | Yes | Yes | Yes | NR | Good
Hussein, 2004^117^ | No | No | No | No | NR | Fair
Ie, 2004^116^ | UTD | Yes | No | Yes | NR | Fair
Iliou, 2003^26^ | UTD | Yes | Yes | Yes | Yes | Good
Ilva, 2008^154^ | Yes | Yes | Yes some | Yes | Yes | Good
Ishii, 2001^138^ | Yes | Yes | Yes | Yes | Yes | Good
Kalaji, 2012^67^ | UTD | Yes | Yes | Yes | NR | Fair
Kang, 2009^88^ | No | Yes | Yes | Yes | No | Fair
Kanwar, 2006^101^ | Yes | Yes | Yes | Yes | Yes | Good
Katerinis, 2008^93^ | UTD | Yes | No | Yes | NR | Poor
Kertai, 2004^121^ | UTD | Yes | Yes some | Yes | NR | Fair
Khan, 2001^11^ | Yes | Yes | Yes | Yes | NR | Good
Lamb, 2007^99^ | UTD | Yes | Yes | Yes | Yes | Good
Lang, 2001^139^ | UTD | UTD | No | Yes | Yes | Fair
Le Goff, 2007^155^ | UTD | UTD | Yes some | UTD | NR | Fair
Levin, 2014^159^ | UTD | Yes | Yes | Yes | Yes | Good
Lowbeer, 2002^134^ | No | Yes | Yes | Yes | No | Fair
Lowbeer, 2003^132^ | UTD | Yes | Yes | Yes | No | Fair
Mallamaci, 2002^136^ | UTD | Yes | Yes | Yes | NR | Good
McGill, 2010^76^ | UTD | Yes | Yes some | Yes | No | Fair
McMurray, 2011^73^ | No | Yes | Yes some | Yes | Yes | Fair
Mockel, 1999^147^ | Yes | Yes | Yes | UTD | Yes | Fair
Morton, 1998^150^ | No | UTD | Yes some | UTD | No | Good
Musso, 1999^148^ | UTD | UTD | No | No | NR | Fair
Ooi, 1999^144^ | No | Yes | Yes | Yes | NR | Fair
Ooi, 2001^140^ | No | Yes | Yes some | Yes | Yes | Good
Orea-Tejeda, 2010^79^ | No | Yes | Yes | Yes | No | Fair
Petrovic, 2009^81^ | UTD | Yes | UTD | UTD | NR | Fair
Porter, 1998^149^ | No | Yes | No | Yes | NR | Fair
Porter, 2000^142^ | UTD | UTD | UTD | Yes | Yes | Fair
Quiroga 2013 156 | No | No | Yes, some | UTD | No | Fair
Roberts, 2009^85^ | UTD | Yes | No | Yes | Yes | Fair
Sahinarslan, 2008^87^ | UTD | UTD | Yes | UTD | NR | Fair
Satyan, 2007^95^ | Yes | Yes | Yes | Yes | No | Good
Scheven, 2012^69^ | UTD | Yes | Yes | Yes | No | Fair
Scott, 2003^130^ | UTD | Yes | Yes some | Yes | No | Good
Sharma, 2005^110^ | UTD | Yes | Yes some | Yes | NR | Good
Sharma, 2006^105^ | UTD | Yes | No | Yes | NR | Fair
Sharma, 2006^106^ | No | Yes | Yes some | Yes | No | Fair
Shroff, 2012^71^ | UTD | Yes | No | UTD | Yes | Fair
Sommerer, 2007^97^ | UTD | Yes | UTD | Yes | NR | Fair
Stolear, 1999^145^ | No | Yes | Yes some | Yes | Yes | Good
Svensson, 2009^153^ | UTD | Yes | Yes some | Yes | Yes | Fair
Trape, 2008^86^ | No | Yes | Yes | Yes | NR | Good
Troyanov, 2005^109^ | No | No | Yes some | UTD | Yes | Fair
Vichairuangthum, 2006^103^ | No | Yes | Yes | Yes | NR | Fair
Wang, 2006^102^ | No | Yes | Yes | Yes | No | Good
Wang, 2007^98^ | UTD | Yes | Yes some | Yes | No | Good
Wang, 2010^152^ | UTD | Yes | Yes | Yes | No | Good
Wolley, 2013 158 | UTD | No | Yes some | UTD | No | Fair
Wood, 2003^125^ | UTD | Yes | Yes some | Yes | NR | Fair
Yakupoglu, 2002^135^ | UTD | UTD | No | Yes | NR | Fair

NR = not reported; UTD = unable to determine

### Results: Inclusion of Studies in Meta-Analysis for KQ 4

Appendix E Tables 1-7 outline the studies used in meta-analysis for KQ4, and whether they were included in meta-analyses for hazard ratios (HR), odds ratios (OR), or excluded from both meta-analyses. We excluded studies from meta-analyses if there was insufficient information to derive any HR or OR, if the study presented troponin as a continuous variable rather than a cutpoint, or if the cutpoint for troponin elevation was unclear. Also, if there are multiple papers of results derived from the same cohort, we presented results from each unique cohort once for each outcome. We also noted the reasons for exclusion in Appendix E Tables 1-7. The meta-anlayses for HRs are stratified by the level of adjustment. The list of covariates for each study is presented in Appendix F.

After performing the literature search, it became clear that the majority of studies reported results in a cohort of patients receiving dialysis. The other studies were a mix of CKD stages 1-5 including or excluding dialysis patients. To avoid further heterogeneity, we presented outcome results for dialysis and nondialysis patients separately in regard to KQs 4.1 and 4.2.

### Results for Patients on Dialysis

Key Points
- Among dialysis patients without suspected ACS, a baseline elevated value of cardiac troponin was associated with a higher risk (∼2-4 fold) for subsequent short- and long-term outcomes including all-cause mortality, cardiovascular-specific mortality, and MACE (i.e., “composite” outcome of MI, cardiovascular death, and/or revascularization) in models adjusted at least for age and CAD or risk equivalent (Figure 6).
- More of the studies we included in the pooled meta-analyses reported outcomes for all-cause mortality than for other outcomes. Thus, the evidence from the pooled meta-analysis is strongest for the association of elevated cardiac troponin with all-cause mortality.
- We found approximately a 3-fold increased risk for the association of cardiac troponin T and I with all-cause mortality, which was highly significant (strength of evidence: moderate). The evidence from meta-analyses for an association of elevated cardiac troponin with cardiovascular-specific mortality and MACE showed similar effect sizes but with wider confidence intervals (CIs) from fewer studies (strength of evidence: moderate for CVD mortality for Troponin T and I; moderate for MACE for Troponin T with insufficient evidence for MACE for Troponin I).
- The association of elevated troponin with adverse outcomes among dialysis patients was generally similar for troponin T versus I. Few studies reported results for high-sensitivity troponin T and high-sensitivity troponin I assays; thus, less is known about how well these assays predict risk (strength of evidence: low).
- A sensitive assay identifies more patients as being elevated.
- While almost all studies supported a positive association for elevated cardiac troponin with adverse cardiovascular outcomes, particularly mortality, there was substantial heterogeneity among the studies, even though troponin T and I were analyzed separately.
- Much of the heterogeneity across results stemmed from differences across the literature between the various types of troponin assays used (different manufacturers, different assay platforms). Troponin assays have been changing, and newer generations of assays can detect lower concentrations of cardiac troponin. Many of the articles did not report which generation of assay they used.
- The studies varied markedly regarding which cutpoints they selected to define as elevated. Many studies did not report what the manufacturer-reported 99^th^ percentile threshold was for that assay. The 99^th^ percentile threshold was also a changing target depending on what reference population or assay generation was used. The reference populations for the 99^th^ percentiles were largely unclear, and were most likely not taken from a dialysis cohort. Therefore, we were not able to perform meta-analyses using the 99^th^ percentile cutpoint, but instead compared the highest cutpoint reported in each study with the lowest cutpoint for consistency.
- The meta-analyses we performed for the pooled ORs were unadjusted results using number of events in each arm. For the meta-analyses for HRs, we selected the most-adjusted regression model. Many studies only reported an unadjusted HR. While many studies did adjust for age, few studies adjusted for a history of CAD, CAD risk equivalent (such as diabetes mellitus), or for other causes of elevated troponin, such as heart failure. Even fewer studies adjusted more comprehensively for other cardiovascular risk factors, such as systolic blood pressure, dyslipidemia, and smoking. However, associations generally did remain robust in adjusted models (when available) and thus we considered them reliable.
- Studies almost exclusively looked at the association of troponin with outcomes in regression models, but did not examine the utility of troponin as a useful marker for prediction by metrics of reclassification or discrimination (i.e. show whether troponin improves re-classification of individuals into lower or higher clinical risk groups).
- Only one study104 rigorously examined whether troponin testing among dialysis patients added incremental prognosis over routine clinical and laboratory factors, but troponin testing did not change the area under curve in their survival model. Thus, it is unknown whether measuring cardiac troponin facilitates risk prediction in dialysis patients better than a traditional risk prediction model using only clinical variables.
- All of the studies related to this question were observational cohort studies. We did not find any intervention studies that compared management strategies of dialysis patients (without suspected ACS) on the basis of elevated troponin. Thus, while elevated cardiac troponin is clearly a marker of increased risk for subsequent cardiac events, it is unknown whether changing patient management (such as more intensified preventive efforts) on the basis of elevated troponin can reduce cardiovascular morbidity and mortality.

Figure 6 Summary of the meta-analysis results of the pooled hazard ratios from studies that adjusted for at least age and CAD (or risk equivalent) for the association of an elevated troponin with outcomes among dialysis and nondialysis patients*

* The strength of evidence for other outcomes not listed here was graded as insufficient because we did not find any studies addressing them or because we were unable to draw a conclusion from the evidence.

CI = confidence interval; cTnI = cardiac troponin I; cTnT = cardiac troponin T; CVD = cardiovascular disease; HR = hazard ratio; MACE = major adverse cardiovascular events; SOE = strength of evidence; Tn = troponin

Figure 6 is a forest plot type diagram depicting the pooled hazard ratio and strength of evidence of the association of elevated troponin T and I with risk of outcomes among patients on dialysis and not on dialysis. All-cause mortality, cardiovascular disease mortality, and major adverse cardiovascular events are included. The information presented in the plot shows outcome, troponin assay, number of studies, number of patients, pooled hazard ratio, 95% confidence interval, and strength of evidence. All outcomes had hazard and odds ratios over one, thus suggesting that elevated troponin T or I is positively associated with outcomes among patients on dialysis. The strength of evidence is moderate for association of risk for all outcomes and elevated troponin.

#### KQ 4.1.a Distribution of Troponin Values Among Patients on Dialysis

The number (percent) of the study populations with elevated troponin values is noted in Table 33. This was only available for studies that listed the number of patients with elevated values out of the total sample. Some studies did not provide this information. As outlined in our methods section, we only abstracted data from studies that also reported outcomes. We did not abstract studies that reported on the prevalence of elevated troponin in their cohort but had no outcome data and thus we did not include them in this list.

Table 33 Prevalence of elevated baseline troponin T and I levels at maximum cut-point among patients on dialysis

Author, year | Troponin T Assay | Troponin T Cutpoint (mcg/L) | % with Elevated Troponin T | Troponin I Assay | Troponin I Cutpoint (mcg/L) | % with Elevated Troponin I
Dierkes, 2000^141^ | Roche | >0.1 | 12 | NA | NA | NA
Conway, 2005^107^ | Roche | >0.1 | 17 | NA | NA | NA
Iliou, 2003^26^ | Roche | >0.1 | 19 | NA | NA | NA
Apple, 2002^133^ | Roche | >0.1 | 20 | Dade | >0.1 | 6
Han, 2009^91^ | Roche | >0.1 | 20 | NA | NA | NA
Abaci, 2004^113^ | Roche | >0.1 | 21 | Abbott | >0.5 | 24
Kalaji, 2012^67^ | Roche | >0.1 | 21 | Siemens | >0.2 | 35
Lang, 2001^139^ | Boehringer Mannheim | >0.1 | 22 | Dade | >0.4 | 7
Sahinarslan, 2008^87^ | NR | >0.1 | 22 | NA | NA | NA
Ishii, 2001^138^ | Roche | >0.1 | 25 | Beckman | >0.1 | 6
Hickman, 2009^77^ | Roche | >0.098 | 25 | Abbott | >0.043 | 25
Trape, 2008^86^ | Roche | >0.1 | 25 | NA | NA | NA
Hassan, 2014^163^ | Roche | >0.101 | 25 | NA | NA | NA
deFilippi, 2003^127^ | Roche | >0.117 | 25 | NA | NA | NA
Brunet, 2008^96^ | Roche | >0.1 | 27 | Beckman | >0.06 | 18
Hojs, 2005^111^ | Roche | >0.1 | 27 | NA | NA | NA
Deegan, 2001^137^ | Boehringer Mannheim | >0.1 | 27 | NA | NA | NA
Sharma, 2005^110^ | Roche | >0.1 | 30 | NA | NA | NA
Ooi, 2001^140^ | Roche | >0.1 | 30 | NA | NA | NA
Wang, 2007^98^ | Roche | >0.1 | 35 | NA | NA | NA
Porter, 2000^142^ | Roche | >0.1 | 37 | Dade | >0.4 | 11
Choy, 2003^126^ | Roche | >0.1 | 42 | Dade | >0.5 | 15
Duman, 2005^112^ | Roche | >0.035 | 45 | DPC | >0.06 | 6
Stolear, 1999^145^ | Boehringer Mannheim | >0.1 | 50 | NA | NA | NA
Farshid, 2013^160^ | Roche | >0.01 | 52 | NA | NA | NA
Helleskov Madsen, 2008^92^ | Roche | >0.03 | 52 | Beckman | >0.06 | 11
Lowbeer, 2002^134^ | Boehringer | >0.04 | 54 | NA | NA | NA
Hallen, 2011^74^ | Roche | >0.01 | 60 | NA | NA | NA
Apple, 1997^151^ | Boehringer | >0.2 | 75 | NR | >0.8 | 19
Ie, 2004^116^ | Roche | >0.03 | 82 | NA | NA | NA
Roppolo, 1999^146^ | NA | NA | NA | Dade | >0.5 | 6
Farkouh, 2003^131^ | NA | NA | NA | Dade | >1 | 7
Porter, 1998^149^ | NA | NA | NA | Dade | >0.4 | 7
Katerinis, 2008^93^ | NA | NA | NA | Beckman | >0.09 | 8
Hussein, 2004^117^ | NA | NA | NA | Abbott | >0 | 10
Roberts, 2004^123^ | NA | NA | NA | Abbott | >0.3 | 10
Geerse, 2012^65^ | NA | NA | NA | Siemens | >0.1 | 12
Khan, 2001^11^ | NA | NA | NA | Sanofi | >0.03 | 19
Yakupoglu, 2002^135^ | NA | NA | NA | DPC | >2.3 | 21
Vichairuangthum, 2006^103^ | NA | NA | NA | Johnson & Johnson | >0.4 | 22
Alam, 2013^162^ | NA | NA | NA | Beckman | >0.06 | 27
Beciani, 2003^129^ | NA | NA | NA | Dade | >0.15 | 29
Kang, 2009^88^ | NA | NA | NA | Beckman | >0.2 | 30
Kanwar, 2006^101^ | NA | NA | NA | Beckman | >0.01 | 60
Sommerer, 2007^97^ | Roche | >0.026 | NA | NA | NA | NA
Gaiki 2012 70 | NA | NA | NA | Ortho Vitros ES | >0.035 | 51
Hung, 2004^120^ | NA | NA | NA | DPC | >0.2 | NA

DPC = Diagnostic Products Corporation; mcg/L = micrograms per liter; NA = not applicable

Prevalences depend on the clinical characteristics (i.e., pre-test probability) of each study group as well as the heterogeneity between assays and cutpoints. As such, we found prevalences widely varied across studies. For troponin T, the prevalence of dialysis patients with troponin levels above cutpoints ranged from 12 to 82 percent. Some of the heterogeneity was due to different cutpoints the studies used to define “elevated,” but heterogeneity across studies remained even when studies used similar cutpoints. In general, lower cutpoints (i.e., 0.03 mcg/L) identified a higher prevalence of patients defined as elevated, as would be anticipated by a more sensitive cutpoint. For example, the prevalence of elevated troponin for cutpoints 0.01 to 0.03 mcg/L ranged from 45 to 82 percent. A more conservative cutpoint (such as 0.1 mcg/L) had a lower prevalence of patients defined as elevated. Still, even for a cutpoint of 0.1 mcg/L, the prevalence ranged from 12 to 50 percent across cohorts, averaging around 25 percent.

For troponin I, the prevalence of patients defined as elevated ranged from 6 to 60 percent. There was no clear pattern of prevalence by cutpoints across studies. For low cutpoints (0.01 to 0.03 mcg/L), the prevalence ranged from 19 to 60 percent. For higher cutpoints (0.3 mcg/L), the prevalence ranged from 6 to 30 percent. Of note, one study used a high cutpoint of 2.3 mcg/L,135 and the prevalence was still high at 21 percent.

Some studies evaluated prevalences of elevated troponin in the same population as noted in Table 33 below. For example, in a study by Apple et al 2002, the prevalence of elevated troponin T (>0.1 mcg/L) was 20 percent but the prevalence of elevated troponin I (>0.1 mcg/L) was 6 percent when tested in the same cohort of patients.

#### KQ 4.2a Troponin Associations With Short- and Long-term Outcomes Among Patients on Dialysis

##### The Association of Cardiac Troponin T With All-Cause Mortality Among Patients on Dialysis

###### Overview

Forty-three unique patient cohorts (among 49 publications) presented results regarding the association of baseline troponin T levels with all-cause mortality among dialysis (only) patients without symptoms of ACS.26, 66, 67, 72, 74, 75, 77, 81, 83, 85-87, 89, 92, 95, 96, 98, 104, 106, 110, 112-114, 116, 118, 122, 124, 126, 127, 130, 133, 134, 136-142, 144, 145, 147-149, 153, 155, 157, 160, 163

We excluded ten studies from the meta-analyses of both HRs and ORs due to insufficient data, or because the studies did not present results separately for dialysis patients only. We included the remaining studies in HR meta-analysis, OR meta-analysis, or both. We included a summary of the inclusion and exclusion reasons in Appendix E, Table 1.

###### Followup Time

All studies except one had a followup time for mortality events equal or greater to 1 year with time ranging from 1 to 5 years. Choy126 reported a followup time of only 6 months.

###### Assays and Cut-Points

The cardiac troponin T assay was generally measured by one manufacturer (Roche) or by Boehringer Mannheim, which was acquired by Roche Diagnostics in 1997. The most common cut-point studies used to define elevated troponin was a troponin T greater than 0.1 mcg/L, with a cut-point of more than 0.03 mcg/L being the second most common. These do not clearly reflect the 99^th^ percentile (as compared with Appendix G, which outlines the 99^th^ percentile by assay as described by the manufacturer). However, the 99^th^ percentile is a changing target based on the assay generation and reference population. Many of the articles did not clearly state which generation of assay they used, or whether the cut-point was the 99^th^ percentile value or some other threshold. Some studies chose a value selected by a Receiver Operator Curve analysis. Therefore it was difficult to compare studies across the 99th percentile.

###### Hazard Ratio for All-Cause Mortality Associated With Elevated Cardiac Troponin T

We listed the results from the meta-analysis (n=21 studies) stratified by the level of adjustment that presented HRs for the association of elevated troponin T with all-cause mortality among dialysis patients in Figure 7. All studies we included in this meta-analysis have reported a HR with CIs or we were able to derive the CIs using the spreadsheet provided by Tierney et al.32

Figure 7 Pooled hazard ratio of the association of elevated troponin T with all-cause mortality among patients on dialysis (stratified by level of adjustment)

* Study used a troponin assay manufactured by Roche.

† Study used a troponin assay manufactured by Boehringer Mannheim (older assays).

CAD = coronary artery disease or risk equivalent; CI = confidence interval; HR = hazard ratio; mcg/L = micrograms per liter; NR = not reported; yrs = years

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 7 is a forest plot type diagram depicting the pooled hazard ratio, with 95% confidence interval, of the association of an elevated troponin T with all-cause mortality stratified by the level of adjustment among patients on dialysis. Twenty-one articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, sample size, and hazard ratio with 95% confidence interval. All trials had hazard ratio over one, thus suggesting that an elevated troponin T is positively associated with all-cause mortality among patients on dialysis. The hazard ratio among studies that adjusted for at least age and coronary artery disease is 3.0, with a 95% confidence interval of 2.4 to 4.3.

Of these studies, six were unadjusted, 15 adjusted at least for age, and 11 adjusted at least for age and history of CAD (or CAD risk equivalents such as cardiovascular disease, congestive heart failure, ejection fraction, or diabetes mellitus) in their models. In two studies, the authors performed a more thorough regression model by additionally adjusting for numerous cardiovascular risk factors including blood pressure, lipids, and diabetes.

In all studies, there was a positive association between elevated cardiac troponin T and all-cause mortality (HR >1.0), although the HRs varied widely—from as low as 1.07 up to 15.5. Most studies were statistically significant, but in three of the 21 studies the CIs crossed 1.0, although the effect estimate was similar to the other studies which were statistically significant. The pooled meta-analysis for the HR among studies that adjusted for at least age and CAD or risk equivalent was statistically significant and provided evidence for a 3-fold increased risk of all-cause mortality associated with elevated troponin T (HR, 3.0; 95% CI, 2.4 to 4.3); heterogeneity not significant (I-squared, 42 percent).

Figure 7 includes studies stratified by level of adjustment, but we also viewed data sorted by year of publication. We found no temporal trends (in terms of strength of association or statistical significance).

###### Odds Ratio for All-Cause Mortality Associated With Elevated Cardiac Troponin T

Twenty-four studies provided the number of events among elevated and nonelevated troponin T groups making it possible to determine an unadjusted OR. Figure 8 presents the results from the pooled meta-analysis for the unadjusted OR for all-cause mortality by elevated troponin T level among dialysis patients.

Figure 8 Pooled odds ratio for the association of elevated troponin T with all-cause mortality among patients on dialysis (sorted by prevalence)

* Study used a troponin assay manufactured by Roche.

† Study did not report the manufacturer of the troponin assay.

‡ Study used a troponin assay manufactured by Boehringer Mannheim (older assays).

CI = confidence interval; cTnT = cardiac troponin T; elev = elevated; mcg/L = micrograms per liter; OR = odds ratio; yrs = years

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 8 is a forest plot type diagram depicting the pooled odds ratio, with 95% confidence interval, of the association of an elevated troponin T with all-cause mortality among patients on dialysis. Twenty-four articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, odds ratio, 95% confidence interval, number of events for those with elevated troponin T, number of those with elevated troponin T, events in those without elevated troponin T, and number of those without elevated troponin T. All trials had odds ratio over one, thus suggesting that an elevated troponin T is positively associated with all-cause mortality among patients on dialysis. The overall odds ratio is 4.7, with a 95% confidence interval of 3.6 to 6.5.

All studies showed a positive association of elevated cardiac troponin T with all-cause mortality (OR >1.0). Most of the studies were statistically significant, but three of the 24 studies reported insignificant associations (CIs crossed 1.0), although the effect estimation was similar to the other studies. The overall pooled OR showed a five-fold increased risk (OR, 4.7; 3.6 to 6.5) with significant heterogeneity (I-squared, 53 percent.)

##### The Association of Cardiac Troponin I With All-Cause Mortality Among Patients on Dialysis

###### Overview

We identified 31 publications representing 30 unique patient cohorts that presented results regarding the association of baseline cardiac troponin I levels with all-cause mortality among dialysis patients without symptoms of ACS.11, 65-67, 70, 75, 77, 81, 88, 92, 93, 96, 101, 112, 113, 117-119, 126, 131, 133, 134, 138, 139, 147-150, 157, 162, 168

We excluded seven studies from the meta-analysis of both HRs and ORs due to insufficient data, troponins presented as continuous variables rather than cut-points, or results that were not presented separately for dialysis patients. We did not include the remaining studies in HR meta-analysis, OR meta-analysis, or both. We presented a summary of these inclusion and exclusion reasons in Appendix E, Table 2.

###### Followup Time

All studies except one had a followup time for mortality of at least 1 year with time ranging from 1 to 5 years. Choy, 2003^126^ reported a followup time of only 6 months.

###### Assays and Cutpoints

The most common cardiac troponin I assays that studies used were the Beckman, Dade-Behring, and Abbott assays. Multiple studies compared two or more troponin I assays in the same study population.92, 96, 118, 139, 147-149 For the purpose of meta-analysis, we only used only one cardiac troponin I assay per population. The cut-points for elevation were extremely heterogeneous, ranging from 0.01 to 0.4 mcg/L.

###### Hazard Ratio for All-Cause Mortality Associated with Elevated Cardiac Troponin I

Ten studies provided HRs and 95 percent CIs suitable for meta-analysis. All of these studies suggested an increased risk of mortality associated with cardiac troponin I elevation (HR >1.0). However two of the studies did not meet statistical significance (CIs crossed 1.0). All except for one of these studies at least adjusted for age, and seven out of 10 additionally adjusted for CAD or CAD risk equivalent (CAD, cardiovascular disease, heart failure, diabetes).

We listed the pooled meta-analysis stratified by level of adjustment in Figure 9. The pooled HR of an elevated cardiac troponin I for all-cause mortality among studies that adjusted for at least age and CAD or risk equivalent was 2.7 (95% CI, 1.9 to 4.6), heterogeneity not-significant (I-squared = 27 percent). Again, we saw no apparent temporal trends when we sorted results by year of publication.

Figure 9 Pooled hazard ratio of the association of an elevated troponin I with all-cause mortality among patients on dialysis (stratified by level of adjustment)

* Study used a troponin assay manufactured by Dade.

† Study used a troponin assay manufactured by Beckman.

‡ Study used a troponin assay manufactured by Siemens.

CAD = coronary artery disease or risk equivalent; CI = confidence interval; HR = hazard ratio; mcg/L = micrograms per liter; NR = not reported; yrs = years

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 9 is a forest plot type diagram depicting the pooled hazard ratio, with 95% confidence interval, of the association of an elevated troponin I with all-cause mortality stratified by the level of adjustment among patients on dialysis. Ten articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, sample size, and hazard ratio with 95% confidence interval. All trials had hazard ratio over one, thus suggesting that an elevated troponin I is positively associated with all-cause mortality among patients on dialysis. The hazard ratio among studies that adjusted for at least age and coronary artery disease is 2.7, with a 95% confidence interval of 1.9 to 4.6

###### Odds Ratios for All-Cause Mortality Associated with Elevated Cardiac Troponin I

Nineteen studies provided enough data (i.e., number of events in each group) to be included in meta-analysis for ORs. The majority of studies showed a positive association between elevated cardiac troponin I and all-cause mortality. In two studies, the point estimate tended toward an inverse association, although not statistically significant. In fact, eleven of the 19 studies did not reach statistical significance, largely due to small sample size and small number of events in each group, as indicated in Figure 10.

Figure 10 Pooled unadjusted odds ratio of the association of an elevated troponin I with all-cause mortality among patients on dialysis (sorted by prevalence)

* Study used a troponin assay manufactured by Diagnostic Products Corporation.

† Study used a troponin assay manufactured by Dade.

‡ Study used a troponin assay manufactured by Beckman.

§ Study used a troponin assay manufactured by Abbott.

ǁ Study used a troponin assay manufactured by Siemens.

¶ Study used a troponin assay manufactured by Sanofi.

** Study used a troponin assay manufactured by Ortho.

CI = confidence interval; cTnI = cardiac troponin I; elev = elevated; mcg/L = micrograms per liter; NR = not reported; OR = odds ratio; yrs = years

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 10 is a forest plot type diagram depicting the pooled odds ratio, with 95% confidence interval, of the association of an elevated troponin I with all-cause mortality among patients on dialysis. Nineteen articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, odds ratio, 95% confidence interval, number of events for those with elevated troponin I, number of those with elevated troponin I, events in those without elevated troponin I, and number of those without elevated troponin I. Sixteen trials had odds ratio over one and three were less than one thus suggesting that an elevated troponin I is positively associated with all-cause mortality among patients on dialysis. The overall odds ratio is 2.6, with a 95% confidence interval of 1.87 to 3.61.

The unadjusted pooled OR for all-cause mortality associated with elevated troponin I was 2.6 (95% CI, 1.9 to 3.6). Heterogeneity was not significant (I-squared=18 percent).

##### The Association of High-Sensitivity Cardiac Troponin T With All-Cause Mortality Among Patients on Dialysis

We found only one study that evaluated the association of a high-sensitivity troponin T assay with mortality. This study76 tested high-sensitivity troponin T (assayed by Roche E411 analyzer) on a continuous scale, rather than using a cut-point. These authors found that for every 2.72 ng/L increase in high-sensitivity troponin T level, the age-adjusted risk of all-cause mortality increased 1.4-fold (HR, 1.4; 95% CI, 1.0 to 2.0, P = 0.049]).

##### The Association of High-Sensitivity Cardiac Troponin I With All-Cause Mortality Among Patients on Dialysis

We found only one study that evaluated the risk of all-cause mortality for high-sensitivity cardiac troponin I among dialysis patients. Assa et al.157 evaluated the risk of high-sensitivity troponin I with all-cause mortality per 10 ng/L increase in troponin and did not find a statistically significant association; but the study may have been underpowered for this outcome.

##### The Association of Cardiac Troponin T With Cardiovascular Mortality Among Patients on Dialysis

###### Overview

We identified 20 studies representing 16 unique patient cohorts that reported results on the association of cardiac troponin T with cardiovascular-specific mortality.26, 89, 95, 98, 104, 111-113, 122, 124, 136-140, 144, 151, 152, 155, 158

We excluded two studies from meta-analysis of both HRs and ORs due to insufficient data. We presented a summary of these inclusion and exclusion reasons in Appendix E, Table 3.

Followup time ranged from 1 to 4.3 years.

###### Hazard Ratio for Cardiovascular-Specific Mortality Associated With Elevated Cardiac Troponin T

We identified seven studies that reported a HR with CIs. All of these studies suggested an increased risk, although three of seven studies did not meet statistical significance. All except one of the studies adjusted at least for age, and five of the seven studies additionally adjusted for CAD or CAD risk equivalent (CAD, cardiovascular disease, diabetes, or heart failure). We listed the pooled meta-analysis in Figure 11. Among the five studies that adjusted for at least age and CAD, there was a 3-fold increased risk (HR, 3.3; 95% CI, 1.8 to 5.4), there was substantial heterogeneity (I-squared, 66 percent), and when we sorted results by year, we saw no temporal trend.

Figure 11 Pooled hazard ratio of the association of an elevated troponin T with cardiovascular mortality among patients on dialysis (stratified by level of adjustment)

* All studies used a troponin assay manufactured by Roche.

CAD = coronary artery disease or risk equivalent; CI = confidence interval; HR = hazard ratio; mcg/L = micrograms per liter; NR = not reported; yrs = years

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 11 is a forest plot type diagram depicting the pooled hazard ratio, with 95% confidence interval, of the association of an elevated troponin T with cardiovascular mortality stratified by level of adjustment among patients on dialysis. Seven articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, sample size, and hazard ratio with 95% confidence interval. All trials had hazard ratio over one, thus suggesting that an elevated troponin T is positively associated with cardiovascular mortality among patients on dialysis. The hazard ratio among studies that adjusted for at least age and coronary artery disease is 3.3, with a 95% confidence interval of 1.8 to 5.4.

###### Odds Ratio for Cardiovascular-Specific Mortality Associated With Elevated Cardiac Troponin T

Nine studies provided the number of events in each group, making it possible to determine unadjusted ORs. In one study (Duman 2005^112^), the authors reported an adjusted OR but did not report the number of events and sample sizes in each group. All of the studies suggested a positive association with increased risk, although three of the nine studies did not meet statistical significance.

We reported the pooled meta-analysis for the odds of cardiovascular mortality for elevated cardiac troponin T in Figure 12; it suggests a 4-fold increase in risk (OR, 4.3; 95% CI, 3.0 to 6.4); no heterogeneity found.

Figure 12 Pooled odds ratio of the association of an elevated troponin T with cardiovascular mortality among patients on dialysis (sorted by prevalence)

* Study used a troponin assay manufactured by Roche.

† Study used a troponin assay manufactured by Boehringer Mannheim (older assays).

CI = confidence interval; cTnT = cardiac troponin T; elev = elevated; mcg/L = micrograms per liter; OR = odds ratio; yrs = years

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 12 is a forest plot type diagram depicting the pooled odds ratio, with 95% confidence interval, of the association of an elevated troponin T with cardiovascular mortality among patients on dialysis. Nine articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, odds ratio, 95% confidence interval, number of events for those with elevated troponin T, number of those with elevated troponin T, events in those without elevated troponin T, and number of those without elevated troponin T. All trials had odds ratio over one thus suggesting that an elevated troponin T is positively associated with cardiovascular mortality among patients on dialysis. The overall odds ratio is 4.26, with a 95% confidence interval of 2.95 to 6.35.

In a sensitivity analysis, including the one study with an adjusted OR, the pooled results were similar (OR, 4.5; 95% CI, 3.2 to 6.3).

##### The Association of High-Sensitivity Cardiac Troponin T With Cardiovascular Mortality Among Patients on Dialysis

One study158 presented results using a high-sensitivity cardiac troponin assay (Roche, 99^th^ percentile 0.0135 mcg/L) but presented results as a continuous variable per 100 U increase (OR 1.5, 95 percent CI 1.2-1.9).

##### The Association of Cardiac Troponin I With Cardiovascular Mortality Among Patients on Dialysis

###### Overview

We identified 13 studies that reported the association of cardiac troponin I with cardiovascular-specific mortality.11, 65, 70, 88, 103, 112, 113, 119, 135, 138, 139, 151, 162

We excluded only one study from meta-analysis of both HRs and ORs due to insufficient data. We presented a summary of these inclusion and exclusion reasons in Appendix E, Table KQ4.

Followup time ranged from 1 to 4 years.

###### Hazard Ratio for Cardiovascular-Specific Mortality Associated With Elevated Cardiac Troponin I

We included three studies that adjusted for at least age and CAD or risk equivalent in the meta-analysis for HR (Figure 13). The pooled risk of the association of elevated cardiac troponin I with cardiovascular mortality by was 4.2 (95% CI, 2.0-9.2). Confidence intervals were wide, but there was not any significant heterogeneity among the studies (I-squared = 0%).

Figure 13 Pooled hazard ratio of the association of an elevated troponin I with cardiovascular mortality among patients on dialysis

* All studies used a troponin assay manufactured by Beckman.

CAD = coronary artery disease; CI = confidence interval; HR = hazard ratio; mcg/L = micrograms per liter; NR = not reported; yrs = years

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 13 is a forest plot type diagram depicting the pooled hazard ratio, with 95% confidence interval, of the association of an elevated troponin I with cardiovascular mortality stratified by level of adjustment among patients on dialysis. Three articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, sample size, and hazard ratio with 95% confidence interval. All trials had hazard ratio over one, thus suggesting that an elevated troponin I is positively associated with all-cause mortality among patients on dialysis. The overall hazard ratio is 4.2, with a 95% confidence interval of 2.0 to 9.2.

###### Odds Ratio for Cardiovascular-Specific Mortality Associated With Elevated Cardiac Troponin I

Nine studies reported the number of events in each group and we included them in our meta-analysis. Two studies103, 151 had very unusual odds ratios (OR 58 and 0.6, respectively). Both studies had zero events in one of the groups, and the Stata statistical program added 0.5 to 0 cells for calculations.

The overall pooled OR showed a 5-fold increased risk (OR, 5.2; 95% CI, 2.8 to 9.0),which was similar to results for elevated cardiac troponin T elevation (Figure 14). Heterogeneity I-squared was 0 percent.

Figure 14 Pooled odds ratio of the association of an elevated troponin I with cardiovascular mortality among patients on dialysis

* Study used a troponin assay manufactured by Beckman.

† Study used a troponin assay manufactured by Dade.

‡ Study used a troponin assay manufactured by Siemens.

§ Study used a troponin assay manufactured by Sanofi.

ǁ Study did not report the manufacturer of the troponin assay.

¶ Study used a troponin assay manufactured by Diagnostic Products Corporation.

** Study used a troponin assay manufactured by Johnson & Johnson.

†† Study used a troponin assay manufactured by Abbott.

‡‡ Study used a troponin assay manufactured by Ortho.

CI = confidence interval; cTnI = cardiac troponin I; elev = elevated; mcg/L = micrograms per liter; OR = odds ratio; yrs = years

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 14 is a forest plot type diagram depicting the pooled odds ratio, with 95% confidence interval, of the association of an elevated troponin I with cardiovascular mortality among patients on dialysis. Nine articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, odds ratio, 95% confidence interval, number of events for those with elevated troponin I, number of those with elevated troponin I, events in those without elevated troponin T, and number of those without elevated troponin I. Eight trials had odds ratio over one and one had less than one thus suggesting that an elevated troponin I is positively associated with cardiovascular mortality among patients on dialysis. The overall odds ratio is 5.2, with a 95% confidence interval of 2.8 to 9.0.

One study135 used a very high cardiac troponin I cut-point of 2.3 mcg/L. In a sensitivity analysis excluding that study, the estimated risk was similar (OR, 4.5; 2.0 to 9.9).

##### The Association of High-Sensitivity Cardiac Troponin I With Cardiovascular Mortality Among Patients on Dialysis

We did not identify any studies that reported an association with a high-sensitivity troponin I assay and cardiovascular mortality among dialysis only patients.

##### The Association of Cardiac Troponin T With Major Adverse Cardiovascular Events Among Patients on Dialysis

###### Overview

Twelve studies reported results of the association of cardiac troponin T with MACE.26, 87, 91, 96-98, 107, 128, 142, 143, 146, 151.

We included all studies in our meta-analysis. We outlined the overview of inclusion/exclusion in Appendix E, Table 5. The followup time ranged from 0.3 to 5 years.

###### Hazard Ratio for Major Adverse Cardiovascular Events Associated With Elevated Cardiac Troponin T

Only one study presented a HR adjusted for at least age and age/CAD risk-equivalent (HR, 1.90; 95% CI 1.02 to 3.4) (Figure 15). One study adjusted for age but not CAD. One study107 only presented an adjusted HR per 0.01 mcg/L increase in cardiac troponin T as a continuous variable, rather than a cut-point. Therefore a meta-analysis could not be performed.

Figure 15 Hazard ratio of the association of an elevated troponin T with major adverse cardiovascular events among patients on dialysis (stratified by level of adjustment)

* Both studies used a troponin assay that was manufactured by Roche.

CAD = coronary artery disease; CI = confidence interval; HR = hazard ratio; mcg/L = micrograms per liter; yrs = years

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 15 is a forest plot type diagram depicting the pooled hazard ratio, with 95% confidence interval, of the association of an elevated troponin T with major adverse cardiovascular events stratified by level of adjustment among patients on dialysis. Two articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, sample size, and hazard ratio with 95% confidence interval. All trials had hazard ratio over one, thus suggesting that an elevated troponin T is positively associated with major adverse cardiovascular events among patients on dialysis. There is no pooled analysis.

###### Odds Ratio for Major Adverse Cardiovascular Events Associated with Elevated Cardiac Troponin T

Nine studies provided results for number of events in each group making it possible to calculate an unadjusted OR. One study169 only presented an adjusted OR.

We listed the pooled meta-analysis in Figure 16, with an estimated 6-fold risk of MACE for elevated cardiac troponin T (OR, 6.0; 95% CI, 3.5 to 12.0) without significant heterogeneity (I-squared = 35 percent). In a sensitivity analysis including the study with an adjusted OR, the pooled meta-analysis association was slightly lower but still significant (OR, 5.1, 95% CI, 2.9 to 8.9). When we sorted results by year, it did appear that odds ratios were generally progressively larger in magnitude with more current years.

Figure 16 Pooled odds ratio of the association of an elevated troponin T with major adverse cardiovascular events among patients on dialysis (sorted by prevalence)

* Study used a troponin assay manufactured by Roche.

† Study did not report the manufacturer of the troponin assay.

‡ Study used a troponin assay manufactured by Dade.

§ Study used a troponin assay manufactured by Boehringer Mannheim (older assay).

CI = confidence interval; cTnT = cardiac troponin T; elev = elevated; mcg/L = micrograms per liter; MACE = major adverse cardiovascular events; OR = odds ratio; yrs = years

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 16 is a forest plot type diagram depicting the pooled odds ratio, with 95% confidence interval, of the association of an elevated troponin T with major cardiovascular events among patients on dialysis. Nine articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, odds ratio, 95% confidence interval, number of events for those with elevated troponin T, number of those with elevated troponin T, events in those without elevated troponin T, and number of those without elevated troponin T. All had odds ratio risk over one and one had less than one thus suggesting that an elevated troponin T is positively associated with cardiovascular mortality among patients on dialysis. The overall odds ratio is 6.0, with a 95% confidence interval of 3.5 to 12.0

##### The Association of High-Sensitivity Cardiac Troponin T With Major Adverse Cardiovascular Events Among Patients on Dialysis

We did not identify any studies reporting an association of high-sensitivity cardiac troponin T assay with MACE among dialysis patients.

##### The Association of Cardiac Troponin I With Major Adverse Cardiovascular Events Among Patients on Dialysis

###### Overview

We identified 12 studies that reported an association of cardiac troponin I with MACE. We outlined these in Appendix E, Table 6.^70, 93, 96, 103, 120, 123, 128, 129, 142, 143, 146, 151^

###### Hazard Ratio for Major Adverse Cardiovascular Events Associated with Elevated Cardiac Troponin I

No study presented results for the association of cardiac troponin I with MACE using HRs.

###### Odds Ratio for Major Adverse Cardiovascular Events Associated with Elevated Cardiac Troponin I

The pooled meta-analysis, including all nine relevant studies (Figure 17), showed a greater than 6-fold association of troponin I with MACE (OR, 6.3; 95% CI, 3.5 to 13.2) without heterogeneity. We could not include Katerinis et al.93 in the meta-analysis because of zero events, and the inability to generate a log OR. Several studies were small with few events and large CIs; thus, there were widely ranging effect sizes—from OR of 0.7 to 87.0. Heterogeneity I-squared was 0 percent. One study reported an unadjusted OR but not the number of events, and two studies had qualitatively different descriptions of a troponin elevation. We performed sensitivity analyses as described below.

Figure 17 Pooled odds ratio of the association of an elevated troponin I with major adverse cardiovascular events among patients on dialysis (sorted by prevalence)

* Study used a troponin assay manufactured by Dade.

† Study used a troponin assay manufactured by Abbott.

‡ Study used a troponin assay manufactured by Beckman.

§ Study did not report the manufacturer of the troponin assay.

ǁ Study used a troponin assay manufactured by Johnson and Johnson.

¶ Study used a troponin assay manufactured by Ortho.

** Study used a troponin assay manufactured by Diagnostic Products Corporation.

CI = confidence interval; cTnI = cardiac troponin I; elev = elevated; MACE = major adverse cardiovascular event; mcg/L = micrograms per liter; NR = not reported; OR = odds ratio; yrs = years

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 17 is a forest plot type diagram depicting the pooled odds ratio, with 95% confidence interval, of the association of an elevated troponin I with major cardiovascular events among patients on dialysis. Nine articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, odds ratio, 95% confidence interval, number of events for those with elevated troponin T, number of those with elevated troponin T, events in those without elevated troponin T, and number of those without elevated troponin T. All had odds ratio risk over one and one had less than one thus suggesting that an elevated troponin I is positively associated with cardiovascular mortality among patients on dialysis. The overall odds ratio is 6.3, with a 95% confidence interval of 3.5 to 13.2.

Results were similar in a sensitivity analysis including only the five studies that reported the number of events in each arm (so that unadjusted OR could be determined).96, 103, 142, 151 The pooled meta-analysis showed a three-fold association of troponin I with MACE with at least 1 year followup (OR, 3.8; 95% CI, 1.6 to 8.9). Heterogeneity I-squared was 6.9 percent.

In another sensitivity meta-analysis of six studies, which additionally included the study by Hung et al.120 and presented an unadjusted OR but not number of events, the results were similar (OR, 4.3; 95% CI, 2.1 to 8.9). Heterogeneity I-squared was 0 percent.

Finally, we performed an additional sensitivity analysis including two additional studies that had qualitatively different assessments of troponin I rather than a single baseline value. For Katerinis et al.,93 an elevated troponin included only those with troponin elevated for more than 3 months. For Beciani et al.,129 an elevated troponin included those with both consistent and variable elevated troponin levels. As mentioned above, Katerinis et al. had zero events and could not generate a log OR. The pooled meta-analysis was again similar (OR, 4.6; 95% CI, 2.4 to 8.7). Heterogeneity I-squared was 0 percent.

##### The Association of High-Sensitivity Cardiac Troponin I With Major Adverse Cardiovascular Events Among Patients on Dialysis

Assa et al.157 found a high-sensitivity troponin I per 10 ng/L increase to be associated with risk of adverse cardiac events [HR 1.21 (95 percent CI 1.06 – 1.38)].

##### The Association of Cardiac Troponin T or I With Outcomes Among Patients on Dialysis Other Than All-Cause Mortality, Cardiovascular Mortality, or Major Adverse Cardiovascular Events

###### Heart Failure

One study102 reported an approximate 3-fold increased risk for cardiovascular congestion (heart failure) for an elevated cardiac troponin T per 1 mcg/L increase in a multivariate model that also adjusted for age, left ventricular mass, and ejection fraction (HR, 3.0; 95% CI, 1.2 to 7.4). This evaluated troponin T on a continuous scale, not a cut-point.

###### Hospital Admissions

Another study11 did not find that dialysis patients with elevated troponin I (>0.03 mcg/L) had increased risk of hospital admissions for any cause or cardiac cause over a 2-year time period (P not significant).

###### Subsequent Acute Coronary Syndrome

Troyanov et al.109 evaluated risk of first ACS event. Both elevated cardiac troponin T and I predicted risk of ACS over a 3-year followup. For elevated cardiac troponin T (> 0.04 mcg/L; Roche Elecsys), the HR was 3.0 (95% CI, 1.0 to 8.6). For elevated cardiac troponin I (>0.3 mcg/L; Abbott AxSym), the HR was 3.4 (95% CI, 1.6 to 7.3). Both had similar areas under the curve for predicting ACS events at 1.5 years (0.73 vs. 0.77 for cardiac Troponin T and I, respectively).

#### KQ 4.3 Troponin Associations With Short- and Long-Term Outcomes by Subgroups

We presented results for dialysis, nondialysis, and kidney transplant subgroups of CKD patients separately as indicated in previous sections. Regarding dialysis-only cohorts, few studies stratified by other subgroups. Studies were too few to generate meta-analyses for subgroup type. Subgroups described were as follows:

- Persistently elevated troponin levels93
- History of CAD83, 101, 116, 119
- Gender89, 122
- Pro-brain natriuretic peptide levels155
- Diabetes124
- Hypotension-prone120
- Hemodialysis versus peritoneal dialysis.132

#### KQ 4.4 Comparisons Between Troponin Assays To Predict Risk

While many studies evaluated multiple troponin assays in the same population (troponin T vs. troponin I, or multiple troponin I assays by different manufacturers compared with each other), they presented no formal interaction testing. They never included Troponin T and I levels in the same multivariate model adjusted for the other cardiac biomarker. Some studies hinted at a stronger association with troponin T than with troponin I among dialysis patients. However, in our pooled meta-analyses, the effect sizes of the association of adverse events for elevated cardiac troponin were similar for both T and I overall. Therefore, we are unable to draw any specific conclusion about which biomarker is better in the CKD patient. Both cardiac troponin markers T and I were similarly associated with an increased risk for adverse outcomes.

#### Strength of Evidence Among Patients on Dialysis

Tables 34 and 35 describe our strength of evidence grading for KQ4 among patients on dialysis.

Table 34 Association of elevated troponin T or I versus nonelevated troponin T or I in terms of risk stratification among patients on dialysis: Strength of evidence domains

Outcome | Troponin Assay | No. Studies | Risk of Bias Limitations | Directness | Consistency | Precision | Strength of Association | Strength of Evidence
All-cause mortality | Troponin T | 43 observational studies overall; 11 in HR meta-analysis adjusting for at least age and CAD; 5 adjusting for at least age; 24 in unadjusted OR meta-analysis | Medium | Direct | Consistent^*^ | Precise | Adjusted HR 3.00; unadjusted OR 4.69 | Moderate
All-cause mortality | Troponin I | 30 observational studies overall; 7 in HR meta-analysis adjusting for at least age and CAD; 2 adjusting for at least age; 19 in unadjusted OR meta-analysis | Medium | Direct | Consistent^*^ | Precise | Adjusted HR 2.70; unadjusted OR 2.55 | Moderate
All-cause mortality | hs troponin T | 1 observational study | Medium | Direct | NA | Precise | HR 1.4 | Low
All-cause mortality | hs troponin I | 1 observational study | High | No | NA | Imprecise | Per 10 ng/L increase, no association found. | Insufficient
Cardiovascular-specific mortality | Troponin T | 20 observational studies overall; 5 in HR meta-analysis adjusting for at least age and CAD; 1 adjusting for age 9 in unadjusted OR meta-analysis | Medium | Direct | Consistent^*^ | Precise | Adjusted HR 3.31; unadjusted OR 4.26 | Moderate
Cardiovascular-specific mortality | Troponin I | 13 observational studies overall; 3 in HR meta-analysis adjusting for at least age and CAD; 9 in unadjusted OR meta-analysis | Medium | Direct | Consistent | Precise | Adjusted HR 4.20; unadjusted OR 5.18 | Moderate
MACE | Troponin T | 12 observational studies overall; 1 adjusting for at least age and CAD; 1 adjusting for at least age; 9 in unadjusted OR meta-analysis | Medium | Direct | Consistent | Precise | Adjusted HR 1.90; unadjusted OR 5.96 | Moderate
MACE | Troponin I | 12 observational studies overall; 9 in unadjusted OR meta-analysis | High | Direct | Consistent | Precise | Unadjusted OR 6.29 | Low
MACE | hs troponin I | 1 study | Medium | Direct | NA | Imprecise | 6 cases [24%] vs. 0, P = 0.022 | Insufficient

HR = hazard ratio; MACE = major adverse cardiovascular events; OR = odds ratio

* Direction of association was consistent, but high I-squared

Table 35 Association of elevated troponin T or I versus nonelevated troponin T or I in terms of risk stratification among patients on dialysis: Details regarding strength of evidence domains

Outcome | Troponin Assay | Study Design | Risk of Bias Details | Reasons for Downgrading Domains Comments About How Overall Strength of Evidence Derived
All-cause mortality | Troponin T | Observational studies | 23 fair quality and 20 good quality studies | All studies were observational, but there were substantial number of studies with adjusted analysis and the direction of association was consistent with precise estimates.
All-cause mortality | Troponin I | Observational studies | 13 good quality, 16 fair quality, and 1 poor quality studies | All studies were observational design and the heterogeneity was high.
All-cause mortality | hs troponin T | Observational studies | 1 fair quality study: 1 with adjusted analyses | Only one study reported adjusted results. We did not conduct meta-analysis because of different troponin categories.
All-cause mortality | hs troponin I | Observational studies | 1 fair study: 0 with adjusted analyses | Neither studies reported adjusted results. We did not conduct meta-analysis due to different troponin cut-point.
Cardiovascular-specific mortality | Troponin T | Observational studies | 9 fair, 10 good and 1 poor quality studies | All studies were observational, but there were substantial number of studies with adjusted analysis and the direction of association was consistent with precise estimates.
Cardiovascular-specific mortality | Troponin I | Observational studies | 8 fair and 5 good quality studies | Only two studies reported adjusted results and both studies were observational design, but the strength of association was high with precise estimates.
MACE | Troponin T | Observational studies | 6 fair and 6 good quality studies | All studies were observational.
MACE | Troponin I | Observational studies | 6 fair, 2 good, 1 poor quality quality studies | All studies were observational design. No studies reported adjusted results.
MACE | hs troponin I | Observational studies | 1 fair quality study with adjusted analysis | Only one study, presented as continuous variable instead of cut-point.

MACE = major adverse cardiovascular events

### Results for Nondialysis Chronic Kidney Disease Patients

Of the publications meeting criteria for Key Question (KQ) 4, 26 included nondialysis chronic kidney disease (CKD) patients as part or all of the study population.25, 68, 69, 71, 73, 78, 79, 82, 84, 90, 94, 99, 100, 105, 108, 115, 121, 125, 132, 147, 148, 154, 156

We described the results for those that analyzed a pre- or post-kidney transplantation population separately and included them with the results for KQ4.3.

#### KQ 4.2b Troponin Associations With Short- and Long-Term Outcomes Among Nondialysis, Nontransplanted Chronic Kidney Disease Patients

Key Points
- Elevated troponin T and troponin I in nondialysis CKD patients predict all-cause mortality (strength of evidence: moderate). Pooled analysis from studies adjusted for at least age and CAD or risk equivalent found the following associations: (Troponin T: pooled HR, 3.1; 95% CI, 1.1 to 11.0. Troponin I: pooled HR 1.7; 95% CI 1.2 to 2.7.) Similar findings were seen for studies with less adjusted HRs and for pooled meta-analyses for the unadjusted ORs.
- Elevated troponin T is associated with an increased risk of composite cardiac outcome (MACE) in nondialysis CKD patients based on pooled analysis (pooled HR, 2.7; 95% CI, 1.1 to 7.6) (strength of evidence: moderate).
- Studies of MACE outcomes with elevated troponin I that included nondialysis patients also included dialysis patients, and ORs were not statistically significant (strength of evidence: insufficient).
- We identified no studies that examined high-sensitivity troponin I in asymptomatic, nondialysis CKD patients (strength of evidence: insufficient).
- The adjusted analyses in nondialysis CKD populations suggest that elevated high-sensitivity troponin T predicts adverse outcomes (strength of evidence: low).

##### The Association of Cardiac Troponin T With All-Cause Mortality Among Nondialysis Chronic Kidney Disease Patients

Troponin T was the most common troponin assay that studies analyzed in the nondialysis CKD population. Nine reports included an endpoint of all-cause mortality.79, 82, 99, 100, 108, 121, 125, 132, 154 Four reports were not included in pooled analysis due to inclusion of dialysis patients or troponin presented continuously. Two studies analyzed an identical population; therefore, we presented the results from the study reporting an adjusted analysis. We list results in Table 36.^99, 108^

Table 36 Summary of the associations of elevated troponin T with all-cause mortality in patients not on dialysis

Author, Year | Troponin Manufacturer; Cutoff | Population | Followup | n with Elevated Troponin | n (%) with Outcome | n with Nonelevated Troponin | n (%) with Outcome | Summary of Results
Orea-Tejeda, 2010^79^ | Roche; 0.02 mcg/L | Stage 3-5 | 42 months | 21 | 15 (71.4%) | 31 | 9 (29.0%) | OR 2.46; 95% CI 0.90-6.65, P = 0.07
Ilva, 2008^154^ | Roche Elecsys; 0.03 mcg/L | CysC >1.2mg/L for age <50, 1.4mg/L age >50 | 6 months | NR (total n = 29) | NR | NR | NR | OR 1.3; 95% CI 0.7-2.5
Lamb, 2007^99^ | Roche Elecsys; 0.01 mcg/L | Stage 3-5 | 32 months | 95 | 26 (27.4%) | 127 | 13 (10.2%) | HR 2.0; 95% CI 1.0-3.9, P = 0.05 adjusted for age, hemoglobin, CAD
Lamb, 2007^99^ | Roche Elecsys; 0.03 mcg/L | Stage 3-5 | 32 months | 57 | 20 (35.1%) | 165 | 19 (11.5%) | HR 2.1; 95% CI 1.1-4.0, P = 0.03 adjusted for age, hemoglobin, CAD
Feringa, 2006^100^ | Roche Elecsys; 0.03-0.09 mcg/L | Stage 3-5 | 4 years | NR (total n = 558) | NR | NR | NR | HR 4.27; 95% CI 1.75-10.4, P < 0.001 adjusted for age, sex, CAD
Feringa, 2006^100^ | Roche Elecsys; >0.1 mcg/L | Stage 3-5 | 4 years | NR (total n = 558) | NR | NR | NR | HR 5.54; 95% CI 2.92-10.52, P < 0.001 adjusted for age, sex, CAD
Kertai, 2004^121^ | Roche; 0.1 mcg/L | CKD (undefined) | 4 years | 16 | 4 (25%) | 42 | 9 (21.4%) | HR 0.9; 95% CI 0.3-3.3, P = 0.08
Wood, 2003^125^ | Roche Elecsys; 0.1 mcg/L | Cr >500 micromol/L | 2 years | 25 | 13 (52%) | 71 | 10 (14.1%) | HR 1.72; 95% CI 1.08-2.74, P = 0.02 adjusted for age, sex, diabetes, CAD, creatinine
Lowbeer, 2003^132^ | Roche Elecsys; 0.1 mcg/L | Stage 5^*^ | 2.7 years | 34 | NR | 81 | NR | HR 2.66; 95% CI 1.07-10.95, P <0.05 adjusted for age, CVD, malnutrition, DM, sex
Chrysochou, 2009^82^ | Roche Elecsys; 0.03 mcg/L | Stages 1-5^*^ | 40 months | 11 | 8 (72.7%) | 71 | 23 (32.4%) | HR 3.9; 95% CI 1.8-8.5, P = 0.001 (significance was lost when adjusted)

CAD = coronary artery disease; CI = confidence interval; CKD = chronic kidney disease; Cr = creatinine; CysC = cystatin C; HR = hazard ratio; mcg/L = micrograms per liter; mg/L = milligams per liter; NR = not reported; OR = odds ratio

* Included dialysis patients at recruitment or during followup

Two studies presented HR adjusted for at least age and CAD or risk equivalent. Four studies, each reporting a HR and CI, were similar enough to be included in a meta-analysis of HRs.99, 100 with pooled HR 3.4 (1.1 to 11.0) (Figure 18). Although we used the highest troponin T threshold value for the pooled analysis, one study using multiple cutoffs found a significant difference in mortality rate when it compared troponin T less than 0.03 mcg/L with values ranging from 0.03 to 0.09 mcg/L (HR, 4.3; 95% CI, 1.8 to 10.4, P < 0.001) and values greater than 0.1 mcg/L (HR, 5.5; 95% CI, 2.9 to 10.5, P < 0.001).100 One study presented an unadjusted analysis, which was not significant.121

Figure 18 Pooled hazard ratio of the association of an elevated troponin T with all-cause mortality among nondialysis patients

* All studies used a troponin assay that was manufactured by Roche.

CAD = coronary artery disease or risk equivalent; CI = confidence interval; HR = hazard ratio; mcg/L = micrograms per liter; NR = not reported; yrs = years

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 18 is a forest plot type diagram depicting the pooled hazard ratio, with 95% confidence interval, of the association of an elevated troponin T with all-cause mortality stratified by level of adjustment among non-dialysis patients. Three articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, sample size, and hazard ratio with 95% confidence interval. Two trials had hazard ratio over one and one trial less than one thus suggesting that, an elevated troponin T is positively associated with all-cause mortality among non-dialysis patients. The hazard ratio among studies that adjusted for at least age and coronary artery disease is 3.4, with a 95% confidence interval of 1.1 to 11.0.

A second pooled analysis included the five studies that presented ORs or numbers of events from which we could derive ORs (Figure 19).79, 99, 121, 125, 154 All results were unadjusted. Threshold values for troponin T ranged from 0.02 mcg/L to 0.1 mcg/L, although all used a troponin T assay from the same manufacturer. The pooled OR was significant and suggested that an elevated troponin T is a predictor of mortality in nondialysis CKD patients (OR, 3.0; 95% CI, 1.4 to 6.7). One study108 provided adjusted OR but not HR.

Figure 19 Pooled odds ratio of the association of an elevated troponin T with all-cause mortality among nondialysis patients

CI = confidence interval; cTnT = cardiac troponin T; elev = elevated; mcg/L = micrograms per liter; NR = not reported; OR = odds ratio; yrs = years

Boxes indicate individual study point estimates. The box size denotes the weight of the study, with larger boxes contributing more to the pooled estimate. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 19 is a forest plot type diagram depicting the pooled odds ratio, with 95% confidence interval, of the association of an elevated troponin T with all-cause mortality among non-dialysis patients. Five articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, odds ratio, 95% confidence interval, number of events for those with elevated troponin T, number of those with elevated troponin T, events in those without elevated troponin T, and number of those without elevated troponin T. All had odds ratio risk over one and one had less than one thus suggesting that an elevated troponin T is positively associated all-cause mortality among non-dialysis patients. The overall odds ratio is 3.0, with a 95% confidence interval of 1.4 to 6.7.

We did not include two reports of all-cause mortality in either pooled analysis due to the inclusion of dialysis patients. One of these found an elevated troponin T to be a predictor of all-cause mortality after adjustment (HR, 2.7; 95% CI, 1.1 to 11.0; P < 0.05),132 but the other reported a loss of significance when they adjusted data.82

A study by Lamb et al. compared two troponin T cutoff values and found sensitivity and specificity to be 67 and 62 percent, respectively, for a threshold of 0.01 mcg/L, and 51 and 80 percent, respectively, for a threshold of 0.03 mcg/L.99

##### The Association of Cardiac Troponin I With All-Cause Mortality Among Nondialysis Chronic Kidney Disease Patients

We found five studies that assessed troponin I with an outcome of all-cause mortality among nondialysis patients with CKD (Table 37).99, 108, 148, 154, 159 Two studies were used to perform a meta-analysis of HR adjusted for at least age and CAD or risk equivalent. The pooled HR was 1.73 (95% CI, 1.2 to 2.7) (Figure 20).

Table 37 Summary of the associations of elevated troponin I with all-cause mortality in patients not on dialysis

Author, Year | Troponin Manufacturer; Cutoff | Population | Followup | n with Elevated Troponin | n (%) with Outcome | n with Nonelevated Troponin | n (%) with Outcome | Summary of Results
Ilva, 2008^154^ | Abbott Architect; 0.32 mcg/L | CysC >1.2mg/L for age <50, 1.4mg/L age >50 | 6 months | NR (total n = 29) | NR | NR | NR | OR 1.4; 95% CI 0.7-2.8
Lamb, 2007^99^ | Bayer ADVIA; 0.07 mcg/L (TnI Standard) | Stages 3-5 | 32 months | 38 | 12 (31.6%) | 177 | 27 (14.3%) | HR 1.4; 95% CI 0.7-3.0, P = 0.3, adjusted for age, hemoglobin, CAD
Lamb, 2007^99^ | Bayer ADVIA; 0.04 mcg/L (TnI Ultra) | Stage 3-5 | 32 months | 63 | 12 (19.0%) | 129 | 14 (10.9%) | HR 1.9, 95% CI 0.9-3.9, P = 0.08 adjusted for age, hemoglobin, CAD
Musso, 1999^148^ | Sanofi Access; 0.04 mcg/L | CKD (undefined)^*^ | 18 months | 2 | 0 (0%) | 47 | 2 (4.3%) | OR 3.80; 95% CI 0.14-102.2, P = 0.43
Levin, 2014 159 | NR | GFR 15-45 ml/min/1.73m2 | 1 year | 37% | NR | NR | NR | HR 1.68, 95% CI 1.17-2.65; P = 0.005
Abbas, 2005 108 | Bayer ADVIA Centaur | CKD (undefined) | 19 months | 18% | NR | NR | NR | OR 2.4, 95% CI 0.78-7.0 adjusted for age, sex, eGFR, diabetes

CAD = coronary artery disease; CI = confidence interval; CKD = chronic kidney disease; CysC = cystatin C; HR = hazard ratio; mcg/L = micrograms per liter; mg/L = milligrams per liter; NR = not reported; OR = odds ratio; TnI = troponin I

* Included dialysis patients at recruitment or during followup

Figure 20 Pooled hazard ratio of the association of an elevated troponin I with all-cause mortality among non-dialysis patients

* Study used a troponin assay that was manufactured by Bayer.

† Study did not specify the manufacturer of the troponin assay.

CAD = coronary artery disease or risk equivalent; CI = confidence interval; HR = hazard ratio; LLD = lower limit of detection; mcg/L = micrograms per liter; yrs = years

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 20 is a forest plot type diagram depicting the pooled hazard ratio, with 95% confidence interval, of the association of an elevated troponin I with all-cause mortality stratified by level of adjustment among non-dialysis patients. Two articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, sample size, and hazard ratio with 95% confidence interval. Both trials had hazard ratio over one thus suggesting that, an elevated troponin I is positively associated with all-cause mortality among non-dialysis patients. The hazard ratio among studies that adjusted for at least age and coronary artery disease is 1.7, with a 95% confidence interval of 1.2 to 2.7.

One study108 provided adjusted OR but not HR. A small study of heart failure patients with CKD (n = 29) used a short-term followup period of 6 months and found no significant difference in mortality in an unadjusted analysis (OR, 1.4; 95% CI, 0.7 to 2.8).154 There was insufficient data to calculate a pooled OR.

One study identified troponin I as having a sensitivity of 60 percent and a specificity of 73 percent for death with an area under the curve of 0.75 (95% CI. 0.66 to 0.84, P < 0.001).99

Musso et al. studied a small cohort consisting of a combination of dialysis, nondialysis, and post-kidney transplant patients (n = 49), and therefore it was difficult to compare this study with the results from other analyses we presented here.148

##### The Association of Cardiac Troponin T With Major Adverse Cardiovascular Events Among Nondialysis Chronic Kidney Disease Patients

Nine studies evaluated Troponin T in the context of cardiac mortality and MACE outcomes (Table 38).25, 68, 69, 73, 82, 100, 125, 147, 148

Table 38 Summary of the associations of elevated troponin T with major adverse cardiovascular events in patients not on dialysis

Author, Year | Troponin Manufacturer; Cutoff | Outcome | Population | Followup | n with Elevated Troponin | n (%) with Outcome | n with Nonelevated Troponin | n (%) with Outcome | Summary of Results
Feringa, 2006^100^ | Roche Elecsys; 0.03-0.09 mcg/L | Nonfatal MI, death caused by MI, arrhythmia, or CHF, or sudden unexpected death | Stage 3-5 | 4 years | NR (total n = 558) | NR | NR | NR | HR 8.09; 95% CI 2.72-24.05, P < 0.001 adjusted for age, sex, CAD
Feringa, 2006^100^ | Roche Elecsys; >0.1 mcg/L | Nonfatal MI, death caused by MI, arrhythmia, or CHF, or sudden unexpected death | Stage 3-5 | 4 years | NR (total n = 558) | NR | NR | NR | HR 7.05; 95% CI 3.44-14.47, P < 0.001 adjusted for age, sex, CAD
Wood, 2003^125^ | Roche Elecsys; 0.1 mcg/L | Cardiac mortality | Cr >500 micromol/L | 2 years | 25 | 6 (24%) | 71 | 5 (7.0%) | OR 3.41; 95% CI 0.96-12.15, P = 0.06
Musso, 1999^148^ | Boerhinger Enzymum; 0.02 mcg/L | Adverse cardiac event | CKD (undefined)^*^ | 18 months | 23 | 0 (0%) | 26 | 2 (7.7%) | OR 0.22; 95% CI 0.01-4.94, P = 0.34
Chrysochou, 2009^82^ | Roche Elecsys; 0.03 mcg/L | Cardiac mortality | Stages 1-5^*^ | 40 months | 11 | 4 (36.4%) | 71 | 11 (15.5%) | OR 2.34; 95% CI 0.63-8.69, P = 0.20
McMurray, 2011^73^ | Roche 0.01-0.028 mcg/L | All-cause death, stroke, HF, or hospitalization for MI | Stage 3-5 | 10 years | NR (n = 955) | NR | NR | NR | HR 1.42; 95% CI 1.05-1.93, P =0.0001
McMurray, 2011^73^ | Roche >0.028 mcg/L | All-cause death, stroke, HF, or hospitalization for MI | Stage 3-5 | 10 years | NR (n = 955) | NR | NR | NR | HR 1.5; 95% CI 1.06-2.13, P = 0.0001
Goicoechea, 2004^25^ | Roche Elecsys; 0.01 mcg/L | Death, AMI, unstable angina, CHF, arrhythmia, stroke, or stenosis of limb arteries | Stage 3-5 | 12.9 months | 20 | NR | 156 | NR | HR 12.34; 95% CI 4.91-31.02, P = 0.0
Mockel, 1999^147^ | Roche Elecsys; 0.1 mcg/L | AMI, rehospitalization, or death | Stage 5^*^ | 9 months | 10 | NR | 30 | NR | OR 1.03; 95% CI 0.18-5.9, P =0.969
Hasegawa, 2012^68^ | Roche 0.01-0.018 mcg/L | Cardiac death, unstable angina, AMI, or heart failure | Stages 3-5 | 22 months | 111 | 11.5 | 113 | 0.88 | HR 2.5; 95% CI 0.5-11.9 adjusted for age, CAD, diabetes, eGFR (reference Troponin T <0.01 mcg/L)
Hasegawa, 2012^68^ | Roche 0.019-0.032 mcg/L | Cardiac death, unstable angina, AMI, or heart failure | Stages 3-5 | 22 months | 110 | 19 | 113 | 0.88 | HR 3.0; 95% CI 0.7-13.7 adjusted for age, CAD, diabetes, eGFR (reference Troponin T <0.01 mcg/L)
Hasegawa, 2012^68^ | Roche >0.033 mcg/L | Cardiac death, unstable angina, AMI, or heart failure | Stages 3-5 | 22 months | 108 | 41.4 | 113 | 0.88 | HR 6.2; 95% CI 1.4-27.7 adjusted for age, CAD, diabetes, eGFR (reference Troponin T <0.01 mcg/L)
Scheven, 2012^69^ | Roche Modular E170; 0.01 mcg/L | AMI, ischemic cardiovascular disease, or revascularization | Stages 1-5 | >10 years | NR total=1505 | NR | NR | NR | HR 1.5; P = 0.008 adjusted for age, sex, CAD, smoking, BMI, BP, cholesterol, diabetes

AMI = acute myocardial infarction; CAD = coronary artery disease; CHF = congestive heart failure; CII = confidence interval; CKD = chronic kidney disease;

Cr = creatinine; HR = hazard ratio; mcg/L = micrograms per liter; MI = myocardial infarction; NR = not reported; OR = odds ratio

* Included dialysis patients at recruitment or during followup

We pooled four comparable studies that adjusted for at least age and CAD or risk equivalent in an analysis of HRs (Figure 21).68, 69, 73, 100. Threshold values for troponin T ranged from 0.01 mcg/L to 0.1 mcg/L. When Hasegawa et al. separated the high-sensitivity troponin T values into four ranges, only the highest cutoff value of 0.033 mcg/L remained significant (HR, 6.2; 95% CI, 1.4 to 27.7).68. We used the highest cutpoint in our meta-analysis. The result of this pooled analysis was statistically significant (HR, 2.7; 95% CI, 1.1 to 7.6). One additional study presented an unadjusted HR.25

Figure 21 Pooled hazard ratio of the association of an elevated troponin T with major adverse cardiovascular events among nondialysis patients

* All studies used a troponin assay manufactured by Roche.

CAD = coronary artery disease or risk equivalent; CI = confidence interval; HR = hazard ratio; MACE = major adverse cardiovascular event; mcg/L = micrograms per liter; NR = not reported; yrs = years

Boxes indicate individual study point estimates. The width of the horizontal lines represents the 95 percent confidence intervals for each study.

Figure 21 is a forest plot type diagram depicting the pooled hazard ratio, with 95% confidence interval, of the association of an elevated troponin T with major adverse cardiovascular events stratified by the level of adjustment among non-dialysis patients. Five articles are included. The information presented in the plot shows author and year, followup time in years, cutoff value in micrograms per liter, prevalence, sample size, and hazard ratio with 95% confidence interval. All trials had hazard ratio over one, thus suggesting that an elevated troponin T is positively associated with major adverse cardiovascular events among non-dialysis patients. The hazard ratio for studies that adjusted for at least age and coronary artery disease is 2.7, with a 95% confidence interval of 1.1 to 7.6.

We did not include two studies with a MACE outcome in this meta-analysis because of inclusion of dialysis patients.147, 148 Neither of these found a significant association between elevated troponin T and MACE.

Two studies analyzed cardiac mortality; however, these results are difficult to compare as one study included both dialysis and nondialysis patients,82 and the other was comprised of predialysis patients, many of whom began dialysis during the followup period.125 Neither of these found troponin T to be a predictor of MACE in asymptomatic nondialysis patients.

##### The Association of Cardiac Troponin I With Major Adverse Cardiovascular Events Among Nondialysis Chronic Kidney Disease Patients

Two studies assessed the association with troponin I and composite MACE (Figure 22). Both studies combined dialysis and nondialysis patients in a small cohort (n = 49 and 40, respectively). One had a followup period of 18 months, and the other 9 months. The latter used two troponin I assays with different cutoff values (0.35 mcg/L for Dade Stratus, and 1.6 mcg/L for Behring OPUS Plus). Results were insignificant for both, despite different rates of elevated and nonelevated troponins within the population. Although results were not statistically significant, the study designs made it impossible to draw the conclusion that troponin I does not predict MACE in this population.147, 148

Figure 22 Summary of the associations of elevated troponin I with major adverse cardiac events in patients not on dialysis

AMI = acute myocardial infarction; CI = confidence interval; CKD = chronic kidney disease; mcg/L = micrograms per liter; NR = not reported; OR = odds ratio

* Included dialysis patients at recruitment or during followup

Figure 22 is a forest plot type diagram depicting the odds ratio, with 95% confidence interval, of the association of an elevated troponin I with major adverse cardiac events among patients not on dialysis. Three articles are included. The information presented in the plot shows author and year, followup time in years, population, manufacturer of assay, cutoff value in micrograms per liter, outcome, odds ratio, and 95% confidence interval. All trials had odds ratio over one, thus suggesting that an elevated troponin I is positively associated with major adverse cardiac events among patients not on dialysis.

##### The Association of High-Sensitivity Troponin T With Risk Among Nondialysis Chronic Kidney Disease Patients

Quiroga et al.,156 using a sensitive cutpoint of troponin T >0.01 ng/L (0.00001 mcg/L), found that elevated troponin T was associated with a 2-fold increase risk of cardiovascular event (unadjusted OR, 2.08; 95 percent CI 1.03-4.16) (Figure 23).

Figure 23 Summary of the associations of high-sensitivity elevated troponin T with major adverse cardiac events in patients not on dialysis

CI = confidence interval; CKD = chronic kidney disease; CVD = cardiovascular disease; mcg/L = micrograms per liter; OR = odds ratio; yrs = years

Figure 23 is a forest plot type diagram depicting the odds ratio, with 95% confidence interval, of the association of an elevated high-sensitivity troponin T with major adverse cardiac events among patients not on dialysis. One articles is included. The information presented in the plot shows author and year, followup time in years, population, manufacturer of assay, cutoff value in micrograms per liter, outcome, odds ratio, and 95% confidence interval. The trial had odds ratio over one, thus suggesting that an elevated troponin T is positively associated with major adverse cardiac events among patients not on dialysis.

##### The Association of High-Sensitivity Troponin I With Risk Among Nondialysis Chronic Kidney Disease Patients

No studies meeting criteria for KQ4 addressed high-sensitivity troponin I assays.

#### KQ 4.3b Troponin Associations With Short- and Long-Term Outcomes by Subgroups of Nondialysis Patients

We presented results for dialysis patients and nondialysis (nontransplanted) CKD patients above in the respective sections.

We found some additional subgroup analyses investigating troponin associations in pre- and post-kidney transplant patients as follows:

Key Points
- We did not identify any studies that analyzed troponin I in pre-kidney transplant patients (strength of evidence: insufficient).
- In pre-kidney transplant populations, data suggested that elevated troponin T values are predictors of adverse outcomes. These studies included both dialysis and nondialysis patients (strength of evidence: moderate).
- Elevations in both troponin I and T are likely predictors of adverse outcomes in the post-kidney transplant period (strength of evidence: low).
- In nondialysis CKD patients with a history of CAD, an elevated troponin I is a predictor of adverse cardiac event (strength of evidence: low).
- Studies did not assess subgroups by age, sex, ethnicity, and comorbidities other than CAD in the asymptomatic, nondialysis CKD population (strength of evidence: insufficient).

##### Pre-Transplantation

We identified three reports of end-stage renal disease (ESRD) patients referred for kidney transplantation, some of whom had been on dialysis and some of whom had not.84, 90, 105 All of these evaluated troponin T (Table 39). Two studies by the same author considered a group of 644 ESRD patients with troponin T values that were measured upon referral for kidney transplant. The studies presented results for the entire population, regardless of whether the patient went on to receive transplantation. During a mean followup of 11.5 months, elevated troponin T of greater than 0.01 mcg/L was associated with death in a model adjusting for sex, age, albumin, history of stroke, body mass index, smoking status, cholesterol, hemoglobin, and time on dialysis (HR, 1.6; 95% CI, 1.1 to 2.5, P = 0.022).90

Table 39 Summary of the association with risk of elevated troponin T in pre-kidney transplantation populations

Author, Year | Troponin Manufacturer; Cutoff | Population | Outcome | Followup | n | Summary of Results
Hickson, 2008^90^ | Roche 0.01 mcg/L | Stage 5^*^ | All-cause mortality | 11.5 months | 603 | HR 1.64; 95% CI 1.07-2.51, P = 0.022 adjusted for sex, race, albumin, stroke, BMI, smoking, time on dialysis, cholesterol, hemoglobin
Sharma, 2006^105^ | Roche Elecsys; 0.06 mcg/L | Stage 5^*^ | All-cause mortality | 3 years | 117 | OR 7.14; 95% CI 5.71-10.22, P = 0.004
Hickson, 2009^84^ | Roche 0.01 mcg/L | Stage 5^*^ | AMI, revascularization, peripheral vascular intervention, or stroke | 54 months | 603 | HR 1.58; 95% CI 1.12-2.22, P = 0.008 adjusted for sex, race, albumin, stroke, BMI, smoking, time on dialysis, cholesterol, hemoglobin

AMI = acute myocardial infarction; BMI = body mass index; CI = confidence interval; HR = hazard ratio; mcg/L = micrograms per liter; NR = not reported; OR = odds ratio

* Included dialysis patients at recruitment or during followup

In a subsequent study of only patients who underwent kidney transplantation, pre-transplant elevated troponin T of at least 0.01 mcg/L was associated with composite MACE (AMI, revascularization, peripheral vascular intervention, or stroke) during a mean followup period of 28.4 months. The study observed this association in a model adjusted for age, time on dialysis, ejection fraction, and delayed graft functioning (HR, 1.6; 95% CI, 1.1 to 2.2, P = 0.008).84

In a study of 117 patients, Sharma et al. found a troponin T of greater than 0.06 mcg/L to be associated with all-cause mortality in a 3-year followup (OR, 7.1; 95% CI, 5.7 to 10.2, P = 0.004), though results were not adjusted. The associated area under the curve was 0.82 (95% CI, 0.64 to 0.99; P =0.02), with a sensitivity of 75 percent and a specificity of 72 percent.105

##### Post-Transplantation

In the studies of post-kidney transplantation populations, three evaluated troponin I71, 78, 115 and one evaluated troponin T.94

###### Troponin I

We describe the results for studies of troponin I in Table 40. A cohort of 34 dialysis patients with troponin I measured prior to and following renal transplantation found that 47.1 percent of the patients had an increase in troponin I value after surgery as compared with pre-surgery levels, although none exceeded the cutoff value of 2.3 mcg/L. The study followed patients for 22 months, and none experienced cardiac events or died.115

Table 40 Summary of the association of elevated troponin I with risk in post-kidney transplantation populations

Author, Year | Troponin Manufacturer; Cutoff | Outcome | Followup | n with Elevated Troponin | n (%) with Outcome | n with Nonelevated Troponin | n (%) with Outcome | Summary of Results
Bozbas, 2004^115^ | DPC Immulite; 2.3 mcg/L | All-cause mortality | 22 months | 0 | 0 (0.0%) | 34 | 0 (0.0%) | OR 69.0; 95% CI 0.56-8490.3801, P = 0.08
Shroff, 2012^71^ | Ortho Clinical Diagnostics Vitros; 0.04 mcg/L | All-cause mortality | In-Hospital | 95 | 3 (3.2%) | 281 | 5 (1.8%) | OR 1.77; 95% CI 0.42-7.57, P = 0.44
Shroff, 2012^71^ | Ortho Clinical Diagnostics Vitros; 0.04 mcg/L | All-cause mortality | 1 year | 95 | 6 (6.3%) | 281 | 0 (0.0%) | OR 38.32; 95% CI 2.14-686.63, P = 0.01
Shroff, 2012^71^ | Ortho Clinical Diagnostics Vitros; 0.04 mcg/L | Revascularization | 1 year | 95 | 5 (5.3%) | 281 | 4 (1.4%) | OR 3.70; 95% CI 0.97-14.05, P = 0.05
Claes, 2010^78^ | Siemens Heterogeneous; 0.07 mcg/L | AMI, revascularization, or death due to an ischemic event | 3 months | NR (total n = 331) | NR | NR | NR | OR 0.104, 95% CI 0.026-0.407 adjusted for CAD; OR 0.096, 95% CI 0.027-0.339 adjusted for age (reference groups reversed compared with other studies)

AMI = acute myocardial infarction; CAD = coronary artery disease; CI = confidence interval; mcg/L = micrograms per liter; NR = not reported; OR = odds ratio

Another study considering postoperative troponin I values following kidney transplant used a threshold value of 0.04 mcg/L. This reported in-hospital acute myocardial infarction (AMI), 1-year all-cause mortality, and 1-year coronary revascularization. Of 376 in-hospital patients, the study observed AMI in 6.3 percent of those with elevated troponin I, but did not observe AMI in patients with a nonelevated value (P < 0.001). Rates of in-hospital death and revascularization were not significant. At 1-year followup, the difference in mortality between the two groups was not significant, and the rate of revascularization (percutaneous coronary intervention or coronary artery bypass graft) was marginally significant at 5.3 percent of those in the elevated troponin I group compared with 1.4 percent of those in the nonelevated troponin I group (P = 0.49); however, neither percutaneous coronary intervention or coronary artery bypass graft was significant when assessed alone.71

A similar study of 331 post-kidney transplantation patients used a higher cutoff value of 0.07 mcg/L. The study defined MACE as AMI, revascularization, or death due to an ischemic event and reported after a 3-month followup. The study noted a significantly lower rate of outcome in those with a nonelevated troponin I when adjusted for a history of CAD (OR, 0.1; 95% CI, 0.03 to 0.4) or age (OR, 0.1; 95% CI 0.03 to 0.3).78

###### Troponin T

We listed the results of troponin T studies in post-kidney transplantation populations in Table 41. A study of 372 patients, who had received kidney transplant in the past 3 months, used troponin T measurements with a cutoff level of 0.03 mcg/L to analyze outcomes during a maximum followup period of 1,626 days. They found a higher rate of all-cause mortality in those with an elevated troponin T (57.1 percent) versus a nonelevated test (14.0 percent) (P < 0.001). The study found a similar result for an outcome of cardiac mortality (33.3 vs. 4.8 percent, P < 0.001). In a model adjusted for age, sex, smoking history, diabetes, blood pressure, cholesterol, body mass index, and blood biochemical levels, troponin T remained significantly associated with all-cause mortality (Exp(β) 2.7; 95% CI, 1.2 to 6.1, P < 0.001).94

Table 41 Summary of the association of elevated troponin T with risk in post-kidney transplantation populations

Author, Year | Troponin Manufacturer; Cutoff | Outcome | Followup | n with Elevated Troponin | n (%) with Outcome | n with Nonelevated Troponin | n (%) with Outcome | Summary of Results
Connolly, 2008^94^ | Roche Elecsys; 0.03 mcg/L | All-cause mortality | 4.5 years | 21 | 12 (57.1%) | 351 | 49 (14.0%) | Exp(β) 2.70; 95% CI 1.20-6.06, P < 0.001 adjusted for age, sex, smoking, DM, BP, cholesterol, BMI, growth hormone, phosphate, parathormone
Connolly, 2008^94^ | Roche Elecsys; 0.03 mcg/L | Cardiac mortality | 4.5 years | 21 | 7 (33.3%) | 351 | 17 (4.8%) | OR 6.88; 95% CI 2.57-18.42, P = 0.0001

BMI = body mass index; BP = blood pressure; CI = confidence interval; DM = diabetes mellitus; Exp(β) = exponent beta; mcg/L = micrograms per liter; OR = odds ratio

##### Other Subgroups

In a subgroup of post-kidney transplantation patients (n = 78) with a history of CAD, Claes et al. found an increased risk of MACE for every 0.01 mcg/L increase in troponin I in an adjusted analysis (OR, 1.2; 95% CI, 1.0 to 1.4, P = 0.038).78

No other studies performed subgroup analysis in nondialysis populations.

#### Strength of Evidence (Nondialysis Chronic Kidney Disease Patients)

Tables 42 and 43 describe our strength of evidence grading for KQ4 among nondialysis patients. Tables 44 and 45 describe our strength of evidence grading for KQ4 among subgroups of nondialysis patients.

Table 42 Association of elevated troponin T or I versus nonelevated troponin T or I in terms of risk stratification among nondialysis patients: Strength of evidence domains

Outcome | Troponin Assay | Study design: No. Studies | Risk of Bias Limitations | Directness | Consistency | Precision | Strength of Association | Strength of evidence
All-cause mortality | Troponin T | 9 observational studies overall; 2 in HR meta-analysis adjusting for at least age and CA; 5 in OR meta-analysis | Medium | Direct | Consistent | Precise | Adjusted HR 3.41; unadjusted OR 2.98 | Moderate
All-cause mortality | Troponin I | 4 observational studies overall; 2 in HR meta-analysis adjusting for at least age and CAD | Medium | Direct | Consistent | Precise | Adjusted HR 1.73; OR range 1.4 to 3.80 | Moderate
MACE | Troponin T | 9 observational studies; 4 in HR meta-analysis adjusted for at least age and CAD | High | Direct | Consistent | Precise | Adjusted HR 2.69 | Moderate
MACE | Troponin I | 2 observational studies overall including both dialysis and non-dialysis patients | High | Indirect | Consistent | Imprecise | N/A (combined dialysis and non-dialysis) | Insufficient
MACE | High- sensitivity troponin T | 1 observational study (unadjusted analysis) | Medium | Direct | NA | Precise | OR 2.08 | Insufficient

CAD = coronary artery disease; HR = hazard ratio; MACE = major adverse cardiovascular events; OR = odds ratio

Table 43 Association of elevated troponin T or I versus nonelevated troponin T or I in terms of risk stratification among nondialysis patients: Details regarding strength of evidence domains

Outcome | Troponin Assay | Study Design | Risk of Bias Details | Reasons for Downgrading Domains Comments About How Overall Strength of Evidence Derived
All-cause mortality | Troponin T | Observational studies | 6 fair quality and 3 good quality studies, none of were blinded, 8 studies with adjusted analyses | Despite the heterogeneity in the study designs, there was a consistent direction of association. Pooled HRs and ORs remained consistent in the sensitivity analyses. Estimates were precise.
All-cause mortality | Troponin I | Observational studies | 2 fair quality and 2 good quality studies, none of the studies were blinded, 2 studies adjusted for confounders | Pooled HR analysis suggested a significant association.
MACE | Troponin T | Observational studies | 6 fair quality and 3 good quality studies, 1 study blinded the laboratory researchers and clinicians, 5 studies adjusted for confounders | Despite the heterogeneity in the study designs, the studies reporting hazard ratios showed a consistent direction of association and precise estimates.
MACE | Troponin I | Observational studies | 2 studies of fair quality, neither blinded outcome assessors and neither adjusted for confounders | Two small studies with imprecise estimates and wide confidence intervals. Both studies included dialysis and nondialysis patients, so neither directly assesses the risk among nondialysis patients.
MACE | High sensitivity troponin T | Prospective | 1 fair quality study | This one observational study had precise estimates.

MACE = major adverse cardiovascular events

Table 44 Association of elevated troponin T or I versus nonelevated troponin T or I in terms of risk stratification among subgroups of nondialysis patients: Strength of evidence domains

Subgroup | Troponin Assay | Study design: No. Studies (N) | Risk of Bias Limitations | Directness | Consistency | Precision | Strength of Association | Strength of Evidence
Pre-transplantation | Troponin T | 3 (720) | Medium | Direct | Consistent | Precise | HR range 1.58 to 1.64; OR 7.14 | Moderate
Post-transplantation | Troponin T | 1 (372) | Low | Direct | n/a | Precise | Exp(Beta) 2.70; OR 6.88 | Low
Post-transplantation | Troponin I | 3 (741) | High | Direct | Consistent | Imprecise | OR range 1.77 to 69.0 | Low
History of CAD; Nondialysis | Troponin I | 1 (78) | Low | Direct | n/a | Precise | OR 1.17 | Low

CAD = coronary artery disease; HR = hazard ratio; N/A = not applicable; OR = odds ratio

Table 45 Association of elevated troponin T or I versus nonelevated troponin T or I in terms of risk stratification among subgroups of nondialysis patients: Details regarding strength of evidence domains

Subgroup | Troponin Assay | Study Design | Risk of Bias Details | Reasons for Downgrading Domains Comments About How Overall Strength of Evidence Derived
Pre-transplantation | Troponin T | Observational studies | 2 good quality studies and 1 fair quality study, 2 studies adjusted for confounders, none of the studies were blinded | Effect estimates showed a consistent direction of association and were precise.
Post-transplantation | Troponin T | Observational study | 1 study of good quality | There was only one study. Effect estimates were direct and precise, but consistency could not be determined.
Post-transplantation | Troponin I | Observational studies | 1 good quality, 1 fair quality, and 1 poor quality observational study, only 1 study provided adjusted results | Despite the heterogeneity in study designs and study quality, the studies showed a consistent direction of association. The effect estimates had wide confidence intervals.
History of CAD; Nondialysis | Troponin I | Observational study | 1 good quality study with adjusted analysis | There was only one study. Effect estimates were direct and precise, but consistency could not be determined.

CAD = coronary artery disease