# References

1 Jaffe AS, Vasile VC, Milone M, Saenger AK, Olson KN, Apple FS. Diseased skeletal muscle: a noncardiac source of increased circulating concentrations of cardiac troponin T. Journal of the American College of Cardiology. Oct. 18. 2011;58(17):1819-24. [pmid: 21962825].
2 Venge P, James S, Jansson L, Lindahl B. Clinical performance of two highly sensitive cardiac troponin I assays. Clinical chemistry. Jan. 2009;55(1):109-16. [pmid: 18988756].
3 Hassan AK, Bergheanu SC, Hasan-Ali H, Liem SS, van der Laarse A, Wolterbeek R, et al. Usefulness of peak troponin-T to predict infarct size and long-term outcome in patients with first acute myocardial infarction after primary percutaneous coronary intervention. The American journal of cardiology. Mar. 15. 2009;103(6):779-84. [pmid: 19268731].
4 Roongsritong C, Warraich I, Bradley C. Common causes of troponin elevations in the absence of acute myocardial infarction: incidence and clinical significance. Chest. May. 2004;125(5):1877-84. [pmid: 15136402].
5 Morrow DA, Cannon CP, Jesse RL, Newby LK, Ravkilde J, Storrow AB, et al. National Academy of Clinical Biochemistry Laboratory Medicine Practice Guidelines: clinical characteristics and utilization of biochemical markers in acute coronary syndromes. Clinical chemistry. Apr. 2007;53(4):552-74. [pmid: 17384001].
6 Mahajan VS, Jarolim P. How to interpret elevated cardiac troponin levels. Circulation. Nov. 22. 2011;124(21):2350-4. [pmid: 22105197].
7 Apple FS, Ler R, Murakami MM. Determination of 19 cardiac troponin I and T assay 99th percentile values from a common presumably healthy population. Clinical chemistry. Nov. 2012;58(11):1574-81. [pmid: 22983113].
8 Apple FS. A new season for cardiac troponin assays: it's time to keep a scorecard. Clinical chemistry. Jul. 2009;55(7):1303-6. [pmid: 19478023].
9 deFilippi C, Seliger SL, Kelley W, Duh SH, Hise M, Christenson RH, et al. Interpreting cardiac troponin results from high-sensitivity assays in chronic kidney disease without acute coronary syndrome. Clinical chemistry. Sep. 2012;58(9):1342-51. [pmid: 22791885].
10 National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases Division of Kidney, Urologic, and Hematologic Diseases. United States Renal Data System 2011 Annual Data Report: Atlas of End-Stage Renal Disease in the United States. Available at: http://wwwusrdsorg/2011/pdf/v2_00_intro_11pdf. 2011;Vol. 2.
11 Khan IA, Wattanasuwan N, Mehta NJ, Tun A, Singh N, Singh HK, et al. Prognostic value of serum cardiac troponin I in ambulatory patients with chronic renal failure undergoing long-term hemodialysis: a two-year outcome analysis. Journal of the American College of Cardiology. Oct. 2001;38(4):991-8. [pmid: 11583870].
12 Wang AY, Lai KN. Use of cardiac biomarkers in end-stage renal disease. Journal of the American Society of Nephrology : JASN. Sep. 2008;19(9):1643-52. [pmid: 18322158].
13 Newby LK, Jesse RL, Babb JD, Christenson RH, De Fer TM, Diamond GA, et al. ACCF 2012 expert consensus document on practical clinical considerations in the interpretation of troponin elevations: a report of the American College of Cardiology Foundation task force on Clinical Expert Consensus Documents. Journal of the American College of Cardiology. Dec. 11. 2012;60(23):2427-63. [pmid: 23154053].
14 Diris JH, Hackeng CM, Kooman JP, Pinto YM, Hermens WT, van Dieijen-Visser MP. Impaired renal clearance explains elevated troponin T fragments in hemodialysis patients. Circulation. Jan. 6. 2004;109(1):23-5. [pmid: 14691043].
15 Ellis K, Dreisbach AW, Lertora JL. Plasma elimination of cardiac troponin I in end-stage renal disease. Southern medical journal. Oct. 2001;94(10):993-6. [pmid: 11702827].
16 Jaffe AS. Chasing troponin: how low can you go if you can see the rise?. Journal of the American College of Cardiology. Nov. 7. 2006;48(9):1763-4. [pmid: 17084246].
17 Thygesen K, Alpert JS, Jaffe AS, Simoons ML, Chaitman BR, White HD, et al. Third universal definition of myocardial infarction. Journal of the American College of Cardiology. Oct. 16. 2012;60(16):1581-98. [pmid: 22958960].
18 Dobre M, Brateanu A, Rashidi A, Rahman M. Electrocardiogram abnormalities and cardiovascular mortality in elderly patients with CKD. Clinical journal of the American Society of Nephrology : CJASN. Jun. 2012;7(6):949-56. [pmid: 22461533].
19 Wu AH, Jaffe AS, Apple FS, Jesse RL, Francis GL, Morrow DA, et al. National Academy of Clinical Biochemistry laboratory medicine practice guidelines: use of cardiac troponin and B-type natriuretic peptide or N-terminal proB-type natriuretic peptide for etiologies other than acute coronary syndromes and heart failure. Clinical chemistry. Dec. 2007;53(12):2086-96. [pmid: 17954494].
20 Anderson JL, Adams CD, Antman EM, Bridges CR, Califf RM, Casey DE Jr, et al. ACC/AHA 2007 guidelines for the management of patients with unstable angina/non-ST-Elevation myocardial infarction: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Writing Committee to Revise the 2002 Guidelines for the Management of Patients With Unstable Angina/Non-ST-Elevation Myocardial Infarction) developed in collaboration with the American College of Emergency Physicians, the Society for Cardiovascular Angiography and Interventions, and the Society of Thoracic Surgeons endorsed by the American Association of Cardiovascular and Pulmonary Rehabilitation and the Society for Academic Emergency Medicine. Journal of the American College of Cardiology. Aug. 14. 2007;50(7):e1-e157. [pmid: 17692738].
21 Morrow DA, Cannon CP, Rifai N, Frey MJ, Vicari R, Lakkis N, et al. Ability of minor elevations of troponins I and T to predict benefit from an early invasive strategy in patients with unstable angina and non-ST elevation myocardial infarction: results from a randomized trial. JAMA : the journal of the American Medical Association. Nov. 21. 2001;286(19):2405-12. [pmid: 11712935].
22 Needham DM, Shufelt KA, Tomlinson G, Scholey JW, Newton GE. Troponin I and T levels in renal failure patients without acute coronary syndrome: a systematic review of the literature. The Canadian journal of cardiology. Oct. 2004;20(12):1212-8. [pmid: 15494773].
23 Khan NA, Hemmelgarn BR, Tonelli M, Thompson CR, Levin A. Prognostic value of troponin T and I among asymptomatic patients with end-stage renal disease: a meta-analysis. Circulation. Nov. 15. 2005;112(20):3088-96. [pmid: 16286604].
24 Goicoechea M, de Vinuesa SG, Gomez-Campdera F, Luno J. Predictive cardiovascular risk factors in patients with chronic kidney disease (CKD). Kidney international Supplement. Jan. 2005;(93):S35-8. [pmid: 15613066].
25 Goicoechea M, Garca de Vinuesa S, Gomez-Campdera F, Gutierrez MJ, Blanco P, Amann R, et al. Clinical significance of cardiac troponin T levels in chronic kidney disease patients: predictive value for cardiovascular risk. American journal of kidney diseases : the official journal of the National Kidney Foundation. May. 2004;43(5):846-53. [pmid: 15112175].
26 Iliou MC, Fumeron C, Benoit MO, Tuppin P, Calonge VM, Moatti N, et al. Prognostic value of cardiac markers in ESRD: Chronic Hemodialysis and New Cardiac Markers Evaluation (CHANCE) study. American journal of kidney diseases : the official journal of the National Kidney Foundation. Sep. 2003;42(3):513-23. [pmid: 12955679].
27 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. Journal of epidemiology and community health. Jun. 1998;52(6):377-84. [pmid: 9764259].
28 AHRQ. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. 2011. Rockville, MD. (AHRQ Publication No. 10(11)-EHC063-EF).
29 AHQR. Methods Guide for Medical Test Reviews. Rockville, MD. 2010.
30 Hardy RJ, Thompson SG. A likelihood approach to meta-analysis with random effects. Stat Med. Mar. 30. 1996;15(6):619-29. [pmid: 8731004].
31 Cornell JE, Mulrow CD, Localio R, Stack CB, Meibohm AR, Guallar E, et al. Random-Effects Meta-analysis of Inconsistent Effects: A Time for Change. Annals of internal medicine. Feb. 18. 2014;160(4).
32 Tierney JF, Stewart LA, Ghersi D, Burdett S, Sydes MR. Practical methods for incorporating summary time-to-event data into meta-analysis. Trials. 2007;8:16. [pmid: 17555582].
33 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. (Clinical research ed). Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
34 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. Dec. 1994;50(4):1088-101. [pmid: 7786990].
35 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. (Clinical research ed). Sep. 13. 1997;315(7109):629-34. [pmid: 9310563].
36 AHRQ. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions -AHRQ and the Effective Health Care Program: An Update. Rockville, MD. 2012.
37 Flores-Solis LM, Hernandez-Dominguez JL, Otero-Gonzalez A, Gonzalez-Juanatey JR. Cardiac troponin I and creatine kinase MB isoenzyme in patients with chronic renal failure. Nefrologia : publicacion oficial de la Sociedad Espanola Nefrologia. 2012;32(6):809-18. [pmid: 23169364].
38 Sukonthasarn A, Ponglopisit S. Diagnostic level of cardiac troponin T in patients with chronic renal dysfunction, a pilot study. Journal of the Medical Association of Thailand = Chotmaihet thangphaet. Sep. 2007;90(9):1749-58. [pmid: 17957915].
39 Alcalai R, Planer D, Culhaoglu A, Osman A, Pollak A, Lotan C. Acute coronary syndrome vs nonspecific troponin elevation: clinical predictors and survival analysis. Archives of internal medicine. Feb. 12. 2007;167(3):276-81. [pmid: 17296884].
40 Flores LM, Hernandez Dominguez JL, Otero A, Gonzalez Juanatey JR. Cardiac troponin I determination in patients with chronic renal failure. Nefrologia : publicacion oficial de la Sociedad Espanola Nefrologia. 2006;26(1):107-12. [pmid: 16649431].
41 Noeller TP, Meldon SW, Peacock WF, Emerman CL, McErlean ES, Vanlente F, et al. Troponin T in elders with suspected acute coronary syndromes. The American journal of emergency medicine. Jul. 2003;21(4):293-7. [pmid: 12898485].
42 Fehr T, Knoflach A, Ammann P, Pei P, Binswanger U. Differential use of cardiac troponin T versus I in hemodialysis patients. Clinical nephrology. Jan. 2003;59(1):35-9. [pmid: 12572929].
43 McCullough PA, Nowak RM, Foreback C, Tokarski G, Tomlanovich MC, Khoury NE, et al. Performance of multiple cardiac biomarkers measured in the emergency department in patients with chronic kidney disease and chest pain. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. Dec. 2002;9(12):1389-96. [pmid: 12460842].
44 Ikeda J, Zenimoto M, Kita M, Mori M. Usefulness of cardiac troponin I in patients with acute myocardial infarction. Rinsho byori The Japanese journal of clinical pathology. Oct. 2002;50(10):982-6. [pmid: 12451679].
45 Apple FS, Christenson RH, Valdes R Jr, Andriak AJ, Berg A, Duh SH, et al. Simultaneous rapid measurement of whole blood myoglobin, creatine kinase MB, and cardiac troponin I by the triage cardiac panel for detection of myocardial infarction. Clinical chemistry. Feb. 1999;45(2):199-205. [pmid: 9931041].
46 Bhagavan NV, Goldstein AP, Honda SA, Uyehara J, Blaisdell J, Sugiyama C, et al. Role of cardiac troponin I in the evaluation of myocardial injury. Journal of clinical laboratory analysis. 1998;12(5):276-9. [pmid: 9773957].
47 Martin GS, Becker BN, Schulman G. Cardiac troponin-I accurately predicts myocardial injury in renal failure. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. Jul. 1998;13(7):1709-12.
48 Chenevier-Gobeaux C, Meune C, Freund Y, Wahbi K, Claessens YE, Doumenc B, et al. Influence of age and renal function on high-sensitivity cardiac troponin T diagnostic accuracy for the diagnosis of acute myocardial infarction. The American journal of cardiology. Jun. 15. 2013;111(12):1701-7. [pmid: 23540652].
49 Haaf P, Reichlin T, Twerenbold R, Hoeller R, Rubini Gimenez M, Zellweger C, et al. Risk stratification in patients with acute chest pain using three high-sensitivity cardiac troponin assays. European heart journal. 2013. Jul. 14.
50 Pfortmueller CA, Funk GC, Marti G, Leichtle AB, Fiedler GM, Schwarz C, et al. Diagnostic performance of high-sensitive troponin T in patients with renal insufficiency. The American journal of cardiology. Dec. 15. 2013;112(12):1968-72. [pmid: 24091183].
51 Barthelemy O, Cayla G, Silvain J, O'Connor SA, Bellemain-Appaix A, Beygui F, et al. Optimal time for catheterization in NSTE-ACS patients with impaired renal function: Insights from the ABOARD Study. International journal of cardiology. 2012. Jul. 12.
52 Acharji S, Baber U, Mehran R, Fahy M, Kirtane AJ, Lansky AJ, et al. Prognostic significance of elevated baseline troponin in patients with acute coronary syndromes and chronic kidney disease treated with different antithrombotic regimens: a substudy from the ACUITY trial. Circulation Cardiovascular interventions. Apr. 2012;5(2):157-65. [pmid: 22354934].
53 Chew HC. Cardiac troponin T in acute coronary syndrome with renal insufficiency. Asian cardiovascular & thoracic annals. Aug. 2008;16(4):284-7. [pmid: 18670019].
54 Kontos MC, Jamal SM, Ornato JP, Tatum JL, Jesse RL, Anderson FP. Comparison of the modification of diet in renal disease and the Cockcroft-Gault equations for predicting mortality in patients admitted for exclusion of myocardial ischemia. The American journal of cardiology. Jul. 15. 2008;102(2):140-5. [pmid: 18602510].
55 Melloni C, Alexander KP, Milford-Beland S, Newby LK, Szczech LA, Pollack CV, et al. Prognostic value of troponins in patients with non-ST-segment elevation acute coronary syndromes and chronic kidney disease. Clinical cardiology. Mar. 2008;31(3):125-9. [pmid: 18383049].
56 Apple FS, Pearce LA, Doyle PJ, Otto AP, Murakami MM. Cardiac troponin risk stratification based on 99th percentile reference cutoffs in patients with ischemic symptoms suggestive of acute coronary syndrome: influence of estimated glomerular filtration rates. American journal of clinical pathology. Apr. 2007;127(4):598-603. [pmid: 17369136].
57 Bueti J, Krahn J, Karpinski M, Bohm C, Fine A, Rigatto C. Troponin I testing in dialysis patients presenting to the emergency room: does troponin I predict the 30-day outcome?. Nephron Clinical practice. 2006;103(4):c129-36. [pmid: 16636580].
58 Kontos MC, Garg R, Anderson FP, Tatum JL, Ornato JP, Jesse RL. Outcomes in patients admitted for chest pain with renal failure and troponin I elevations. American heart journal. Oct. 2005;150(4):674-80. [pmid: 16209963].
59 Kontos MC, Garg R, Anderson FP, Tatum JL, Ornato JP, Jesse RL. Predictive power of ejection fraction and renal failure in patients admitted for chest pain without ST elevation in the troponin era. American heart journal. Oct. 2005;150(4):666-73. [pmid: 16209962].
60 Han JH, Lindsell CJ, Ryan RJ, Gibler WB. Changes in cardiac troponin T measurements are associated with adverse cardiac events in patients with chronic kidney disease. The American journal of emergency medicine. Jul. 2005;23(4):468-73. [pmid: 16032613].
61 Aviles RJ, Askari AT, Lindahl B, Wallentin L, Jia G, Ohman EM, et al. Troponin T levels in patients with acute coronary syndromes, with or without renal dysfunction. The New England journal of medicine. Jun. 27. 2002;346(26):2047-52. [pmid: 12087140].
62 Gruberg L, Fuchs S, Waksman R, Pichard AD, Kent KM, Laird JR, et al. Prognostic value of cardiac troponin I elevation after percutaneous coronary intervention in patients with chronic renal insufficiency: a 12-month outcome analysis. Catheterization and cardiovascular interventions : official journal of the Society for Cardiac Angiography & Interventions. Feb. 2002;55(2):174-9. [pmid: 11835642].
63 Wayand D, Baum H, Schatzle G, Scharf J, Neumeier D. Cardiac troponin T and I in end-stage renal failure. Clinical chemistry. Sep. 2000;46(9):1345-50. [pmid: 10973864].
64 Van Lente F, McErlean ES, DeLuca SA, Peacock WF, Rao JS, Nissen SE. Ability of troponins to predict adverse outcomes in patients with renal insufficiency and suspected acute coronary syndromes: a case-matched study. Journal of the American College of Cardiology. Feb. 1999;33(2):471-8. [pmid: 9973028].
65 Geerse DA, van Berkel M, Vogels S, Kooman JP, Konings CJ, Scharnhorst V. Moderate elevations of high-sensitivity cardiac troponin I and B-type natriuretic peptide in chronic hemodialysis patients are associated with mortality. Clinical chemistry and laboratory medicine : CCLM / FESCC. Dec. 10. 2012:1-8.
66 Artunc F, Mueller C, Breidthardt T, Twerenbold R, Peter A, Thamer C, et al. Sensitive troponins--which suits better for hemodialysis patients? Associated factors and prediction of mortality. PloS one. 2012;7(10):e47610. [pmid: 23077650].
67 Kalaji FR, Albitar S. Predictive value of cardiac troponin T and I in hemodialysis patients. Saudi journal of kidney diseases and transplantation : an official publication of the Saudi Center for Organ Transplantation, Saudi Arabia. Sep. 2012;23(5):939-45.
68 Hasegawa M, Ishii J, Kitagawa F, Kanayama K, Takahashi H, Ozaki Y, et al. Prognostic value of highly sensitive troponin T on cardiac events in patients with chronic kidney disease not on dialysis. Heart and vessels. 2012. Aug. 23.
69 Scheven L, de Jong PE, Hillege HL, Lambers Heerspink HJ, van Pelt LJ, Kootstra JE, et al. High-sensitive troponin T and N-terminal pro-B type natriuretic peptide are associated with cardiovascular events despite the cross-sectional association with albuminuria and glomerular filtration rate. European heart journal. Sep. 2012;33(18):2272-81. [pmid: 22740385].
70 Gaiki MR, DeVita MV, Michelis MF, Panagopoulos G, Rosenstock JL. Troponin I as a prognostic marker of cardiac events in asymptomatic hemodialysis patients using a sensitive troponin I assay. International urology and nephrology. Dec. 2012;44(6):1841-5. [pmid: 22311387].
71 Shroff GR, Akkina SK, Miedema MD, Madlon-Kay R, Herzog CA, Kasiske BL. Troponin I levels and postoperative myocardial infarction following renal transplantation. American journal of nephrology. 2012;35(2):175-80. [pmid: 22286592].
72 Holden RM, Beseau D, Booth SL, Adams MA, Garland JS, Morton RA, et al. FGF-23 is associated with cardiac troponin T and mortality in hemodialysis patients. Hemodialysis international International Symposium on Home Hemodialysis. Jan. 2012;16(1):53-8. [pmid: 22099949].
73 McMurray JJ, Uno H, Jarolim P, Desai AS, de Zeeuw D, Eckardt KU, et al. Predictors of fatal and nonfatal cardiovascular events in patients with type 2 diabetes mellitus, chronic kidney disease, and anemia: an analysis of the Trial to Reduce cardiovascular Events with Aranesp (darbepoetin-alfa) Therapy (TREAT). American heart journal. Oct. 2011;162(4):748-55 e3. [pmid: 21982669].
74 Hallen J, Madsen L, Ladefoged S, Fagerland MW, Serebruany VL, Agewall S, et al. Incremental value of a combination of cardiac troponin T, N-terminal pro-brain natriuretic peptide and C-reactive protein for prediction of mortality in end-stage renal disease. Scandinavian journal of urology and nephrology. Mar. 2011;45(2):151-8. [pmid: 21091090].
75 Codognotto M, Piccoli A, Zaninotto M, Mion MM, Ruzza L, Barchita A, et al. Effect of a dialysis session on the prognostic values of NT-proBNP, troponins, endothelial damage and inflammation biomarkers. Journal of nephrology. Jul-Aug. 2010;23(4):465-71. [pmid: 20540041].
76 McGill D, Talaulikar G, Potter JM, Koerbin G, Hickman PE. Over time, high-sensitivity TnT replaces NT-proBNP as the most powerful predictor of death in patients with dialysis-dependent chronic renal failure. Clinica chimica acta; international journal of clinical chemistry. Jul. 4. 2010;411(13-14):936-9.
77 Hickman PE, McGill DA, Talaulikar G, Hiremagalur B, Bromley J, Rahman A, et al. Prognostic efficacy of cardiac biomarkers for mortality in dialysis patients. Internal medicine journal. Dec. 2009;39(12):812-8. [pmid: 20233242].
78 Claes K, Bammens B, Evenepoel P, Kuypers D, Coosemans W, Darius T, et al. Troponin I is a predictor of acute cardiac events in the immediate postoperative renal transplant period. Transplantation. Feb. 15. 2010;89(3):341-6. [pmid: 20145526].
79 Orea-Tejeda A, Sanchez-Gonzalez LR, Castillo-Martinez L, Valdespino-Trejo A, Sanchez-Santillan RN, Keirns-Davies C, et al. Prognostic value of cardiac troponin T elevation is independent of renal function and clinical findings in heart failure patients. Cardiology journal. 2010;17(1):42-8. [pmid: 20104456].
80 Kostrubiec M, Labyk A, Pedowska-Wloszek J, Pacho S, Wojciechowski A, Jankowski K, et al. Assessment of renal dysfunction improves troponin-based short-term prognosis in patients with acute symptomatic pulmonary embolism. Journal of thrombosis and haemostasis : JTH. Apr. 2010;8(4):651-8. [pmid: 20088923].
81 Petrovic D, Stojimirovic BB. Cardiac troponins: outcome predictors in hemodialysis patients. Journal of artificial organs : the official journal of the Japanese Society for Artificial Organs. 2009;12(4):258-63. [pmid: 20035399].
82 Chrysochou C, Manzoor S, Wright J, Roberts SA, Wood G, McDowell G, et al. Role of renal function and cardiac biomarkers (NT-proBNP and Troponin) in determining mortality and cardiac outcome in atheromatous renovascular disease. Kidney & blood pressure research. 2009;32(5):373-9. [pmid: 19887825].
83 Bagheri N, Taziki O, Falaknazi K. C- Reactive protein, cardiac troponin T and low albumin are predictors of mortality in hemodialysis patients. Saudi journal of kidney diseases and transplantation : an official publication of the Saudi Center for Organ Transplantation, Saudi Arabia. Sep. 2009;20(5):789-93.
84 Hickson LT, El-Zoghby ZM, Lorenz EC, Stegall MD, Jaffe AS, Cosio FG. Patient survival after kidney transplantation: relationship to pretransplant cardiac troponin T levels. American journal of transplantation : official journal of the American Society of Transplantation and the American Society of Transplant Surgeons. Jun. 2009;9(6):1354-61.
85 Roberts MA, Hare DL, Macmillan N, Ratnaike S, Sikaris K, Ierino FL. Serial increased cardiac troponin T predicts mortality in asymptomatic patients treated with chronic haemodialysis. Annals of clinical biochemistry. Jul. 2009;46(Pt 4):291-5. [pmid: 19454539].
86 Trape J, Perez A, Naval I, Escudero J, Comerma I, Sans A, et al. Nt-proBNP in haemodialysis patients: a preliminary study. Scandinavian journal of clinical and laboratory investigation. 2008;68(5):415-20. [pmid: 19172698].
87 Sahinarslan A, Guz G, Okyay K, Mutluay R, Yalcin R, Bali M, et al. Prognostic value of troponin T and homocysteine in patients with end-stage renal disease. Turk Kardiyoloji Dernegi arsivi : Turk Kardiyoloji Derneginin yayin organidir. Sep. 2008;36(6):382-7. [pmid: 19155641].
88 Kang EW, Na HJ, Hong SM, Shin SK, Kang SW, Choi KH, et al. Prognostic value of elevated cardiac troponin I in ESRD patients with sepsis. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. May. 2009;24(5):1568-73.
89 Hocher B, Kalk P, Godes M, Liefeldt L, Ziebig R, Stasch JP, et al. Gender-dependent impact of risk factors for cardiovascular and non-cardiovascular mortality in end-stage renal disease patients on haemodialysis. Kidney & blood pressure research. 2008;31(5):360-6. [pmid: 19023219].
90 Hickson LJ, Cosio FG, El-Zoghby ZM, Gloor JM, Kremers WK, Stegall MD, et al. Survival of patients on the kidney transplant wait list: relationship to cardiac troponin T. American journal of transplantation : official journal of the American Society of Transplantation and the American Society of Transplant Surgeons. Nov. 2008;8(11):2352-9.
91 Han SH, Choi HY, Kim DK, Moon SJ, Lee JE, Yoo TH, et al. Elevated cardiac troponin T predicts cardiovascular events in asymptomatic continuous ambulatory peritoneal dialysis patients without a history of cardiovascular disease. American journal of nephrology. 2009;29(2):129-35. [pmid: 18719346].
92 Helleskov Madsen L, Ladefoged S, Hildebrandt P, Atar D. Comparison of four different cardiac troponin assays in patients with end-stage renal disease on chronic haemodialysis. Acute cardiac care. 2008;10(3):173-80. [pmid: 18608043].
93 Katerinis I, Nguyen QV, Magnin JL, Descombes E. Cardiac findings in asymptomatic chronic hemodialysis patients with persistently elevated cardiac troponin I levels. Renal failure. 2008;30(4):357-62. [pmid: 18569907].
94 Connolly GM, Cunningham R, McNamee PT, Young IS, Maxwell AP. Troponin T is an independent predictor of mortality in renal transplant recipients. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. Mar. 2008;23(3):1019-25.
95 Satyan S, Light RP, Agarwal R. Relationships of N-terminal pro-B-natriuretic peptide and cardiac troponin T to left ventricular mass and function and mortality in asymptomatic hemodialysis patients. American journal of kidney diseases : the official journal of the National Kidney Foundation. Dec. 2007;50(6):1009-19. [pmid: 18037101].
96 Brunet P, Oddoze C, Paganelli F, Indreies M, Faure V, Opris-Saveanu A, et al. Cardiac troponins I and T in hemodialysis patients without acute coronary syndrome. International journal of cardiology. Sep. 26. 2008;129(2):205-9. [pmid: 17662483].
97 Sommerer C, Beimler J, Schwenger V, Heckele N, Katus HA, Giannitsis E, et al. Cardiac biomarkers and survival in haemodialysis patients. European journal of clinical investigation. May. 2007;37(5):350-6. [pmid: 17461980].
98 Wang AY, Lam CW, Wang M, Chan IH, Goggins WB, Yu CM, et al. Prognostic value of cardiac troponin T is independent of inflammation, residual renal function, and cardiac hypertrophy and dysfunction in peritoneal dialysis patients. Clinical chemistry. May. 2007;53(5):882-9. [pmid: 17395709].
99 Lamb EJ, Kenny C, Abbas NA, John RI, Webb MC, Price CP, et al. Cardiac troponin I concentration is commonly increased in nondialysis patients with CKD: experience with a sensitive assay. American journal of kidney diseases : the official journal of the National Kidney Foundation. Apr. 2007;49(4):507-16. [pmid: 17386318].
100 Feringa HH, Bax JJ, de Jonge R, Elhendy A, van Domburg RT, Dunkelgrun M, et al. Impact of glomerular filtration rate on minor troponin T elevations for risk assessment in patients undergoing operation for abdominal aortic aneurysm or lower extremity arterial obstruction. The American journal of cardiology. Dec. 1. 2006;98(11):1515-8. [pmid: 17126662].
101 Kanwar M, Hashem M, Rosman H, Kamalakannan D, Cheema A, Ali A, et al. Usefulness of clinical evaluation, troponins, and C-reactive protein in predicting mortality among stable hemodialysis patients. The American journal of cardiology. Nov. 1. 2006;98(9):1283-7. [pmid: 17056347].
102 Wang AY, Lam CW, Yu CM, Wang M, Chan IH, Lui SF, et al. Troponin T, left ventricular mass, and function are excellent predictors of cardiovascular congestion in peritoneal dialysis. Kidney international. Aug. 2006;70(3):444-52. [pmid: 16871255].
103 Vichairuangthum K, Leowattana W, Ong-Ajyooth L, Pokum S. The relationship between serum concentration of cardiac troponin I in chronic renal failure patients and cardiovascular events. Journal of the Medical Association of Thailand = Chotmaihet thangphaet. May. 2006;89(5):714-20. [pmid: 16756060].
104 Havekes B, van Manen JG, Krediet RT, Boeschoten EW, Vandenbroucke JP, Dekker FW. Serum troponin T concentration as a predictor of mortality in hemodialysis and peritoneal dialysis patients. American journal of kidney diseases : the official journal of the National Kidney Foundation. May. 2006;47(5):823-9. [pmid: 16632021].
105 Sharma R, Gaze DC, Pellerin D, Mehta RL, Gregson H, Streather CP, et al. Ischemia-modified albumin predicts mortality in ESRD. American journal of kidney diseases : the official journal of the National Kidney Foundation. Mar. 2006;47(3):493-502. [pmid: 16490629].
106 Sharma R, Gaze DC, Pellerin D, Mehta RL, Gregson H, Streather CP, et al. Cardiac structural and functional abnormalities in end stage renal disease patients with elevated cardiac troponin T. Heart (British Cardiac Society). Jun. 2006;92(6):804-9. [pmid: 16216854].
107 Conway B, McLaughlin M, Sharpe P, Harty J. Use of cardiac troponin T in diagnosis and prognosis of cardiac events in patients on chronic haemodialysis. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. Dec. 2005;20(12):2759-64.
108 Abbas NA, John RI, Webb MC, Kempson ME, Potter AN, Price CP, et al. Cardiac troponins and renal function in nondialysis patients with chronic kidney disease. Clinical chemistry. Nov. 2005;51(11):2059-66. [pmid: 16166165].
109 Troyanov S, Ly QH, Schampaert E, Ammann H, Lalumiere G, Madore F, et al. Diagnostic specificity and prognostic value of cardiac troponins in asymptomatic chronic haemodialysis patients: a three year prospective study. Heart (British Cardiac Society). Sep. 2005;91(9):1227-8. [pmid: 16103574].
110 Sharma R, Pellerin D, Gaze DC, Shah JS, Streather CP, Collinson PO, et al. Dobutamine stress echocardiography and cardiac troponin T for the detection of significant coronary artery disease and predicting outcome in renal transplant candidates. European journal of echocardiography : the journal of the Working Group on Echocardiography of the European Society of Cardiology. Oct. 2005;6(5):327-35.
111 Hojs R, Ekart R, Hojs Fabjan T, Balon BP, Gorenjak M. Cardiac troponin T (cTnT) in hemodialysis patients with asymptomatic and symptomatic atherosclerosis. Archives of medical research. Jul-Aug. 2005;36(4):367-71. [pmid: 15950076].
112 Duman D, Tokay S, Toprak A, Oktay A, Ozener IC, Unay O. Elevated cardiac troponin T is associated with increased left ventricular mass index and predicts mortality in continuous ambulatory peritoneal dialysis patients. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. May. 2005;20(5):962-7.
113 Abaci A, Ekici E, Oguzhan A, Tokgoz B, Utas C. Cardiac troponins T and I in patients with end-stage renal disease: the relation with left ventricular mass and their prognostic value. Clinical cardiology. Dec. 2004;27(12):704-9. [pmid: 15628116].
114 Fernandez-Reyes MJ, Mon C, Heras M, Guevara P, Garcia MC, Sanchez R, et al. Predictive value of troponin T levels for ischemic heart disease and mortality in patients on hemodialysis. Journal of nephrology. Sep-Oct. 2004;17(5):721-7. [pmid: 15593041].
115 Bozbas H, Korkmaz ME, Atar I, Eroglu S, Ozin B, Yildirir A, et al. Serum levels of cardiac enzymes before and after renal transplantation. Clinical cardiology. Oct. 2004;27(10):559-62. [pmid: 15553307].
116 Ie EH, Klootwijk PJ, Weimar W, Zietse R. Significance of acute versus chronic troponin T elevation in dialysis patients. Nephron Clinical practice. 2004;98(3):c87-92. [pmid: 15528943].
117 Hussein M, Mooij J, Roujouleh H, Al Shenawi O. Cardiac troponin-I and its prognostic significance in a dialysis population. Hemodialysis international International Symposium on Home Hemodialysis. Oct. 1. 2004;8(4):332-7. [pmid: 19379438].
118 Apple FS, Murakami MM, Pearce LA, Herzog CA. Multi-biomarker risk stratification of N-terminal pro-B-type natriuretic peptide, high-sensitivity C-reactive protein, and cardiac troponin T and I in end-stage renal disease for all-cause death. Clinical chemistry. Dec. 2004;50(12):2279-85. [pmid: 15364888].
119 Boulier A, Jaussent I, Terrier N, Maurice F, Rivory JP, Chalabi L, et al. Measurement of circulating troponin Ic enhances the prognostic value of C-reactive protein in haemodialysis patients. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. Sep. 2004;19(9):2313-8.
120 Hung SY, Hung YM, Fang HC, Yeh JH, Hung GC, Wu CJ, et al. Cardiac troponin I and creatine kinase isoenzyme MB in patients with intradialytic hypotension. Blood purification. 2004;22(4):338-43. [pmid: 15218282].
121 Kertai MD, Boersma E, Klein J, Van Urk H, Bax JJ, Poldermans D. Long-term prognostic value of asymptomatic cardiac troponin T elevations in patients after major vascular surgery. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. Jul. 2004;28(1):59-66.
122 Hocher B, Ziebig R, Krause R, Asmus G, Neumayer HH, Liefeldt L, et al. Relaxin is an independent risk factor predicting death in male patients with end-stage kidney disease. Circulation. May. 18. 2004;109(19):2266-8. [pmid: 15136497].
123 Roberts MA, Fernando D, Macmillan N, Proimos G, Bach LA, Power DA, et al. Single and serial measurements of cardiac troponin I in asymptomatic patients on chronic hemodialysis. Clinical nephrology. Jan. 2004;61(1):40-6. [pmid: 14964456].
124 Hocher B, Ziebig R, Altermann C, Krause R, Asmus G, Richter CM, et al. Different impact of biomarkers as mortality predictors among diabetic and nondiabetic patients undergoing hemodialysis. Journal of the American Society of Nephrology : JASN. Sep. 2003;14(9):2329-37. [pmid: 12937310].
125 Wood GN, Keevil B, Gupta J, Foley R, Bubtana A, McDowell G, et al. Serum troponin T measurement in patients with chronic renal impairment predicts survival and vascular disease: a 2 year prospective study. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. Aug. 2003;18(8):1610-5.
126 Choy JB, Armstrong PW, Ulan RA, Campbell PM, Gourishankar S, Prosser CI, et al. Do cardiac troponins provide prognostic insight in hemodialysis patients?. The Canadian journal of cardiology. Jul. 2003;19(8):907-11. [pmid: 12876611].
127 deFilippi C, Wasserman S, Rosanio S, Tiblier E, Sperger H, Tocchi M, et al. Cardiac troponin T and C-reactive protein for predicting prognosis, coronary atherosclerosis, and cardiomyopathy in patients undergoing long-term hemodialysis. JAMA : the journal of the American Medical Association. Jul. 16. 2003;290(3):353-9. [pmid: 12865376].
128 Peetz D, Schutt S, Sucke B, Faldum A, Wandel E, Hafner G, et al. Prognostic value of troponin T, troponin I, and CK-MBmass in patients with chronic renal failure. Medizinische Klinik (Munich, Germany : 1983). Apr. 15. 2003;98(4):188-92.
129 Beciani M, Tedesco A, Violante A, Cipriani S, Azzarito M, Sturniolo A, et al. Cardiac troponin I (2nd generation assay) in chronic haemodialysis patients: prevalence and prognostic value. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. May. 2003;18(5):942-6.
130 Scott B, Deman A, Peeters P, Van den Branden C, Stolear JC, Van Camp G, et al. Cardiac troponin T and malondialdehyde modified plasma lipids in haemodialysis patients. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. Apr. 2003;18(4):737-42.
131 Farkouh ME, Robbins MJ, Zafar MU, Shimbo D, Davidson KW, Puttappa R, et al. Association between troponin I levels and mortality in stable hemodialysis patients. The American journal of medicine. Feb. 15. 2003;114(3):224-6. [pmid: 12637137].
132 Lowbeer C, Stenvinkel P, Pecoits-Filho R, Heimburger O, Lindholm B, Gustafsson SA, et al. Elevated cardiac troponin T in predialysis patients is associated with inflammation and predicts mortality. Journal of internal medicine. Feb. 2003;253(2):153-60. [pmid: 12542555].
133 Apple FS, Murakami MM, Pearce LA, Herzog CA. Predictive value of cardiac troponin I and T for subsequent death in end-stage renal disease. Circulation. Dec. 3. 2002;106(23):2941-5. [pmid: 12460876].
134 Lowbeer C, Gutierrez A, Gustafsson SA, Norrman R, Hulting J, Seeberger A. Elevated cardiac troponin T in peritoneal dialysis patients is associated with CRP and predicts all-cause mortality and cardiac death. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. Dec. 2002;17(12):2178-83.
135 Yakupoglu U, Ozdemir FN, Arat Z, Haberal A, Agca E, Bilgin N. Can troponin-I predict cardiovascular mortality due to myocardial injury in hemodialysis patients?. Transplantation proceedings. Sep. 2002;34(6):2033-4. [pmid: 12270303].
136 Mallamaci F, Zoccali C, Parlongo S, Tripepi G, Benedetto FA, Cutrupi S, et al. Troponin is related to left ventricular mass and predicts all-cause and cardiovascular mortality in hemodialysis patients. American journal of kidney diseases : the official journal of the National Kidney Foundation. Jul. 2002;40(1):68-75. [pmid: 12087563].
137 Deegan PB, Lafferty ME, Blumsohn A, Henderson IS, McGregor E. Prognostic value of troponin T in hemodialysis patients is independent of comorbidity. Kidney international. Dec. 2001;60(6):2399-405. [pmid: 11737616].
138 Ishii J, Nomura M, Okuma T, Minagawa T, Naruse H, Mori Y, et al. Risk stratification using serum concentrations of cardiac troponin T in patients with end-stage renal disease on chronic maintenance dialysis. Clinica chimica acta; international journal of clinical chemistry. Oct. 2001;312(1-2):69-79.
139 Lang K, Schindler S, Forberger C, Stein G, Figulla HR. Cardiac troponins have no prognostic value for acute and chronic cardiac events in asymptomatic patients with end-stage renal failure. Clinical nephrology. Jul. 2001;56(1):44-51. [pmid: 11499658].
140 Ooi DS, Zimmerman D, Graham J, Wells GA. Cardiac troponin T predicts long-term outcomes in hemodialysis patients. Clinical chemistry. Mar. 2001;47(3):412-7. [pmid: 11238290].
141 Dierkes J, Domrose U, Westphal S, Ambrosch A, Bosselmann HP, Neumann KH, et al. Cardiac troponin T predicts mortality in patients with end-stage renal disease. Circulation. Oct. 17. 2000;102(16):1964-9. [pmid: 11034946].
142 Porter GA, Norton T, Bennett WM. Long term follow up of the utility of troponin T to assess cardiac risk in stable chronic hemodialysis patients. Clinical laboratory. 2000;46(9-10):469-76. [pmid: 11034532].
143 Heeschen C, Deu A, Langenbrink L, Goldmann BU, Hamm CW. Analytical and diagnostic performance of troponin assays in patients suspicious for acute coronary syndromes. Clinical biochemistry. Jul. 2000;33(5):359-68. [pmid: 11018687].
144 Ooi DS, Veinot JP, Wells GA, House AA. Increased mortality in hemodialyzed patients with elevated serum troponin T: a one-year outcome study. Clinical biochemistry. Nov. 1999;32(8):647-52. [pmid: 10638948].
145 Stolear JC, Georges B, Shita A, Verbeelen D. The predictive value of cardiac troponin T measurements in subjects on regular haemodialysis. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. Aug. 1999;14(8):1961-7.
146 Roppolo LP, Fitzgerald R, Dillow J, Ziegler T, Rice M, Maisel A. A comparison of troponin T and troponin I as predictors of cardiac events in patients undergoing chronic dialysis at a Veteran's Hospital: a pilot study. Journal of the American College of Cardiology. Aug. 1999;34(2):448-54. [pmid: 10440158].
147 Mockel M, Schindler R, Knorr L, Muller C, Heller G Jr, Stork TV, et al. Prognostic value of cardiac troponin T and I elevations in renal disease patients without acute coronary syndromes: a 9-month outcome analysis. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. Jun. 1999;14(6):1489-95.
148 Musso P, Cox I, Vidano E, Zambon D, Panteghini M. Cardiac troponin elevations in chronic renal failure: prevalence and clinical significance. Clinical biochemistry. Mar. 1999;32(2):125-30. [pmid: 10211629].
149 Porter GA, Norton T, Bennett WB. Troponin T, a predictor of death in chronic haemodialysis patients. European heart journal. Nov. Suppl N. 1998;19:N34-7. [pmid: 9857937].
150 Morton AR, Collier CP, Ali N, Dagnone LE. Cardiac troponin I in patients receiving renal replacement therapy. ASAIO journal (American Society for Artificial Internal Organs : 1992). Sep-Oct. 1998;44(5):M433-5. [pmid: 9804466].
151 Apple FS, Sharkey SW, Hoeft P, Skeate R, Voss E, Dahlmeier BA, et al. Prognostic value of serum cardiac troponin I and T in chronic dialysis patients: a 1-year outcomes analysis. American journal of kidney diseases : the official journal of the National Kidney Foundation. Mar. 1997;29(3):399-403. [pmid: 9041216].
152 Wang AYM, Lam CW, Chan IH, Wang M, Lui SF, Sanderson JE. Sudden cardiac death in end-stage renal disease patients: A 5-year prospective analysis. NDT Plus. 2010;3:iii291.
153 Svensson M, Gorst-Rasmussen A, Schmidt EB, Jorgensen KA, Christensen JH. NT-pro-BNP is an independent predictor of mortality in patients with end-stage renal disease. Clinical nephrology. 2009;71(4):380-6. [pmid: 19356370].
154 Ilva T, Lassus J, Siirila-Waris K, Melin J, Peuhkurinen K, Pulkki K, et al. Clinical significance of cardiac troponins I and T in acute heart failure. European journal of heart failure. 2008;10(8):772-9. [pmid: 18599345].
155 Le Goff C, Bovy C, Aldenhoff MC, Krzesinski JM, Chapelle JP. Three-year prognostic interest of cardiac troponin T (cTnT) and amino-terminal pro-B-natriuretic peptide (NT-proBNP) in hemodialyzed patients. Immuno-Analyse et Biologie Specialisee. 2007;22(6):377-83.
156 Quiroga B, Verdalles U, Reque J, Garcia de Vinuesa S, Goicoechea M, Luno J. Cardiovascular events and mortality in chronic kidney disease (stages I-IV). Nefrologia : publicacion oficial de la Sociedad Espanola Nefrologia. Jul. 19. 2013;33(4):539-45. [pmid: 23897186].
157 Assa S, Gansevoort RT, Westerhuis R, Kobold AC, Voors AA, de Jong PE, et al. Determinants and prognostic significance of an intra-dialysis rise of cardiac troponin I measured by sensitive assay in hemodialysis patients. Clinical research in cardiology : official journal of the German Cardiac Society. Jun. 2013;102(6):439-45. [pmid: 23397594].
158 Wolley M, Stewart R, Curry E, Davidson J, White H, Pilmore H. Variation in and prognostic importance of troponin T measured using a high-sensitivity assay in clinically stable haemodialysis patients. Clinical Kidney Journal. 2013;6(4):402-9.
159 Levin A, Rigatto C, Barrett B, Madore F, Muirhead N, Holmes D, et al. Biomarkers of inflammation, fibrosis, cardiac stretch and injury predict death but not renal replacement therapy at 1 year in a Canadian chronic kidney disease cohort. Nephrology, dialysis, transplantation : official publication of the European Dialysis and Transplant Association - European Renal Association. May. 2014;29(5):1037-47.
160 Farshid A, Pathak R, Shadbolt B, Arnolda L, Talaulikar G. Diastolic function is a strong predictor of mortality in patients with chronic kidney disease. BMC nephrology. 2013;14:280. [pmid: 24359445].
161 Bayes-Genis A, Zamora E, de Antonio M, Galan A, Vila J, Urrutia A, et al. Soluble ST2 serum concentration and renal function in heart failure. Journal of cardiac failure. Nov. 2013;19(11):768-75. [pmid: 24263122].
162 Alam A, Palumbo A, Mucsi I, Barre PE, Sniderman AD. Elevated troponin I levels but not low grade chronic inflammation is associated with cardiac-specific mortality in stable hemodialysis patients. BMC nephrology. 2013;14:247. [pmid: 24206774].
163 Hassan HC, Howlin K, Jefferys A, Spicer ST, Aravindan AN, Suryanarayanan G, et al. High-sensitivity troponin as a predictor of cardiac events and mortality in the stable dialysis population. Clinical chemistry. Feb. 2014;60(2):389-98. [pmid: 24185551].
164 Bassand JP, Hamm CW, Ardissino D, Boersma E, Budaj A, Fernandez-Aviles F, et al. Guidelines for the diagnosis and treatment of non-ST-segment elevation acute coronary syndromes. European heart journal. Jul. 2007;28(13):1598-660. [pmid: 17569677].
165 Alpert JS, Thygesen K, Antman E, Bassand JP. Myocardial infarction redefined--a consensus document of The Joint European Society of Cardiology/American College of Cardiology Committee for the redefinition of myocardial infarction. Journal of the American College of Cardiology. Sep. 2000;36(3):959-69. [pmid: 10987628].
166 Douketis JD, Crowther MA, Stanton EB, Ginsberg JS. Elevated cardiac troponin levels in patients with submassive pulmonary embolism. Archives of internal medicine. Jan. 14. 2002;162(1):79-81. [pmid: 11784223].
167 Wang AY, Lam CW, Chan IH, Wang M, Lui SF, Sanderson JE. Sudden cardiac death in end-stage renal disease patients: a 5-year prospective analysis. Hypertension. Aug. 2010;56(2):210-6. [pmid: 20606110].
168 Vestergaard P, Mosekilde L. Cohort study on effects of parathyroid surgery on multiple outcomes in primary hyperparathyroidism. BMJ. (Clinical research ed). Sep. 6. 2003;327(7414):530-4. [pmid: 12958111].
169 Allie DE, Hebert CJ, Patlola R, Lirtzman MD, Wyatt CH, Keller VA, et al. A review of the early experience with Targeted Renal Therapy for renal function preservation during endovascular and surgical treatments for cardiovascular disease. EuroIntervention : journal of EuroPCR in collaboration with the Working Group on Interventional Cardiology of the European Society of Cardiology. May. 2007;3(1):121-7.
170 Javed U, Aftab W, Ambrose JA, Wessel RJ, Mouanoutoua M, Huang G, et al. Frequency of elevated troponin I and diagnosis of acute myocardial infarction. The American journal of cardiology. Jul. 1. 2009;104(1):9-13. [pmid: 19576313].
171 Ng SM, Krishnaswamy P, Morrisey R, Clopton P, Fitzgerald R, Maisel AS. Mitigation of the clinical significance of spurious elevations of cardiac troponin I in settings of coronary ischemia using serial testing of multiple cardiac markers. The American journal of cardiology. Apr. 15. 2001;87(8):994-9. A4. [pmid: 11305993].
172 Palamalai V, Murakami MM, Apple FS. Diagnostic performance of four point of care cardiac troponin I assays to rule in and rule out acute myocardial infarction. Clinical biochemistry. 2013. Jul. 11.
173 Dohi T, Kasai T, Miyauchi K, Takasu K, Kajimoto K, Kubota N, et al. Prognostic impact of chronic kidney disease on 10-year clinical outcomes among patients with acute coronary syndrome. Journal of cardiology. Dec. 2012;60(6):438-42. [pmid: 23063662].
174 Sarnak MJ, Levey AS, Schoolwerth AC, Coresh J, Culleton B, Hamm LL, et al. Kidney disease as a risk factor for development of cardiovascular disease: a statement from the American Heart Association Councils on Kidney in Cardiovascular Disease, High Blood Pressure Research, Clinical Cardiology, and Epidemiology and Prevention. Circulation. Oct. 28. 2003;108(17):2154-69. [pmid: 14581387].
175 Apple FS. Counterpoint: Standardization of cardiac troponin I assays will not occur in my lifetime. Clinical chemistry. Jan. 2012;58(1):169-71. [pmid: 21940657].