# Methods

This topic was nominated via the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program's Web site. Our Evidence-based Practice Center established a team and a protocol to develop the evidence report. The project involved formulating and refining the questions, developing a protocol with input from selected technical experts, performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, synthesizing the evidence, and submitting the report for peer review.

## Topic Refinement

A panel of Key Informants was recruited to provide input on the selection and refinement of the questions to be examined. We posted our draft Key Questions (KQs) on the AHRQ Effective Health Care Program's Web site in March 2012 for public comment. With input from the Key Informants, representatives of AHRQ, and public comments, we developed the KQs that we presented in the Scope of Review and KQs section of the Introduction.

## Technical Expert Panel

We recruited a Technical Expert Panel (TEP) to review a draft of the protocol for preparing this evidence report. The TEP included clinical chemists, cardiologists, nephrologists, emergency medicine physicians, and a representative from the Food and Drug Administration. The TEP reviewed our protocol and provided feedback on the proposed methods for addressing the KQs. With the feedback from the TEP and AHRQ representatives, we finalized the protocol and posted it on AHRQ Effective Health Care Program's Web site (www.effectivehealthcare.ahrq.gov).

## Search Strategy

We searched the following databases for primary studies: MEDLINE^®^, Embase^®^, and the Cochrane Central Register of Controlled Trials from January 1990 through September 2013. We updated our MEDLINE search in May 2014. We developed a search strategy for MEDLINE, accessed via PubMed^®^, based on an analysis of medical subject headings (MeSH^®^) and text from key articles we identified a priori (Appendix A).

To identify additional studies, the Evidence-based Practice Center Program's Scientific Resource Center submitted requests to troponin assay manufacturers for any published or unpublished randomized controlled trials or observational studies.

## Study Selection

Two independent reviewers conducted title scans. For a title to be eliminated at this level, both reviewers must indicate that the study was ineligible. If the reviewers disagreed, we advanced the article to the next level (Appendix B, Title Review Form).

We designed the abstract review phase to identify studies that could potentially report on the use of troponin levels to guide management decisions for patients with chronic kidney disease. Two investigators independently reviewed abstracts and excluded them if both investigators agreed that the article met one or more of the exclusion criteria (Appendix B, Abstract Review Form). At this phase, we excluded articles that (1) had no original data; (2) were conference abstracts; (3) included only patients with normal renal function; (4) were a case report; (5) did not apply to the key questions; (6) did not include human adult subjects; and (7) were published prior to 1990. We excluded studies published prior to 1990 because troponin started to be used as a cardiac marker in the early 1990s. We tracked and resolved differences between investigators regarding the inclusion or exclusion of abstracts through consensus adjudication.

Two independent investigators reviewed articles that we promoted on the basis of the abstract review to determine if they should be included in the final systematic review. Two investigators independently reviewed articles and excluded them if both investigators agreed that the article met one or more of the exclusion criteria (Table 3 and Appendix B, Article Review Form). We tracked and resolved the differences regarding article inclusion through consensus adjudication. For articles that were not in English, we tried to find at least two people (either an investigator or a person with a medical or public health background) who was fluent in the language to review the article.

Table 3 Inclusion and exclusion criteria

| Inclusion Criteria | Exclusion Criteria
Population and condition of interest | - All studies included human subjects exclusively.; - We included studies of adult patients with CKD including ESRD.; ○ For KQs 1, 2, and 3, we included patients who also are clinically suspected of having ACS; ○ For KQ 1.5, we only included patients with normal renal function if the studies made a direct comparison with CKD.; ○ For KQ 4, we included patients who are clinically stable and asymptomatic for ACS.
Interventions | - We included studies that evaluated troponin I, troponin T, high-sensitivity troponin T, or high-sensitivity troponin I.
Comparisons of interest | - We included studies that compared troponin elevation versus no elevation.; - We included studies that directly compared different types of troponin assays with each other (KQs 1.4, 3.3, and 4.4).; - We included studies that directly compared the utility of troponin elevation for diagnosing ACS in patients with or without CKD (KQ 1.5). | - We excluded studies that did not have a comparison group.
Outcomes | - For KQ 1, we included studies that evaluated sensitivity, specificity, and positive and negative predictive values compared with clinical diagnosis of ACS (adjudicated using strict criteria according to guidelines).; - For KQ 2a, we included studies that evaluated differences in the effects of patient management strategies, interventions, or treatments for ACS by troponin level thresholds.; - For KQs 3 and 4, we included studies that evaluated:; ○ All-cause mortality; ○ Cardiovascular mortality; ○ MACE; ○ Hospitalizations; ○ Other major adverse events
Type of study | - We included randomized controlled trials and observational studies with a comparison group.; - We did not place any restrictions based on sample size or language. | - We excluded articles with no original data (reviews, editorials, and commentaries).; - We excluded studies published before 1990 because troponin started being used a cardiac marker in the early 1990s.
Timing and setting | - We included studies regardless of the followup length.; - We included all study settings.

Abbreviations: ACS = acute coronary syndrome; CAD =coronary artery disease; CHD = coronary heart disease; CKD = chronic kidney disease; ECG = electrocardiogram; ESRD = end-stage renal disease; MACE = major adverse cardiovascular event

## Data Abstraction

We used a systematic approach to extract all data to minimize the risk of bias in this process. We created standardized forms for data extraction (Appendix B, Study Design Form, Population Characteristics Form, Interventions Form, and Outcomes Form), which we pilot tested.

The study investigators double-reviewed each article for data abstraction. The second reviewer confirmed the first reviewer's abstracted data for completeness and accuracy. We formed reviewer pairs to include personnel with both clinical and methodological expertise. We did not mask reviewers to the authors of the articles, their respective institutions, nor the journals that published the articles.

For all articles, the reviewers extracted information on general study characteristics (e.g., study design, study period, and followup), study participants (e.g., age, sex, dialysis status, history of coronary artery disease (CAD), stage of kidney disease, glomerular filtration rates (GFR), and race/ethnicity), characteristics of the troponin assays (assay type, manufacturer, brand of assay, troponin cut-off level), outcome measures, definitions, and the results of each outcome, including measures of variability. For KQs 1, 2, and 3, we collected information on how the ACS outcome was defined in the studies. We collected data on prespecified subgroups of interest, including sex, age, ethnicity, stage of kidney disease, dialysis status, pre/post dialysis (in patients receiving dialysis), status after renal transplant, presence of baseline or previously elevated troponins, presence of ischemic ECG changes (for patients with clinically suspected ACS only), comorbidities (e.g., diabetes, hypertension), smoking status, 10-year CAD risk, and history of CAD. We collected the number with elevated versus nonelevated troponin values and the number of events in each arm. If regression models were presented with various degrees of covariate adjustment, we abstracted results from the most-adjusted model.

The individual completing the review entered all information from the article review process into a DistillerSR database (Evidence Partners Inc., Ottawa, Canada). Reviewers entered comments into the system whenever applicable. We used the DistillerSR database to maintain the data and to create detailed evidence tables and summary tables.

## Quality Assessment

Two reviewers independently assessed study quality. We used the Downs and Black quality assessment tool to assess the quality of all included studies.27 We supplemented this tool with additional quality assessment questions based on recommendations in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter Methods Guide).28 Our quality assessment tool included items on the reporting, external validity, internal validity, power, and conflicts of interest (Appendix B, Study Quality Form). The reporting questions evaluated clear descriptions of the objectives, main outcomes, subject characteristics, tests of interest, distribution of principal confounders, main findings, estimates of random variability, characteristics of subjects lost to followup, and actual p-values. External validity questions assessed the representativeness of those asked to participate in the study, the representativeness of those willing to participate in the study, and the representativeness of the staff, places, and facilities. Internal validity questions assessed the blinding of the outcome assessors, a priori specification of the results, adjustment for different lengths of followup, appropriateness of the statistical tests, accuracy of the main outcome measures, selection of patients in the different intervention groups, adequate adjustment for confounding, and accounting for loss to followup. We assessed the overall study quality in terms of:

- Good (low risk of bias). These studies had the least bias, and the results were considered valid. These studies adhered to the commonly held concepts of high quality, including the following: a clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; a low dropout rate; and clear reporting of dropouts.
- Fair. These studies were susceptible to some bias, but not enough to invalidate the results. They did not meet all the criteria required for a rating of good quality because they had some deficiencies, but no flaw was likely to cause major bias. The study may have been missing information, making it difficult to assess limitations and potential problems.
- Poor (high risk of bias). These studies had significant flaws that might have invalidated the results. They had serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.

Differences between reviewers were resolved by a third party adjudicator.

## Applicability

We assessed the applicability of studies in terms of the degree to which the study population, interventions, outcomes, and settings are typical for adult patients with CKD or ESRD. Factors that may limit applicability include sex, age, ethnicity, stage of kidney disease, dialysis status, status after renal transplant, presence of baseline or previously elevated troponins, presence of ischemic ECG changes (for patients with suspected ACS only), comorbidity, smoking status, 10-year CAD risk, and history of CAD.

## Data Analysis and Synthesis

We conducted meta-analyses when there were sufficient data and studies were sufficiently homogenous with respect to key variables (population characteristics, study duration, and treatment). For KQ 1, we followed the meta-analytic methods for studies that had an imperfect reference standard.29 We constructed 2 × 2 tables and calculated sensitivity, specificity, and positive and negative predictive values where possible. If we found at least five studies that were sufficiently homogenous, we conducted a hierarchical summary receiver operator curve meta-analysis to analyze sensitivity and specificity.

For KQ 3, there was insufficient data to conduct meta-analyses. For KQ 4, meta-analyses were performed separately for time to event data (hazard ratios) and for regression models (odds ratios) as it is inappropriate to combine data from hazard ratios and odds ratios in the same meta-analysis. We conducted a meta-analysis if we found at least two studies that reported on these measures and were sufficiently homogenous.

For studies that reported a hazards ratio with a confidence interval, we pooled the hazards ratios by using the profile likelihood estimate for calculating between-study variance.30 This method is felt to provide better accounting of uncertainty in estimation of between-study variance than the DerSimonian-Laird estimator.31 Pooled hazard ratio meta-analyses were stratified by level of adjustment. We considered the highest level of adjustment to be models tht adjusted for age and CAD and/or similar risk equivalent (cerebrovascular disease, peripheral vascular disease, reduced left ventricular ejection fraction, heart failure, and/or diabetes). If a study reported hazard ratios by tertiles or quartiles of troponin levels, then we selected the hazard ratio that compared the highest group with the lowest group. For studies that presented a hazard ratio but no confidence intervals, if enough information was provided (such as total events and the number randomized on each arm), we derived confidence intervals using the methods provided by Tierney et al.32 Studies that presented results by troponin only as a continuous variable, rather than a cutpoint, could not be included in meta-analyses.

For studies that reported the incidence of events, we pooled the odds ratios by using the profile likelihood estimate.30 Sometimes, if the number of events in each group was not directly provided by the authors, that information was abstracted from a Kaplan-Meier survival figure in the published article using the DigitizeIt software program (DigitizeIt, Braunschweig, Germany). If a study reported on more than one troponin assay, we selected the assay that was most commonly used to include in the meta-analysis. Most of the odds ratios were derived from the number of events in the elevated and non-elevated troponin groups. These are all unadjusted odds ratios.

If the authors reported a hazard ratio and the number of events, that study was included in both meta-analyses. If the authors reported a hazard ratio and not the number of events, then it was only included in the hazard meta-analysis.

For studies that had two or more publications presenting outcome results from the same patient population, only one result per one unique cohort was presented. We typically selected the publication with the longest followup, unless the cutpoints for troponin elevation were not clear, and then the study with the clearest reporting of results was selected.

For studies that presented outcome results at multiple time points, the longest followup time point was abstracted. For studies that presented both unadjusted and adjusted measures of association, the results from the most adjusted regression model were abstracted.

Heterogeneity among the trials in all the meta-analyses was tested by using a standard chi-squared test with a significance level of alpha ≤ 0.10. Heterogeneity was also examined among studies by using an I^2^ statistic, which describes the variability in effect estimates that is due to heterogeneity rather than random chance.33 A value greater than 50 percent was considered to connote substantial variability.

Publication bias was examined by using Begg's test34 and Egger's test35 including evaluation of the asymmetry of funnel plots for each comparison of interest for the outcomes for which meta-analyses are conducted.

We used STATA statistical software (Intercooled, Version 12.1, StataCorp, College Station, TX) for all meta-analyses. Studies that were not amenable to pooling were summarized qualitatively.

For studies that presented multiple cut-points for troponin elevation (such as tertiles or quartiles rather than dichotomous cut-points), the results comparing the highest cut-point compared with the lowest cut-point was reported.

We report troponin levels in terms of mcg/L, because most studies used this unit. However, some of the newer high sensitivity troponin assays report troponin levels in terms of ng/L. To convert from mcg/L to ng/L, multiply by 1000.

## Data Entry and Quality Control

A second reviewer checked the data that had been entered into DistillerSR. Second reviewers were generally more experienced members of the research team. We discussed any problems with a reviewer's data abstraction at a meeting with the reviewers.

## Rating the Strength of the Body of Evidence

At the completion of our review, at least two reviewers independently rated the strength of the body of evidence on each of the troponin assays. We graded the strength of evidence addressing KQs 1, 2, 3, and 4 by adapting an evidence grading scheme recommended in the Methods Guide.36 We applied evidence grades to the bodies of evidence about each troponin assay for each outcome.

We assessed the study limitations of individual studies according to internal validity measures described in the Quality Assessment section. Since most of the studies addressing these questions would be observational studied, we started with the assumption of a low level of study limitations. The study limitations domain was downgraded to medium or high if there was one or more than one concern about study quality.

We rated the body of evidence as “consistent” if most of the studies showed the same direction of effect. We rated the consistency of a single study as “not applicable,” without downgrading the strength of evidence.

We rated the body of the evidence as “direct” if most of the studies directly addressed the question. Since we included only clinical outcomes and allowed for only direct comparisons, most evidence bodies were graded as direct.

We based our rating of precision on the magnitude and the width of the confidence intervals of the hazard ratios. If the hazard ratio was greater than 1.5 and its confidence interval did not cross 1, then we graded it as precise.

We classified the strength of evidence pertaining to the KQs into four basic grades: (1) “high” grade (indicating high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of the effect), (2) “moderate” grade (indicating moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of the effect and may change the estimate), (3) “low” grade (indicating low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate), and (4) “insufficient” grade (evidence is unavailable or does not permit a conclusion).

## Peer Review and Public Commentary

Experts in nephrology, cardiology, emergency medicine, and clinical chemistry and representatives from other government agencies were invited to provide external peer review of this CER; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revising the text as appropriate, and documented everything in a “disposition of comments report” that will be made available 3 months after the Agency posts the final CER on the AHRQ Web site.