# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Ruth Chesler, M.T. (ASCP)
  Branch Chief, Cardio-Renal Diagnostic Devices
  Division of Chemistry and Toxicology
  Devices in the Office of In Vitro
  Diagnostics and Radiological Health
  Center for Devices and Radiological Health
  U.S. Food and Drug Administration
  Silver Spring, MD
- Ian de Boer, M.D., M.S.
  University of Washington
  Seattle, WA
- Ty Gluckman, M.D.
  Providence Heart and Vascular Institute
  Portland, OR
- Allan Jaffe, M.D.
  Mayo Clinic
  Rochester, MN
- Peter McCullough, M.D., M.P.H.
  Baylor University Medical Center
  Baylor Heart and Vascular Institute
  Baylor Jack and Jane Hamilton Heart and Vascular Hospital
  Dallas, TX
  The Heart Hospital
  Plano, TX
- Michal Melamed, M.D.
  Albert Einstein College of Medicine
  Bronx, NY
- Andrew Worster, M.D., M.Sc.
  McMaster University
  Hamilton, ON
- Alan Wu, Ph.D.
  San Francisco General Hospital
  University of California, San Francisco
  San Francisco, CA