# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Fred Apple, Ph.D., DABCC
  University of Minnesota School of Medicine
  Minneapolis, MN
- Ruth Chesler, M.T. (ASCP)
  Branch Chief, Cardio-Renal Diagnostic Devices
  Division of Chemistry and Toxicology
  Devices in the Office of In Vitro
  Diagnostics and Radiological Health
  Center for Devices and Radiological Health
  U.S. Food and Drug Administration
  Silver Spring, MD
- Ian de Boer, M.D., M.S.
  University of Washington
  Seattle, WA
- Andrew DeFilippis, M.D., M.Sc.
  University of Louisville
  Louisville, KY
- Allan Jaffe, M.D.
  Mayo Clinic
  Rochester, MN
- Susan Promes, M.D.
  UCSF School of Medicine
  San Francisco, CA
- Alan Wu, Ph.D.
  San Francisco General Hospital
  University of California, San Francisco
  San Francisco, CA