# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Fred Apple, Ph.D., DABCC
  University of Minnesota School of Medicine
  Minneapolis, MN
- Ronald Booth, M.Sc., Ph.D.
  University of Ottawa
  Ottawa, ON
- David Charytan, M.D., M.Sc.
  Harvard Medical School
  Boston, MA
- Robert Christenson, Ph.D., DABCC
  University of Maryland School of Medicine
  Baltimore, MD
- Christopher DeFilippi, M.D.
  University of Maryland School of Medicine
  Baltimore, MD
- Allan Jaffe, M.D.
  Mayo Clinic
  Rochester, MN
- Terry Ruddy, M.D.
  University of Ottawa Heart Institute
  Ottawa, ON