# Acknowledgments

The Evidence-based Practice Center thanks Elisabeth Haberl, Brijesh Patel, Brian G. Ockerse, Sunil Agarwal, Allen Zhang, Sylvia Wang, and Oluwaseun Shogbesan for their assistance in reviewing articles, Erika Douglass and Ayu Katada for their help in reviewing non-English language articles, and Eric Vohr for copy editing. We would also like to thank the Key Informants, Technical Expert Panel, Peer Reviewers, Task Order Officer, and Associate Editor, Mark Helfand, M.D., M.S., M.P.H., of Oregon Health & Science University.