# Discussion

## Key Findings

### KQ 1 Use of Troponin for Diagnosis of Acute Coronary Syndrome Among Patients With Chronic Kidney Disease

We systematically reviewed the available evidence regarding the utility of troponin testing with final (usually adjudicated) ACS diagnosis. However, we only found low-quality or insufficient evidence regarding the use troponin T and I assays to diagnose ACS in CKD patients. Troponin levels were associated with a wide range of sensitivity and specificity compared to final ACS diagnosis.

Studies addressing these operating characteristics were markedly heterogeneous in setting, population, and completeness of reporting regarding adjudication of ACS. In addition, there is also heterogeneity between studies regarding the assay manufacturer and cutpoints used for diagnosing ACS. We found limited evidence directly comparing the use of troponin T and I assays to diagnose ACS in a comparable population of CKD patients, and limited evidence examining the operating characteristics among relevant subgroups. We were unable to perform a meta-analysis of the summary statistics due to insufficient data.

The National Academy of Clinical Biochemistry had recommended that patients with ESRD and suspected ACS should have a dynamic change in troponin levels of greater than 20 percent within 9 hours (with at least one value above the 99^th^ percentile) to warrant a clinical diagnosis of acute MI. We did not find any studies that tested this guideline in terms of operating characteristics (sensitivity, specificity, positive predictive value, and negative predictive value).

Overall, we were struck by the paucity of evidence for this KQ, and thus could not establish a clear cutpoint that maximizes sensitivity and specificity. The lack of direct comparison to patients without CKD in the same population cohort is another major limitation.

The sensitivities and specificities for diagnosing MI, among patients with CKD that we identified in our review may seem problematically low or too variable to draw conclusions (sensitivities ranging from 43 to 100 percent and specificities ranging from 31 to 100 percent).

However, one must keep in mind that using troponin levels to diagnose ACS can be problematic even in a general population of patients (not explicitly CKD). In a study of patients presenting to an emergency room with positive troponin I at a threshold of 0.04 mcg/L, clinicians diagnosed 20.4 percent with type I MI, 9.1 percent with type II MI, but the majority (65.8 percent) did not meet criteria for acute MI.170 In another study of patients presenting to an emergency room with positive troponin, clinicians ultimately diagnosed only 55 percent with MI.171 Furthermore, a recent study evaluating four new point-of-care assays for troponin I among patients with suspected ACS found that at the 99^th^ percentile for each assay, sensitivities varied from 26 to 68 percent and specificities varied from 81 to 93 percent for diagnosing MI, versus the gold standard of the Universal Guidelines for MI.172

Thus, our findings must be put in context of what we already know about using troponin to diagnose ACS in the general population—that the utility of the diagnostic test is dependent on the pre-test probability for suspected ACS (i.e., Bayes Theorem). Newby et al., in a review on troponins for a consensus document on behalf of the American College of Cardiology Foundation (ACCF),13 cites this following example: If the pre-test probability for ACS is high, such as 90 percent, based on classic symptoms and ECG changes, the post-test probability for a positive troponin above the 99^th^ percentile is still 95 percent even if the false positive rate is 40 percent. Conversely, if the pre-test probability is very low, such as 10 percent (due to atypical symptoms or symptoms suggestive of other cause), the post-test probability for ACS is only 50 percent even if false positive rate is only 10 percent. Even with lab evidence suggestive of myocardial necrosis, the post-test probability for ACS for positive troponin is still low if the pre-test probability is low. Conversely, low values do not exclude ACS if the pre-test probability is high. Therefore, it is difficult to interpret the sensitivities and specificities of troponin testing for diagnosing ACS for studies included in our report that do not specifically state the pre-test probability of the population. Furthermore, relying on a single value should be avoided, especially those from a high-sensitivity assay, in favor of serial values.

Newby et al. stress that the problem with troponin testing, like any laboratory test, is inappropriate testing (when not indicated) or inappropriate interpretation of results, not the marker itself, and that clinicians should only test for troponin when appropriate (i.e., clinically indicated). In patients with non-ST elevation ACS, global risk assessment rather than any single marker should be used for diagnosis and to guide therapy.

Therefore, to directly compare the utility of troponin testing in CKD and non-CKD populations, the pre-test probabilities should be similar in order to draw conclusions about comparisons. Although we found no studies that directly compared the use of troponin for diagnosing ACS in CKD versus non-CKD in the same population, our indirect comparison does not suggest that troponin is less effective in diagnosing ACS in CKD.

### KQ 2 Do Troponin Levels Help Guide Management Decisions in Acute Coronary Syndrome for Patients With Chronic Kidney Disease?

As described in the background section, frequently, clinicians use troponin levels, along with clinical factors, to further risk-stratify patients presenting with suspected ACS. In regard to ACS management, glycoprotein IIb/IIIA inhibitors, low-molecular-weight heparin, and an early invasive strategy may have a better effect for troponin-positive patients than for troponin-negative patients. Patients with CKD also have a worse prognosis when presenting with ACS compared with non-CKD patients.173 Furthermore, many RCTs that tested therapeutic agents for ACS management excluded patients with advanced CKD.

Unfortunately, since elevated cardiac biomarkers are such an integral component of the diagnosis and risk-assessment in ACS, it is difficult to study this question in an evidence-based way. It may not be ethical to randomize or withhold therapy based on troponin values alone, as ACS treatment algorithms depend on a whole host of clinical factors and timing of presentation.

As was anticipated, we did not find any study that directly addressed the question of whether troponin levels can affect management strategies in CKD patients with ACS symptoms (i.e., no studies randomized patients to any management strategy by troponin levels). Therefore we cannot draw conclusions to directly answer this question. We recommend further study in this area, such as a carefully-designed post hoc analyses of clinical trials testing ACS management strategies, comparing gradations of troponin elevation across treatment groups with a highlighted focus on CKD patients.

### KQ 3 Do Troponin Levels Facilitate Short- and Long-Term Prognosis in Patients With Chronic Kidney Disease Presenting With Suspected Acute Coronary Syndrome?

As described in the background section, studies have examined elevated troponin as an independent predictor of morbidity and mortality in populations following an acute ischemic event but data is limited in CKD.

Overall, evidence is limited for the prognostic significance of elevated cardiac troponin with regard to short-term and long-term MACE, as well as for the mortality of patients with both CKD and ACS. Our review lends support toward higher rates of MACE within 1 year in CKD patients with ACS who have elevated (vs. nonelevated) troponins for both troponin T and I, with more available evidence linking an association of troponin I with MACE within 1 year than for troponin T. Regarding the outcome of all-cause mortality following a suspected ACS event, we also found limited data for troponin T (two insignificant studies), but did find a generally positive association of troponin I with all-cause mortality. However, few studies met our inclusion criteria for KQ3, and many studies were small and/or at risk of bias.

Overall, our findings suggest that elevated cardiac troponin (particularly troponin I) compared with nonelevated cardiac troponin, does appear to identify CKD patients who are at higher risk for subsequent MACE (following a presentation for ACS). However, all studies were observational in design. And no studies evaluated changes in management decision. Clinicians treat all patients with suspected ACS based on the guideline-recommended treatment for acute ACS interventions, and then prescribe subsequent secondary prevention management (antiplatelet therapy, statins, angiotensin-converting enzyme inhibitors or angiotensin receptor blockers, beta-blockers, etc.). Thus, although elevated troponin can identify a CKD patient as being a higher prognostic risk, the available evidence does not indicate how to lower a patient's risk (based on elevated troponin), beyond usual guideline-directed therapy.

### KQ 4 Risk Stratification Among Patients With Chronic Kidney Disease Without Acute Coronary Syndrome

#### Risk Prediction

The results from our systematic review found that in observational data, elevated troponin (defined by varying cutpoints across studies) strongly and fairly consistently identifies CKD patients at higher risk for subsequent adverse events, compared with patients with nonelevated troponin. Among dialysis patients without suspected ACS, a baseline elevated cardiac troponin is associated with a higher risk (∼2-4 fold) for all-cause mortality, cardiovascular-specific mortality, and MACE (e.g., “composite” outcome of MI, cardiovascular death, and/or revascularization) in pooled analyses of studies adjusted for at least age and CAD or risk equivalent.

A substantial number of observational studies confirmed this association among patients on dialysis, and results were largely consistent (in terms of direction of a positive association). More of the studies included in the pooled meta-analyses reported outcomes for all-cause mortality than for other outcomes. Thus, the evidence from the pooled meta-analysis is strongest for the association of elevated cardiac troponin with all-cause mortality; an approximately 3-fold increased risk was found, which was highly significant. The evidence from meta-analyses for the association of elevated cardiac troponin with cardiovascular-specific mortality and MACE, showed similar effect sizes but with wider confidence intervals from fewer studies.

The association of elevated troponin with adverse outcomes among dialysis patients was generally similar for troponin T versus I. Few studies reported results for high-sensitivity troponin T and I assays, so less is known about how well these assays predict risk. Studies that used a sensitive assay identified more patients as having elevated troponin.

While almost all studies of dialysis patients supported a positive association for elevated cardiac troponin with adverse cardiovascular outcomes (particularly mortality), we noted heterogeneity in some of the pooled meta-analyses results (as defined by the I-squared statistic) among the studies, even though we analyzed troponin T and I separately. We performed sensitivity analyses, such as only including studies that adjusted for age or age and CAD, but we were unable to eliminate all of the heterogeneity in the meta-analyses. Generally, the direction of association was similar (indicating increased risk for elevated troponin levels), but the magnitude of risk varied substantially across studies.

Previous to our report, Khan et al. published the largest meta-analysis of the use of cardiac troponin for risk prediction among dialysis patients in 2005.^23^ The authors reviewed studies through December 2004, and found 17 studies evaluating troponin T for all-cause mortality (pooled relative risk 2.6; 95% confidence interval, 2.2 to 3.2, also with high heterogeneity). Of note, this pooled meta-analysis used a relatively high troponin T cutpoint of >0.1 mcg/L, almost 10-fold higher than the lower limit of detection. They found 12 studies for troponin I for all-cause mortality (pooled relative risk, 1.7; 95% confidence interval, 1.3 to 2.4). Many of the individual studies identified for troponin I were not statistically significant, but their pooled relative risk was significant.

We have now updated the literature by performing a comprehensive review through May 2014. We found 43 studies for troponin T and 30 studies for troponin I for all-cause mortality. We were able to perform meta-analyses for both HRs (time to event) and ORs (relative risk) as available, whereas Khan et al. only performed relative risk analyses. We used all cut-points available in literature (and did not limit studies to troponin T >0.1 mcg/L as per Khan's study). In our meta-analyses, we found similar (if not stronger) effect sizes for both troponin T and I with all-cause mortality compared with the previous results by Khan et al. We similarly noted heterogeneity across studies. We also performed meta-analyses for the other outcomes of cardiovascular-specific mortality and MACE.

Researchers has previously questioned troponin I as not being an important prognostic marker for risk prediction among dialysis patients given null results from several of the individual studies. However, the results from our meta-analyses do not clearly support this conclusion, as our pooled results showed a strong association (albeit slightly less than for troponin T). Differences may be due to more heterogeneity of the troponin I assays (multiple manufacturers) compared with troponin T (largely handled by one manufacturer).

We can conclude that elevated troponin T levels, and to a slightly lesser extent elevated troponin I levels, are both strongly associated with increased risk of mortality among dialysis patients (strength of evidence: moderate). Therefore, elevated baseline troponin among CKD and dialysis patients is not “spurious” but portends a worse prognosis. Of note, in May 2004 the U.S. Food and Drug Administration approved the measurement of troponin T in dialysis patients for the express purpose of risk stratification (i.e., prediction of mortality). The findings of our updated review lend continuing support for this recommendation for risk prediction. However, how to manage patients based on the results from risk prediction (i.e., whether dialysis patients with elevated troponin should be treated differently than dialysis patients with nonelevated level beyond usual clinical risk-factor guided care), remains an important clinical question that this review did not answer.

#### Troponin Testing Versus Clinical Risk Markers

Almost all of the studies found by our review determined the “prognostic” value of troponin by its associations with outcomes in regression models. However, while one must critically examine the utility of a biomarker for “prediction”, the more clinically relevant question is how the marker stacks up in metrics of discrimination and re-classification. Discrimination [which is most often measured by the area under the curve (AUC) of a receiver operating characteristics (ROC)] is a measure of how well a model can distinguish those who and who do not have the disease of interest. Net reclassification index (NRI) is a newer statistical measure that quantifies the number of people correctly reclassified to higher and lower risk categories. Can troponin re-classify CKD patients into higher and lower risk groups (i.e., net reclassification index)? And, is this better than existing clinical models (i.e., comparing the area under the curve with clinical models)? We found very few studies that used AUC results and no studies that used NRI.

The meta-analyses performed for the pooled ORs were unadjusted results using number of events in each arm. For the meta-analyses for HRs, we selected the most-adjusted regression model. However, many studies only reported an unadjusted HR. While many studies adjusted for age, fewer studies adjusted for a history of CAD or CAD risk equivalent, such as diabetes mellitus, or adjusted for other cause of elevated troponin, such as heart failure. Even fewer studies adjusted more comprehensively for other cardiovascular risk factors, such as systolic blood pressure, dyslipidemia, and smoking. Elevated troponin levels may simply be a surrogate marker of someone with underlying CAD (i.e., a person already known to be at predicted higher risk). However, for the studies presenting adjusted HRs, results generally showed a positive association of elevated troponin levels with adverse outcomes even in progressively adjusted models, but again this was not well assessed.

The most robust evidence after adjustment for clinical factors was for the association of elevated troponin T and all-cause mortality among dialysis patients (strength of evidence: moderate). Of 21 studies available for HR analyses, 6 were unadjusted, 15 adjusted at least for age, and eleven adjusted at least for age and history of CAD (or CAD risk equivalents such as cardiovascular disease, congestive heart failure, ejection fraction, or diabetes mellitus) in their models. In two studies, the authors performed a more thorough regression model by additionally adjusting for numerous cardiovascular risk factors including blood pressure, lipids, and diabetes. For the HR analyses for troponin I, all of these studies at least adjusted for age, and six out of nine additionally adjusted for CAD or CAD risk equivalent (CAD, cardiovascular disease, heart failure, and diabetes). These studies predominantly used traditional regression models to show that the associations persisted after adjustment for clinical factors, but most did not use a more rigorous method of comparing C-statistics (area under the curve) against clinical models.

Havekes et al.104 was one of the largest studies (847 dialysis patients) to rigorously examine whether troponin testing adds incremental prognosis over routine clinical factors. While a troponin T level greater than 0.1 mcg/L was a potent predictor of mortality in their study (adjusted HR, 2.2; 95 percent confidence interval, 1.5 to 3.3), it did not improve prediction over clinical factors. A survival model with clinical factors and routine laboratory markers predicted mortality with an area under the curve of 0.81, but adding troponin T to this model did not change this estimate. The area under the curve for predicting mortality for troponin T alone was 0.67. This data suggests that the troponin T biomarker is a potent predictor of mortality on its own, however, it may have little prognostic utility over clinical factors when more rigorously assessed (i.e., change in the C-statistic).

Thus, whether measuring this biomarker of cardiac troponin facilitates risk prediction in dialysis patients better than a traditional risk prediction model using only clinical variables is still somewhat uncertain.

#### Management of Nonacute Coronary Syndrome Patients Based on Troponin Testing

The National Kidney Foundation already endorses that all patients with CKD should be considered in the “highest risk” group for cardiovascular disease risk prediction, irrespective of levels of traditional cardiovascular risk factors (i.e., that CKD should be considered a CAD risk equivalent).174 Therefore, if patients with CKD are already candidates for intensive management of their cardiovascular risk factors for prevention, what, if any, is the additive role of measuring troponin?

All of the studies we found that related to KQ4 were observational cohort studies. We did not find any intervention studies that compared management strategies of dialysis patients (without suspected ACS) on the basis of elevated troponin. Thus, while elevated cardiac troponin is clearly a marker of a patient at increased risk for subsequent cardiac events, it is unknown whether changing or altering patient management (such as implementing more intensified preventive efforts) on the basis of elevated troponin can reduce/prevent cardiovascular events and mortality. This is even a greater concern with the introduction of high-sensitivity assays, as more patients are labeled as having elevated troponin.

In the absence of MI, there are no specific interventions recommended to reduce cardiovascular disease risk in patients with CKD based solely on elevated troponin. Therefore the role of screening asymptomatic individuals, or how to use the prognostic information from the results in a way that affects patient management and outcomes is not clear.

### KQs 1–4 Heterogeneity With Assays Platforms, Cutpoints, and 99^th^ Percentile Considerations

Much heterogeneity across results for KQs 1–4 stemmed from differences between studies in the types of troponin assays used (different manufacturers, different assay platforms). Troponin assays have been changing over time, and newer generations of assays can detect lower and lower concentrations of cardiac troponin. Many of the papers did not report which generation of assay they used; and this was a significant limitation of our analyses. For troponin T, there was generally only one manufacturer (Roche, or Boehringer Mannheim which was acquired by Roche Diagnostics in 1997). However, there were multiple manufacturers of the troponin I assay. The studies were also heterogeneous regarding what cutpoints they considered elevated. Many studies did not report what the manufacturer-reported 99^th^ percentile threshold was for that assay. The 99^th^ percentile threshold also changed depending on the reference population and assay generation that the study used. The reference populations for the 99^th^ percentiles were largely unclear, and were most likely not from a dialysis cohort. Therefore, we were not able to perform meta-analyses using the 99^th^ percentile cutpoint, but instead compared the highest cutpoint reported with the lowest for consistency. All of our findings in this systematic review must be interpreted with this important caveat in mind.

The European Society of Cardiology/American College of Cardiology guidelines support a 99^th^ percentile cutpoint, and studies that have used the 99^th^ percentile cutpoint did confirm its utility in predicting risk. However, most studies presented results using higher cutpoints. For example, the Roche Elecsys assay lists a 99^th^ percentile of 0.014 mcg/L, but most studies presented the 0.1 mcg/L cutpoint, which is 10-fold higher. A current list (as of 2013) of the 99^th^ percentile for commercial and research assays is on the Web site for the International Federation of Clinical Chemistry and Laboratory Medicine (see http://www.ifcc.org/ifcc-scientific-division/documents-of-the-sd/troponinassayanalyticalcharacteristics2013/).

## Applicability

### Chronic Kidney Disease Stages

We found the largest body of evidence relating to dialysis patients without suspected ACS. Whereas these findings are most likely generalizable to the typical cohort of dialysis patients treated in clinical practice, these findings cannot necessarily be extrapolated to other stages of CKD I-IV. We did find limited data for nondialysis patients with CKD with strength of evidence ranging from low to moderate, suggesting a positive association for all-cause mortality, but results were not stratified by CKD stages.

### Other Subgroups

We found limited data regarding subgroups classified by gender, history of CAD, and pre-or post-renal transplantation, but data were insufficient to generate pooled meta-analyses results by these subgroups or to make conclusive statements about generalizability to apply findings across these select groups. Regarding dialysis-only cohorts, few studies stratified by other subgroups. Subgroups described were as follows: persistently elevated troponin levels (one study), history of CAD (four studies), gender (two studies), pro-brain natriuretic peptide levels (one study), diabetes (one study), hypotension-prone (one study), and hemodialysis versus peritoneal dialysis (one study). We did not find any data in regard to subgroups of ECG changes or 10-year CAD risk status.

## Limitations

We identified over 6,000 titles on this topic, narrowing it down to 130 publications that met our inclusion criteria. All of these studies were observational in design and have at least a moderate risk of bias due to known confounding associations. Patients with elevated troponin levels are more likely to have underlying CAD, heart failure, or co-morbidities that place them at higher risk of mortality. As described further in the above sections, we were limited by the fact that most studies were either unadjusted or minimally adjusted for other risk factors. Studies determined the use of troponin for “prognosis” by its association with outcomes in regression models, which is not the most clinically useful way to evaluate a biomarker. None of the studies evaluated the utility of troponin as a predictor by metrics of net reclassification index (i.e., its ability to re-classify patients into higher or lower risk groups). Only one study compared discrimination against a model of clinical factors.

As described above, studies were very heterogeneous in the assays (particularly for troponin I), troponin cutpoints, and definitions of ACS they used. This limited our ability to pool data and perform meta-analyses. Many studies failed to report any rigorous adjudication for ACS diagnosis. Therefore, without a “gold standard” outcome to gauge troponin testing, we were limited in our ability to draw conclusions about the operating characteristics of the troponin biomarker for diagnosing ACS in CKD patients.

Our inclusion criteria deliberately selected only studies that reported clinical outcomes. This is because evidence-based guidelines are largely directed by studies with clinical outcomes, as there are many examples where findings in surrogate outcome studies do not translate into clinical benefits. Thus we did not evaluate elevated troponin with any surrogate markers (echocardiography, stress testing, left ventricular hypertrophy, etc.), only hard clinical outcomes. Therefore, our review is unable to explore potential mediating mechanisms for the associations presented, for which therapeutic strategies could be devised.

We did not explore the prevalence of elevated baseline troponin across all potential studies, but only for studies that also reported hard outcomes (i.e., we did not include cross-sectional studies). Thus, our assessment of the prevalence of elevated baseline troponin may be incomplete (KQ4.1).

We only reviewed studies that included results for patients with CKD by troponin levels. To keep the scope of our review specific to the topic at hand, we did not review all studies relevant to troponin testing and did not report results for general populations that did not specifically stratify by CKD subgroups. As further described above, 99^th^ percentiles for troponin vary across study populations as well as pre-test probabilities for ACS; this makes indirect comparisons across studies very problematic. Therefore, we were unable to make any indirect comparisons of our results to non-CKD patients. There were no studies that directly compared troponin testing for non-CKD and CKD in the same population.

## Research Gaps

### Issues Related to Troponin Assays (KQ 1–4)

#### Need for Harmonization

Standardization of the troponin assays (particularly troponin I, where assays vary between numerous manufacturers), would facilitate interpretation across future studies. This is currently one of the goals of the International Federation of Clinical Chemistry Working Group on Standardization of Cardiac Troponin I. This goal is challenging given the complexity of troponin I (multiple isoforms), and that the antibodies used in the various immunoassays recognize different epitopes with variable reactivity.175 In spite of these challenges, the need for harmonization, so that results can be compared across studies, is paramount. This need is only further emphasized by our review.

### Need To Rigorously Standardize and Test the 99^th^ Percentile

As further described above, we need to standardize the 99^th^ percentile threshold in a unifying reference population. While universal guidelines have endorsed the 99^th^ percentile threshold, studies are still being published using higher cutpoints, sometimes 10-fold higher. Thus, we need more studies that actually test the 99^th^ percentile cutpoint for diagnosis and prognosis. Future studies should focus on using guideline-established cutpoints for consistency in the literature and relevance to clinical practice.

### Timing of Measurement

Some studies involving only dialysis patients imply that the timing of troponin measurement (before vs. after a dialysis session) may be important. If clinicians are going to use troponin for risk stratification, studies recommend that troponin be measured prior to dialysis as dialysis can affect cardiac troponin levels. This review did not consider this, and it may be a research gap.

### Diagnosis of Acute Coronary Syndrome (KQ 1)

Future work should seek to compare the operating characteristics of troponin T and I as an a priori objective of a well-designed series of studies using standardized assays and cutoffs. These studies should consider, in their design, testing the use of troponin among different subgroups of patients with CKD (such as stages 1 to 5) among which the operating characteristics of a troponin assay for ACS diagnosis might vary. Therapeutic options and likelihood of impact on outcomes may vary across stages of CKD. Studies also need to include a direct comparison to non-CKD patients to assess the assay head-to-head among the same reference population with the same pre-test probability. Furthermore, future studies should emphasize the pre-test probability of their population for suspected ACS using global risk assessment criteria in their reports, as the interpretation of troponin post-testing is largely driven by the pre-test probabilities.

The 20 percent rise/fall guideline (with at least one value above the 99^th^ percentile) for acute MI diagnosis should be vetted against other potential diagnostic criteria such as single absolute thresholds or other delta of change in CKD patients.

Since RCTs are unlikely to be done, well-designed retrospective and post hoc analyses could potentially address this question. Such studies would provide highly useful information to clinicians as to the use of troponin assays in the real-world care of CKD patients.

### Management of Acute Coronary Syndrome (KQ 2)

Whether the results from troponin testing for patients with CKD and suspected ACS are associated with differences in the comparative effectiveness of interventions or management strategies remains uncertain. This is an area for potential further investigation. Since RCTs likely will never be done, future research should focus on post hoc analyses of pre-existing clinical trials of ACS management.

### Prognosis After Acute Coronary Syndromes (KQ 3)

The articles included for this study focused mainly on troponin values measured at the time of ACS presentation. Baseline, or previous values, of troponin are largely unknown. Thus, there is limited data supporting that a change in troponin from baseline is associated or not associated with different prognosis for adverse cardiac events in CKD patients with ACS.

It is unclear from this review if major increases in troponin levels in CKD patients with ACS should carry more weight than minor increases, as the studies we identified generally evaluated above and below a diagnostic cutpoint (of modest elevation) and not gradations of more significant increases in troponin. However prior literature among general populations supports that a large increase of troponin (evidence of more myocardial damage) portends a worse prognosis.3

There are current guidelines already in existence for management of ACS.20 Area of future research should focus on management to reduce the risk of both short and long term events in CKD patients with suspected ACS who have elevated troponins. Future studies should address whether management in CKD patients is different than non-CKD patients with similar degrees of elevated troponins. And if more elevated troponin levels in ACS are associated with worse outcomes, should these patients be managed differently (i.e., subjected to different medications and interventions) than CKD patients with ACS who have absent or lower degrees of troponin elevation? A prognostic biomarker by itself is insufficient without guidance of how to use this biomarker to guide or alter therapy.

### Risk Prediction in Nonacute Coronary Syndrome Chronic Kidney Disease Patients (KQ 4)

#### What is the Pathophysiological Mechanism for the Association?

Elevated cardiac troponin levels indicate that a patient is at higher risk for adverse outcomes, particularly all-cause mortality among patients without suspected ACS. Cardiovascular mortality and MACE were also higher in patients with elevated troponin. But what is the precise cause of death? Is elevated cardiac troponin simply a marker of underlying CAD or a marker of silent ischemia? Are patients dying from MIs, heart failure, arrhythmias, or other causes? Once we clearly define the cause of death associated with elevated troponin, we can test and implement potential interventional strategies.

#### Need To Compare Troponin Testing Against Conventional Risk Prediction/Clinical Factors

As described above, a CKD patient with elevated troponin is at higher risk of adverse outcomes (the evidence being strongest for dialysis patients). It is less clear whether troponin testing offers incremental prognostic value over assessing risk based on clinical factors alone. Any future studies published on this topic should vigorously test troponin against other clinical models (i.e., whether troponin testing changes the area under the curve compared with other traditional clinical and laboratory risk markers). Studies should focus on metrics of net reclassification to determine whether this biomarker can appropriately re-classify CKD patients into higher and lower risk groups.

#### Need for Guidance for Management—Next Step Beyond Risk Prediction

Once a patient is identified at higher risk on the basis of an elevated serum troponin level, what is the next step? Should cardiac troponin testing include other diagnostic tests, such as stress testing or echocardiography? Should clinicians prescribe additional preventive medications such as aspirin, statins, or beta-blockers to CKD patients with elevated troponin levels? Many patients may already have indications for these therapies; what additional treatment should clinicians prescribe in these cases?

The next area of investigation should be large-scale clinical trials or carefully designed post hoc analyses to determine the next steps in therapeutic intervention and clinical management.

## Conclusion

In summary, we conclude that even relatively minor elevations of cardiac troponin are associated with a worse prognosis for patients with and without suspected ACS. In particular, for dialysis patients without suspected ACS, increased troponin T or I is a potent predictor of subsequent mortality. Whether elevated troponin provides strong incremental prognostic value over and above carefully assessed clinical risk factors for CAD and mortality, is not conclusive.

Regarding troponin testing, until there is harmonization and standardization of the troponin assay (similar to other laboratory markers), comparison of results from study to study and from population to population remains problematic.

Regarding patients with suspected ACS, troponin is already the gold standard for diagnosing MI and it is measured routinely in patients with suspected ACS. Established guidelines for ACS diagnosis and management are already in existence for the general population of patients. Successfully interpreting troponin levels in diagnosing ACS (vs. non-ACS) conditions largely depends on pre-test probability based on symptoms, ECG changes, and clinical factors.

Our findings do not dispute the utility of troponin for diagnosis or prognosis among CKD patients, with findings generally similar to studies reported for general populations of patients (indirect comparison), but we found very limited evidence for guiding disease management based on troponin levels alone.

Regarding CKD patients without suspected ACS, our findings support the current Food and Drug Administration and National Kidney Foundation recommendations that measuring troponin levels may be reasonable for additional risk stratification. Further work in this area should focus on improving our knowledge of the utility of this biomarker in regard to discrimination and the ability to appropriately reclassify CKD patients into higher and lower risk groups. However, unless we can identify the next steps regarding how best to manage these patients with elevated troponin levels (how and if treatments would vary from those treatments indicated by clinical factors alone), the applicability of this screening recommendation is incomplete. Thus it is difficult to endorse the routine measurement of cardiac troponin in clinical practice because of the uncertainty regarding appropriate clinical strategies that may use this information. New research should focus on testing patient management strategies that incorporate measuring this biomarker in their algorithms.