# Background

## Cardiac Troponin Assays

### Troponin Detection in Normal and Disease States

Troponin is a protein complex of three subunits (T, I, and C) that's involved in the contractile process of skeletal and cardiac muscle. Both cardiac and skeletal muscle express troponin C; whereas troponin T and I are generally thought to be cardiac-specific. (However, a recent study has challenged whether troponin T is exclusively cardiac-specific.1) Blood from healthy individuals with no evidence of cardiac disease contains very low amounts of cardiac troponin.2 Some of the newer high-sensitivity assays may be able to measure troponin in normal individuals; although many of the commercially available assays cannot detect troponin at all or cannot quantify it at levels below the measuring range of the assay.

When cardiac injury occurs (from ischemia or various other causes), cardiomyocytes release cardiac troponin into the blood in proportion to the degree of damage.3 Troponin levels increase within 3 to 4 hours after the onset of damage and remain high for up to 4 to 7 days (troponin I) or 10 to 14 days (troponin T).

Clinically, the most important use of troponin testing is to detect elevated troponin levels so as to identify patients suspected of having an acute coronary syndrome (ACS). ACS is defined as a spectrum of conditions caused by insufficient supply of oxygen to the myocardium by the coronary arteries. However, elevated cardiac troponin levels are not specific for the diagnosis of ACS or acute spontaneous myocardial infarction (MI) [type 1 MI]. Individuals with non-ACS conditions can also have elevated cardiac troponin.4 Non-ACS conditions can include noncoronary causes (e.g., sepsis, congestive heart failure, myocarditis, drug toxicity, pulmonary embolism, hypoxia, and global hypoperfusion) and coronary causes from ischemic imbalance [i.e., increased demand in the setting of stable coronary artery disease (CAD) lesions] classified as type 2 MI. Many symptoms associated with non-ACS conditions may overlap with symptoms of ACS (e.g., chest pain or dyspnea). This presents a diagnostic dilemma to the clinician and often requires an extended evaluation before the clinician can make an accurate diagnosis.

### The 99^th^ Percentile Cutpoint—Challenges

Because we can detect troponin even among presumably healthy adults, we must set guidelines regarding what is considered an “elevated” level. The joint European Society of Cardiology/American College of Cardiology guidelines define a clinically relevant increase in troponin levels as a level that exceeds the 99^th^ percentile of a normal reference population.5 However, we must interpret elevated troponin levels in the context of a intermediate to high pre-test probability of suspected ACS.6

Currently, there is no universally adopted 99^th^ percentile value because there is no reference standard for detecting either troponin T or I, as each test manufacturer independently develops its own assays. Additionally, no consensus exists on how to define a reference population for the assays (in terms of age, gender, race/ethnicity, comorbidities, or number of participants), and many of the 99^th^ percentile values come from diverse and poorly defined study participants.7 When studies compare troponin T and I assays in the same population, assays can differ regarding troponin concentrations at the 99^th^ percentile by as much as five-fold. Recommendations call for cardiac troponin assays to have a coefficient of variation less than or equal to 10 percent at the 99^th^ percentile cutpoint. However, many current assays have a coefficient of variation between 10 and 20 percent at the 99^th^ percentile.8

### High-Sensitivity Troponin Assays

Troponin assays have evolved over time, becoming ever more sensitive with detection limits 10 to 100 times lower than currently available commercial troponin assays. This also challenges the precision guidelines for acceptable coefficient of variation.9 For example, a contemporary sensitive cardiac troponin I (such as TnI-Ultra) can detect concentrations as low as 0.006 mcg/L, and the high-sensitive cardiac troponin T assay (Roche, approved in Europe but not the United States) can detect as low as 0.005 mcg/L.6 Manufacturers are continuing to develop new generations of high-sensitivity assays that are more precise at even lower concentrations, such as less than 1 ng/L (0.001 mcg/L).

Thus, the high-sensitivity assays detect measurable troponin levels in a larger percentage of presumably healthy people—redefining what is “normal”.7 For patients with suspected ACS, this means potentially earlier detection for the diagnosis of ACS which may aid management in emergency room departments. On the other hand, this increased sensitivity comes at a cost of reduced specificity for ACS. High-sensitivity assays may also aid in our ability to detect increases in cardiac troponin, which will help distinguish patients with acute disease from more chronic disease—where levels, while elevated, are more static.

With constantly evolving and newer assays, there is a need to define how these new high-sensitivity assays compare with contemporary and older generations of troponin assays. In 2009, Apple et al. proposed a “scorecard” based on imprecisions (coefficient of variation percent) of each assay at the 99^th^ percentile and how many samples from normal individuals are measurable below the 99^th^ percentile.8

## Troponin Elevation in Chronic Kidney Disease

Given that the prevalence of chronic kidney disease (CKD) in the United States reached 15 percent in 2008, how to interpret troponin levels in this population is an important issue.10, 11 We listed a description of the stages of CKD in Table 1. Of note, even more recently, there are new guidelines for classifying CKD that incorporate albuminuria: http://www.kdigo.org/clinical_practice_guidelines/pdf/CKD/KDIGO_2012_CKD_GL.pdf

Table 1 Stages of chronic kidney disease

Stage | Description | GFR, mL/min/ 1.73 m2
1 | Kidney damage with normal or increased GFR | ≥90
2 | Kidney damage with mildly decreased GFR | 60–89
3 | Moderately decreased GFR | 30–59
4 | Severely decreased GFR | 15–29
5 | End-stage renal disease | <15 or dialysis

GFR = glomerular filtration rate; mL/min/1.73 m2 = milliliters per minute for 1.73 meters squared

Patients with CKD (particularly those with end-stage renal disease [ESRD]) have a greater prevalence of persistently-elevated cardiac troponin when compared with patients who do not have CKD. Although somewhat controversial, reduced renal clearance most likely is not the primary mechanism for troponin elevation in CKD, but rather it represents a marker of myocardial injury.12, 13 The intact troponin molecule is large and it is unlikely that the kidneys are primarily responsible for clearance from serum. However, work by Diris et al. suggests that the troponin molecule is degraded into smaller fragments, which can be detected by the assays and are small enough to be filtered by the kidneys. This mechanism may contribute to the elevation of troponin in severe renal failure.14 Despite this, Ellis et al.15 did not observe a statistically significant difference in the half-life and the elimination rate constant of troponin I in patients with myocardial infarction (MI) and ESRD when compared with patients with MI and normal kidney function.

As with non-CKD patients, we must interpret elevated troponin levels in patients with CKD in the context of one's pre-test probability for suspecting an ACS event. Elevated levels may also be due to cardiac injury associated with chronic structural heart disease (e.g., CAD, heart failure, etc.), which is highly prevalent among CKD patients, rather than from acute ischemia, especially when the levels do not change rapidly over time.16 Among patients without suspected ACS, potential reasons for detectable small increases in troponin include micro-infarctions, microvascular disease, subendocardial ischemia associated with left ventricular hypertrophy and diastolic dysfunction, and nonischemic cardiomyopathic processes, all of which are more common in patients with CKD.

## Use of Troponin for the Diagnosis of Acute Coronary Syndrome in Patients With Chronic Kidney Disease (Background for Key Question 1)

In patients with symptoms of ACS, without other causes for increased troponin, clinicians use elevated troponin levels (along with clinical factors) to diagnosis MI as outlined by the Global Task Force's Third Universal Definition of MI (Table 2).17

Table 2 Definition of myocardial infarction according to 2012 Third Universal Definition

Both are required for a diagnosis of myocardial infarction:; 3 Rise and/or fall of troponin (or another cardiac biomarker) with at least one value above the 99^th^ percentile reference limit; 4 Evidence of myocardial ischemia from symptoms, electrocardiogram, or cardiac imaging

The diagnosis of ACS among patients with CKD (especially those with ESRD) can be particularly challenging. Electrocardiograms (ECGs) are frequently abnormal in CKD patients (indicating left ventricular hypertrophy, intraventricular conduction delay, wide QRS, etc.), which can reduce the sensitivity/specificity of detecting ischemia.18 Also, baseline troponin levels are often not known in patients with CKD on initial presentation, making it hard to define elevated troponin levels (increased troponin is considered, along with symptoms and other clinical factors, in diagnosing ACS, as per the global definition of MI). Whether clinicians should use an alternative threshold, other than the 99^th^ percentile, of elevated cardiac troponin when assessing patients with CKD is unknown. Since not all CKD patients will have elevated levels, high cut-off values will disadvantage those who do not have elevated levels. Therefore, using alternate cutpoints may not be preferable.

On the other hand, the patterns of changes in troponin levels (rise, fall, and magnitude of change) can also be very helpful for clinicians in distinguishing ACS from non-ACS in symptomatic patients. The National Academy of Clinical Biochemistry19 has recommended that for patients with ESRD and suspected ACS, a diagnosis of acute MI (Type I) should require a dynamic change in troponin levels of greater than 20 percent within 9 hours (with at least one value above the 99^th^ percentile).13 However, clinicians should also consider the timing of presentation from the onset of symptoms. If the patient presents late in the course of ACS, testing could take place during the “plateau phase,” and clinicians may miss the rise/fall pattern. Although widely applied in the guidelines, researchers have not yet studied this 20 percent rule in a vigorous evidence-based fashion and compared it with other degrees of change or the use of a single elevated value in the context of high pre-test probability.

No consensus exists about whether the diagnostic criteria for MI using troponin levels should be different for patients with CKD and those without CKD. It's also unclear whether elevated baseline troponin levels make it more difficult to diagnose ACS in patients with ESRD than in patients with milder forms of CKD.

The following clinical vignette highlights some of the clinical diagnostic dilemmas: The patient is a 68-year-old man with a history of diabetes and CAD who has had remote coronary artery bypass surgery. He has CKD (creatinine 1.8 mg/dL) and previously had a troponin I level of 0.06 mcg/L on his last admission. He is admitted to the hospital with pneumonia but repeated tests of troponin indicate a level of 0.24 mcg/L. He is short of breath but has no chest pain and his ECG shows a left bundle branch block (old). What is the clinical significance of his newly elevated troponin? Should he additionally be managed for ACS?

## Use of Troponin Level as a Management Strategy for Patients With Chronic Kidney Disease and Acute Coronary Syndrome (Background for Key Question 2)

Frequently, clinicians use troponin levels, along with clinical factors, to stratify patients according to risk when a diagnosis of non-ST-elevation MI (NSTEMI)/unstable angina is likely. Clinicians usually treat patients at high risk for ACS with an “early invasive” strategy (i.e., diagnostic angiography with the intent of revascularization), while clinicians may treat patients with low-to-intermediate risk of ACS with an “initially conservative” (i.e., selectively invasive) management strategy.20

The “troponin hypothesis” suggests that patients with elevated troponin levels (troponin-positive) are likely to have more thrombus burden, complex lesions, and be at higher risk for worse outcomes than patients with normal troponin levels (troponin-negative). Therefore, it stands to reason that clinicians should treat troponin-positive patients more aggressively. Results from a general population of patients presenting with ACS (not exclusively CKD), found that even minor troponin elevations identify patients who benefit from an early invasive strategy (compared with initially conservative management).21 In addition to an early invasive strategy, the use of glycoprotein IIb/IIIa inhibitors and low-molecular-weight heparin also appear more beneficial in troponin-positive versus troponin-negative patients with suspected ACS.13 However, in the Clopidogrel in Unstable Angina to prevent Recurrent Events (CURE) clinical trial of ACS patients, clopidogrel use did not confer a preferential benefit in troponin-positive versus troponin-negative patients. Therefore, the troponin hypothesis may not be applicable to all therapeutic management in ACS.

As with the initial diagnosis of ACS, elevated background troponin levels in patients with CKD may limit the applicability of treatment algorithms that are based on troponin levels in non-CKD populations. Whether elevated background troponin levels in patients with CKD and suspected ACS are associated with differences in the comparative effectiveness of interventions or management strategies is unknown.

## Use of Troponin Level as a Prognostic Indicator in Patients With Chronic Kidney Disease Following Acute Coronary Syndrome (Background for Key Question 3)

In addition to their use in diagnosing and managing ACS, studies have examined troponin assays as potential independent risk predictors of morbidity and mortality in populations following an acute ischemic event. Previous reviews and meta-analyses have investigated the prognostic performance of troponin testing in patients with kidney failure, but often excluded studies on patients with ACS.22, 23 Therefore, the prognostic significance of elevated cardiac troponin levels with regard to short- and long-term major adverse cardiovascular events (MACE) for patients with both CKD and ACS remains uncertain.

## Use of Troponins in Adults With Chronic Kidney Disease Who Do Not Have Symptoms of Acute Coronary Syndrome: A Role for Risk Stratification (Background for Key Question 4)

Patients with CKD are known to be at increased risk for cardiovascular morbidity and mortality. Despite established guidelines for primary and secondary cardiovascular disease prevention (i.e., blood pressure, lipid, and glucose targets), cardiovascular disease remains the number one cause of death for CKD patients. Among asymptomatic CKD patients without suspected ACS, prior studies have shown that chronic elevated cardiac troponin is associated with increased risk of cardiovascular morbidity and mortality.23-26 For this reason, in May 2004 the U.S. Food and Drug Administration approved the measurement of troponin T in dialysis patients for the express purpose of risk stratification (i.e., prediction of mortality). However, it is unknown whether measuring troponins improves risk prediction when compared with (or used in conjunction with) existing models that are based on traditional clinical and laboratory risk factors. Whether troponin testing improves metrics of discrimination and re-classification of patients into higher or lower risk groups is unknown.

It is also unclear whether clinicians should manage asymptomatic patients with CKD and chronically-elevated cardiac troponin levels differently than patients with CKD who have normal troponin levels.

## Types of Troponin Assays and Special Subgroups of Patients With Chronic Kidney Disease (Key Questions 1–4)

There are multiple commercially available troponin assays including cardiac troponin T, troponin I, high-sensitivity troponin T, and high-sensitivity troponin I. Whether all of these troponin assays are equal in distinguishing ACS from non-ACS conditions and prognosticating and risk-stratifying CKD patients (with and without ACS) is unclear.

Furthermore, whether troponin testing leads to changes in management and outcomes among certain subgroups of patients with CKD is also unknown (e.g., categories of CKD stages, dialysis status, age, race, gender, and those with prior history of CAD).

## Scope and Key Questions

The purpose of this comparative effectiveness review will be to present information for the appropriate use of troponin levels to guide evidence-based management decisions for patients with CKD. These findings should be useful for a diverse set of contingents including cardiologists, nephrologists, emergency room physicians, and laboratory medicine scientists who use and interpret troponin testing in the clinical management of patients. Findings may also be useful for epidemiologists in tackling research gaps for further studies. We addressed the following Key Questions (KQs) in this review (Figures 1 and 2):

Figure 1 Analytic framework for interpreting troponin as a cardiac marker among patients with chronic kidney disease and suspected acute coronary syndrome

Abbreviations: ACS = acute coronary syndrome; CKD = chronic kidney disease; ESRD = end-stage renal disease; KQ = key question; MACE = major adverse cardiovascular event

The figure shows an analytic framework which describes the key questions. Moving from left to right, there is text, arrows, boxes, and circles that have text within and around. The first thing on the left show the population, which is patients with chronic kidney disease including patients with end stage renal disease. There is an arrow pointing to symptoms, concerns for ACS and two subpoints of high and low pretest probability. Those two have an arrow pointing to them denoting Key Question 1.2, 2.2, and 3.2 subgroups. From symptoms, concerns for ACS, there is a horizontal arrow labeled Troponin Assay that points to a box. There is also an arrow that points down to a circle labeled Harms of over-diagnosing ACS Key Question 1.3. Two arrows point to Troponin Essay and they are labeled Key Question 1.5 CKD vs. non-CKD and Key questions 1.4 and 3.3 specific troponin assays. The box to the right of Troponin Assay is labeled Key Question 1 diagnosis and inside the box it says diagnostic accuracy ACS and no ACS. There is then a dotted arrow pointing to the next box labeled Key question two, management of patients with ACS. The box has inside it patient management, early invasive strategy and early conservative strategy. The final box on the right is labeled Key Question 3 prognosis in patients with suspected ACS and inside has long term (greater than or equal to one year) outcomes, MACE, and all-cause mortality and then short term outcomes (less than a year) MACE and all-cause mortality. There is also an arrow that points all the way from Troponin Assay directly to this right-most box of Key Question 3.

Figure 2 Analytic framework for interpreting troponin as a cardiac marker during renal function impairment among patients with chronic kidney disease without symptoms of acute coronary syndrome

Abbreviations: ACS = acute coronary syndrome; CKD = chronic kidney disease; ESRD = end-stage renal disease; KQ = key question; MACE = major adverse cardiovascular event

The figure shows an analytic framework for key question 4. The leftmost text says patients with chronic kidney disease including end stage renal disease. Then there is an arrow pointing to no symptoms of ACS. This has an arrow pointing from below that says Key Question 4.3 Subgroups. There is an arrow pointing right from no symptoms of ACS to Troponin Assay. Troponin Assay has Key Question 4.4 Specific troponin assays above it and Key Question 4.1 Prevalence of troponin elevation. The box to the right of Troponin assay says high risk and low risk, then the next box is patient management, then the rightmost box is long term and short term outcomes of MACE and all-cause mortality . The last three boxes have a line above with the label Key Question 4.2 prognosis in a stable population.

### KQ 1 Diagnosis of ACS

What is the diagnostic performance of a troponin elevation (troponin I, troponin T, high-sensitivity troponin T, or high-sensitivity troponin I) >99^th^ percentile (compared to no elevation) for the detection of ACS in adult patients with CKD (including those with ESRD)?

1.1 What are the operating characteristics of a troponin elevation (compared with no elevation) in distinguishing between ACS and non-ACS, including sensitivity, specificity, and positive and negative predictive values?
  1.1a How do the positive predictive value and the negative predictive value vary with the population's pre-test probability for ACS?
  1.1b Does a significant delta of change (such as greater than 20 percent within 9 hours) better discriminate between ACS and non-ACS compared with a single troponin elevation?
1.2 What are the operating characteristics of troponin elevation for distinguishing ACS from non-ACS among the following subgroups?
  1.2a Gender, age, ethnicity, stage of kidney disease (CKD stages I-IV or ESRD), dialysis status (for ESRD), status post-renal transplant, presence of baseline or prior elevated troponins, presence of ischemic ECG changes, comorbidities (e.g., diabetes, hypertension), smoking status, 10-year CAD predicted risk, or history of CAD.
1.3 What are the harms associated with a false-positive diagnosis of ACS based on an elevated troponin level?
1.4 Among studies that [underlined: directly] compared one type of troponin assay (troponin I, troponin T, high-sensitivity troponin T, or high-sensitivity troponin I) against another type of troponin assay, do the operating characteristics of a certain type of troponin test perform better for diagnosis of ACS?
1.5 Among studies that [underlined: directly] compared troponin testing in patients with CKD versus patients with normal renal function, do the operating characteristics of a troponin elevation perform similarly?

### KQ 2 Management in ACS

In adults with CKD (including ESRD), do troponin levels improve management of ACS?

2.1 Does a troponin elevation modify the comparative effectiveness of interventions or management strategies for ACS (e.g., is an aggressive strategy better than a initially conservative strategy for high troponin levels, but not for low/normal troponin levels)?
2.2 Among adults with CKD with suspected ACS, how does a troponin elevation change the effects of interventions or management strategies according to the following characteristics?
  2.2a Gender, age, ethnicity, stage of kidney disease (CKD stages I-IV or ESRD), dialysis status (for ESRD), status post-renal transplant, presence of baseline or prior elevated troponins, presence of ischemic ECG changes, comorbidities (e.g., diabetes, hypertension), smoking status, 10-year CAD predicted risk, or history of CAD

### KQ 3 Prognosis in ACS

In adult patients with CKD (including those with ESRD) and suspected ACS, does an elevated troponin level help to estimate prognosis?

3.1 Do troponin results relate to:
  3.1a Long-term outcomes (all-cause mortality and major adverse cardiovascular events [MACE] such as subsequent MI, stroke or cardiovascular death, over at least 1 year of followup)?
  3.1b Short-term outcomes (all-cause mortality and MACE during the initial hospitalization or within 1 year of followup)?
3.2 Does a troponin elevation help to estimate prognosis after ACS in the following subgroups?
  3.2a Gender, age, ethnicity, stage of kidney disease (CKD stages I-IV or ESRD), dialysis status (for ESRD), status post renal transplant, presence of baseline or prior elevated troponins, presence of ischemic ECG changes, comorbidities (e.g., diabetes, hypertension), smoking status, 10-year CAD predicted risk, or history of CAD
3.3 Among studies that [underlined: directly] compared one type of troponin assay (troponin I, troponin T, high-sensitivity troponin T, or high-sensitivity troponin I) against another type of troponin assay, does a certain type of troponin test estimate prognosis better after ACS?

### KQ 4 Risk Stratification in non-ACS

Does an elevated troponin level (compared with no elevation) help with risk stratification in adults with CKD (including those with ESRD) who do not have symptoms of ACS?

4.1 In clinically stable adults with CKD (including those with ESRD) who do not have symptoms of ACS, what is the distribution of troponin values?
  4.1a What is the distribution by CKD stages I-IV and in ESRD?
4.2 Do troponin threshold levels or patterns of troponin change in this population improve prediction for MACE or all-cause mortality, compared with or supplementing existing models?
4.3 Does troponin elevation improve CHD risk prediction for the following subgroups:
  4.3a Gender, age, ethnicity, stage of kidney disease (CKD stages I-IV or ESRD on dialysis), status post-renal transplant, presence of baseline or prior elevated troponins, presence of ischemic ECG changes, comorbidities (e.g., diabetes, hypertension), smoking status, 10-year CAD predicted risk, or history of CAD
4.4 Among studies that [underlined: directly] compared one type of troponin assay (troponin I, troponin T, hs troponin T, or hs troponin I) against another type of troponin assay, does a certain type of troponin test predict risk better?