# References for Appendixes

1 Abaci A, Ekici E, Oguzhan A, et al. Cardiac troponins T and I in patients with end-stage renal disease: the relation with left ventricular mass and their prognostic value. Clin Cardiol. Dec. 2004;27(12):704-9. [pmid: 15628116].
2 Abbas NA, John RI, Webb MC, et al. Cardiac troponins and renal function in nondialysis patients with chronic kidney disease. Clin Chem. Nov. 2005;51(11):2059-66. [pmid: 16166165].
3 Acharji S, Baber U, Mehran R, et al. Prognostic significance of elevated baseline troponin in patients with acute coronary syndromes and chronic kidney disease treated with different antithrombotic regimens: a substudy from the ACUITY trial. Circ Cardiovasc Interv. Apr. 2012;5(2):157-65. [pmid: 22354934].
4 Alcalai R, Planer D, Culhaoglu A, et al. Acute coronary syndrome vs nonspecific troponin elevation: clinical predictors and survival analysis. Arch Intern Med. Feb. 12. 2007;167(3):276-81. [pmid: 17296884].
5 Apple FS, Sharkey SW, Hoeft P, et al. Prognostic value of serum cardiac troponin I and T in chronic dialysis patients: a 1-year outcomes analysis. Am J Kidney Dis. Mar. 1997;29(3):399-403. [pmid: 9041216].
6 Apple FS, Christenson RH, Valdes R Jr, et al. Simultaneous rapid measurement of whole blood myoglobin, creatine kinase MB, and cardiac troponin I by the triage cardiac panel for detection of myocardial infarction. Clin Chem. Feb. 1999;45(2):199-205. [pmid: 9931041].
7 Apple FS, Murakami MM, Pearce LA, et al. Predictive value of cardiac troponin I and T for subsequent death in end-stage renal disease. Circulation. Dec. 3. 2002;106(23):2941-5. [pmid: 12460876].
8 Apple FS, Murakami MM, Pearce LA, et al. Multi-biomarker risk stratification of N-terminal pro-B-type natriuretic peptide, high-sensitivity C-reactive protein, and cardiac troponin T and I in end-stage renal disease for all-cause death. Clin Chem. Dec. 2004;50(12):2279-85. [pmid: 15364888].
9 Apple FS, Pearce LA, Doyle PJ, et al. Cardiac troponin risk stratification based on 99th percentile reference cutoffs in patients with ischemic symptoms suggestive of acute coronary syndrome: influence of estimated glomerular filtration rates. Am J Clin Pathol. Apr. 2007;127(4):598-603. [pmid: 17369136].
10 Artunc F, Mueller C, Breidthardt T, et al. Sensitive troponins--which suits better for hemodialysis patients? Associated factors and prediction of mortality. PLoS One. 2012;7(10):e47610. [pmid: 23077650].
11 Assa S, Gansevoort RT, Westerhuis R, et al. Determinants and prognostic significance of an intra-dialysis rise of cardiac troponin I measured by sensitive assay in hemodialysis patients. Clin Res Cardiol. Jun. 2013;102(6):439-45. [pmid: 23397594].
12 Aviles RJ, Askari AT, Lindahl B, et al. Troponin T levels in patients with acute coronary syndromes, with or without renal dysfunction. N Engl J Med. Jun. 27. 2002;346(26):2047-52. [pmid: 12087140].
13 Bagheri N, Taziki O, Falaknazi K. C- Reactive protein, cardiac troponin T and low albumin are predictors of mortality in hemodialysis patients. Saudi J Kidney Dis Transpl. Sep. 2009;20(5):789-93. [pmid: 19736474].
14 Barthelemy O, Cayla G, Silvain J, et al. Optimal time for catheterization in NSTE-ACS patients with impaired renal function: Insights from the ABOARD Study. Int J Cardiol. 2012. Jul. 12. [pmid: 22795712].
15 Beciani M, Tedesco A, Violante A, et al. Cardiac troponin I (2nd generation assay) in chronic haemodialysis patients: prevalence and prognostic value. Nephrol Dial Transplant. May. 2003;18(5):942-6. [pmid: 12686669].
16 Bhagavan NV, Goldstein AP, Honda SA, et al. Role of cardiac troponin I in the evaluation of myocardial injury. J Clin Lab Anal. 1998;12(5):276-9. [pmid: 9773957].
17 Boulier A, Jaussent I, Terrier N, et al. Measurement of circulating troponin Ic enhances the prognostic value of C-reactive protein in haemodialysis patients. Nephrol Dial Transplant. Sep. 2004;19(9):2313-8. [pmid: 15252159].
18 Bozbas H, Korkmaz ME, Atar I, et al. Serum levels of cardiac enzymes before and after renal transplantation. Clin Cardiol. Oct. 2004;27(10):559-62. [pmid: 15553307].
19 Brunet P, Oddoze C, Paganelli F, et al. Cardiac troponins I and T in hemodialysis patients without acute coronary syndrome. Int J Cardiol. Sep. 26. 2008;129(2):205-9. [pmid: 17662483].
20 Bueti J, Krahn J, Karpinski M, et al. Troponin I testing in dialysis patients presenting to the emergency room: does troponin I predict the 30-day outcome?. Nephron Clin Pract. 2006;103(4):c129-36. [pmid: 16636580].
21 Chew HC. Cardiac troponin T in acute coronary syndrome with renal insufficiency. Asian Cardiovasc Thorac Ann. Aug. 2008;16(4):284-7. [pmid: 18670019].
22 Choy JB, Armstrong PW, Ulan RA, et al. Do cardiac troponins provide prognostic insight in hemodialysis patients?. Can J Cardiol. Jul. 2003;19(8):907-11. [pmid: 12876611].
23 Chrysochou C, Manzoor S, Wright J, et al. Role of renal function and cardiac biomarkers (NT-proBNP and Troponin) in determining mortality and cardiac outcome in atheromatous renovascular disease. Kidney Blood Press Res. 2009;32(5):373-9. [pmid: 19887825].
24 Claes K, Bammens B, Evenepoel P, et al. Troponin I is a predictor of acute cardiac events in the immediate postoperative renal transplant period. Transplantation. Feb. 15. 2010;89(3):341-6. [pmid: 20145526].
25 Codognotto M, Piccoli A, Zaninotto M, et al. Effect of a dialysis session on the prognostic values of NT-proBNP, troponins, endothelial damage and inflammation biomarkers. J Nephrol. Jul-Aug. 2010;23(4):465-71. [pmid: 20540041].
26 Connolly GM, Cunningham R, McNamee PT, et al. Troponin T is an independent predictor of mortality in renal transplant recipients. Nephrol Dial Transplant. Mar. 2008;23(3):1019-25. [pmid: 18065785].
27 Conway B, McLaughlin M, Sharpe P, et al. Use of cardiac troponin T in diagnosis and prognosis of cardiac events in patients on chronic haemodialysis. Nephrol Dial Transplant. Dec. 2005;20(12):2759-64. [pmid: 16188899].
28 Deegan PB, Lafferty ME, Blumsohn A, et al. Prognostic value of troponin T in hemodialysis patients is independent of comorbidity. Kidney Int. Dec. 2001;60(6):2399-405. [pmid: 11737616].
29 deFilippi C, Wasserman S, Rosanio S, et al. Cardiac troponin T and C-reactive protein for predicting prognosis, coronary atherosclerosis, and cardiomyopathy in patients undergoing long-term hemodialysis. JAMA. Jul. 16. 2003;290(3):353-9. [pmid: 12865376].
30 deFilippi C, Seliger SL, Kelley W, et al. Interpreting cardiac troponin results from high-sensitivity assays in chronic kidney disease without acute coronary syndrome. Clin Chem. Sep. 2012;58(9):1342-51. [pmid: 22791885].
31 Dierkes J, Domrose U, Westphal S, et al. Cardiac troponin T predicts mortality in patients with end-stage renal disease. Circulation. Oct. 17. 2000;102(16):1964-9. [pmid: 11034946].
32 Duman D, Tokay S, Toprak A, et al. Elevated cardiac troponin T is associated with increased left ventricular mass index and predicts mortality in continuous ambulatory peritoneal dialysis patients. Nephrol Dial Transplant. May. 2005;20(5):962-7. [pmid: 15741207].
33 Farkouh ME, Robbins MJ, Zafar MU, et al. Association between troponin I levels and mortality in stable hemodialysis patients. Am J Med. Feb. 15. 2003;114(3):224-6. [pmid: 12637137].
34 Fehr T, Knoflach A, Ammann P, et al. Differential use of cardiac troponin T versus I in hemodialysis patients. Clin Nephrol. Jan. 2003;59(1):35-9. [pmid: 12572929].
35 Feringa HH, Bax JJ, de Jonge R, et al. Impact of glomerular filtration rate on minor troponin T elevations for risk assessment in patients undergoing operation for abdominal aortic aneurysm or lower extremity arterial obstruction. Am J Cardiol. Dec. 1. 2006;98(11):1515-8. [pmid: 17126662].
36 Fernandez-Reyes MJ, Mon C, Heras M, et al. Predictive value of troponin T levels for ischemic heart disease and mortality in patients on hemodialysis. J Nephrol. Sep-Oct. 2004;17(5):721-7. [pmid: 15593041].
37 Flores LM, Hernandez Dominguez JL, Otero A, et al. Cardiac troponin I determination in patients with chronic renal failure. Nefrologia. 2006;26(1):107-12. [pmid: 16649431].
38 Flores-Solis LM, Hernandez-Dominguez JL, Otero-Gonzalez A, et al. Cardiac troponin I and creatine kinase MB isoenzyme in patients with chronic renal failure. Nefrologia. 2012;32(6):809-18. [pmid: 23169364].
39 Gaiki MR, DeVita MV, Michelis MF, et al. Troponin I as a prognostic marker of cardiac events in asymptomatic hemodialysis patients using a sensitive troponin I assay. Int Urol Nephrol. Dec. 2012;44(6):1841-5. [pmid: 22311387].
40 Geerse DA, van Berkel M, Vogels S, et al. Moderate elevations of high-sensitivity cardiac troponin I and B-type natriuretic peptide in chronic hemodialysis patients are associated with mortality. Clin Chem Lab Med. Dec. 2012;10:1-8. [pmid: 23241607].
41 Goicoechea M, Garca de Vinuesa S, Gomez-Campdera F, et al. Clinical significance of cardiac troponin T levels in chronic kidney disease patients: predictive value for cardiovascular risk. Am J Kidney Dis. May. 2004;43(5):846-53. [pmid: 15112175].
42 Gruberg L, Fuchs S, Waksman R, et al. Prognostic value of cardiac troponin I elevation after percutaneous coronary intervention in patients with chronic renal insufficiency: a 12-month outcome analysis. Catheter Cardiovasc Interv. Feb. 2002;55(2):174-9. [pmid: 11835642].
43 Haaf P, Reichlin T, Twerenbold R, et al. Risk stratification in patients with acute chest pain using three high-sensitivity cardiac troponin assays. Eur Heart J. 2013. Jul. 14. [pmid: 23821402].
44 Hallen J, Madsen L, Ladefoged S, et al. Incremental value of a combination of cardiac troponin T, N-terminal pro-brain natriuretic peptide and C-reactive protein for prediction of mortality in end-stage renal disease. Scand J Urol Nephrol. Mar. 2011;45(2):151-8. [pmid: 21091090].
45 Han JH, Lindsell CJ, Ryan RJ, et al. Changes in cardiac troponin T measurements are associated with adverse cardiac events in patients with chronic kidney disease. Am J Emerg Med. Jul. 2005;23(4):468-73. [pmid: 16032613].
46 Han SH, Choi HY, Kim DK, et al. Elevated cardiac troponin T predicts cardiovascular events in asymptomatic continuous ambulatory peritoneal dialysis patients without a history of cardiovascular disease. Am J Nephrol. 2009;29(2):129-35. [pmid: 18719346].
47 Hasegawa M, Ishii J, Kitagawa F, et al. Prognostic value of highly sensitive troponin T on cardiac events in patients with chronic kidney disease not on dialysis. Heart Vessels. 2012. Aug. 23. [pmid: 22914904].
48 Havekes B, van Manen JG, Krediet RT, et al. Serum troponin T concentration as a predictor of mortality in hemodialysis and peritoneal dialysis patients. Am J Kidney Dis. May. 2006;47(5):823-9. [pmid: 16632021].
49 Heeschen C, Deu A, Langenbrink L, et al. Analytical and diagnostic performance of troponin assays in patients suspicious for acute coronary syndromes. Clin Biochem. Jul. 2000;33(5):359-68. [pmid: 11018687].
50 Helleskov Madsen L, Ladefoged S, Hildebrandt P, et al. Comparison of four different cardiac troponin assays in patients with end-stage renal disease on chronic haemodialysis. Acute Card Care. 2008;10(3):173-80. [pmid: 18608043].
51 Hickman PE, McGill DA, Talaulikar G, et al. Prognostic efficacy of cardiac biomarkers for mortality in dialysis patients. Intern Med J. Dec. 2009;39(12):812-8. [pmid: 20233242].
52 Hickson LJ, Cosio FG, El-Zoghby ZM, et al. Survival of patients on the kidney transplant wait list: relationship to cardiac troponin T. Am J Transplant. Nov. 2008;8(11):2352-9. [pmid: 18785956].
53 Hickson LT, El-Zoghby ZM, Lorenz EC, et al. Patient survival after kidney transplantation: relationship to pretransplant cardiac troponin T levels. Am J Transplant. Jun. 2009;9(6):1354-61. [pmid: 19459818].
54 Hocher B, Ziebig R, Altermann C, et al. Different impact of biomarkers as mortality predictors among diabetic and nondiabetic patients undergoing hemodialysis. J Am Soc Nephrol. Sep. 2003;14(9):2329-37. [pmid: 12937310].
55 Hocher B, Ziebig R, Krause R, et al. Relaxin is an independent risk factor predicting death in male patients with end-stage kidney disease. Circulation. May. 18. 2004;109(19):2266-8. [pmid: 15136497].
56 Hocher B, Kalk P, Godes M, et al. Gender-dependent impact of risk factors for cardiovascular and non-cardiovascular mortality in end-stage renal disease patients on haemodialysis. Kidney Blood Press Res. 2008;31(5):360-6. [pmid: 19023219].
57 Hojs R, Ekart R, Hojs Fabjan T, et al. Cardiac troponin T (cTnT) in hemodialysis patients with asymptomatic and symptomatic atherosclerosis. Arch Med Res. Jul-Aug. 2005;36(4):367-71. [pmid: 15950076].
58 Holden RM, Beseau D, Booth SL, et al. FGF-23 is associated with cardiac troponin T and mortality in hemodialysis patients. Hemodial Int. Jan. 2012;16(1):53-8. [pmid: 22099949].
59 Hung SY, Hung YM, Fang HC, et al. Cardiac troponin I and creatine kinase isoenzyme MB in patients with intradialytic hypotension. Blood Purif. 2004;22(4):338-43. [pmid: 15218282].
60 Hussein M, Mooij J, Roujouleh H, et al. Cardiac troponin-I and its prognostic significance in a dialysis population. Hemodial Int. Oct. 1. 2004;8(4):332-7. [pmid: 19379438].
61 Ie EH, Klootwijk PJ, Weimar W, et al. Significance of acute versus chronic troponin T elevation in dialysis patients. Nephron Clin Pract. 2004;98(3):c87-92. [pmid: 15528943].
62 Ikeda J, Zenimoto M, Kita M, et al. Usefulness of cardiac troponin I in patients with acute myocardial infarction. Rinsho Byori. Oct. 2002;50(10):982-6. [pmid: 12451679].
63 Iliou MC, Fumeron C, Benoit MO, et al. Prognostic value of cardiac markers in ESRD: Chronic Hemodialysis and New Cardiac Markers Evaluation (CHANCE) study. Am J Kidney Dis. Sep. 2003;42(3):513-23. [pmid: 12955679].
64 Ilva T, Lassus J, Siirila-Waris K, et al. Clinical significance of cardiac troponins I and T in acute heart failure. Eur J Heart Fail. 2008;10(8):772-9. [pmid: 18599345].
65 Ishii J, Nomura M, Okuma T, et al. Risk stratification using serum concentrations of cardiac troponin T in patients with end-stage renal disease on chronic maintenance dialysis. Clin Chim Acta. Oct. 2001;312(1-2):69-79. [pmid: 11580911].
66 Jensen JK, Ueland T, Aukrust P, et al. Highly sensitive troponin T in patients with acute ischemic stroke. Eur Neurol. 2012;68(5):287-93. [pmid: 23051820].
67 Kalaji FR, Albitar S. Predictive value of cardiac troponin T and I in hemodialysis patients. Saudi J Kidney Dis Transpl. Sep. 2012;23(5):939-45. [pmid: 22982904].
68 Kang EW, Na HJ, Hong SM, et al. Prognostic value of elevated cardiac troponin I in ESRD patients with sepsis. Nephrol Dial Transplant. May. 2009;24(5):1568-73. [pmid: 19145004].
69 Kanwar M, Hashem M, Rosman H, et al. Usefulness of clinical evaluation, troponins, and C-reactive protein in predicting mortality among stable hemodialysis patients. Am J Cardiol. Nov. 1. 2006;98(9):1283-7. [pmid: 17056347].
70 Katerinis I, Nguyen QV, Magnin JL, et al. Cardiac findings in asymptomatic chronic hemodialysis patients with persistently elevated cardiac troponin I levels. Ren Fail. 2008;30(4):357-62. [pmid: 18569907].
71 Kertai MD, Boersma E, Klein J, et al. Long-term prognostic value of asymptomatic cardiac troponin T elevations in patients after major vascular surgery. Eur J Vasc Endovasc Surg. Jul. 2004;28(1):59-66. [pmid: 15177233].
72 Khan IA, Wattanasuwan N, Mehta NJ, et al. Prognostic value of serum cardiac troponin I in ambulatory patients with chronic renal failure undergoing long-term hemodialysis: a two-year outcome analysis. J Am Coll Cardiol. Oct. 2001;38(4):991-8. [pmid: 11583870].
73 Kontos MC, Garg R, Anderson FP, et al. Outcomes in patients admitted for chest pain with renal failure and troponin I elevations. Am Heart J. Oct. 2005;150(4):674-80. [pmid: 16209963].
74 Kontos MC, Garg R, Anderson FP, et al. Predictive power of ejection fraction and renal failure in patients admitted for chest pain without ST elevation in the troponin era. Am Heart J. Oct. 2005;150(4):666-73. [pmid: 16209962].
75 Kontos MC, Jamal SM, Ornato JP, et al. Comparison of the modification of diet in renal disease and the Cockcroft-Gault equations for predicting mortality in patients admitted for exclusion of myocardial ischemia. Am J Cardiol. Jul. 15. 2008;102(2):140-5. [pmid: 18602510].
76 Kostrubiec M, Labyk A, Pedowska-Wloszek J, et al. Assessment of renal dysfunction improves troponin-based short-term prognosis in patients with acute symptomatic pulmonary embolism. J Thromb Haemost. Apr. 2010;8(4):651-8. [pmid: 20088923].
77 Lamb EJ, Kenny C, Abbas NA, et al. Cardiac troponin I concentration is commonly increased in nondialysis patients with CKD: experience with a sensitive assay. Am J Kidney Dis. Apr. 2007;49(4):507-16. [pmid: 17386318].
78 Lang K, Schindler S, Forberger C, et al. Cardiac troponins have no prognostic value for acute and chronic cardiac events in asymptomatic patients with end-stage renal failure. Clin Nephrol. Jul. 2001;56(1):44-51. [pmid: 11499658].
79 Le Goff C, Bovy C, Aldenhoff MC, et al. Three-year prognostic interest of cardiac troponin T (cTnT) and amino-terminal pro-B-natriuretic peptide (NT-proBNP) in hemodialyzed patients. Immuno-Analyse et Biologie Specialisee. 2007;22(6):377-83.
80 Lowbeer C, Gutierrez A, Gustafsson SA, et al. Elevated cardiac troponin T in peritoneal dialysis patients is associated with CRP and predicts all-cause mortality and cardiac death. Nephrol Dial Transplant. Dec. 2002;17(12):2178-83. [pmid: 12454230].
81 Lowbeer C, Stenvinkel P, Pecoits-Filho R, et al. Elevated cardiac troponin T in predialysis patients is associated with inflammation and predicts mortality. J Intern Med. Feb. 2003;253(2):153-60. [pmid: 12542555].
82 Mallamaci F, Zoccali C, Parlongo S, et al. Troponin is related to left ventricular mass and predicts all-cause and cardiovascular mortality in hemodialysis patients. Am J Kidney Dis. Jul. 2002;40(1):68-75. [pmid: 12087563].
83 Martin GS, Becker BN, Schulman G. Cardiac troponin-I accurately predicts myocardial injury in renal failure. Nephrol Dial Transplant. Jul. 1998;13(7):1709-12. [pmid: 9681716].
84 McCullough PA, Nowak RM, Foreback C, et al. Performance of multiple cardiac biomarkers measured in the emergency department in patients with chronic kidney disease and chest pain. Acad Emerg Med. Dec. 2002;9(12):1389-96. [pmid: 12460842].
85 McGill D, Talaulikar G, Potter JM, et al. Over time, high-sensitivity TnT replaces NT-proBNP as the most powerful predictor of death in patients with dialysis-dependent chronic renal failure. Clin Chim Acta. Jul. 4. 2010;411(13-14):936-9. [pmid: 20298685].
86 McMurray JJ, Uno H, Jarolim P, et al. Predictors of fatal and nonfatal cardiovascular events in patients with type 2 diabetes mellitus, chronic kidney disease, and anemia: an analysis of the Trial to Reduce cardiovascular Events with Aranesp (darbepoetin-alfa) Therapy (TREAT). Am Heart J. Oct. 2011;162(4):748-55 e3. [pmid: 21982669].
87 Melloni C, Alexander KP, Milford-Beland S, et al. Prognostic value of troponins in patients with non-ST-segment elevation acute coronary syndromes and chronic kidney disease. Clin Cardiol. Mar. 2008;31(3):125-9. [pmid: 18383049].
88 Mockel M, Schindler R, Knorr L, et al. Prognostic value of cardiac troponin T and I elevations in renal disease patients without acute coronary syndromes: a 9-month outcome analysis. Nephrol Dial Transplant. Jun. 1999;14(6):1489-95. [pmid: 10383013].
89 Morton AR, Collier CP, Ali N, et al. Cardiac troponin I in patients receiving renal replacement therapy. ASAIO J. Sep-Oct. 1998;44(5):M433-5. [pmid: 9804466].
90 Musso P, Cox I, Vidano E, et al. Cardiac troponin elevations in chronic renal failure: prevalence and clinical significance. Clin Biochem. Mar. 1999;32(2):125-30. [pmid: 10211629].
91 Noeller TP, Meldon SW, Peacock WF, et al. Troponin T in elders with suspected acute coronary syndromes. Am J Emerg Med. Jul. 2003;21(4):293-7. [pmid: 12898485].
92 Ooi DS, Veinot JP, Wells GA, et al. Increased mortality in hemodialyzed patients with elevated serum troponin T: a one-year outcome study. Clin Biochem. Nov. 1999;32(8):647-52. [pmid: 10638948].
93 Ooi DS, Zimmerman D, Graham J, et al. Cardiac troponin T predicts long-term outcomes in hemodialysis patients. Clin Chem. Mar. 2001;47(3):412-7. [pmid: 11238290].
94 Orea-Tejeda A, Sanchez-Gonzalez LR, Castillo-Martinez L, et al. Prognostic value of cardiac troponin T elevation is independent of renal function and clinical findings in heart failure patients. Cardiol J. 2010;17(1):42-8. [pmid: 20104456].
95 Peetz D, Schutt S, Sucke B, et al. Prognostic value of troponin T, troponin I, and CK-MBmass in patients with chronic renal failure. Med Klin (Munich). Apr. 15. 2003;98(4):188-92. [pmid: 12715142].
96 Petrovic D, Stojimirovic BB. Cardiac troponins: outcome predictors in hemodialysis patients. J Artif Organs. 2009;12(4):258-63. [pmid: 20035399].
97 Porter GA, Norton T, Bennett WB. Troponin T, a predictor of death in chronic haemodialysis patients. Eur Heart J. Nov. Suppl N. 1998;19:N34-7. [pmid: 9857937].
98 Porter GA, Norton T, Bennett WM. Long term follow up of the utility of troponin T to assess cardiac risk in stable chronic hemodialysis patients. Clin Lab. 2000;46(9-10):469-76. [pmid: 11034532].
99 Quiroga B, Verdalles U, Reque J, et al. Cardiovascular events and mortality in chronic kidney disease (stages I-IV). Nefrologia. Jul. 19. 2013;33(4):539-45. [pmid: 23897186].
100 Roberts MA, Fernando D, Macmillan N, et al. Single and serial measurements of cardiac troponin I in asymptomatic patients on chronic hemodialysis. Clin Nephrol. Jan. 2004;61(1):40-6. [pmid: 14964456].
101 Roberts MA, Hare DL, Macmillan N, et al. Serial increased cardiac troponin T predicts mortality in asymptomatic patients treated with chronic haemodialysis. Ann Clin Biochem. Jul. 2009;46(Pt 4):291-5. [pmid: 19454539].
102 Roppolo LP, Fitzgerald R, Dillow J, et al. A comparison of troponin T and troponin I as predictors of cardiac events in patients undergoing chronic dialysis at a Veteran's Hospital: a pilot study. J Am Coll Cardiol. Aug. 1999;34(2):448-54. [pmid: 10440158].
103 Sahinarslan A, Guz G, Okyay K, et al. Prognostic value of troponin T and homocysteine in patients with end-stage renal disease. Turk Kardiyol Dern Ars. Sep. 2008;36(6):382-7. [pmid: 19155641].
104 Satyan S, Light RP, Agarwal R. Relationships of N-terminal pro-B-natriuretic peptide and cardiac troponin T to left ventricular mass and function and mortality in asymptomatic hemodialysis patients. Am J Kidney Dis. Dec. 2007;50(6):1009-19. [pmid: 18037101].
105 Scheven L, de Jong PE, Hillege HL, et al. High-sensitive troponin T and N-terminal pro-B type natriuretic peptide are associated with cardiovascular events despite the cross-sectional association with albuminuria and glomerular filtration rate. Eur Heart J. Sep. 2012;33(18):2272-81. [pmid: 22740385].
106 Scott B, Deman A, Peeters P, et al. Cardiac troponin T and malondialdehyde modified plasma lipids in haemodialysis patients. Nephrol Dial Transplant. Apr. 2003;18(4):737-42. [pmid: 12637643].
107 Sharma R, Pellerin D, Gaze DC, et al. Dobutamine stress echocardiography and cardiac troponin T for the detection of significant coronary artery disease and predicting outcome in renal transplant candidates. Eur J Echocardiogr. Oct. 2005;6(5):327-35. [pmid: 15985387].
108 Sharma R, Gaze DC, Pellerin D, et al. Ischemia-modified albumin predicts mortality in ESRD. Am J Kidney Dis. Mar. 2006;47(3):493-502. [pmid: 16490629].
109 Sharma R, Gaze DC, Pellerin D, et al. Cardiac structural and functional abnormalities in end stage renal disease patients with elevated cardiac troponin T. Heart. Jun. 2006;92(6):804-9. [pmid: 16216854].
110 Shroff GR, Akkina SK, Miedema MD, et al. Troponin I levels and postoperative myocardial infarction following renal transplantation. Am J Nephrol. 2012;35(2):175-80. [pmid: 22286592].
111 Sommerer C, Beimler J, Schwenger V, et al. Cardiac biomarkers and survival in haemodialysis patients. Eur J Clin Invest. May. 2007;37(5):350-6. [pmid: 17461980].
112 Stolear JC, Georges B, Shita A, et al. The predictive value of cardiac troponin T measurements in subjects on regular haemodialysis. Nephrol Dial Transplant. Aug. 1999;14(8):1961-7. [pmid: 10462278].
113 Sukonthasarn A, Ponglopisit S. Diagnostic level of cardiac troponin T in patients with chronic renal dysfunction, a pilot study. J Med Assoc Thai. Sep. 2007;90(9):1749-58. [pmid: 17957915].
114 Svensson M, Gorst-Rasmussen A, Schmidt EB, et al. NT-pro-BNP is an independent predictor of mortality in patients with end-stage renal disease. Clin Nephrol. 2009;71(4):380-6. [pmid: 19356370].
115 Trape J, Perez A, Naval I, et al. Nt-proBNP in haemodialysis patients: a preliminary study. Scand J Clin Lab Invest. 2008;68(5):415-20. [pmid: 19172698].
116 Troyanov S, Ly QH, Schampaert E, et al. Diagnostic specificity and prognostic value of cardiac troponins in asymptomatic chronic haemodialysis patients: a three year prospective study. Heart. Sep. 2005;91(9):1227-8. [pmid: 16103574].
117 Van Lente F, McErlean ES, DeLuca SA, et al. Ability of troponins to predict adverse outcomes in patients with renal insufficiency and suspected acute coronary syndromes: a case-matched study. J Am Coll Cardiol. Feb. 1999;33(2):471-8. [pmid: 9973028].
118 Vichairuangthum K, Leowattana W, Ong-Ajyooth L, et al. The relationship between serum concentration of cardiac troponin I in chronic renal failure patients and cardiovascular events. J Med Assoc Thai. May. 2006;89(5):714-20. [pmid: 16756060].
119 Wang AY, Lam CW, Yu CM, et al. Troponin T, left ventricular mass, and function are excellent predictors of cardiovascular congestion in peritoneal dialysis. Kidney Int. Aug. 2006;70(3):444-52. [pmid: 16871255].
120 Wang AY, Lam CW, Wang M, et al. Prognostic value of cardiac troponin T is independent of inflammation, residual renal function, and cardiac hypertrophy and dysfunction in peritoneal dialysis patients. Clin Chem. May. 2007;53(5):882-9. [pmid: 17395709].
121 Wang AYM, Lam CW, Chan IH, et al. Sudden cardiac death in end-stage renal disease patients: A 5-year prospective analysis. NDT Plus. 2010;3:iii291.
122 Wang AY, Lam CW, Chan IH, et al. Sudden cardiac death in end-stage renal disease patients: a 5-year prospective analysis. Hypertension. Aug. 2010;56(2):210-6. [pmid: 20606110].
123 Wayand D, Baum H, Schatzle G, et al. Cardiac troponin T and I in end-stage renal failure. Clin Chem. Sep. 2000;46(9):1345-50. [pmid: 10973864].
124 Wolley M, Stewart R, Curry E, et al. Variation in and prognostic importance of troponin T measured using a high-sensitivity assay in clinically stable haemodialysis patients. Clinical Kidney Journal. 2013;6(4):402-9.
125 Wood GN, Keevil B, Gupta J, et al. Serum troponin T measurement in patients with chronic renal impairment predicts survival and vascular disease: a 2 year prospective study. Nephrol Dial Transplant. Aug. 2003;18(8):1610-5. [pmid: 12897102].
126 Yakupoglu U, Ozdemir FN, Arat Z, et al. Can troponin-I predict cardiovascular mortality due to myocardial injury in hemodialysis patients?. Transplant Proc. Sep. 2002;34(6):2033-4. [pmid: 12270303].
127 Chenevier-Gobeaux C, Meune C, Freund Y, et al. Influence of age and renal function on high-sensitivity cardiac troponin T diagnostic accuracy for the diagnosis of acute myocardial infarction. Am J Cardiol. Jun. 15. 2013;111(12):1701-7. [pmid: 23540652].
128 Facila L, Nunez J, Bodi V, et al. Prognostic value of serum creatinine in non-ST-elevation acute coronary syndrome. Rev Esp Cardiol. Mar. 2006;59(3):209-16. [pmid: 16712744].
129 Alam A, Palumbo A, Mucsi I, et al. Elevated troponin I levels but not low grade chronic inflammation is associated with cardiac-specific mortality in stable hemodialysis patients. BMC Nephrology. 2013;14:247. [pmid: 24206774].
130 Bayes-Genis A, Zamora E, De Antonio M, et al. Soluble ST2 Serum Concentration and Renal Function in Heart Failure. Journal of Cardiac Failure. 2013;19(11):768-75. [pmid: 24263122].
131 Farshid A, Pathak R, Shadbolt B, et al. Diastolic function is a strong predictor of mortality in patients with chronic kidney disease. BMC Nephrology. 2013;14:280. [pmid: 24359445].
132 Hassan HC, Howlin K, Jefferys A, et al. High-Sensitivity Troponin as a Predictor of Cardiac Events and Mortality in the Stable Dialysis Population. Clinical Chemistry. 2014;60(2):389-98. [pmid: 24185551].
133 Levin A, Rigatto C, Barrett B, et al. Biomarkes of inflammation, fibrosis, cardiac stretch and injury predict death but not renal replacement therapy at 1 year in a Canadian chronic kidney disease cohort. Nephrol Dial Transplant. 2014;29:1037-47. [pmid: 24371297].