# Overview of Studies Included in the Meta-Analyses

Table 1 Studies included/excluded for cTnT and all-cause mortality for dialysis patients

Table 2 Studies included/excluded in the meta-analysis for cTnI and all-cause mortality for dialysis patients

Table 3 Studies included/excluded for cTnT and cardiovascular mortality for dialysis patients

Table 4 Studies included/excluded for cTnI and cardiovascular mortality for dialysis patients

Table 5 Studies included/excluded for cTnT and MACE >1 year for dialysis patients

Table 6 Studies included/excluded for cTnI and MACE >1 year for dialysis patients

Table 7 Studies included/excluded for cTnI and MACE <1 year for dialysis patients