# Evidence Tables

Table 1 Study design characteristics of included articles

Table 2 Study population characteristics of studies included in Troponin report

Table 3 Key Question 1: Outcomes

Table 4 Outcomes reported for Key Question 2, 3, and 4

Table 5a Study quality data for articles included in KQ1

Table 5b Study quality data for articles included in KQ2 and KQ3

Table 5c Study quality data for articles included in KQ4