# Exclusion Report

## No Original Data

1 Babinska M, Chudek J, Owczarek AJ, et al. Acute coronary syndrome in patients with chronic kidney disease--risk stratification. Pol Arch Med Wewn. Dec. 2005;114(6):1226-35. [pmid: 16789494].
2 Bodor GS. Cardiac troponin-I: A highly specific biochemical marker for myocardial infarction. Journal of Clinical Immunoassay. 1994;17(1):40-4.
3 Capodanno D, Angiolillo DJ. Antithrombotic therapy in patients with chronic kidney disease. Circulation. 2012;125(21):2649-61. [pmid: 22644369].
4 Carney EF. Acute coronary syndromes: Management of acute coronary syndrome-renal outcomes. Nat Rev Nephrol. Sep. 2013;9(9):492. [pmid: 23877589].
5 Celik T, Iyisoy A, Yilmaz MI, et al. Another battlefield for drug-eluting coronary stents: Chronic kidney disease. Int J Cardiol. 2009;133(2):245-6. [pmid: 18055042].
6 Chen BH. Cardiac troponin T levels in patients with renal failure. CMAJ. Sep. 17. 2002;167(6):671. [pmid: 12358205].
7 Chen P, Tanasijevic M. Use of serum cardiac troponin-I levels in dialysis patients. Semin Dial. Jan-Feb. 2000;13(1):58-9. [pmid: 10740676].
8 Cichocka E, Gumprecht J. Diabetes, renal dysfunction and acute coronary syndrome. Kardiol Pol. 2012;70(3):287-90. [pmid: 22430415].
9 Dehoux M, Provenchere S, Benessiano J, et al. Utility of cardiac troponin measurement after cardiac surgery. Clin Chim Acta. Sep. 15. 2001;311(1):41-4. [pmid: 11557251].
10 Dewantoro O, Harun S. Troponin in heart disorder and chronic renal failure. Acta Med Indones. Oct-Dec. 2005;37(4):218-23. [pmid: 16317219].
11 Foussas SG, Tsiaousis GZ. Coronary revascularisation in patients with chronic renal disease. Hellenic Journal of Cardiology. 2007;48(4):218-27. [pmid: 17715613].
12 Giannitsis E, Katus HA. Troponin T release in hemodialysis patients. Circulation. Jul. 20. 2004;110(3):e25-6. author reply e-6. [pmid: 15262860].
13 Haller C, Stevanovich A, Katus HA. Are cardiac troponins reliable serodiagnositic markers of cardiac ischaemia in end-stage renal disease?. Nephrol Dial Transplant. Jun. 1996;11(6):941-4. [pmid: 8671943].
14 Herzog CA. Dismal long-term survival of dialysis patients after acute myocardial infarction: Can we alter the outcome?. Nephrology Dialysis Transplantation. 2002;17(1):7-10.
15 Johnston N, Dargie H, Jardine A. Diagnosis and treatment of coronary artery disease in patients with chronic kidney disease. Heart. 2008;94(8):1080-8. [pmid: 18625799].
16 Katus HA, Haller C, Muller-Bardorff M, et al. Cardiac troponin T in end-stage renal disease patients undergoing chronic maintenance hemodialysis. Clin Chem. Aug. 1995;41(8 Pt 1):1201-3. [pmid: 7677915].
17 Kavsak PA. Serial cardiac troponin T measurements in haemodialysis patients: absolute versus changing concentrations?. Ann Clin Biochem. Jan. 2010;47(Pt 1):97. [pmid: 19900984].
18 Kavsak PA, Jaffe AS. High-sensitivity cardiac troponin assays--change is important. Clin Chem. Jan. 2012;58(1):311-3. author reply 3-4. [pmid: 21976552].
19 Kes P, Basic-Jukic N, Juric I, et al. Diagnostic significance of cardiac troponins in chronic renal failure. Lijec Vjesn. Jan-Feb. 2007;129(1-2):44-5. [pmid: 17489518].
20 Musayev KK. Open heart surgery in patients with acute coronary syndrome who receive treatment for chronic kidney disease. Azerbaijan Medical Journal. 2012;(4):94-6.
21 Rabelink TJ, Truin G, de Jaegere P. Treatment of coronary artery disease in patients with renal failure. Nephrology Dialysis Transplantation. 2000;15(SUPPL. 5):117-21.
22 Rifkin DE, Sarnak MJ. Chronic kidney disease: Absence of evidence or evidence of absence? ACS treatment in CKD. Nature Reviews Nephrology. 2010;6(8):449-50.
23 Stoffel MP, Pollok M, Baldamus CA. Troponin I is a better prognostic parameter of cardiovascular events in asymptomatic patients on haemodialysis than troponin T. Nephrol Dial Transplant. Aug. 2000;15(8):1259-60. [pmid: 10910462].
24 Szummer K, Jernberg T. Renal impairment and myocardial infarction--a combination of risks. Lakartidningen. May. 22-28. 2013;110(21):1037-40. [pmid: 23805770].
25 Watine J. Troponins: diagnostic and prognostic value in patients with renal failure. Ann Biol Clin (Paris). Jul-Aug. 2005;63(4):434-5. [pmid: 16104063].
26 Widimsky P, Rychlik I. Renal disease and acute coronary syndrome. Heart. Jan. 2010;96(1):86-92. [pmid: 20019214].

## Abstract Only

27 Acharji S, Nikolsky E, Weisz G, et al. Impact of troponin elevation on outcomes of patients with acute coronary syndromes and chronic renal insufficiency. J Am Coll Cardiol. 2010;55(10):A118. E1108.
28 Adib K, Yacoub R, Gupta V, et al. The clinical significance of serial cardiac markers (Troponin I) measurements in hospitalized patients study (stop-IT study). J Am Coll Cardiol. 2011;57(14):E1105.
29 Akerblom A, Wallentin L, Siegbahn A, et al. Serial cystatin C measurements and changes in glomerular filtration rate as predictors for death or myocardial infarction in ACS patients. Eur Heart J. 2012;33:135.
30 Aoyama T, Ishii H, Takahashi H, et al. Elevated cardiac troponin T and C-reactive protein interactively increased cardiovascular and all-cause mortality risk in chronic hemodialysis patients -10-year prospective study. Eur Heart J. 2011;32:646. [pmid: 20581005].
31 Assa S, Witte EC, Gansevoort RT, et al. Determinants of pre-dialysis levels and intra-dialytic rises of cardiac troponin T (cTnT) levels. Blood Purif. 2009;28(4):306-7.
32 Avdoshina S, Villevalde S, Tyukhmenev E, et al. Acute kidney injury in patients with non-st-elevation acute coronary syndrome. Nephrology Dialysis Transplantation. 2012;27:ii358.
33 Baber U, Mehran R, Brener S, et al. Impact of chronic kidney disease on myocardial infarct size and adverse events in ST-elevation myocardial infarction: Results from the INFUSE-AMI trial. J Am Coll Cardiol. 2012;60:B43.
34 Bahrmann P, Bahrmann A, Christ M, et al. Performance of high-sensitivity troponin T in the early diagnosis of non-ST-elevation myocardial infarction in elderly patients presenting to an emergency department. Eur Heart J. 2012;33:909.
35 Ballo P, Chechi T, Spaziani G, et al. Risk stratification by estimated glomerular filtration rate in patients with non ST-elevation acute coronary syndrome: Which method is best?. Eur Heart J. 2010;31:339.
36 Barra SNC, Providencia R, Gomes P, et al. Predicting risk of stroke following a myocardial infarctionEuropean Journal of Cardiovascular Prevention and Rehabilitation. European Journal of Cardiovascular Prevention and Rehabilitation. 2010;17:S98.
37 Barra SNC, Silva J, Gomes P, et al. The role of glomerular filtration rate in acute cardiac patients: STEMI vs NSTEMI. European Heart Journal, Supplement. 2010;12:F44-F5.
38 Barthelemy O, Cayla G, Silvain J, et al. Is there an optimal time for catheterization in NSTE-ACS patients with renal failure? Insights from the ABOARD study. Eur Heart J. 2010;31:340. [pmid: 19897497].
39 Barthelemy O, Helft G, Silvain J, et al. One year clinical outcomes after percutaneous coronary intervention with drug-eluting stent in patients with chronic renal failure. Eur Heart J. 2009;30:787.
40 Bashardoost B, Ghaemian N. Impact of troponin i level and left ventricular hyperthropy on long term risk of mortality in patients on hemodialysis. NDT Plus. 2010;3:iii493.
41 Berton G, Cordiano R, Palmieri R, et al. Clinical predictors of ten-year event-free survival after myocardial infarction. Eur Heart J. 2011;32:883.
42 Bianco H, Helfenstein T, Izar MC, et al. Predictors of long-term cardiovascular outcomes in patients with type 2 diabetes mellitus. Eur Heart J. 2012;33:893.
43 Bosselmann HS, Rossing K, Egstrup M, et al. The association between renal function and mortality risk is attenuated by pro-adrenomedullin and troponin T in outpatients with systolic heart failure: A long term follow up study. Eur Heart J. 2011;32:476. [pmid: 21036775].
44 Bossola M, Colacicco L, Scribano D, et al. Reactive Oxygen Metabolites (ROMS) are associated with cardiovascular disease and new cardiovascular events in chronic hemodialysis patients. Nephrology Dialysis Transplantation. 2012;27:ii239.
45 Britt EB, Wu Y, Hazen SL, et al. Prediction of future cardiovascular risk by detecting subclinical myocardial necrosis in stable patients with diabetes mellitus. J Card Fail. 2011;17(8):S30-S1.
46 Brouwers FPJ, De Boer RA, Van Der Harst P, et al. Incident heart failure with preserved ejection fraction in the general population. Eur Heart J. 2012;33:939.
47 Brunner NW, Scheuermeyer F, Grafstein E, et al. Prognosis of patients discharged from the emergency department with a positive troponin: A retrospective cohort study. Canadian Journal of Cardiology. 2011;27(5):S142.
48 Buchholz S, Nojoumian A, Hoo SS, et al. Incidence, risk factors, and in-hospital mortality of contrast-induced nephropathy in field triaged patients with acute myocardial infarction. Heart Lung and Circulation. 2010;19:S133.
49 Cabanas Grandio P, Alvarez Alvarez B, Gonzalez Cambeiro C, et al. Cockcroft-gault, modification of diet in renal disease or chronic kidney disease epidemiology collaboration in renal disease and acute coronary syndromes?. Eur Heart J. 2012;33:1086.
50 Caetano AFSMA, Barra S, Silva J, et al. Cardiorenal syndrome in ischemic cardiomyopathy: Can cystatin-C predict it?. European Heart Journal, Supplement. 2010;12:F66.
51 Caetano F, Almeida I, Seca L, et al. The best predictor of cardiorenal syndrome in ischemic cardiomyopathy. Intensive Care Med. 2011;37:S240.
52 Campard S, Bielefeld M, Richard C, et al. High preoperative troponin before elective surgery is associated with a poor prognosis. Eur Heart J. 2011;32:538-9.
53 Campbell NG, Varagunam M, Sawhney V, et al. Mild pre-procedural renal impairment is associated with increased mortality after emergency catheter laboratory admission in a contemporary population with ST-segment elevation myocardial infarction. Eur Heart J. 2010;31:211. [pmid: 19854729].
54 Charpentier S, Ducasse JL, Cournot M, et al. Clinical assessment of ischemia modified albumin and heart-fatty acid binding protein in early diagnosis of non ST elevation acute coronary syndrome in emergency department. Eur Heart J. 2009;30:188.
55 Chen Y, Chen H. Highsensitivity creactive protein levels at admission can not be used to predict inhospital mortality in patients with acute myocardial infarction a retrospective study. Heart. 2010;96:A133.
56 Chitalia N, Rahman S, Farrell N, et al. Elevated pulse pressure is associated with increased cardiiovascular events in patients on maintenance dialysis. NDT Plus. 2010;3:iii347.
57 Choi JC, Cha KS, Ahn JH, et al. The incidence and clinical predictors of persistent renal dysfunction in patients with acute myocardial infarction undergoing percutaneous coronary intervention: Results from the Korea working group on myocardial infarction. Circulation. 2012;126(21).
58 Chong C, Van Gaal W, Profitis K, et al. Electrocardiograph changes and correlation to troponin levels and cardiac complications after orthopaedic surgery. Intern Med J. 2010;40:10.
59 Chorianopoulos E, Krumsdorf U, Pleger S, et al. Prognostic value of preinterventional troponin t levels in patients with severe aortic stenosis undergoing TAVR. J Am Coll Cardiol. 2012;60:B247-B8.
60 Chou MT, Chieng CC, Wang TC. Acute coronary syndrome on end-stage renal disease dialysis patients:taiwan national cohort study. Eur Heart J. 2012;33:1085. [pmid: 21998404].
61 Chow KV, Roberts MA, Lerino FL. Cardiac troponin T as a predictor of long term mortality in patients undergoing haemodialysis. Nephrology. 2011;16:70.
62 Chu CY, Lin TH, Su HM, et al. Influences of the early invasive strategy on patients with chronic kidney diseases in non-st segment elevation acute coronary syndrome, a population-based study from nhird of Taiwan. American Journal of Cardiology. 2012;109(7):62S.
63 Cieszynski K, Kaczmarek A, Grzegorzewska AE. High-sensitivity cardiac troponin T (HS-CTNT) in stable dialysis patients. Hemodialysis International. 2012;16(1):147-8.
64 Clark D, Mok M, Charter K, et al. Is measurement of troponin-I (Tn-I) post-elective percutaneous coronary intervention (PCI) required to predict adverse events?. Heart Lung and Circulation. 2011;20:S131.
65 Coats W, Pak Y, Chan E, et al. Are there clinical predictors of nonobstructive coronary artery disease among patients with end-stage renal disease on dialysis referred for coronary angiography?. Hemodialysis International. 2011;15(1):135-6.
66 Cordeiro Da Rocha AS, Pittella FJM, Dutra Da Silva PR, et al. High-sensitivity C-reactive protein: New marker of operative risk in coronary artery bypass graft surgery?. Eur Heart J. 2011;32:1049. [pmid: 21460364].
67 Covic A, Besarab A, Provenzano R, et al. Relationship between cardiovascular (CV) events and hemoglobin (HB) level or Hb rate of change in hemodialysis (HD) patients on peginesatide. Nephrology Dialysis Transplantation. 2012;27:ii133-ii4.
68 Cudjoe TK, Clavell AL, Olson LJ, et al. Predictors of outcome in an elderly population presenting with acute decompensated heart failure. J Am Coll Cardiol. 2009;53(10):A237-A8.
69 Dai K, Ishihara M, Inoue I, et al. Impact of chronic kidney disease and anemia on 5-year mortality after acute myocardial infarction. J Am Coll Cardiol. 2010;55(10):A102. E956.
70 Daniels LB, Laughlin GA, Maisel AS, et al. Galectin-3 is independently associated with cardiovascular disease in community-dwelling older adults: The rancho bernardo study. Circulation. 2012;126(21).
71 Dankovtseva EN, Evdokimova MA, Reznichenko NE, et al. Cystatin C associates with unfavorable outcome after acute coronary syndrome in patients with high level of BNP-fragment of brain natriuretic peptide and normal renal function. European Journal of Heart Failure, Supplement. 2011;10:S51.
72 De Lima JJG, Gowdak LHW, De Paula FJ, et al. Cardioprotective drugs and acute coronary syndrome in patients on the waiting list for renal transplantation. American Journal of Transplantation. 2012;12:100.
73 Desai AS, Jarolim P, Uno H, et al. Serum levels of N-terminal pro-B-type natriuretic peptide and cardiac troponin T predict renal disease progression in patients with diabetes mellitus, anemia, and chronic kidney disease. Eur Heart J. 2010;31:449-50.
74 Desai M, Hegazi A, Campbell L, et al. Coronary heart disease is associated with renal impairment in HIV positive patients. HIV Medicine. 2012;13:3.
75 Drueke T, Clyne N, Eckardt K, et al. Diagnostic value of nt-probnp and cardiac troponin t in chronic kidney disease patients: correlation with baseline characteristics in the CREATE study [abstract]. 41st Congress. European Renal Association. European Dialysis and Transplantation Association. 2004 May 15-18. Lisbon, Portugal. 2004:85.
76 Echols MR, Kontos MC, Prather K, et al. Predictive value of ejection fraction and renal function in high risk acute coronary syndrome patients: Results from the synergy trial. J Am Coll Cardiol. 2010;55(10):A141. E1323.
77 Edwards M, Matsuura AC, Robey J, et al. Relationship between kidney disease and outcomes in emergency department patients presenting with potential acute coronary syndromes. Academic Emergency Medicine. 2011;18(5):S42.
78 Eubanks AM, Raza F, Alkhouli M, et al. Troponins predict long term outcomes in DKA patients without acute coronary syndrome. J Am Coll Cardiol. 2011;57(14):E934.
79 Fabbian F, Pala M, De Giorgi A, et al. Mortality for myocardial infarction and pulmonary embolism in chronic kidney disease patients. A study on the emilia-romagna regional database of hospital admissions. G Ital Cardiol. 2011;12(12):e54.
80 Faes D, Jamart J, Chenu P, et al. Differential impact of bleeding complications on inhospital outcome at the time of PCI. Eur Heart J. 2009;30:537.
81 Fakheri S, Contreras R, Mansukhani P, et al. Prognostic implications of minor troponin i elevation in the setting of renal insufficiency: Results from the troponin I in the emergency room (TiER) study. J Am Coll Cardiol. 2010;56(13):B72.
82 Fakheri S, Shen A, Khan S, et al. Determining a troponin i threshold for predicting 30-day mortality: Results from the troponin i in the emergency room (TiER) study. J Am Coll Cardiol. 2011;58(20):B109.
83 Fan W, Ping Y, Leiming L, et al. Association of glomerular filtration rate with high-sensitivity cardiac troponin t in a community-based population study in Beijing. Heart. 2011;97:A94-A5.
84 Faria R, Trigo J, Gago P, et al. Association between kidney function and mortality in patients with acute coronary syndromes without ST elevation undergoing catheterization. European Heart Journal, Supplement. 2010;12:F26.
85 Felker GM, Tang WHW, Hernandez AF, et al. High sensitivity troponin I in acute decompensated heart failure: Insights from the ASCEND-HF study. Circulation. 2011;124(21).
86 Feres MC, Rizzi C, Lorenzon P, et al. Evaluation of the role of biomarkers for prediction of cardiovascular risk in patients with obstructive sleep apnoea and dyslipidaemia. Journal of Sleep Research. 2010;19:164.
87 Ferrieres J, Berkenboom G, Coufal Z, et al. Risk of cardiovascular and bleeding events and mortality in patients with chronic kidney disease and ACS undergoing PCI: Results from the APTOR-II study. Eur Heart J. 2011;32:188.
88 Fischer L, Shiv kumar J, Sudhakar S, et al. Comparison of drug-eluting stents with bare-metal stents in patients with mild and moderate chronic kidney disease undergoing primary percutaneous coronary intervention. American Journal of Cardiology. 2010;105(9):33B.
89 Flu WJ, Van Kuijk JP, Hoeks SE, et al. Intima media-thickness of the common carotid artery in major vascular surgery patients: A predictor of postoperative and late cardiovascular events. Eur Heart J. 2009;30:348.
90 Ford ML, Smith ER, Tomlinson LA, et al. Plasma osteoprotegerin and proteinuria are independently associated with highly sensitive troponin t in chronic kidney disease (ckd) stages 3 & 4. Artery Research. 2010;4(4):152.
91 Frank D, Stark S, Lutz M, et al. High-sensitive troponin t levels independently predict survival in tavi patients. Circulation. 2012;126(21).
92 Gago M, Semret M, Pelikka PA, et al. Survival of kidney transplant candidates and recipients with diabetes (DM). Stratification of risk using cardiac troponin T (cTNT). American Journal of Transplantation. 2010;10:69. [pmid: 19889125].
93 Gallagher S, Hassan S, Jones D, et al. Is contrast-induced nephropathy following primary PCI for STEMI associated with increased long-term mortality?. EuroIntervention. 2012;8:N37.
94 Gallagher S, Jones D, Rathod K, et al. Baseline renal dysfunction is associated with worse outcomes in patients undergoing primary percutaneous coronary intervention for ST-elevation myocardial infarction. J Am Coll Cardiol. 2011;58(20):B136.
95 Garcia Gonzalez MJ, Arroyo Ucar E, Hernandez Garcia C, et al. Impact of impaired renal function on admission and reduced left ventricular function on in-hospital outcome of acute coronary syndrome in clinical practice. Results of a single center registry. Eur Heart J. 2010;31:340-1. [pmid: 19897497].
96 Gashi M, Korca H, Kocinaj D, et al. Clinical manifestations of coronary heart disease in endstage renal disease (hemodialysis). International Journal of Artificial Organs. 2010;33:466.
97 Genereux P, Bernard S, Palmerini T, et al. Incidence, predictors and impact of stroke in acute coronary syndrome: Insights from the acuity trial. J Am Coll Cardiol. 2012;59(13):E378.
98 Giannini F, Perkan A, Vitrella G, et al. The impact of renal insufficiency on mortality and role of abciximab in patients undergoing primary percutaneous coronary intervention for ST-segment elevation myocardial infarction. G Ital Cardiol. 2011;12(5):107S.
99 Gierlotka M, Gasior M, Tajstra M, et al. Invasive treatment of patients with non-ST-segment elevation myocardial infarction and severe renal dysfunction - Early and 12-month outcomes from the PL-ACS registry. J Am Coll Cardiol. 2011;58(20):B138.
100 Goncalves S, Ferreira Santos J, Amador P, et al. Impact of renal failure on the bleeding risk of patients with non-ST acute coronary syndromes submitted to percutaneous coronary intervention. Eur Heart J. 2010;31:56.
101 Gonzalez MA, Collins SD, Ben-Dor I, et al. The contribution of renal failure and diabetes mellitus to the prognosis of patients with acute myocardial infarction undergoing percutaneous coronary intervention. J Am Coll Cardiol. 2010;55(10):A119. E1113.
102 Gonzalez MJG, Ucar EA, Garcia CH, et al. ST elevation acute myocardial infarction: Impact of renal dysfunction on management and in-hospital outcome in clinical practice. European Heart Journal, Supplement. 2010;12:F43.
103 Gowdak LHW, De Paula FJ, Cesar LAM, et al. The nullGeneral Cardiovascular Disease Risk Scorenull underestimates the risk of cardiovascular events in patients with end-stage renal disease. Eur Heart J. 2011;32:94.
104 Gruberg L, Parikh PB, Jeremias A, et al. Higher mortality rates after percutaneous coronary intervention in female patients on hemodialysis. J Am Coll Cardiol. 2010;55(10):A210. E1986.
105 Grundeken MJD, Damman P, Kikkert WJ, et al. Gender difference in the prognostic value of estimated glomerular filtration rate at admission in ST-segment elevation myocardial infarction. Eur Heart J. 2011;32:737-8. [pmid: 21266374].
106 Grygier M, Janus M, Araszkiewicz A, et al. Combined treatment with ascorbic acid and N-acetylcysteine prevents contrast-induced nephropathy in patients with acute coronary syndome undergoing coronary intervention. Eur Heart J. 2009;30:529.
107 Gupta S, Figueredo V. Effects of renal function on outcomes of patients with non-st elevation myocardial infarction (NSTEMI) treated with early invasive strategy. Crit Care Med. 2009;37(12):A459.
108 Guttmann OP, Rathod K, Rathod B, et al. Prognostic value of baseline renal function on long term outcome in patients undergoing primary percutaneous coronary intervention for ST-elevation myocardial infarction. Heart. 2011;97:A31.
109 Ha SJ, Woo SH, Kim W, et al. Triple versus dual antiplatelet therapy in acute myocardial infarction in relation to renal function: Data from the korean acute myocardial infarction registry: Data from the Korean acute myocardial. Eur Heart J. 2011;32:877.
110 Hao T, Jingguo W, Jia X, et al. The anticoagulant therapy of haemodialysis patients with acute coronary syndrome. Heart. 2012;98:E199.
111 Hashimoto T, Ishii J, Okumura M, et al. Prognostic value of high-sensitivity cardiac troponin i in patients with chronic kidney disease. J Card Fail. 2011;17(9):S164.
112 Helvig A, Naess H. Troponin in 574 patients with acute ischemic stroke. European Journal of Neurology. 2010;17:28. [pmid: 20590805].
113 Hira RS, Shenoy M, Fatemi O, et al. Troponin I is chronically and persistently elevated in hospitalized heart failure patients and is associated with increased mortality over five years. J Am Coll Cardiol. 2010;55(10):A17. E162.
114 Hochholzer W, Valina CM, Stratz C, et al. Utility of high-sensitivity cardiac troponin T in patients undergoing elective coronary angiography. Eur Heart J. 2012;33:776. [pmid: 21893487].
115 Hogg K, Hinchliffe E, Haslam S, et al. Biomarkers in mortality prediction after venous thromboembolism. Journal of Thrombosis and Haemostasis. 2011;9:865.
116 Holmes D, Abizaid A, Banning A, et al. The use of the Sirolimus-eluting CYPHER Select plus coronary stent in patients with renal failure, 1-year results from the e-SELECT registry. EuroIntervention. 2010;6.
117 Hong YJ, Mintz GS, Jeong MH, et al. Coronary plaque characteristics according to renal function in patients with acute myocardial infarction: An intravascular ultrasound analysis. American Journal of Cardiology. 2010;105(9):29B. [pmid: 20102886].
118 Hussien A, Battah A, Ashraf M, et al. Electrocardiography as a predictor of left main or three-vessel disease in patients with non-ST segment elevation acute coronary syndrome. Egyptian Heart Journal. 2011;63(2):103-7.
119 Hutchison A, Barns S, Barton T, et al. Mortality in patients with coronary and non coronary causes of an elevated Troponin. Heart Lung and Circulation. 2011;20:S209.
120 Inoue T, Arasaki O, Kajiwara K, et al. The impact of elevated heart rate and chronic kidney disease on all-cause death and cardiovascular events in coronary artery disease patients with type II diabetes. Eur Heart J. 2012;33:449.
121 Irfan A, Reichlin T, Twerenbold R, et al. Prevalence and determinants of elevated high-sensitive cardiac troponin T levels among patients with non-cardiac cause of chest pain. Eur Heart J. 2011;32:99-100.
122 Ishii J, Hashimoto T, Naruse H, et al. Prognostic value of combination of cystatin C with BNP and cardiac troponin T for cardiac ortality in acute heart failure without advanced renal impairment. J Mol Cell Cardiol. 2010;48(5):S69-S70.
123 Ishii J, Okuyama R, Hashimoto T, et al. Interaction of b-type natriuretic peptide and cardiac troponin t improves the prediction of mortality in patients on hemodialysis. Circulation. 2012;126(21).
124 Itaya H, Hara H, Takagi T, et al. Impact of disappeared circadian variation on acute coronary syndrome to the patients with chronic kidney disease. Eur Heart J. 2010;31:982.
125 Iwasaki Y, Yamada T, Okuyama Y, et al. Usefulness of anticoagulant therapy for atrial fibrillation in chronic kidney disease patients after percutaneous coronary intervention with stenting. J Am Coll Cardiol. 2010;55(10):A54. E513.
126 Jarai R, Leherbauer L, Farhan S, et al. Blood urea nitrogen (BUN) predicts all-cause mortality in chronic stable heart failure in addition to plasma Nt-proBNP and troponin T. Eur Heart J. 2010;31:132.
127 Jarai R, Pavlovic I, Farhan S, et al. Prediction of acute heart failure by lactate dehydrogenase (LDH): An old player among the new stars. European Heart Journal, Supplement. 2010;12:F49.
128 Jin HY, Choi KN, Seo JS, et al. The impact of admission serum creatinine on contrast induced nephropathy and 1 year mortality in patients with ST elevation myocardial infarction underwent primary percutaneous coronary intervention. Eur Heart J. 2012;33:630. [pmid: 22009446].
129 Jin HY, Jung SR, Seo JS, et al. The prognostic value of admission serum creatinine for contrast induced nephropathy and 12 months mortality in patients with acute ST elevation myocardial infarction underwent primary percutaneous coronary intervention. J Am Coll Cardiol. 2011;58(20):B135-B6.
130 Joki N, Iwasaki M, Tanaka Y, et al. The best cut-off value for diagnosing of acute coronary syndrome at emergency room in patients with end stage kidney disease. Nephrology Dialysis Transplantation. 2012;27:ii238-ii9.
131 Josefsson A, Fu M, Bjornsson E, et al. Pretransplant renal impairment predicts post transplant cardiac events in patients with liver cirrhosis. Gastroenterology. 2011;140(5):S901-S2.
132 Kasiske BL, Snyder JJ, Skeans MA, et al. Predicting coronary heart disease after kidney transplant. American Journal of Transplantation. 2009;9:362-3.
133 Kato H, Kubota S, Takasawa Y, et al. Strain of the left ventricular myocardium by 2D speckle tracking echchocardiography predicts cardiac events and mortality in patients with advanced chronic kidney disease: A 3-year follow-up study. Eur Heart J. 2012;33:16. [pmid: 22041548].
134 Keddis MT, El Ters M, Rodrigo E, et al. Cardiac troponin T (CTNT) before and after kidney transplantation (KTx): Cardiovascular (CV) risk and patient survival. American Journal of Transplantation. 2012;12:32.
135 Khan J, Kingree R, Thameem D, et al. Predictors of hospital and postdischarge mortality among patients with pulmonary embolism. Chest. 2010;138(4).
136 Khan MF, Shah N, Torabi A, et al. Impact of revascularisation on longer term survival of patients presenting with troponin positive acute coronary syndrome: A real world experience. EuroIntervention. 2011;7:M9.
137 Khandekar A, Khandge J. Incidence of Cardiovascular Disease (CVD) in chronic kidney disease subjects (PRE-DIALYSIS): The role of plasma high sensitivity C-reactive protein (HS-CRP), homocysteine (HCY), carotid intima media thickness (CIMT) and left ventricular hypertrophy (LVH). Nephrology Dialysis Transplantation. 2012;27:ii246.
138 Kim D, Jeong MH, Ahn Y, et al. Benefit of statin therapy in acute myocardial infarction and renal insufficiency from the korea acute myocardial infarction registry. American Journal of Cardiology. 2012;109(7):115S-6S.
139 Kim D, Jeong MH, Ahn Y, et al. Comparison between drug-eluting stent and bare-metal stent in ischemic cardiomyopathy combined with renal insufficiency. American Journal of Cardiology. 2012;109(7):102S.
140 Kim IC, Kim HT, Cho YK, et al. The impact of renal insufficiency on clinical outcomes after percutaneous coronary intervention in acute myocardial infarction. American Journal of Cardiology. 2009;103(9):1B. [pmid: 19101220].
141 Kim W, Woo JS, Kim WS, et al. Triple versus dual antiplatelet therapy in acute myocardial infarction in relation to renal function. Circulation. 2011;124(21).
142 Kohsaka S, Endo Y, Koide K, et al. Impact of serum biomarkers by the presence or absence of kidney disease in predicting long-term outcome among advanced systolic heart failure patients. J Mol Cell Cardiol. 2010;48(5):S68.
143 Kokubu N, Otsuka Y, Oe Y, et al. Short- and long-term prognostic impacts of metabolic syndrome and chronic kidney disease in patients after acute myocardial infarction. J Am Coll Cardiol. 2010;55(10):A198. E1863.
144 Kokubu N, Otsuka Y, Yamane T, et al. Impacts of metabolic syndrome and chronic kidney disease on short-and long-term outcomes of patients after acute myocardial infarction. American Journal of Cardiology. 2009;104(6):128D. [pmid: 19576333].
145 Komarov A, Shakhmatova O, Chuvilina M, et al. Renal impairment as a risk factor of cardiovascular events in patients with stable coronary artery disease: The results of 4 years follow-up. Eur Heart J. 2009;30:781.
146 Konishi M, Suzuki H, Okada K, et al. The prevalence and comorbidity of nonspecific troponin elevation detected by highly sensitive assay in patients with acute chest pain. Circulation. 2011;124(21).
147 Kooiman J, Spaans B, Van Beers CJ, et al. Increased arterial thrombo-embolic events and major bleeding in patients with atrial fibrillation and chronic kidney disease on vitamin K-antagonist treatment. Circulation. 2012;126(21).
148 Kostrubiec M, Labyk A, Pedowska-Wloszek J, et al. Renal function improves troponin-based short term prognosis in patients with acute pulmonary embolism. Eur Heart J. 2009;30:106.
149 Kosuge M, Kimura K, Kojima S, et al. Differential impact of renal dysfunction on mortality following first acute myocardial infarction in nonelderly and elderly patients. J Am Coll Cardiol. 2010;55(10):A119. E1115.
150 Kotwal SS, Ranasinghe I, Gallagher MP, et al. The impact of chronic kidney disease on clinical outcomes in patients admitted with acute myocardial infraction in an Australian setting. Circulation. 2012;126(21).
151 Kozhukhov S, Parkhomenko A. Renal effects of intravenous lipoxygenase inhibitor Quercetin in patients with acute myocardial infarction: Prospective randomized study. Eur Heart J. 2009;30:469. [pmid: 19066207].
152 Krishnaswami A, Leong TK, Hlatky M, et al. Predictors of death following coronary artery bypass surgery in adults with endstage renal disease. J Am Coll Cardiol. 2012;59(13):E510.
153 Kuster N, Patrier L, Bargnoux AS, et al. Does high sensitivity troponin T modify long term risk stratification in dialysis patients?. Nephrology Dialysis Transplantation. 2012;27:ii291.
154 Kyuichi F, Hideki I, Hiroshi T, et al. Multiple biomarkers improve the prediction of cardiovascular mortality in patients on chronic hemodialysis. Circulation. 2011;124(21).
155 Lai H, Patil A, Aronow W, et al. Causes of increased cardiac troponin i levels in hospitalized patients without coronary artery disease. Chest. 2011;140(4).
156 Lankeit M, Jimenez D, Kostrubiec M, et al. Validation of NT-proBNP cut-off values for risk stratification of acute non-high-risk pulmonary embolism. Eur Heart J. 2012;33:412.
157 Lazaros G, Tsiachris D, Patialiakas A, et al. Acute kidney injury is a stronger predictor of one-year mortality than chronic kidney disease in patients with acute myocardial infarction. the HEROES study. Eur Heart J. 2011;32:97.
158 Lazaros G, Tsiachris D, Patialiakas A, et al. Worsening renal function but not baseline creatinine levels adversely affects one year mortality in patients with myocardial infarction. The HEROES registry. Eur Heart J. 2009;30:42.
159 Lazaros G, Tsiachris D, Patialiakas A, et al. Admission white blood cell count predicts acute kidney injury in patients with acute myocardial infarction. Eur Heart J. 2012;33:785.
160 Lee EA, Stone GW, Mehran R, et al. The predictive value of CRP on 30-day and 1-year mortality in acute coronary syndromes: An analysis from the ACUITY trial. American Journal of Cardiology. 2009;104(6):108D.
161 Lee JE, Moon SJ, Choi KH, et al. Noninvasive detection of coronary artery stenosis with multidetector row computed tomography in chronic kidney disease patients at the initiation of renal replacement therapy. Nephrology Dialysis Transplantation. 2012;27:ii246-ii7.
162 Lee JH, Kang JK, Jang SY, et al. Prognostic value of occult renal failure in patients with acute myocardial infarction. Eur Heart J. 2012;33:1085. [pmid: 21998404].
163 Lee JH, Kim KH, Choi WS, et al. Prognostic value of N-terminal pro-brain natriuretic peptide in patients with acute myocardial infarction and chronic kidney disease. J Am Coll Cardiol. 2012;59(13):E397.
164 Lee JK, Yu WC, Lin SJ, et al. Multiple-biomarkers assessment offers additive risk prediction in patients with acute coronary syndrome. Eur Heart J. 2011;32:729.
165 Lee S, Lee SR, Rhee K, et al. Echocardiographic and laboratory indicators of in-hospital and all-cause mortality in end-stage renal disease patients. European Journal of Heart Failure, Supplement. 2010;9:S71-S2.
166 Lee T, Kakuta T, Murai T, et al. Association between increased levels of cardiac troponin before elective stenting and optical coherence tomography findings in stable angina pectoris. Eur Heart J. 2012;33:776-7. [pmid: 21893487].
167 Lekston A, Gasior M, Hudzik B, et al. Impact of multivessel coronary artery disease on the outcomes of patients with ST-segment elevation myocardial infarction undergoing percutaneous coronary intervention. 5-year follow-up. Eur Heart J. 2009;30:928-9.
168 Levin A, Madore F, Rigatto C, et al. Canpreddict: Canadian study for the prediction of dialysis, death and cardiovascular risk in CKD patients. NDT Plus. 2010;3:iii373.
169 Levin A, Rigatto C, Barrett B, et al. Canadian study of prediction of death, dialysis and interim cardiovascular events: Canpreddict: Biomarkers improve prediction of one year outcomes in chronic kidney cohort. Nephrology Dialysis Transplantation. 2012;27(ii63).
170 Li H, Wang SX. Analysis of death causes and its related factors in young patients on maintenance hemodialysis. Blood Purif. 2012;33(4):247-8.
171 Lim SY, Bae EH, Kim SW, et al. Statin use decreased short-term and long-term major adverse cardiac events in acute myocardial infarction in patients with renal insufficiency. EuroIntervention. 2012;8:N157.
172 Linnemann B, Sutter T, Sixt S, et al. Troponin T and renal function indicate worse in-hospital outcome in patients with acute limb ischemia. Vasa - Journal of Vascular Diseases. 2010;39:53-4.
173 Liu YW. Longitudinal strain as a novel predictor of all-cause and cardiovascular mortality in asymptomatic hemodialysis patients with preserved left ventricular ejection fraction. Circulation. 2012;126(21).
174 Liu YW, Su CT, Huang YY, et al. Evidence of subtle left ventricular systolic dysfunction and worse prognosis in asymptomatic hemodialysis patients with preserved left ventricular ejection fraction and elevated cardiac troponin T. Eur Heart J. 2011;32:289-90.
175 Liu YW, Su CT, Yang CS, et al. Left ventricular systolic dysfunction in high risk hemodialysis patients with preserved left ventricular ejection fraction. Journal of the American Society of Echocardiography. 2011;24(5):B5.
176 Loh J, Kitabata H, Barbash I, et al. The impact of first-versus second-generation drug-eluting stents on immediate-and intermediate-term outcomes in a complex st-segment elevation myocardial infarction population. J Am Coll Cardiol. 2012;60:B136.
177 Lopes RD, White JA, Atar D, et al. Antithrombotic use and outcomes in patients with atrial fibrillation complicating acute coronary syndromes. Circulation. 2011;124(21).
178 Lotze U, Lemm H, Heyer A, et al. Combined determination of troponin T high sensitive and copeptin for early rule out of acute myocardial infarction: First experience in a general emergency department. Eur Heart J. 2011;32:1063.
179 Luo L. Incidence of cardiac events in patients undergoing renal transplantation with left ventricular dystolic dysfunction versus normal left-ventricular function. European Heart Journal, Supplement. 2009;11:S30.
180 Manzano Fernandez S, Bonaque-Gonzalez JC, Munoz-Esparza C, et al. Usefulness of beta-trace protein and cystatin c to predict outcomes in patients with acute heart failure. European Journal of Heart Failure, Supplement. 2010;9:S234-S5.
181 Matsue Y, Suzuki M, Nagahori W, et al. Head-to-head comparison of cardiac high-sensitive troponin I, high-sensitive troponin T and NT-proBNP for risk stratification in asymptomatic patients with end-stage renal disease. Eur Heart J. 2012;33:128.
182 Mehran R, Nikolsky E, Lansky A, et al. Impact of chronic kidney disease on one-year outcomes of patients with acute myocardial infarction undergoing primary angioplasty: Results from the HORIZONS AMI trial. J Am Coll Cardiol. 2009;53(10):A74-A5.
183 Milicic D, Ljubas J, Skoric B, et al. Predictors of mortality and clinical usefulness of NT-proBNP, troponin T and C-reactive protein in follow-up after heart transplantation. Eur Heart J. 2009;30:389. [pmid: 19181707].
184 Miyajima E, Nishijima H, Murakami N, et al. Cardiac troponin levels before labour predict complications with proteinuria in the postpartum period. Eur Heart J. 2012;33:452. [pmid: 22238330].
185 Miyata M, Kusumoto A, Tei C. The role of natriuretic peptides and highly sensitive troponin t in heart failure. J Card Fail. 2011;17(9):S129.
186 Mohamad T, Mahajan N, Kondur A, et al. Impact of renal insufficiency on percutaneous coronary interventions outcomes in octogenarians: A single tertiary center experience. Catheterization and Cardiovascular Interventions. 2011;77:S47-S8.
187 Monteiro S, Antonio N, Lourenco C, et al. Combining renal function and glucose metabolism data: A more efficient way to assess outcomes in acute coronary syndromes patients. J Am Coll Cardiol. 2009;53(10):A336.
188 Moral JAU, Llergo JT, Rodriguez RS, et al. Predictors of in-hospital mortality in patients with cardiogenic shock complicating acute coronary syndrome, treated with urgent percutaneous coronary intervention. European Heart Journal, Supplement. 2010;12:F46.
189 Moreira A, Souza A, Costa R, et al. Incidence and predictors of major adverse cardiac events(MACE) following drug-eluting stents implantation in patients with chronic kidney disease. Insights from the DESIRE (drug-eluting stents in the real world) Registry. J Am Coll Cardiol. 2010;56(13):B65.
190 Moretz C, Robinson SB, Johnson B. Validation of high-sensitivity troponin I method in ACS patients. Crit Pathw Cardiol. 2012;11(3):166.
191 Munoz Jimenez LD, Cabrera Calandria AM, Munoz Bono J, et al. Elevated troponin levels predictive role in coronary revascularization surgery postoperative management. Intensive Care Med. 2010;36:S266.
192 Munoz-Jimenez LD, Cabrera-Calandria AM, Urbano-Carrillo CA, et al. Short-term outcomes and post-operative management of patients underwent off-pump coronary artery bypass. Intensive Care Med. 2009;35:S77.
193 Nabais S, Gaspar A, Rocha S, et al. Estimation of renal function in acute coronary syndromes: MDRD or Cockcroft-Gault?. Eur Heart J. 2009;30:171-2.
194 Nair SB, Chacko SM, Dixit A, et al. Comparison of patients' demographics, in-hospital and 3-year mortality rates and independent predictors of death in ST-elevation vs non-ST elevation myocardial infarction-an interventional centre experience. Heart. 2010;96:A71-A2.
195 Nakachi T, Fukui K, Nakagawa T, et al. Renal function and coronary artery disease progression in patients with acute coronary syndrome. Circulation. 2011;124(21).
196 Nakachi T, Kosuge M, Hibi K, et al. Renal dysfunction and rapid coronary artery disease progression in patients with non-ST-segment elevation acute coronary syndrome. J Am Coll Cardiol. 2009;53(10):A353-A4.
197 Nakatani D, Sakata Y, Suna S, et al. Independent and combined effect of heart failure and renal dysfunction on one-year mortality in patients with acute myocardial infarction. Circulation. 2012;126(21).
198 Naruse H, Ishii J, Hashimoto T, et al. Prognostic ability of combination of cystatin C, BNP and troponin t in acute heart failure patients without advanced renal impairment. J Card Fail. 2011;17(9):S147-S8.
199 Naruse H, Ishii J, Okuyama R, et al. Prognostic value of combination of ultra-sensitive troponin i and b-type natriuretic peptide in outpatients with chronic kidney disease. Circulation. 2012;126(21).
200 Ng A, Chow V, Yong A, et al. Elevated troponin T predicts both short and long-term mortality after pulmonary embolism. Heart Lung and Circulation. 2010;19:S216-S7.
201 Nishimura M, Okamoto Y, Tokoro T, et al. Risk stratification of cardiac death in hemodialysis patients without coronary artery disease by myocardial fatty acid imaging. Nephrology Dialysis Transplantation. 2012;27:ii59-ii60.
202 Nishimura M, Okamoto Y, Tokoro T, et al. Oral nicorandil to reduce sudden cardiac death of hemodialysis patients with left ventricular hypertrophy. Nephrology Dialysis Transplantation. 2012;27:ii232-ii3.
203 Nishimura M, Tokoro T, Nishida M, et al. Coexistence of impaired myocardial fatty acid metabolism and insulin resistance predicts cardiac death of hemodialysis patients with normal coronary arteries. NDT Plus. 2010;3:iii557.
204 Ntalianis A, Cuisset T, Hamilos M, et al. PCI-related myocardial infarction in patients with renal insufficiency reloaded with clopidogrel; an open-label multicenter registry. Eur Heart J. 2011;32:1039. [pmid: 21156721].
205 Ogando RA, Luis CH, Fuentes MGS, et al. Prognostic factors of clinical outcome and mortality in patients with Acute Coronary Syndrome requiring Mechanical Ventilation. European Heart Journal, Supplement. 2010;12:F116.
206 Oh JH, Lee HW, Choi J, et al. Clinical outcomes in patients over 75 years old with acute myocardial infarction from the Korean acute myocardial infarction registry. EuroIntervention. 2012;8:N47.
207 Ohsawa M, Itai K, Tanno K, et al. Relative risks for total mortality, incident myocardial infarction and incident stroke among Japanese hemodialysis patients. Eur Heart J. 2009;30:964.
208 Ouzouni A, Miari F, Mademtzoglou S, et al. The predictive value of cardiac troponin t in hemodialysis patients: A two year prospective study. NDT Plus. 2010;3:iii498.
209 Oyake N, Suzuki K, Tanabe K, et al. A pivotal link between hepatocyte growth factor and cardiovascular damage in end-stage renal disease. NDT Plus. 2010;3:iii494.
210 Pages PA, Aboyans V, Tanguy B, et al. Renal function degradation before coronary artery bypass surgery is associated with long-term mortality. Eur Heart J. 2012;33:70.
211 Parissis JT, Delgado J, Mebazaa A, et al. Predictors of in-hospitat mortality in acute heart failure syndromes: A sub-analysis of ALARM-HF survey. European Journal of Heart Failure, Supplement. 2009;8:ii473-ii4.
212 Parissis JT, Nikolaou M, Mebazaa A, et al. Prognostic markers in acute pulmonary oedema: Data from ALARM-HF registry. Eur Heart J. 2009;30:612.
213 Parsa AFZ, Sedaghti M, Abdolahi A, et al. The impact of chronic kidney disease on cardiac biomarkers and left ventricular function. Eur J Intern Med. 2011;22:S101.
214 Pathak R, Alasady M, Talaulikar G, et al. Clinical variables predictive of mortality in ESRD patients. Heart Lung and Circulation. 2011;20:S203-S4.
215 Patiakas S, Charalampous C, Basiliou E. Risk of coronary heart disease in patients with chronic renal failure - Evaluation study. Atherosclerosis Supplements. 2010;11(2):167.
216 Patsourakos N, Zairis M, Nini S, et al. Evaluating the prognostic value of glomerular filtration rate added to the TIMI risk score in patients with acute coronary syndromes. Eur Heart J. 2010;31:342.
217 Peacock W, Hoekstra J, Krucoff M, et al. Early objective identification of chest pain patients at very low risk of 30-day adverse outcomes. Ann Emerg Med. 2009;54(3):S2.
218 Pereg D, Benderly M, Behar S, et al. Decreased renal function associated with incident adverse cardiovascular outcomes in patients with acute coronary syndromes. Eur Heart J. 2009;30:468.
219 Perna E, Valle R, Canella JPC, et al. The relevance of troponin and natriuretic peptides as prognostic markers in patients with acute pulmonary edema and preserved left ventricular systolic function: A report from ciast-HF study. J Am Coll Cardiol. 2011;57(14):E367.
220 Persic V, Kovac J, Marn-Pernat A, et al. Troponin I levels in chronic hemodialysis patients. International Journal of Artificial Organs. 2010;33:487.
221 Petrovic D, Obrenovic R, Trbojevic-Stankovic J, et al. Cardiovascular mortality in hemodialysis patients: Clinical and epidemiological analysis. Journal of Medical Biochemistry. 2011;30(4):302-8.
222 Piegas L, Avezum A, Guimaraes HP, et al. How different is the management? Results from the brazilian acute coronary syndrome registry. Eur Heart J. 2011;32:883.
223 Planer D, Ohman EM, White H, et al. Prognosis of patients presenting with non st-segment elevation myocardial infarction and non-obstructive coronary artery disease: Propensity score matched cohort from the acuity trial. J Am Coll Cardiol. 2012;60:B136.
224 Podolecki T, Lenarczyk R, Kowalczyk J, et al. Risk of stroke in patients with acute myocardial infarction treated invasively. Eur Heart J. 2010;31:885.
225 Pugliese G, Penno G, Bonora E, et al. Association of normoalbuminuric renal impairment with cardiovascular disease. Diabetologia. 2011;54:S23.
226 Rahman A, Kirchner HL, Sartorius J, et al. Risk factors for 30-day hospital readmission among patients with non-dialysis dependent CKD. American Journal of Kidney Diseases. 2011;57(4):A81.
227 Ramchand J, Barlis P, Mehta N, et al. Acute reduction in renal function and cardiovascular risk in acute coronary syndromes. European Heart Journal, Supplement. 2010;12:S1.
228 Rampat R, Liew R, Suliman A, et al. The relation between haemoglobin concentration and eight year mortality rates after acute coronary syndromes. Eur Heart J. 2010;31:350-1.
229 Rastan A, Mohr M, Dege A, et al. Risk analysis of patients with acute myocardial infarction complicated by deep cardiogenic shock receiving emergency coronary artery bypass grafting and perioperative ECMO support. Thoracic and Cardiovascular Surgeon. 2011;58.
230 Raval J, Deshmukh T, Reece G, et al. Primary diagnoses in patients admitted to intensive care or coronary care units with an elevated troponin level but no clinical or ECG evidence of myocardial ischaemia. Heart Lung and Circulation. 2011;20:S39.
231 Robson R. The use of bivalirudin in patients with renal impairment. J Invasive Cardiol. Dec. Suppl F. 2000;12:33F-6. [pmid: 11156732].
232 Rubin J, Matsushita K, Ballantyne CM, et al. Association of cardiovascular risk factors with minimally elevated cardiac troponin T detected by a novel highly sensitive assay. Circulation. 2011;124(21).
233 Rumenjak V, Brajkovic-Bralic M, Oranullanic-Braic D, et al. N-terminal probnp and high sensitivity cardiac troponin I concentrations in haemodialysis patients. Clinical Chemistry and Laboratory Medicine. 2011;49:S572.
234 Saltzman AJ, Claessen BE, Narula A, et al. Impact of chronic kidney disease on long-term outcomes in ST-elevation myocardial infarction patients treated with primary percutaneous coronary intervention and alternative antithrombotic treatment strategies: A HORIZONS-AMI substudy. J Am Coll Cardiol. 2011;57(14):E904.
235 Sammut EC, Jones DA, Rathod K, et al. Prognostic value of baseline renal function on long term outcome in patients undergoing primary percutaneous coronary intervention for ST-elevation myocardial infarction. Eur Heart J. 2011;32:188.
236 Sanchez-Perales C, Vazquez E, Merino E, et al. Valvular calcification predicts atrial fibrillation on chronic dialysis patients. Nephrology Dialysis Transplantation. 2012;27:ii228.
237 Sanchez-Perales C, Vazquez E, Segura P, et al. Acute myocardial infarction in incident dialysis patients. Nephrology Dialysis Transplantation. 2012;27:ii248.
238 Sanganalmath P, Sohail H, Durairaj S. Can troponin-I be a good indicator for severity assessment and determine the length of stay in patients with diagnosis of pulmonary embolism?-A retrospective study done in south east of england. Am J Respir Crit Care Med. 2011;183(1).
239 Santos AR, Picarra B, Celeiro M, et al. Influence of chronic kidney disease on the acute therapy, in-hospital events and mortality in patients with acute myocardial infarction. Eur Heart J. 2012;33:1085-6. [pmid: 21998404].
240 Santos N, Serrao M, Cafe H, et al. Prognostic value of glomerular filtration rate in the context of acute myocardial infarction with ST-segment elevation. Eur Heart J. 2010;31:343.
241 Sato K, Fukuda H, Kunimasa T, et al. Predictive importance of prior history of coronary artery disease and current myocardial ischemia in patients with hemodialysis. Circulation. 2010;122(2):e251.
242 Savic L, Mrdovic I, Krljanac G, et al. The prognostic significance of combined left ventricular systolic dysfunction and chronic kidney disease in patients treated with primary percutaneous coronary intervention. European Journal of Heart Failure, Supplement. 2011;10:S145.
243 Sbarzaglia P, Savonitto S, Violini R, et al. Impact of isolated troponin elevations after PCI on two-year mortality. Eur Heart J. 2009;30:525.
244 Schmidt N, Woodle ES, Alloway RR, et al. Cardiovascular events and cardiovascular-related mortality after renal transplantation: Effect of maintenance steroid therapy. American Journal of Transplantation. 2011;11:36.
245 Schouten O, Winkel TA, Flu WJ, et al. Asymptomatic postoperative troponin release is associated with poor long-term outcome after vascular surgery. Eur Heart J. 2009;30:158.
246 Schouten O, Winkel TA, Welten GMJM, et al. Asymptomatic perioperative myocardial damage is associated with poor long-term outcome after vascular surgery. J Vasc Surg. 2009;49(5):7S-8S.
247 Semret M, Gago M, Pellikka PA, et al. Using cardiac troponin T (cTNT) to stratify the risks and benefits of kidney transplantation (KTx) in patients without diabetes (DM). American Journal of Transplantation. 2010;10:69. [pmid: 19889125].
248 Serpytis P, Rucinskas K, Kalinauskas A, et al. Risk factors for operation and inhospital mortality of patients with acute cardiac syndrome. European Heart Journal, Supplement. 2010;12:F45-F6.
249 Setsuta K, Nishizawa A, Kitahara Y, et al. Clinical value of increased high-sensitivity cardiac troponin T in patients with essential hypertension. Circulation. 2012;126(21).
250 Setsuta K, Seino Y, Mizuno K. Neurohumoral factors and development of heart failure in hypertensive patients. J Card Fail. 2011;17(9):S129.
251 Sezer S, Karakan S, Acar NO. Increased cardiac troponin T levels are correlated with inflammatory markers and various indices of renal function in chronic renal disease patients. NDT Plus. 2010;3:iii138.
252 Shin ES, Park J, Chung HC, et al. Effect of remote ischemic preconditioning on myocardial injury during hemodialysis: A pilot study. American Journal of Cardiology. 2012;109(7):53S-4S.
253 Shroff G, Li S, Herzog CA. Survival of us dialysis patients after acute myocardial infarction: Is it finally getting better in the modern treatment era?. Circulation. 2012;126(21).
254 Silva D, Cortez-Dias N, Jorge C, et al. Prognostic value of cystatin c in ST-segment elevation acute myocardial infarction. European Heart Journal, Supplement. 2010;12:F9-F10.
255 Simoes Marques Assuncao Caetan AF, Barra S, Faustino C, et al. Cardiorenal syndrome in acute heart failure: An inevitable side effect?. European Journal of Heart Failure, Supplement. 2010;9:S260.
256 Simoes Marques Assuncao Caetano AF, Barra S, Gomes P, et al. Cystatin-C and acute coronary syndromes: A better risk marker?. Eur Heart J. 2010;31:650.
257 Sinkovic A, Svensek F. Predictors of in-hospital mortality in patients with acute ST-elevation myocardial infarction. Intensive Care Med. 2009;35:S285.
258 Smith SW, Pearce LA, Murakami MM, et al. Diagnosis of type i versus type ii myocardial infarction in emergency department patients with ischemic symptoms. Ann Emerg Med. 2011;58(4):S211-S2.
259 Solak Y, Yilmaz MI, Caglar K, et al. Red cell distribution width independently predicts cardiovascular events in patients with chronic kidney disease. Nephrology Dialysis Transplantation. 2012;27:ii385.
260 Solberg OG, Ueland T, Wergeland R, et al. The predictive value of troponin, C-reactive protein and brain natriuretic peptide in patients with symptomatic aortic stenosis. Eur Heart J. 2011;32:769.
261 Spasic-Obradovic G, Radakovic A, Obradovic S. High sensitive (HS) troponin t stat assay diagnostic val ue in patients with chest pain and underlying chronic disease. Clinical Chemistry and Laboratory Medicine. 2011;49:S362.
262 Taglieri N, Fernandez Berges DJ, Koenig W, et al. Plasma cystatin C for prediction of one year mortality in mediterranean patients with non ST elevation acute coronary syndrome. Eur Heart J. 2009;30:618. [pmid: 19098018].
263 Tagore R, Tai BC, Richards AM, et al. E/Em and plasma BNP predict adverse cardiovascular outcome in predialysis chronic kidney disease: A prospective cohort study. Circulation. 2011;124(21).
264 Takashio S, Yamamuro M, Kojima S, et al. Cardiac troponin t release is correlated with diastolic load in patients with nonischemic heart failure. Circulation. 2011;124(21).
265 Tanaka A, Suzuki Y, Miki K, et al. Can BNP and Troponin T predict coronary artery disease and mortality in patients with chronic kidney disease at initiation of renal replacement therapy ?. Eur Heart J. 2009;30:187-8.
266 Teixeira R, Lourenco C, Baptista R, et al. Does diabetes matter in completely revascularized acute coronary syndrome patients?. Eur Heart J. 2010;31:530. [pmid: 20106842].
267 Thirawuth V, Tangcharoen T, Vathesatogkit P, et al. A retrospective cohort of long term all-cause mortality and recurrent cardiovascular events in patients with acute coronary syndrome in Thailand. Eur Heart J. 2012;33:898.
268 Timoteo AT, Lousinha A, Miranda F, et al. Estimated glomerular filtration rate on admission and bleeding risk in the real world of acute coronary syndromes. Eur Heart J. 2010;31:52.
269 Timoteo AT, Ramos R, Toste A, et al. Predictors of mortality in octogenarian patients with acute myocardial infarction. Eur Heart J. 2009;30:464-5.
270 Tomaszuk-Kazberuk A, Kozuch M, Malyszko J, et al. Which method of glomerular filtration rate has the best prognostic value in STEMI treated with PCI: Cockcroft's index or MDRD equation or CKD-EPI index? A 6-year follow-up. Eur Heart J. 2011;32:1062-3.
271 Toutouzas K, Patsa CH, Tsiamis E, et al. Effectiveness and safety of drug eluting stents in patients with chronic renal failure. Eur Heart J. 2009;30:468.
272 Twerenbold R, Reichlin T, Reiter M, et al. Early diagnosis of acute myocardial infarction in patients with kidney disease using more sensitive cardiac troponin assays. Eur Heart J. 2012;33:910-1.
273 Unterhuber M, Moes N, Pachinger O, et al. Outcome of left main percutaneous coronary interventions - A single-centre retrospective study. Journal fur Kardiologie. 2012;19(5-6):168.
274 Van Berkel M, Vogels S, Geerse D, et al. Troponin i as a cardiac biomarker for cardiovascular mortality in patients on haemodialysis. Nederlands Tijdschrift voor Klinische Chemie en Laboratoriumgeneeskunde. 2011;36(2):91.
275 Vardhan A, Khattar R, Brenchley P, et al. The significance of minimally elevated cardiac troponin-T levels in predicting cardiovascular events & sudden death in clinically well patients with end-stage chronic kidney disease. Eur Heart J. 2010;31:804.
276 Vieira C, Nabais S, Ramos V, et al. Cystatin C in acute coronary syndromes: Predictor of prognosis independent of renal function?. Eur Heart J. 2012;33:630. [pmid: 22009446].
277 Vieira C, Rocha S, Ramos V, et al. In hospital deterioration of glomerular filtration rate - Prognostic predictor in acute coronary syndromes. Eur Heart J. 2011;32:98.
278 Villarraga H, Adjei-Twum K, Cudjoe TKM, et al. Predictors of cardiac re-hospitalization in elderly adults presenting with decompensated heart failure. European Journal of Echocardiography. 2010;11(ii99).
279 Volz K, Sanchez L, Horowitz G, et al. CK-MB index should be eliminated in patients with indeterminate troponins in the emergency department. Academic Emergency Medicine. 2011;18(5):S200.
280 Wojakowski W, Tendera M, Tubaro M, et al. Impact of anemia and reduced left ventricular ejection fraction on in-hospital outcome of acute coronary syndromes. Euro Heart Survey ACS III registry (2006-2008). Eur Heart J. 2009;30:171.
281 Wong PSC, Jones J, Ashrafi R, et al. Long term prognostic effect of cardiac troponin T in hospitalised patients. Eur Heart J. 2011;32:94.
282 Woo JS, Kim W, Kim CJ, et al. Triple versus dual antiplatelet therapy in acute myocardial infarction in relation to renal function. American Journal of Cardiology. 2012;109(7):10S.
283 Woudstra P, Damman P, Clayton T, et al. Routine invasive versus selective invasive strategy and long-term outcomes in patients with reduced renal function presenting with non-ST segment elevation acute coronary syndrome. J Am Coll Cardiol. 2012;59(13):E392.
284 Yim S, Bae EH, Kim SW, et al. Renal dysfunction and cardiovascular outcome after acute myocardial infarction: Results from Korea acute myocardial infarction registry. Eur Heart J. 2011;32:92.
285 Yoo BS, Lee JH, Lee JW, et al. A multi-marker approach for the prediction of adverse events in patients with acute myocardial infarction. Circulation. 2012;126(21).
286 Yoshimura Y, Toyama T, Hoshizaki H, et al. The risk of chronic kidney disease for later major cardiac events in patients with initial acute myocardial infarction. European Heart Journal, Supplement. 2011;13:A65.
287 Yoshimura Y, Toyama T, Hoshizaki H, et al. Chronic Kidney Disease can contribute to later major cardiac events in patients with initial acute myocardial infarction. European Heart Journal, Supplement. 2009;11:S5.
288 Yu J, Pinnelas R, Vlachojannis G, et al. Which glomerular filtration rate equation best predicts poor outcomes in patients with acute myocardial infarction undergoing primary PCI: Results from the horizonsami study. J Am Coll Cardiol. 2012;59(13):E64.
289 Zairis M, Patsourakos N, Panayiotinos J, et al. The prognostic value of comorbidities from extracardiac vascular beds in patients with acute coronary syndromes. Eur Heart J. 2010;31:353-4.
290 Zeymer U, Bauer T, Hochadel M, et al. The high event rate in patients with diabetes mellitus treated with PCI for acute coronary syndromes is observed in the subgroup of patients with impaired renal function. Results of the Euro Heart Survey. Eur Heart J. 2011;32:1039-40. [pmid: 21156721].
291 Zhao Y, Li X, Wang D, et al. Glomerular filtration rate in the elderly with acute myocardial infarction as a prognostic factor of in-hospital events. Circulation. 2010;122(2):e138.

## No Chronic Kidney Disease or End-Stage Renal Disease

292 Al-Aqeedi R, Sulaiman K, Al Suwaidi J, et al. Characteristics, management and outcomes of patients with acute coronary syndrome and prior coronary artery bypass surgery: findings from the second Gulf Registry of Acute Coronary Events. Interact Cardiovasc Thorac Surg. Dec. 2011;13(6):611-8. [pmid: 21920933].
293 Antman EM, Tanasijevic MJ, Thompson B, et al. Cardiac-specific troponin I levels to predict the risk of mortality in patients with acute coronary syndromes. N Engl J Med. Oct. 31. 1996;335(18):1342-9. [pmid: 8857017].
294 Apple FS, Maturen AJ, Mullins RE, et al. Multicenter clinical and analytical evaluation of the AxSYM troponin-I immunoassay to assist in the diagnosis of myocardial infarction. Clin Chem. Feb. 1999;45(2):206-12. [pmid: 9931042].
295 Bakkouch AK, Graine H, Lavoinne A, et al. Myoglobin and troponin Ic immunoassay performances as evaluated on ACS 180(TM). Immuno-Analyse et Biologie Specialisee. 1999;14(5):348-53.
296 Barasch E, Kaushik V, Gupta R, et al. Elevated cardiac troponin levels do not predict adverse outcomes in hospitalized patients without clinical manifestations of acute coronary syndromes. Cardiology. 2000;93(1-2):1-6. [pmid: 10894899].
297 Bennett AE, Bertholf RL. Discordant results of CK-MB and troponin I measurements: a review of 14 cases. Ann Clin Lab Sci. Apr. 2000;30(2):167-73. [pmid: 10807160].
298 Carlson ER, Percy RF, Angiolillo DJ, et al. Prognostic significance of troponin T elevation in patients without chest pain. Am J Cardiol. Sep. 15. 2008;102(6):668-71. [pmid: 18773985].
299 Carrabba N, Valenti R, Migliorini A, et al. Prognostic value of myocardial injury following transcatheter aortic valve implantation. Am J Cardiol. May. 15. 2013;111(10):1475-81. [pmid: 23465097].
300 Chance JJ, Segal JB, Wallerson G, et al. Cardiac troponin T and C-reactive protein as markers of acute cardiac allograft rejection. Clin Chim Acta. Oct. 2001;312(1-2):31-9. [pmid: 11580907].
301 Chang CC, Ip MP, Hsu RM, et al. Evaluation of a proposed panel of cardiac markers for the diagnosis of acute myocardial infarction in patients with atraumatic chest pain. Arch Pathol Lab Med. Apr. 1998;122(4):320-4. [pmid: 9648898].
302 Chen TH, Chang CH, Lin CY, et al. Acute kidney injury biomarkers for patients in a coronary care unit: a prospective cohort study. PLoS One. 2012;7(2):e32328. [pmid: 22384218].
303 Chenevier-Gobeaux C, Bailleul S, Mzabi A, et al. Upper reference limits of high-sensitivity cardiac troponin T in a general population: comparison with those of sensitive cardiac troponin I. Clin Lab. 2013;59(3-4):333-6. [pmid: 23724622].
304 Chi Z, Mi SH, Zhang XX, et al. Impact of anemia on long-term outcome in elderly patients with acute coronary syndrome undergoing percutaneous coronary interventions. Zhonghua Xin Xue Guan Bing Za Zhi. Nov. 2012;40(11):920-3. [pmid: 23363672].
305 Christenson RH, Apple FS, Morgan DL, et al. Cardiac troponin I measurement with the ACCESS immunoassay system: analytical and clinical performance characteristics. Clin Chem. Jan. 1998;44(1):52-60. [pmid: 9550558].
306 Demondion P, Fournel L, Golmard JL, et al. Predictors of 30-day mortality and outcome in cases of myocardial infarction with cardiogenic shock treated by extracorporeal life support. Eur J Cardiothorac Surg. 2013. Apr. 24. [pmid: 23616484].
307 Eggers KM, Al-Shakarchi J, Berglund L, et al. High-sensitive cardiac troponin T and its relations to cardiovascular risk factors, morbidity, and mortality in elderly men. Am Heart J. Sep. 2013;166(3):541-8 e1. [pmid: 24016505].
308 Eggers KM, Jaffe AS, Lind L, et al. Value of cardiac troponin I cutoff concentrations below the 99th percentile for clinical decision-making. Clin Chem. Jan. 2009;55(1):85-92. [pmid: 18988758].
309 Eigel P, van Ingen G, Wagenpfeil S. Predictive value of perioperative cardiac troponin I for adverse outcome in coronary artery bypass surgery. Eur J Cardiothorac Surg. Sep. 2001;20(3):544-9. [pmid: 11509277].
310 Fiorina P, Astorri E, Albertini R, et al. Soluble antiapoptotic molecules and immune activation in chronic heart failure and unstable angina pectoris. J Clin Immunol. Mar. 2000;20(2):101-6. [pmid: 10821461].
311 Giannitsis E, Kurz K, Hallermayer K, et al. Analytical validation of a high-sensitivity cardiac troponin T assay. Clin Chem. Feb. 2010;56(2):254-61. [pmid: 19959623].
312 Hallen J, Johansen OE, Birkeland KI, et al. Determinants and prognostic implications of cardiac troponin T measured by a sensitive assay in type 2 diabetes mellitus. Cardiovasc Diabetol. 2010;9:52. [pmid: 20843304].
313 Heeschen C, Hamm CW, Goldmann B, et al. Troponin concentrations for stratification of patients with acute coronary syndromes in relation to therapeutic efficacy of tirofiban. PRISM Study Investigators. Platelet Receptor Inhibition in Ischemic Syndrome Management. Lancet. Nov. 20. 1999;354(9192):1757-62. [pmid: 10577636].
314 Hetland O, Dickstein K. Cardiac troponins I and T in patients with suspected acute coronary syndrome: a comparative study in a routine setting. Clin Chem. Jul. 1998;44(7):1430-6. [pmid: 9665420].
315 Hsu HP, Jou YL, Lin SJ, et al. Comparison of in-hospital outcome of acute ST elevation myocardial infarction in patients with versus without diabetes mellitus. Acta Cardiologica Sinica. 2011;27(3):145-51.
316 Hwang SH, Jeong MH, Ahmed K, et al. Different clinical outcomes of acute kidney injury according to acute kidney injury network criteria in patients between ST elevation and non-ST elevation myocardial infarction. Int J Cardiol. Jul. 1. 2011;150(1):99-101. [pmid: 21481955].
317 Jacob J, Martin-Sanchez FJ, Herrero P, et al. Prognostic value of troponin in patients with acute heart failure attended in Spanish Emergency Departments: TROPICA study (TROPonin in acute heart failure). Med Clin (Barc). Feb. 16. 2013;140(4):145-51. [pmid: 23122607].
318 James S, Armstrong P, Califf R, et al. Troponin T levels and risk of 30-day outcomes in patients with the acute coronary syndrome: prospective verification in the GUSTO-IV trial. Am J Med. Aug. 15. 2003;115(3):178-84. [pmid: 12935823].
319 Jug M, Rumenjak V, Alpeza I, et al. Clinical value of biochemical markers in the diagnosis of acute myocardial infarction. Acta Med Croatica. 2000;54(3):113-7. [pmid: 11268788].
320 Keller T, Zeller T, Peetz D, et al. Sensitive troponin I assay in early diagnosis of acute myocardial infarction. N Engl J Med. Aug. 27. 2009;361(9):868-77. [pmid: 19710485].
321 Khan IA, Tun A, Wattanasauwan N, et al. Elevation of serum cardiac troponin I in noncardiac and cardiac diseases other than acute coronary syndromes. Am J Emerg Med. May. 1999;17(3):225-9. [pmid: 10337875].
322 Koshkina EV, Krasnosel'skii M, Fedorovskii NM, et al. Diagnostic value of cardiac troponin T increase in critically ill patients. Anesteziol Reanimatol. Nov-Dec. 2009;(6):42-6. [pmid: 20101793].
323 Koszta G, Kacska Z, Szatmari K, et al. Lower whole blood selenium level is associated with higher operative risk and mortality following cardiac surgery. J Anesth. Dec. 2012;26(6):812-21. [pmid: 22847607].
324 Kratz A, Lewandrowski KB, Januzzi JL, et al. Comparison of cardiac marker concentrations in healthy blood donors and hospital patients without acute coronary syndrome. Am J Cardiol. 2002:177-8. [pmid: 12106854].
325 Krishnan E, Baker JF, Furst DE, et al. Gout and the risk of acute myocardial infarction. Arthritis Rheum. Aug. 2006;54(8):2688-96. [pmid: 16871533].
326 Lafci B, Ozsoyler I, Kestelli M, et al. Predictors of mortality in elderly patients undergoing coronary revascularization. Chirurgia. 2008;21(3):139-42.
327 Landesberg G, Vesselov Y, Einav S, et al. Myocardial ischemia, cardiac troponin, and long-term survival of high-cardiac risk critically ill intensive care unit patients. Crit Care Med. Jun. 2005;33(6):1281-7. [pmid: 15942345].
328 Lim P, Collet JP, Moutereau S, et al. Fetuin-A is an independent predictor of death after ST-elevation myocardial infarction. Clin Chem. Oct. 2007;53(10):1835-40. [pmid: 17702860].
329 Lin JC, Apple FS, Murakami MM, et al. Rates of positive cardiac troponin I and creatine kinase MB mass among patients hospitalized for suspected acute coronary syndromes. Clin Chem. Feb. 2004;50(2):333-8. [pmid: 14670826].
330 Mainet Gonzalez D, Sorell Gomez L, Pichardo Diaz D, et al. Evaluation of a rapid immunoassay for the quantification of cardiac troponin I in the diagnosis of acute myocardial infarction. Quimica Clinica. 2003;22(6):419-30.
331 Manzano-Fernandez S, Boronat-Garcia M, Albaladejo-Oton MD, et al. Complementary prognostic value of cystatin C, N-terminal pro-B-type natriuretic Peptide and cardiac troponin T in patients with acute heart failure. Am J Cardiol. Jun. 15. 2009;103(12):1753-9. [pmid: 19539088].
332 McKie PM, Heublein DM, Scott CG, et al. Defining high-sensitivity cardiac troponin concentrations in the community. Clin Chem. Jul. 2013;59(7):1099-107. [pmid: 23592511].
333 Morariu AM, Loef BG, Aarts LP, et al. Dexamethasone: benefit and prejudice for patients undergoing on-pump coronary artery bypass grafting: a study on myocardial, pulmonary, renal, intestinal, and hepatic injury. Chest. Oct. 2005;128(4):2677-87. [pmid: 16236942].
334 Munzer T, Heim C, Riesen W. Perioperative myocardial infarction and cardiac complications after noncardiac surgery in patients with prior myocardial infarction. III: Troponin T--a significant diagnostic alternative in perioperative myocardial infarction?. Anaesthesist. Mar. 1996;45(3):225-30. [pmid: 8919894].
335 Neeland IJ, Drazner MH, Berry JD, et al. Biomarkers of chronic cardiac injury and hemodynamic stress identify a malignant phenotype of left ventricular hypertrophy in the general population. J Am Coll Cardiol. Jan. 15. 2013;61(2):187-95. [pmid: 23219305].
336 O'Connor CM, Fiuzat M, Lombardi C, et al. Impact of serial troponin release on outcomes in patients with acute heart failure: analysis from the PROTECT pilot study. Circ Heart Fail. Nov. 2011;4(6):724-32. [pmid: 21900185].
337 Parenti N, Bartolacci S, Carle F, et al. Cardiac troponin I as prognostic marker in heart failure patients discharged from emergency department. Intern Emerg Med. Mar. 2008;3(1):43-7. [pmid: 18273567].
338 Penttila K, Penttila I, Bonnell R, et al. Comparison of the troponin T and troponin I ELISA tests, as measured by microplate immunoassay techniques, in diagnosing acute myocardial infarction. Eur J Clin Chem Clin Biochem. Oct. 1997;35(10):767-74. [pmid: 9368795].
339 Pervaiz S, Anderson FP, Lohmann TP, et al. Comparative analysis of cardiac troponin I and creatine kinase-MB as markers of acute myocardial infarction. Clin Cardiol. Mar. 1997;20(3):269-71. [pmid: 9068915].
340 Rigattieri S, Cera M, Sciahbasi A, et al. Primary percutaneous coronary intervention in nonagenarians: six-month outcomes from a single-center registry. J Invasive Cardiol. May. 2013;25(5):242-5. [pmid: 23645049].
341 Rodriguez-Reyna TS, Arrieta O, Castillo-Martinez L, et al. Tumour Necrosis Factor alpha and Troponin T as predictors of poor prognosis in patients with stable heart failure. Clin Invest Med. Feb. 2005;28(1):23-9. [pmid: 15770879].
342 Sabate S, Mases A, Guilera N, et al. Incidence and predictors of major perioperative adverse cardiac and cerebrovascular events in non-cardiac surgery. Br J Anaesth. Dec. 2011;107(6):879-90. [pmid: 21890661].
343 Saiki A, Iwase M, Takeichi Y, et al. Diversity of the elevation of serum cardiac troponin I levels in patients during their first visit to the emergency room. Circ J. Sep. 2007;71(9):1458-62. [pmid: 17721028].
344 Sathisha TG, Manjunatha GBK, Avinash SS, et al. Microalbuminuria in non-diabetic, non-hypertensive myocardial infarction in South Indian patients with relation to lipid profile and cardiac markers. Journal of Clinical and Diagnostic Research. 2012;5(6):1158-60.
345 Sato Y, Kataoka K, Matsumori A, et al. Measuring serum aminoterminal type III procollagen peptide, 7S domain of type IV collagen, and cardiac troponin T in patients with idiopathic dilated cardiomyopathy and secondary cardiomyopathy. Heart. Nov. 1997;78(5):505-8. [pmid: 9415013].
346 Sato Y, Yamamoto E, Sawa T, et al. High-sensitivity cardiac troponin T in essential hypertension. J Cardiol. Nov. 2011;58(3):226-31. [pmid: 21885250].
347 Saunders JT, Nambi V, de Lemos JA, et al. Cardiac troponin T measured by a highly sensitive assay predicts coronary heart disease, heart failure, and mortality in the Atherosclerosis Risk in Communities Study. Circulation. Apr. 5. 2011;123(13):1367-76. [pmid: 21422391].
348 Schuuring MJ, van Riel AC, Vis JC, et al. High-sensitivity Troponin T Is Associated with Poor Outcome in Adults with Pulmonary Arterial Hypertension due to Congenital Heart Disease. Congenit Heart Dis. 2012. Dec. 14. [pmid: 23241414].
349 Setsuta K, Kitahara Y, Arae M, et al. Elevated cardiac troponin T predicts adverse outcomes in hypertensive patients. Int Heart J. 2011;52(3):164-9. [pmid: 21646739].
350 Seyfert H, Bohlscheid V, Kaddatz J. Hyponatremia and acute myocardial infarction. Pravention und Rehabilitation. 2012;24(2):74-9.
351 Singh A, Uthappa S, Govindaraju V, et al. Serum markers for early diagnosis of non-‘Q’ wave and ‘Q’ wave myocardial infarction. Indian J Clin Biochem. Jan. 2002;17(1):25-8. [pmid: 23105332].
352 Song D, de Zoysa JR, Ng A, et al. Troponins in acute kidney injury. Ren Fail. 2012;34(1):35-9. [pmid: 22010639].
353 Toso A. Protective effect of rosuvastatin and antiplatelet therapy on contrast-induced nephropathy and myocardial damage in patients with acute coronary syndrome undergoing coronary intervention (PRATO-ACS Trial). clinicaltrials.gov/ct2/show/NCT01185938. 2011.
354 Urban P, Radovanovic D, Erne P, et al. Impact of changing definitions for myocardial infarction: a report from the AMIS registry. Am J Med. Dec. 2008;121(12):1065-71. [pmid: 19028202].
355 Venge P, Johnston N, Lindahl B, et al. Normal plasma levels of cardiac troponin I measured by the high-sensitivity cardiac troponin I access prototype assay and the impact on the diagnosis of myocardial ischemia. J Am Coll Cardiol. Sep. 22. 2009;54(13):1165-72. [pmid: 19761938].
356 Wi J, Ko YG, Kim JS, et al. The impact of contrast-induced nephropathy on long-term outcomes in patients with acute myocardial infarction undergoing percutaneous coronary interventions. J Am Coll Cardiol. 2010;56(13):B97.
357 Windhausen F, Hirsch A, Fischer J, et al. Cystatin C for enhancement of risk stratification in non-ST elevation acute coronary syndrome patients with an increased troponin T. Clin Chem. Jun. 2009;55(6):1118-25. [pmid: 19359536].
358 Young PJ, Dalley P, Garden A, et al. A pilot study investigating the effects of remote ischemic preconditioning in high-risk cardiac surgery using a randomised controlled double-blind protocol. Basic Res Cardiol. 2012;107(3):256. [pmid: 22406977].
359 Zaninotto M, Altinier S, Lachin M, et al. Strategies for the early diagnosis of acute myocardial infarction using biochemical markers. Am J Clin Pathol. Mar. 1999;111(3):399-405. [pmid: 10078116].

## Troponin Not Evaluated

360 Abbott JD, Ahmed HN, Vlachos HA, et al. Comparison of outcome in patients with ST-elevation versus non-ST-elevation acute myocardial infarction treated with percutaneous coronary intervention (from the National Heart, Lung, and Blood Institute Dynamic Registry). Am J Cardiol. Jul. 15. 2007;100(2):190-5. [pmid: 17631068].
361 Abbott KC, Bucci JR, Cruess D, et al. Graft loss and acute coronary syndromes after renal transplantation in the United States. J Am Soc Nephrol. Oct. 2002;13(10):2560-9. [pmid: 12239246].
362 Abu-Assi E, Lear P, Cabanas-Grandio P, et al. A comparison of the CKD-EPI, MDRD-4, and Cockcroft-Gault equations to assess renal function in predicting all-cause mortality in acute coronary syndrome patients. Int J Cardiol. 2012. Dec. 4. [pmid: 23218581].
363 Abu-Assi E, Lear P, Cabanas-Grandio P, et al. A comparison of the CKD-EPI, MDRD-4, and Cockcroft-Gault equations to assess renal function in predicting all-cause mortality in acute coronary syndrome patients. Int J Cardiol. Sep. 1. 2013;167(5):2325-6. [pmid: 23218581].
364 Abu-Assi E, Raposeiras-Roubin S, Riveiro-Cruz A, et al. Creatinine-or cystatin C-based equations to estimate glomerular filtration rate in acute myocardial infarction: A disparity in estimating renal function and in mortality risk prediction. Int J Cardiol. 2013. May. 25. [pmid: 23714598].
365 Afshinnia F, Ayazi P, Chadow HL. Glomerular filtration rate on admission independently predicts short-term in-hospital mortality after acute myocardial infarction. Am J Nephrol. 2006;26(4):408-14. [pmid: 16926535].
366 Ahmed S, Cannon CP, Giugliano RP, et al. The independent and combined risk of diabetes and non-endstage renal impairment in non-ST-segment elevation acute coronary syndromes. Int J Cardiol. Dec. 17. 2008;131(1):105-12. [pmid: 18187215].
367 Akerblom A, Wallentin L, Siegbahn A, et al. Cystatin C and estimated glomerular filtration rate as predictors for adverse outcome in patients with ST-elevation and non-ST-elevation acute coronary syndromes: results from the Platelet Inhibition and Patient Outcomes study. Clin Chem. Jan. 2012;58(1):190-9. [pmid: 22126936].
368 Akkaya E, Ayhan E, Uyarel H, et al. The impact of chronic kidney disease on in-hospital clinical outcomes in patients undergoing primary percutaneous angioplasty for ST-segment elevation myocardial infarction. Turk Kardiyol Dern Ars. Jun. 2011;39(4):276-82. [pmid: 21646828].
369 Al Faleh HF, AlSuwaida AO, Hersi AS, et al. In-hospital adverse clinical outcomes of ST elevation myocardial infarction patients with renal dysfunction. Insights from the Saudi Project for Assessment of Coronary Events. Saudi Med J. Aug. 2011;32(8):806-12. [pmid: 21858389].
370 Al Suwaidi J, Reddan DN, Williams K, et al. Prognostic implications of abnormalities in renal function in patients with acute coronary syndromes. Circulation. Aug. 20. 2002;106(8):974-80. [pmid: 12186803].
371 Alcock RF, Yong AS, Ng AC, et al. Acute coronary syndrome and stable coronary artery disease: Are they so different? Long-term outcomes in a contemporary PCI cohort. Int J Cardiol. 2012. Apr. 23. [pmid: 22534045].
372 Al-Hweish A, Sultan SS, Mogazi K, et al. Plasma myeloperoxidase, NT-proBNP, and troponin-I in patients on CAPD compared with those on regular hemodialysis. Hemodial Int. Jul. 2010;14(3):308-15. [pmid: 20597992].
373 Ali M, Soaly E, Asim M, et al. Cardiovascular risk assessment among potential kidney transplant candidates and perioperative outcome: analysis of 75 consecutive Middle Eastern patients. Transplant Proc. Jun. 2011;43(5):1531-6. [pmid: 21693230].
374 Amabile N, Guerin AP, Tedgui A, et al. Predictive value of circulating endothelial microparticles for cardiovascular mortality in end-stage renal failure: a pilot study. Nephrol Dial Transplant. May. 2012;27(5):1873-80. [pmid: 22036944].
375 Amin ST, Morrow DA, Braunwald E, et al. Dynamic TIMI risk score for STEMI. J Am Heart Assoc. Feb. 2013;2(1):e003269. [pmid: 23525425].
376 Anavekar NS, McMurray JJ, Velazquez EJ, et al. Relation between renal dysfunction and cardiovascular outcomes after myocardial infarction. N Engl J Med. Sep. 23. 2004;351(13):1285-95. [pmid: 15385655].
377 Anavekar NS, Solomon SD, McMurray JJ, et al. Comparison of renal function and cardiovascular risk following acute myocardial infarction in patients with and without diabetes mellitus. Am J Cardiol. Apr. 1. 2008;101(7):925-9. [pmid: 18359309].
378 Andronesi A, Iliuta L, Patruleasa M, et al. Predictive Factors for Coronary Artery Disease among Peritoneal Dialysis Patients without Diabetic Nephropathy. Maedica (Buchar). Sep. 2012;7(3):227-35. [pmid: 23400329].
379 Arantes RL, Gowdak LHW, De Paula FJ, et al. Myocardial scintigraphy and clinical stratification as predictors of events in renal transplant candidates. J Nephrol. 2010;23(3):314-20. [pmid: 20349410].
380 Armstrong KA, Rakhit DJ, Case C, et al. Derivation and validation of a disease-specific risk score for cardiac risk stratification in chronic kidney disease. Nephrol Dial Transplant. Oct. 2005;20(10):2097-104. [pmid: 16014347].
381 Aronson D, Hammerman H, Beyar R, et al. Serum blood urea nitrogen and long-term mortality in acute ST-elevation myocardial infarction. Int J Cardiol. Jul. 21. 2008;127(3):380-5. [pmid: 17765341].
382 Aronson D, Kapeliovich M, Hammerman H, et al. The relation between serum phosphorus levels and clinical outcomes after acute myocardial infarction. PLoS One. 2013;8(3):e58348. [pmid: 23505492].
383 Arribas-Leal JM, Pascual-Figal DA, Tornel-Osorio PL, et al. Prognostic role of a new biomarkers in off-pump coronary artery bypass surgery. Rev Esp Cardiol. 2006;59(3):280-3.
384 Asif A, Castro H, Waheed AA, et al. Blood pressure recordings during hemodialysis access interventions: implications for acute management. Semin Dial. Jul-Aug. 2013;26(4):E30-2. [pmid: 23551213].
385 Asinger RW, Henry TD, Herzog CA, et al. Clinical outcomes of PTCA in chronic renal failure: a case-control study for comorbid features and evaluation of dialysis dependence. J Invasive Cardiol. Jan. 2001;13(1):21-8. [pmid: 11146683].
386 Assali AR, Brosh D, Ben-Dor I, et al. The impact of renal insufficiency on patients' outcomes in emergent angioplasty for acute myocardial infarction. Catheter Cardiovasc Interv. Feb. 15. 2007;69(3):395-400. [pmid: 17195964].
387 Baber U, Kini AS, Sharma SK, et al. Thrombolysis In Myocardial Infarction (TIMI) risk score and mortality in patients with advanced chronic kidney disease and on dialysis. Am J Cardiol. Jun. 1. 2009;103(11):1513-7. [pmid: 19463508].
388 Baber U, Stone GW, Weisz G, et al. Coronary plaque composition, morphology, and outcomes in patients with and without chronic kidney disease presenting with acute coronary syndromes. JACC Cardiovasc Imaging. Mar. 2012;5(3 Suppl):S53-61. [pmid: 22421231].
389 Bacak-Kocman I, Basic-Jukic N, Lovcic V, et al. Renal replacement therapy in cardiology wards: changing trends in a transitional country. Ther Apher Dial. Apr. 2012;16(2):163-8. [pmid: 22458396].
390 Baldovinos G, Petraglia A, Larre Borges P, et al. Ischemic cadiopathy in patients undergoing chronic hemodialysis. Nefrologia. 2002;22(1):60-5. [pmid: 11987686].
391 Barthelemy O, Helft G, Silvain J, et al. One-year clinical outcomes in patients with chronic renal failure treated by percutaneous coronary intervention with drug-eluting stent. Arch Cardiovasc Dis. Dec. 2011;104(12):604-10. [pmid: 22152512].
392 Bataille Y, Dery JP, Larose E, et al. Incidence and clinical impact of concurrent chronic total occlusion according to gender in ST- elevation myocardial infarction. Catheter Cardiovasc Interv. 2012. Oct. 16. [pmid: 23074092].
393 Beattie JN, Soman SS, Sandberg KR, et al. Determinants of mortality after myocardial infarction in patients with advanced renal dysfunction. Am J Kidney Dis. Jun. 2001;37(6):1191-200. [pmid: 11382688].
394 Berger AK, Duval S, Krumholz HM. Aspirin, beta-blocker, and angiotensin-converting enzyme inhibitor therapy in patients with end-stage renal disease and an acute myocardial infarction. J Am Coll Cardiol. Jul. 16. 2003;42(2):201-8. [pmid: 12875751].
395 Berger JS, Slater JN, Sherman W, et al. Impact of platelet glycoprotein IIb/IIIa inhibitor therapy on in-hospital outcomes and long-term survival following percutaneous coronary rotational atherectomy. J Thromb Thrombolysis. Feb. 2005;19(1):47-54. [pmid: 15976967].
396 Bertomeu-Gonzalez V, Nunez J, Nunez E, et al. Prognostic effect of renal dysfunction after ST-segment elevation myocardial infarction with and without heart failure. Int J Cardiol. Sep. 20. 2006;112(2):159-65. [pmid: 16290104].
397 Bevc S, Penko M, Kanic V, et al. Mortality of patients with renal dysfunction after percutaneous coronary intervention. Angiology. Feb-Mar. 2010;61(1):24-30. [pmid: 19525280].
398 Bittner HB, Savitt MA. Off-pump coronary artery bypass grafting decreases morbidity and mortality in a selected group of high-risk patients. Ann Thorac Surg. Jul. 2002;74(1):115-8. [pmid: 12118740].
399 Boaz M, Smetana S, Weinstein T, et al. Secondary prevention with antioxidants of cardiovascular disease in endstage renal disease (SPACE): randomised placebo-controlled trial. Lancet. Oct. 7. 2000;356(9237):1213-8. [pmid: 11072938].
400 Bonello L, De Labriolle A, Roy P, et al. Impact of optimal medical therapy and revascularization on outcome of patients with chronic kidney disease and on dialysis who presented with acute coronary syndrome. Am J Cardiol. Sep. 1. 2008;102(5):535-40. [pmid: 18721508].
401 Borentain M, Le Feuvre C, Helft G, et al. Long-term outcome after coronary angioplasty in renal transplant and hemodialysis patients. J Interv Cardiol. 2005;18(5):331-7. [pmid: 16202107].
402 Bottle A, Sanders RD, Mozid A, et al. Provider profiling models for acute coronary syndrome mortality using administrative data. Int J Cardiol. Sep. 20. 2013;168(1):338-43. [pmid: 23063211].
403 Bruetto RG, Rodrigues FB, Torres US, et al. Renal function at hospital admission and mortality due to acute kidney injury after myocardial infarction. PLoS One. 2012;7(4):e35496. [pmid: 22539974].
404 Brzosko S, Hryszko T, Lebkowska U, et al. Plasma tissue-type plasminogen activator, fibrinogen, and time on dialysis prior to transplantation are related to carotid intima media thickness in renal transplant recipients. Transplant Proc. Dec. 2003;35(8):2931-4. [pmid: 14697941].
405 Buckley BS, Simpson CR, McLernon DJ, et al. Five year prognosis in patients with angina identified in primary care: incident cohort study. BMJ. 2009;339:b3058. [pmid: 19661139].
406 Cabrerizo Garcia JL, Zalba Etayo B, Perez Calvo JI. Prognostic value of glomerular filtrate in acute coronary syndrome: Cockcroft's index or MDRD equation?. Med Clin (Barc). May. 15. 2010;134(14):624-9. [pmid: 20202652].
407 Cai Q, Serrano R, Kalyanasundaram A, et al. A preoperative echocardiographic predictive model for assessment of cardiovascular outcome after renal transplantation. J Am Soc Echocardiogr. May. 2010;23(5):560-6. [pmid: 20381999].
408 Campbell LJ, Desai M, Hegazi A, et al. Renal impairment is associated with coronary heart disease in HIV-positive men. HIV Clin Trials. Nov-Dec. 2012;13(6):343-9. [pmid: 23195672].
409 Campbell NG, Varagunam M, Sawhney V, et al. Mild chronic kidney disease is an independent predictor of long-term mortality after emergency angiography and primary percutaneous intervention in patients with ST-elevation myocardial infarction. Heart. Jan. 2012;98(1):42-7. [pmid: 21880649].
410 Cardarelli F, Bellasi A, Ou FS, et al. Combined impact of age and estimated glomerular filtration rate on in-hospital mortality after percutaneous coronary intervention for acute myocardial infarction (from the American College of Cardiology National Cardiovascular Data Registry). Am J Cardiol. Mar. 15. 2009;103(6):766-71. [pmid: 19268729].
411 Celik T, Iyisoy A, Yuksel CU, et al. Impact of admission glomerular filtration rate on the development of poor myocardial perfusion after primary percutaneous intervention in patients with acute myocardial infarction. Coron Artery Dis. Dec. 2008;19(8):543-9. [pmid: 19005288].
412 Chan MY, Becker RC, Sim LL, et al. Reperfusion strategy and mortality in ST-elevation myocardial infarction among patients with and without impaired renal function. Ann Acad Med Singapore. Mar. 2010;39(3):179-84. [pmid: 20372752].
413 Chan W, Stub D, Clark DJ, et al. Usefulness of transient and persistent no reflow to predict adverse clinical outcomes following percutaneous coronary intervention. Am J Cardiol. Feb. 15. 2012;109(4):478-85. [pmid: 22176999].
414 Chang YT, Wu JL, Hsu CC, et al. Diabetes and end-stage renal disease synergistically contribute to increased incidence of cardiovascular events: A nation-wide follow-up study during 1998-2009. Diabetes Care. 2013. Aug. 6. [pmid: 23920086].
415 Chantrel F, Enache I, Bouiller M, et al. Abysmal prognosis of patients with type 2 diabetes entering dialysis. Nephrol Dial Transplant. Jan. 1999;14(1):129-36. [pmid: 10052492].
416 Charytan D, Mauri L, Agarwal A, et al. The use of invasive cardiac procedures after acute myocardial infarction in long-term dialysis patients. Am Heart J. Sep. 2006;152(3):558-64. [pmid: 16923431].
417 Chen HH, Wu CJ, Chen YC, et al. Metabolic syndrome is associated with severe coronary artery disease and poor cardiac outcome in end-stage renal disease patients with acute coronary syndrome. Coron Artery Dis. Nov. 2006;17(7):593-6. [pmid: 17047442].
418 Chen SC, Chang JM, Liu WC, et al. Decrease in ankle-brachial index over time and cardiovascular outcomes in patients with hemodialysis. Am J Med Sci. Dec. 2012;344(6):457-61. [pmid: 23190561].
419 Chen SC, Chang JM, Liu WC, et al. Echocardiographic parameters are independently associated with increased cardiovascular events in patients with chronic kidney disease. Nephrol Dial Transplant. Mar. 2012;27(3):1064-70. [pmid: 21813825].
420 Chertow GM, Block GA, Correa-Rotter R, et al. Effect of cinacalcet on cardiovascular disease in patients undergoing dialysis. N Engl J Med. Dec. 27. 2012;367(26):2482-94. [pmid: 23121374].
421 Chertow GM, Normand SL, Silva LR, et al. Survival after acute myocardial infarction in patients with end-stage renal disease: results from the cooperative cardiovascular project. Am J Kidney Dis. Jun. 2000;35(6):1044-51. [pmid: 10845815].
422 Cheung AK, Sarnak MJ, Yan G, et al. Cardiac diseases in maintenance hemodialysis patients: results of the HEMO Study. Kidney Int. Jun. 2004;65(6):2380-9. [pmid: 15149351].
423 Choi SG, Jeong MH, Ahn Y, et al. Relationship between obesity and N-terminal brain natriuretic Peptide level as a prognostic value after acute myocardial infarction. Korean Circ J. Nov. 2010;40(11):558-64. [pmid: 21217932].
424 Choi YH, Suh SH, Choi JS, et al. Triple vs. dual antiplatelet therapy in patients with acute myocardial infarction and renal dysfunction. Circ J. Sep. 25. 2012;76(10):2405-11. [pmid: 22785460].
425 Chonchol MB, Aboyans V, Lacroix P, et al. Long-term outcomes after coronary artery bypass grafting: preoperative kidney function is prognostic. J Thorac Cardiovasc Surg. Sep. 2007;134(3):683-9. [pmid: 17723818].
426 Chong E, Shen L, Tan HC, et al. A cohort study of risk factors and clinical outcome predictors for patients presenting with unstable angina and non ST segment elevation myorardial infraction undergoing coronary intervention. Med J Malaysia. Aug. 2011;66(3):249-52. [pmid: 22111450].
427 Chou MT, Wang JJ, Sun YM, et al. Epidemiology and mortality among dialysis patients with acute coronary syndrome: Taiwan National Cohort Study. Int J Cardiol. 2012. Jul. 12. [pmid: 22795721].
428 Chou MT, Wang JJ, Sun YM, et al. Epidemiology and mortality among dialysis patients with acute coronary syndrome: Taiwan National Cohort Study. Int J Cardiol. Sep. 10. 2013;167(6):2719-23. [pmid: 22795721].
429 Christenson JT, Schmuziger M, Simonet F. Reoperative coronary artery bypass procedures: risk factors for early mortality and late survival. Eur J Cardiothorac Surg. Jan. 1997;11(1):129-33. [pmid: 9030801].
430 Chuang P, Gibney EM, Chan L, et al. Predictors of cardiovascular events and associated mortality within two years of kidney transplantation. Transplant Proc. Jun. 2004;36(5):1387-91. [pmid: 15251339].
431 Coles AH, Fisher KA, Darling C, et al. Recent trends in post-discharge mortality among patients with an initial acute myocardial infarction. Am J Cardiol. Oct. 15. 2012;110(8):1073-7. [pmid: 22762720].
432 Cooper HA, Monge C, Panza JA. Patients with end-stage renal disease and acute myocardial infarction have poor short-term outcomes despite modern cardiac intensive care. Coron Artery Dis. Jun. 2008;19(4):231-5. [pmid: 18480666].
433 Dai X, Bumgarner J, Spangler A, et al. Acute ST-elevation myocardial infarction in patients hospitalized for noncardiac conditions. J Am Heart Assoc. Apr. 2013;2(2):e000004. [pmid: 23557748].
434 Dalal D, de Jong JS, Tjong FV, et al. Mild-to-moderate kidney dysfunction and the risk of sudden cardiac death in the setting of acute myocardial infarction. Heart Rhythm. Apr. 2012;9(4):540-5. [pmid: 22079886].
435 de la Torre-Hernandez JM, Alfonso F, Hernandez F, et al. Drug-eluting stent thrombosis: results from the multicenter Spanish registry ESTROFA (Estudio ESpanol sobre TROmbosis de stents FArmacoactivos). J Am Coll Cardiol. Mar. 11. 2008;51(10):986-90. [pmid: 18325436].
436 de Zeeuw D, Remuzzi G, Parving HH, et al. Albuminuria, a therapeutic target for cardiovascular protection in type 2 diabetic patients with nephropathy. Circulation. Aug. 24. 2004;110(8):921-7. [pmid: 15302780].
437 DeCarolis DD, Thorson JG, Clairmont MA, et al. Enoxaparin outcomes in patients with moderate renal impairment. Arch Intern Med. 2012;172(22):1713-8. [pmid: 23128835].
438 Dheir H, Ozkahya M, Kircelli F, et al. Glycosylated hemoglobin levels are associated with cardiovascular events in nondiabetic peritoneal dialysis patients. J Nephrol. 2012;25(1):107-12. [pmid: 21607914].
439 Dohi T, Kasai T, Miyauchi K, et al. Prognostic impact of chronic kidney disease on 10-year clinical outcomes among patients with acute coronary syndrome. J Cardiol. Dec. 2012;60(6):438-42. [pmid: 23063662].
440 Dohi T, Miyauchi K, Okazaki S, et al. Long-term impact of mild chronic kidney disease in patients with acute coronary syndrome undergoing percutaneous coronary interventions. Nephrol Dial Transplant. Sep. 2011;26(9):2906-11. [pmid: 21300704].
441 Dudek D, Chyrchel B, Siudak Z, et al. Renal insufficiency increases mortality in acute coronary syndromes regardless of TIMI risk score. Kardiol Pol. Jan. 2008;66(1):28-34. discussion 5-6. [pmid: 18266185].
442 Duran M, Uysal OK, Gunebakmaz O, et al. Glomerular Filtration Rate is Associated With Burden of Coronary Atherosclerosis in Patients With Acute Coronary Syndrome. Angiology. 2013. May. 1. [pmid: 23636853].
443 Dziewierz A, Siudak Z, Rakowski T, et al. More aggressive pharmacological treatment may improve clinical outcome in patients with non-ST-elevation acute coronary syndromes treated conservatively. Coron Artery Dis. Jun. 2007;18(4):299-303. [pmid: 17496494].
444 El-Menyar A, Zubaid M, Sulaiman K, et al. In-hospital major clinical outcomes in patients with chronic renal insufficiency presenting with acute coronary syndrome: data from a Registry of 8176 patients. Mayo Clin Proc. Apr. 2010;85(4):332-40. [pmid: 20360292].
445 Etter C, Straub Y, Hersberger M, et al. Pregnancy-associated plasma protein-A is an independent short-time predictor of mortality in patients on maintenance haemodialysis. Eur Heart J. Feb. 2010;31(3):354-9. [pmid: 19850559].
446 Fabbian F, Pala M, De Giorgi A, et al. In-hospital mortality in patients with renal dysfunction admitted for myocardial infarction: the Emilia-Romagna region of Italy database of hospital admissions. Int Urol Nephrol. 2012. Jul. 25. [pmid: 22828743].
447 Fabbri A, Ottani F, Marchesini G, et al. Predicting unfavorable outcome in subjects with diagnosis of chest pain of undifferentiated origin. Am J Emerg Med. Jan. 2012;30(1):61-7. [pmid: 21035982].
448 Facila L, Nunez J, Bodi V, et al. Prognostic value of serum creatinine in non-ST-elevation acute coronary syndrome. Rev Esp Cardiol. Mar. 2006;59(3):209-16. [pmid: 16712744].
449 Fazelzadeh A, Mehdizadeh AR, Ostovan MA, et al. Predictors of cardiovascular events and associated mortality of kidney transplant recipients. Transplant Proc. Mar. 2006;38(2):509-11. [pmid: 16549162].
450 Feldman DN, Minutello RM, Gade CL, et al. Outcomes following immediate (ad hoc) versus staged percutaneous coronary interventions (report from the 2000 to 2001 New York State Angioplasty Registry). Am J Cardiol. Feb. 15. 2007;99(4):446-9. [pmid: 17293181].
451 Ferguson ER, Hudson SL, Diethelm AG, et al. Outcome after myocardial revascularization and renal transplantation: a 25-year single-institution experience. Ann Surg. Aug. 1999;230(2):232-41. [pmid: 10450738].
452 Ferrer-Hita JJ, Dominguez-Rodriguez A, Garcia-Gonzalez MJ, et al. Renal dysfunction is an independent predictor of in-hospital mortality in patients with ST-segment elevation myocardial infarction treated with primary angioplasty. Int J Cardiol. May. 31. 2007;118(2):243-5. [pmid: 16997402].
453 Fischer MJ, Ho PM, McDermott K, et al. Chronic kidney disease is associated with adverse outcomes among elderly patients taking clopidogrel after hospitalization for acute coronary syndrome. BMC Nephrol. May. 20. 2013;14(1):107. [pmid: 23688069].
454 Flu WJ, van Kuijk JP, Hoeks SE, et al. Intima media thickness of the common carotid artery in vascular surgery patients: a predictor of postoperative cardiovascular events. Am Heart J. Aug. 2009;158(2):202-8. [pmid: 19619695].
455 Freeman RV, Mehta RH, Al Badr W, et al. Influence of concurrent renal dysfunction on outcomes of patients with acute coronary syndromes and implications of the use of glycoprotein IIb/IIIa inhibitors. J Am Coll Cardiol. Mar. 5. 2003;41(5):718-24. [pmid: 12628712].
456 Frilling B, Zahn R, Fraiture B, et al. Comparison of efficacy and complication rates after percutaneous coronary interventions in patients with and without renal insufficiency treated with abciximab. Am J Cardiol. Feb. 15. 2002;89(4):450-2. [pmid: 11835927].
457 Fu S, Yi S, Zhu B, et al. Prevalence, clinical predictors, and prognostic impact of chronic renal insufficiency in very old Chinese patients with coronary artery disease. Aging Clin Exp Res. Aug. 2013;25(4):385-91. [pmid: 23760945].
458 Fu SH, Zhu B, Zhang YX, et al. Chronic kidney disease: an independent risk factor of all-cause mortality for elderly Chinese patients with chronic heart failure. J Geriatr Cardiol. Dec. 2012;9(4):355-60. [pmid: 23341840].
459 Funayama A, Shishido T, Miyashita T, et al. Renal tubulointerstitial damage is associated with short-term cardiovascular events in patients with myocardial infarction. Circ J. Jan. 25. 2013;77(2):484-9. [pmid: 23123554].
460 Furuhashi T, Moroi M, Joki N, et al. The predictive value of chronic kidney disease for assessing cardiovascular events under consideration of pretest probability for coronary artery disease in patients who underwent stress myocardial perfusion imaging. Int J Cardiovasc Imaging. Feb. 2013;29(2):513-9. [pmid: 22806318].
461 Furuhashi T, Moroi M, Joki N, et al. Prediction of cardiovascular events in pre-dialysis chronic kidney disease patients with normal SPECT myocardial perfusion imaging. J Cardiol. 2013. Aug. 31. [pmid: 24001741].
462 Furuhashi T, Moroi M, Joki N, et al. Predictors of cardiovascular events in hemodialysis patients after stress myocardial perfusion imaging. Hemodial Int. 2013. Apr. 9. [pmid: 23574392].
463 Gai JJ, Gai LY, Liu HB, et al. Correlation of heart and kidney biomarkers to the pathogenesis of cardiorenal syndrome. Nan Fang Yi Ke Da Xue Xue Bao. May. 2010;30(5):1122-6. [pmid: 20501410].
464 Garg P, Charytan DM, Novack L, et al. Impact of moderate renal insufficiency on restenosis and adverse clinical events after sirolimus-eluting and bare metal stent implantation (from the SIRIUS trials). American Journal of Cardiology. 2010;106(10):1436-42. [pmid: 21059433].
465 Garrido P, Bobadilla JF, Albertos J, et al. Cardiac surgery in patients under chronic hemodialysis. Eur J Cardiothorac Surg. 1995;9(1):36-9. [pmid: 7727144].
466 Gevaert SA, De Bacquer D, Evrard P, et al. Renal dysfunction in STEMI-patients undergoing primary angioplasty: higher prevalence but equal prognostic impact in female patients; an observational cohort study from the Belgian STEMI registry. BMC Nephrol. 2013;14:62. [pmid: 23506004].
467 Gibson CM, Pinto DS, Murphy SA, et al. Association of creatinine and creatinine clearance on presentation in acute myocardial infarction with subsequent mortality. J Am Coll Cardiol. Nov. 5. 2003;42(9):1535-43. [pmid: 14607434].
468 Gimeno-Orna JA, Lou-Arnal LM, Boned-Juliani B, et al. Mild renal insufficiency as a cardiovascular risk factor in non-proteinuric type II diabetes. Diabetes Res Clin Pract. Jun. 2004;64(3):191-9. [pmid: 15126007].
469 Go J, Narmi A, Sype J, et al. Impact of renal dysfunction on the prognostic value of the TIMI risk score in patients with non-ST elevation acute coronary syndrome. Coron Artery Dis. 2011;22(6):411-5. [pmid: 21691204].
470 Goldberg A, Hammerman H, Petcherski S, et al. Inhospital and 1-year mortality of patients who develop worsening renal function following acute ST-elevation myocardial infarction. Am Heart J. Aug. 2005;150(2):330-7. [pmid: 16086939].
471 Goldenberg I, Subirana I, Boyko V, et al. Relation between renal function and outcomes in patients with non-ST-segment elevation acute coronary syndrome: real-world data from the European Public Health Outcome Research and Indicators Collection Project. Arch Intern Med. May. 24. 2010;170(10):888-95. [pmid: 20498417].
472 Gurm HS, Gore JM, Anderson FA Jr, et al. Comparison of acute coronary syndrome in patients receiving versus not receiving chronic dialysis (from the Global Registry of Acute Coronary Events [GRACE] Registry). Am J Cardiol. Jan. 1. 2012;109(1):19-25. [pmid: 21974963].
473 Hachinohe D, Jeong MH, Saito S, et al. Management of non-ST-segment elevation acute myocardial infarction in patients with chronic kidney disease (from the Korea Acute Myocardial Infarction Registry). Am J Cardiol. Jul. 15. 2011;108(2):206-13. [pmid: 21712106].
474 Hachinohe D, Jeong MH, Saito S, et al. Management of NonST-segment elevation acute myocardial infarction in patients with chronic kidney disease (from the Korea Acute Myocardial Infarction Registry). American Journal of Cardiology. 2011;108(2):206-13. [pmid: 21712106].
475 Hage FG, Smalheiser S, Zoghbi GJ, et al. Predictors of survival in patients with end-stage renal disease evaluated for kidney transplantation. Am J Cardiol. Sep. 15. 2007;100(6):1020-5. [pmid: 17826390].
476 Halkin A, Selzer F, Marroquin O, et al. Clinical outcomes following percutaneous coronary intervention with drug-eluting vs. bare-metal stents in dialysis patients. Journal of Invasive Cardiology. 2006;18(12):577-83. [pmid: 17197706].
477 Halkin A, Singh M, Nikolsky E, et al. Prediction of mortality after primary percutaneous coronary intervention for acute myocardial infarction: the CADILLAC risk score. J Am Coll Cardiol. May. 3. 2005;45(9):1397-405. [pmid: 15862409].
478 Han JH, Chandra A, Mulgund J, et al. Chronic kidney disease in patients with non-ST-segment elevation acute coronary syndromes. Am J Med. Mar. 2006;119(3):248-54. [pmid: 16490471].
479 Harris S, Tepper D, Ip R. Comparison of hospital mortality with intra-aortic balloon counterpulsation insertion before vs after primary percutaneous coronary intervention for cardiogenic shock complicating acute myocardial infarction. Congestive Heart Failure. 2010;16(5):240.
480 Hartopo AB, Setianto BY, Gharini PP. Predictive value of different estimated glomerular filtration rates on hospital adverse events following acute myocardial infarction. Acta Med Indones. Apr. 2013;45(2):114-22. [pmid: 23770791].
481 Hase H, Joki N, Ishikawa H, et al. Independent risk factors for progression of coronary atherosclerosis in hemodialysis patients. Ther Apher Dial. Aug. 2006;10(4):321-7. [pmid: 16911184].
482 Hassani SE, Chu WW, Wolfram RM, et al. Clinical outcomes after percutaneous coronary intervention with drug-eluting stents in dialysis patients. J Invasive Cardiol. Jun. 2006;18(6):273-7. [pmid: 16751681].
483 Herlitz J, Brandrup-Wognsen G, Karlsson T, et al. Predictors of death and other cardiac events within 2 years after coronary artery bypass grafting. Cardiology. Oct. 1998;90(2):110-4. [pmid: 9778547].
484 Herzog CA. Acute myocardial infarction in patients with end-stage renal disease. Kidney Int Suppl. Jul. 1999;71:S130-3. [pmid: 10412756].
485 Herzog CA, Ma JZ, Collins AJ. Poor long-term survival after acute myocardial infarction among patients on long-term dialysis. N Engl J Med. Sep. 17. 1998;339(12):799-805. [pmid: 9738087].
486 Herzog CA, Ma JZ, Collins AJ. Long-term outcome of renal transplant recipients in the United States after coronary revascularization procedures. Circulation. Jun. 15. 2004;109(23):2866-71. [pmid: 15159290].
487 Hoftman N, Prunean A, Dhillon A, et al. Revised Cardiac Risk Index (RCRI) Is a Useful Tool for Evaluation of Perioperative Cardiac Morbidity in Kidney Transplant Recipients. Transplantation. 2013. Jul. 15. [pmid: 23860084].
488 Holme I, Fayyad R, Faergeman O, et al. Cardiovascular outcomes and their relationships to lipoprotein components in patients with and without chronic kidney disease: results from the IDEAL trial. J Intern Med. 2010:567-75. [pmid: 20141566].
489 Holzmann MJ, Janszky I, Al-Khalili F, et al. Renal dysfunction as a predictor of long-term mortality in middle-aged women following an acute coronary syndrome. J Womens Health (Larchmt). Aug. 2010;19(8):1487-91. [pmid: 20626267].
490 Hsieh TH, Wang JD, Tsai LM. Improving in-hospital mortality in elderly patients after acute coronary syndrome--a nationwide analysis of 97,220 patients in Taiwan during 2004-2008. Int J Cardiol. Feb. 23. 2012;155(1):149-54. [pmid: 22062897].
491 Hsieh YC, Ting CT, Liu TJ, et al. Short- and long-term renal outcomes of immediate prophylactic hemodialysis after cardiovascular catheterizations in patients with severe renal insufficiency. Int J Cardiol. Jun. 8. 2005;101(3):407-13. [pmid: 15907408].
492 Huang CC, Chan WL, Chen YC, et al. The beneficial effects of statins in patients undergoing hemodialysis. Int J Cardiol. 2013. Aug. 5. [pmid: 23928338].
493 Huo Y, Ho W. Renal insufficiency and clinical outcomes in patients with acute coronary syndrome undergoing percutaneous coronary intervention: a multi-centre study. Beijing Da Xue Xue Bao. Dec. 18. 2007;39(6):624-9. [pmid: 18087555].
494 Ifudu O, Miles AM, Friedman EA. Hemodialysis immediately after acute myocardial infarction. Nephron. 1996;74(1):104-9. [pmid: 8883026].
495 Inoue T, Tokuyama K, Yoshi S, et al. Elevated resting heart rate is an independent predictor of all-cause death and cardiovascular events in Japanese ambulatory hemodialysis patients. Clin Exp Nephrol. Dec. 2012;16(6):938-44. [pmid: 22588277].
496 Inrig JK, Patel UD, Briley LP, et al. Mortality, kidney disease and cardiac procedures following acute coronary syndrome. Nephrol Dial Transplant. Mar. 2008;23(3):934-40. [pmid: 17984102].
497 Iqbal Z, Cohen M, Pollack C, et al. Safety and efficacy of adjuvant glycoprotein IIb/IIIa inhibitors during primary percutaneous coronary intervention performed from the radial approach for acute ST segment elevation myocardial infarction. Am J Cardiol. Jun. 15. 2013;111(12):1727-33. [pmid: 23528027].
498 Iseki K, Fukiyama K. Long-term prognosis and incidence of acute myocardial infarction in patients on chronic hemodialysis. The Okinawa Dialysis Study Group. Am J Kidney Dis. Oct. 2000;36(4):820-5. [pmid: 11007686].
499 Iseki K, Kinjo K, Kimura Y, et al. Evidence for high risk of cerebral hemorrhage in chronic dialysis patients. Kidney Int. Nov. 1993;44(5):1086-90. [pmid: 8264139].
500 Israni AK, Snyder JJ, Skeans MA, et al. Predicting coronary heart disease after kidney transplantation: Patient Outcomes in Renal Transplantation (PORT) Study. Am J Transplant. Feb. 2010;10(2):338-53. [pmid: 20415903].
501 Itaya H, Shiba M, Joki N, et al. Combined assessment of chronic kidney disease and subclinical peripheral artery disease used to predict future cardiac events. Nephrology (Carlton). Mar. 2010;15(2):230-5. [pmid: 20470284].
502 James MT, Tonelli M, Ghali WA, et al. Renal outcomes associated with invasive versus conservative management of acute coronary syndrome: propensity matched cohort study. BMJ. 2013;347:f4151. [pmid: 23833076].
503 Januzzi JL, Cannon CP, DiBattiste PM, et al. Effects of renal insufficiency on early invasive management in patients with acute coronary syndromes (The TACTICS-TIMI 18 Trial). Am J Cardiol. Dec. 1. 2002;90(11):1246-9. [pmid: 12450608].
504 Jeong HC, Jeong JM, Jeong MH, et al. Effect of single or dual blockade of renin-angiotensin system in acute myocardial infarction patients according to renal function. Int J Cardiol. Jun. 14. 2012;157(3):408-11. [pmid: 22513185].
505 Jerbi B, Sahnoun M, Abid L, et al. Chronic kidney disease and myocardial infarction: epidemiological, clinical, therapeutic and prognostic characteristics (about 231 cases). Ann Cardiol Angeiol (Paris). Jun. 2011;60(3):127-34. [pmid: 21458774].
506 Joki N, Tanaka Y, Ishikawa H, et al. Optimum second screening point for detection of coronary artery disease in hemodialysis patients without advanced coronary artery disease. Am J Nephrol. 2009;29(5):420-5. [pmid: 18997458].
507 Jujo K, Yamaguchi J, Obayashi K, et al. Clinical impact of nephropathy induced by contrast medium in patients with acute myocardial infarction undergoing emergent coronary angiography. J Cardiol. Jul. 2006;48(1):9-16. [pmid: 16886495].
508 Kamimura MA, Carrero JJ, Canziani ME, et al. Visceral obesity assessed by computed tomography predicts cardiovascular events in chronic kidney disease patients. Nutr Metab Cardiovasc Dis. 2012. Jul. 25. [pmid: 22841184].
509 Kaya E, Cuneo A, Hochadel M, et al. Impact of chronic kidney disease on the prognosis of patients undergoing percutaneous coronary interventions using drug-eluting stents. Clinical Research in Cardiology. 2011;100(12):1103-9. [pmid: 21912915].
510 Keane WF, Tomassini JE, Neff DR. Lipid Abnormalities in Patients with Chronic Kidney Disease: Implications for the Pathophysiology of Atherosclerosis. J Atheroscler Thromb. 2012. Oct. 25. [pmid: 23095239].
511 Keeley EC, Kadakia R, Soman S, et al. Analysis of long-term survival after revascularization in patients with chronic kidney disease presenting with acute coronary syndromes. Am J Cardiol. Sep. 1. 2003;92(5):509-14. [pmid: 12943868].
512 Kelly AM, Dabee P, Klim S, et al. External validation of the GRACE Freedom from Events score. Heart Lung Circ. Sep. 2012;21(9):582-5. [pmid: 22710146].
513 Keltai M, Tonelli M, Mann JF, et al. Renal function and outcomes in acute coronary syndrome: impact of clopidogrel. Eur J Cardiovasc Prev Rehabil. Apr. 2007;14(2):312-8. [pmid: 17446813].
514 Keough-Ryan TM, Kiberd BA, Dipchand CS, et al. Outcomes of acute coronary syndrome in a large Canadian cohort: impact of chronic renal insufficiency, cardiac interventions, and anemia. Am J Kidney Dis. Nov. 2005;46(5):845-55. [pmid: 16253724].
515 Kessler M, Zannad F, Lehert P, et al. Predictors of cardiovascular events in patients with end-stage renal disease: an analysis from the Fosinopril in dialysis study. Nephrol Dial Transplant. Dec. 2007;22(12):3573-9. [pmid: 17611249].
516 Kestenbaum B, Sampson JN, Rudser KD, et al. Serum phosphate levels and mortality risk among people with chronic kidney disease. J Am Soc Nephrol. Feb. 2005;16(2):520-8. [pmid: 15615819].
517 Khambatta S, Farkouh ME, Wright RS, et al. Chronic kidney disease as a risk factor for acute coronary syndromes in patients presenting to the emergency room with chest pain. Transl Res. May. 2012;159(5):391-6. [pmid: 22500512].
518 Kilickesmez KO, Kocas C, Abaci O, et al. Follow-up of aspirin-resistant patients with end-stage kidney disease. Int Urol Nephrol. 2012. Jun. 20. [pmid: 22714143].
519 Kim CS, Choi JS, Bae EH, et al. Association of metabolic syndrome and renal insufficiency with clinical outcome in acute myocardial infarction. Metabolism. 2012. Dec. 5. [pmid: 23218489].
520 Kim CS, Choi JS, Bae EH, et al. Association of metabolic syndrome and renal insufficiency with clinical outcome in acute myocardial infarction. Metabolism. May. 2013;62(5):669-76. [pmid: 23218489].
521 Kim CS, Choi JS, Park JW, et al. Concomitant renal insufficiency and diabetes mellitus as prognostic factors for acute myocardial infarction. Cardiovasc Diabetol. 2011;10:95. [pmid: 22035298].
522 Kim JY, Jeong MH, Ahn YK, et al. Decreased Glomerular Filtration Rate is an Independent Predictor of In-Hospital Mortality in Patients With ST-Segment Elevation Myocardial Infarction Undergoing Primary Percutaneous Coronary Intervention. Korean Circ J. Apr. 2011;41(4):184-90. [pmid: 21607168].
523 Kinoshita N, Imai K, Kinjo K, et al. Longitudinal study of acute myocardial infarction in the southeast Osaka district from 1988 to 2002. Circ J. Oct. 2005;69(10):1170-5. [pmid: 16195611].
524 Koganei H, Kasanuki H, Ogawa H, et al. Association of glomerular filtration rate with unsuccessful primary percutaneous coronary intervention and subsequent mortality in patients with acute myocardial infarction: from the HIJAMI registry. Circ J. Feb. 2008;72(2):179-85. [pmid: 18219150].
525 Komarov AL, Shakhmatova OO, Il'ishchenko TA, et al. Factors determining prognosis of patients with stable ischemic heart disease (results of a five years prospective study). Kardiologiia. 2012;52(1):4-14. [pmid: 22304346].
526 Komukai K, Ogawa T, Yagi H, et al. Renal insufficiency is related to painless myocardial infarction. Circ J. Sep. 2007;71(9):1366-9. [pmid: 17721012].
527 Kowalczyk J, Francuz P, Swoboda R, et al. Prognostic significance of hyperuricemia in patients with different types of renal dysfunction and acute myocardial infarction treated with percutaneous coronary intervention. Nephron Clin Pract. 2010;116(2):c114-22. [pmid: 20502047].
528 Kowalczyk J, Lenarczyk R, Kowalski O, et al. Different types of renal dysfunction in patients with acute myocardial infarction treated with percutaneous coronary intervention. J Interv Cardiol. Apr. 2007;20(2):143-52. [pmid: 17391223].
529 Kowalczyk J, Lenarczyk R, Strojek K, et al. Prognosis in diabetic patients with acute myocardial infarction treated invasively is related to renal function. Med Sci Monit. Feb. 2010;16(2):CR67-74. [pmid: 20110917].
530 Krause MW, Massing M, Kshirsagar A, et al. Combination therapy improves survival after acute myocardial infarction in the elderly with chronic kidney disease. Ren Fail. Nov. 2004;26(6):715-25. [pmid: 15600265].
531 Kumagai S, Ishii H, Amano T, et al. Impact of chronic kidney disease on the incidence of peri-procedural myocardial injury in patients undergoing elective stent implantation. Nephrology Dialysis Transplantation. 2012;27(3):1059-63.
532 Kuo PI, Severino R, Pashkow FJ. Mortality rates and hemorrhagic complications in asian-pacific islanders during treatment of acute myocardial infarction. Am J Cardiol. Sep. 1. 2004;94(5):644-6. A9. [pmid: 15342299].
533 Landray MJ, Emberson JR, Blackwell L, et al. Prediction of ESRD and death among people with CKD: the Chronic Renal Impairment in Birmingham (CRIB) prospective cohort study. Am J Kidney Dis. Dec. 2010;56(6):1082-94. [pmid: 21035932].
534 Lansky AJ, Goto K, Cristea E, et al. Clinical and angiographic predictors of short- and long-term ischemic events in acute coronary syndromes: results from the Acute Catheterization and Urgent Intervention Triage strategY (ACUITY) trial. Circ Cardiovasc Interv. Aug. 2010;3(4):308-16. [pmid: 20647564].
535 Latchamsetty R, Fang J, Kline-Rogers E, et al. Prognostic value of transient and sustained increase in in-hospital creatinine on outcomes of patients admitted with acute coronary syndrome. Am J Cardiol. Apr. 1. 2007;99(7):939-42. [pmid: 17398188].
536 Lauzurica R, Pastor C, Bayes B, et al. Pretransplant pregnancy-associated plasma protein-a as a predictor of chronic allograft nephropathy and posttransplant cardiovascular events. Transplantation. Nov. 27. 2005;80(10):1441-6. [pmid: 16340789].
537 Lawesson SS, Todt T, Alfredsson J, et al. Gender difference in prevalence and prognostic impact of renal insufficiency in patients with ST-elevation myocardial infarction treated with primary percutaneous coronary intervention. Heart. 2011;97(4):308-14. [pmid: 21212134].
538 Lazzeri C, Valente S, Chiostri M, et al. Trends in mortality rates in elderly ST elevation myocardial infarction patients submitted to primary percutaneous coronary intervention: a 7-year single-center experience. Geriatr Gerontol Int. Jul. 2013;13(3):711-7. [pmid: 23279734].
539 Lee A, Lum JJ, Seto TB, et al. Severity of chronic kidney disease did not influence bleeding during treatment of acute coronary syndromes. Hawaii Med J. Nov. 2004;63(11):333-6. [pmid: 15633659].
540 Lee D, Goodman SG, Fox KAA, et al. Prognostic significance of presenting blood pressure in non-ST-segment elevation acute coronary syndrome in relation to prior history of hypertension. Am Heart J. 2013.
541 Lee SH, Ha JW, Kim JS, et al. Plasma adiponectin and resistin levels as predictors of mortality in patients with acute myocardial infarction: data from infarction prognosis study registry. Coron Artery Dis. Jan. 2009;20(1):33-9. [pmid: 18997620].
542 Lee SH, Kim YJ, Kim W, et al. Clinical outcomes and therapeutic strategy in patients with acute myocardial infarction according to renal function: data from the Korean Acute Myocardial Infarction Registry. Circ J. Sep. 2008;72(9):1410-8. [pmid: 18724014].
543 Lehmann R, Fichtlscherer S, Schachinger V, et al. Favorable long-term survival in patients undergoing multivessel-PCI compared to predicted prognosis of CABG estimated by EuroSCORE: procedural and clinical determinants of long-term outcome. J Interv Cardiol. Dec. 2009;22(6):511-9. [pmid: 19732282].
544 Lesaffre F, Wynckel A, Nazeyrollas P, et al. Echocardiography to predict adverse cardiac and vascular events in patients with severe chronic kidney disease (stage 4): a prospective study. Arch Cardiovasc Dis. Apr. 2013;106(4):220-7. [pmid: 23706368].
545 Lewis EF, Velazquez EJ, Solomon SD, et al. Predictors of the first heart failure hospitalization in patients who are stable survivors of myocardial infarction complicated by pulmonary congestion and/or left ventricular dysfunction: a VALIANT study. Eur Heart J. Mar. 2008;29(6):748-56. [pmid: 18308687].
546 Lim SY, Bae EH, Choi JS, et al. Percutaneous coronary intervention for acute myocardial infarction in elderly patients with renal dysfunction: results from the Korea Acute Myocardial Infarction Registry. J Korean Med Sci. Jul. 2013;28(7):1027-33. [pmid: 23853485].
547 Limkakeng AT Jr, Chandra A. Impact of renal dysfunction on acute coronary syndrome evaluation in observation unit patients. Am J Emerg Med. Jul. 2010;28(6):658-62. [pmid: 20637379].
548 Lin Z, Gong Q, Zhou Z, et al. Increased plasma CXCL16 levels in patients with chronic kidney diseases. Eur J Clin Invest. Aug. 2011;41(8):836-45. [pmid: 21299552].
549 Liu X, Chen YD, Lu SZ, et al. Analysis of the risk factors of patients with acute coronary syndrome sufferin hemorrhage during hospitalization. Zhonghua Xin Xue Guan Bing Za Zhi. Nov. 2012;40(11):902-7. [pmid: 23363669].
550 Liu YW, Su CT, Chou CC, et al. Association of subtle left ventricular systolic dysfunction with elevated cardiac troponin T in asymptomatic hemodialysis patients with preserved left ventricular ejection fraction. Acta Cardiologica Sinica. 2012;28(2):95-102.
551 Lopez-Cuenca A, Manzano-Fernandez S, Marin F, et al. Beta-Trace Protein and Cystatin C as Predictors of Major Bleeding in Non-ST-Segment Elevation Acute Coronary Syndrome. Circ J. 2013;77(8):2088-96. [pmid: 23698027].
552 Lorusso R, Gelsomino S, De Cicco G, et al. Mitral valve surgery in emergency for severe acute regurgitation: analysis of postoperative results from a multicentre study. Eur J Cardiothorac Surg. Apr. 2008;33(4):573-82. [pmid: 18313322].
553 Lubos E, Messow CM, Schnabel R, et al. Resistin, acute coronary syndrome and prognosis results from the AtheroGene study. Atherosclerosis. Jul. 2007;193(1):121-8. [pmid: 16814296].
554 Lum HD, Studenski SA, Degenholtz HB, et al. Early hospital readmission is a predictor of one-year mortality in community-dwelling older Medicare beneficiaries. J Gen Intern Med. Nov. 2012;27(11):1467-74. [pmid: 22692634].
555 Lum JJ, Madison JR, Seto TB, et al. Management of patients with chronic kidney disease presenting with acute coronary syndrome. Hawaii Med J. Nov. 2004;63(11):330-2. [pmid: 15633658].
556 Luo Y, Li GL, Pan YZ, et al. Determinants and prognostic implications of reperfusion injury during primary percutaneous coronary intervention in Chinese patients with acute myocardial infarction. Clin Cardiol. Mar. 2009;32(3):148-53. [pmid: 19301290].
557 Luo Y, Lu L, Li GL, et al. Analysis on correlative factors for occurrence of myocardial ischemia-reperfusion injury during primary percutaneous coronary intervention for acute myocardial infarction. Zhonghua Xin Xue Guan Bing Za Zhi. Aug. 2005;33(8):691-4. [pmid: 16188049].
558 Ma C, Cao J, Lu XC, et al. Cardiovascular and cerebrovascular outcomes in elderly hypertensive patients treated with either ARB or ACEI. J Geriatr Cardiol. Sep. 2012;9(3):252-7. [pmid: 23097655].
559 Manoukian SV, Feit F, Mehran R, et al. Impact of major bleeding on 30-day mortality and clinical outcomes in patients with acute coronary syndromes: an analysis from the ACUITY Trial. J Am Coll Cardiol. Mar. 27. 2007;49(12):1362-8. [pmid: 17394970].
560 Manzano-Fernandez S, Lopez-Cuenca A, Januzzi JL, et al. Usefulness of beta-trace protein and cystatin C for the prediction of mortality in non ST segment elevation acute coronary syndromes. Am J Cardiol. Nov. 1. 2012;110(9):1240-8. [pmid: 22818840].
561 Marenzi G, Lauri G, Assanelli E, et al. Contrast-induced nephropathy in patients undergoing primary angioplasty for acute myocardial infarction. J Am Coll Cardiol. Nov. 2. 2004;44(9):1780-5. [pmid: 15519007].
562 Marenzi G, Moltrasio M, Assanelli E, et al. Impact of cardiac and renal dysfunction on inhospital morbidity and mortality of patients with acute myocardial infarction undergoing primary angioplasty. Am Heart J. May. 2007;153(5):755-62. [pmid: 17452149].
563 Marouf R, Zubaid M, Mojiminiyi OA, et al. Determinants of plasma homocysteine in relation to hematological and biochemical variables in patients with acute myocardial infarction. South Med J. Aug. 2006;99(8):811-6. [pmid: 16929874].
564 Masoudi FA, Plomondon ME, Magid DJ, et al. Renal insufficiency and mortality from acute coronary syndromes. Am Heart J. Apr. 2004;147(4):623-9. [pmid: 15077076].
565 Matsue Y, Matsumura A, Abe M, et al. Prognostic implications of chronic kidney disease and anemia after percutaneous coronary intervention in acute myocardial infarction patients. Heart Vessels. Jan. 2013;28(1):19-26. [pmid: 22160439].
566 McClellan WM, Langston RD, Presley R. Medicare patients with cardiovascular disease have a high prevalence of chronic kidney disease and a high rate of progression to end-stage renal disease. J Am Soc Nephrol. Jul. 2004;15(7):1912-9. [pmid: 15213281].
567 McCullough PA, Nowak RM, Foreback C, et al. Emergency evaluation of chest pain in patients with advanced kidney disease. Arch Intern Med. Nov. 25. 2002;162(21):2464-8. [pmid: 12437406].
568 McCullough PA, Sandberg KR, Borzak S, et al. Benefits of aspirin and beta-blockade after myocardial infarction in patients with chronic kidney disease. Am Heart J. Aug. 2002;144(2):226-32. [pmid: 12177638].
569 Medi C, Chew DP, Amerena J, et al. An invasive management strategy is associated with improved outcomes in high-risk acute coronary syndromes in patients with chronic kidney disease. Intern Med J. Oct. 2011;41(10):743-50. [pmid: 21040324].
570 Medi C, Montalescot G, Budaj A, et al. Reperfusion in patients with renal dysfunction after presentation with ST-segment elevation or left bundle branch block: GRACE (Global Registry of Acute Coronary Events). JACC Cardiovasc Interv. Jan. 2009;2(1):26-33. [pmid: 19463394].
571 Medina HM, Cannon CP, Fonarow GC, et al. Reperfusion strategies and quality of care in 5339 patients age 80 years or older presenting with ST-elevation myocardial infarction: analysis from get with the guidelines-coronary artery disease. Clin Cardiol. Oct. 2012;35(10):632-40. [pmid: 22744844].
572 Mehran R, Nikolsky E, Lansky AJ, et al. Impact of chronic kidney disease on early (30-day) and late (1-year) outcomes of patients with acute coronary syndromes treated with alternative antithrombotic treatment strategies: an ACUITY (Acute Catheterization and Urgent Intervention Triage strategY) substudy. JACC Cardiovasc Interv. Aug. 2009;2(8):748-57. [pmid: 19695543].
573 Mehta RH, Chen AY, Pollack CV Jr, et al. Challenges in predicting the need for coronary artery bypass grafting at presentation in patients with non-ST-segment elevation acute coronary syndromes. Am J Cardiol. Sep. 1. 2006;98(5):624-7. [pmid: 16923449].
574 Meizels A, Zeitoun DM, Bataille V, et al. Impact of polyvascular disease on baseline characteristics, management and mortality in acute myocardial infarction. The Alliance project. Arch Cardiovasc Dis. Apr. 2010;103(4):207-14. [pmid: 20656631].
575 Mielniczuk LM, Pfeffer MA, Lewis EF, et al. Estimated glomerular filtration rate, inflammation, and cardiovascular events after an acute coronary syndrome. Am Heart J. Apr. 2008;155(4):725-31. [pmid: 18371483].
576 Mihalcea C, Pandele GI. Chronic miocardial infarction among patients with diabetes mellitus or impaired glucose tolerance. Rev Med Chir Soc Med Nat Iasi. Jul-Sep. 2009;113(3):685-91. [pmid: 20191816].
577 Mishkel GJ, Varghese JJ, Moore AL, et al. Short- and long-term clinical outcomes of coronary drug-eluting stent recipients presenting with chronic renal disease. Journal of Invasive Cardiology. 2007;19(8):331-7. [pmid: 17712200].
578 Moody WE, Edwards NC, Chue CD, et al. Arterial disease in chronic kidney disease. Heart. 2013;99(6):365-72. [pmid: 23118349].
579 Moroi M, Tamaki N, Nishimura M, et al. Association between abnormal myocardial fatty acid metabolism and cardiac-derived death among patients undergoing hemodialysis: results from a cohort study in Japan. Am J Kidney Dis. Mar. 2013;61(3):466-75. [pmid: 23201161].
580 Moscucci M, Kline-Rogers E, Share D, et al. Simple bedside additive tool for prediction of in-hospital mortality after percutaneous coronary interventions. Circulation. Jul. 17. 2001;104(3):263-8. [pmid: 11457742].
581 Mota FM, Araujo J, Arruda JA, et al. Clinical outcome of renal transplant patients after coronary stenting. Arq Bras Cardiol. May. 2007;88(5):521-4. [pmid: 17589625].
582 Nabais S, Rocha S, Joao C, et al. Prognostic impact of moderate renal dysfunction in acute coronary syndromes. Rev Port Cardiol. Mar. 2008;27(3):303-12. discussion 15-7. [pmid: 18551917].
583 Nagashima M, Hagiwara N, Koyanagi R, et al. Chronic kidney disease and long-term outcomes of myocardial infarction. Int J Cardiol. Sep. 10. 2013;167(6):2490-5. [pmid: 22569317].
584 Nagashima M, Hagiwara N, Koyanagi R, et al. Chronic kidney disease and long-term outcomes of myocardial infarction. Int J Cardiol. 2012. May. 6. [pmid: 22569317].
585 Naiman N, Cheung AK, Goldfarb-Rumyantzev AS. Familiality of cardiovascular mortality in end-stage renal disease patients. Am J Nephrol. 2009;29(3):237-43. [pmid: 18799871].
586 Naito K, Anzai T, Yoshikawa T, et al. Impact of chronic kidney disease on postinfarction inflammation, oxidative stress, and left ventricular remodeling. J Card Fail. Dec. 2008;14(10):831-8. [pmid: 19041046].
587 Naruse Y, Makuuchi H, Kobayashi T, et al. Coronary artery bypass grafting in patients with dialysis-dependent renal failure. Artif Organs. Apr. 2001;25(4):260-2. [pmid: 11318753].
588 Nayak AK, Kawamura A, Nesto RW, et al. Myocardial infarction as a presentation of clinical in-stent restenosis. Circ J. Aug. 2006;70(8):1026-9. [pmid: 16864936].
589 Newsome BB, McClellan WM, Allison JJ, et al. Racial differences in the competing risks of mortality and ESRD after acute myocardial infarction. Am J Kidney Dis. Aug. 2008;52(2):251-61. [pmid: 18468746].
590 Newsome BB, McClellan WM, Coffey CS, et al. Survival advantage of black patients with kidney disease after acute myocardial infarction. Clin J Am Soc Nephrol. Sep. 2006;1(5):993-9. [pmid: 17699318].
591 Nishida H, Uchikawa S, Chikazawa G, et al. Coronary artery bypass grafting in 105 patients with hemodialysis-dependent renal failure. Artif Organs. Apr. 2001;25(4):268-72. [pmid: 11318755].
592 Nishimura M, Sakoda C, Murakawa M, et al. Oral nicorandil for prevention of cardiac death in hemodialysis patients without obstructive coronary artery disease: a propensity-matched patient analysis. Nephron Clin Pract. 2011;119(4):c301-9. [pmid: 21934329].
593 Nishimura M, Tokoro T, Nishida M, et al. Oral nicorandil to reduce cardiac death after coronary revascularization in hemodialysis patients: a randomized trial. Am J Kidney Dis. Aug. 2009;54(2):307-17. [pmid: 19535190].
594 Nitta Y, Yamamoto R, Yamaguchi Y, et al. Impact of long-acting calcium channel blockers on the prognosis of patients with coronary artery disease with and without chronic kidney disease: A comparison of three drugs. Journal of International Medical Research. 2010;38(1):253-65. [pmid: 20233537].
595 Noh H, Lee SW, Kang SW, et al. Serum C-reactive protein: a predictor of mortality in continuous ambulatory peritoneal dialysis patients. Perit Dial Int. Jul-Aug. 1998;18(4):387-94. [pmid: 10505560].
596 Nurozler F, Kutlu T, Kucuk G. Off-pump CABG in diabetic patients: does insulin dependency matter?. Scand Cardiovasc J. Jan. 2007;41(1):39-43. [pmid: 17365976].
597 Oduncu V, Erkol A, Kurt M, et al. The prognostic value of very low admission LDL-cholesterol levels in ST-segment elevation myocardial infarction compared in statin-pretreated and statin-naive patients undergoing primary percutaneous coronary intervention. Int J Cardiol. 2012. Feb. 1. [pmid: 22305817].
598 Ogita M, Sakakura K, Nakamura T, et al. Association between deteriorated renal function and long-term clinical outcomes after percutaneous coronary intervention. Heart Vessels. Sep. 2012;27(5):460-7. [pmid: 21822708].
599 Oishi K, Nagake Y, Yamasaki H, et al. The significance of atherogenic indices in patients on hemodialysis. Am J Nephrol. Mar-Apr. 2000;20(2):107-15. [pmid: 10773610].
600 Okumura S, Sakakibara M, Hayashida R, et al. Accelerated decline in renal function after acute myocardial infarction in patients with high low-density lipoprotein-cholesterol to high-density lipoprotein-cholesterol ratio. Heart Vessels. 2013. Jan. 29. [pmid: 23358876].
601 Orii K, Hioki M, Iedokoro Y, et al. Prognostic factors affecting clinical outcomes after coronary artery bypass surgery: analysis of patients with chronic kidney disease after 5.9 years of follow-up. J Nippon Med Sch. 2011;78(3):156-65. [pmid: 21720089].
602 Osaka S, Osawa H, Miyazawa M, et al. Immediate and long-term results of coronary artery bypass operation in hemodialysis patients. Artif Organs. Apr. 2001;25(4):252-5. [pmid: 11318751].
603 Palmer SC, Yandle TG, Frampton CM, et al. Renal and cardiac function for long-term (10 year) risk stratification after myocardial infarction. Eur Heart J. Jun. 2009;30(12):1486-94. [pmid: 19389787].
604 Palmerini T, Genereux P, Caixeta A, et al. A new score for risk stratification of patients with acute coronary syndromes undergoing percutaneous coronary intervention: the ACUITY-PCI (Acute Catheterization and Urgent Intervention Triage Strategy-Percutaneous Coronary Intervention) risk score. JACC Cardiovasc Interv. Nov. 2012;5(11):1108-16. [pmid: 23174634].
605 Paoletti E, Bellino D, Marsano L, et al. Effects of ACE inhibitors on long-term outcome of renal transplant recipients: A randomized controlled trial. Transplantation. 2013;95(6):889-95. [pmid: 23380881].
606 Park JJ, Jang HJ, Oh IY, et al. Prognostic Value of Neutrophil to Lymphocyte Ratio in Patients Presenting With ST-Elevation Myocardial Infarction Undergoing Primary Percutaneous Coronary Intervention. Am J Cardiol. 2012. Dec. 27. [pmid: 23273716].
607 Pendyala LK, Torguson R, Loh JP, et al. Comparison of Adverse Outcomes After Contemporary Percutaneous Coronary Intervention in Women Versus Men With Acute Coronary Syndrome. Am J Cardiol. 2013. Jan. 23. [pmid: 23352262].
608 Penko M, Fabjan TH, Bevc S, et al. A prospective study about impact of renal dysfunction and morbidity and mortality on cardiovascular events after ischemic stroke. Cardiol J. 2013. Aug. 30. [pmid: 23799556].
609 Penno G, Solini A, Zoppini G, et al. Hemoglobin A1c variability as an independent correlate of cardiovascular disease in patients with type 2 diabetes: a cross-sectional analysis of the renal insufficiency and cardiovascular events (RIACE) Italian multicenter study. Cardiovasc Diabetol. 2013;12:98. [pmid: 23829205].
610 Peterson PN, Ambardekar AV, Jones PG, et al. Increased mortality among survivors of myocardial infarction with kidney dysfunction: the contribution of gaps in the use of guideline-based therapies. BMC Cardiovasc Disord. 2009;9:29. [pmid: 19586550].
611 Pfister R, Tan D, Thekkanal J, et al. NT-pro-BNP is associated with long-term outcome in a heterogeneous sample of cardiac inpatients. Eur J Intern Med. May. 2007;18(3):215-20. [pmid: 17449394].
612 Pimenta E, Ramos RF, Gun C, et al. Renal function outcome in acute myocardial infarction as a prognostic factor of in-hospital events and at one-year follow-up. Arq Bras Cardiol. Mar. 2006;86(3):170-4. [pmid: 16612442].
613 Pinto de Carvalho L, McCullough PA, Gao F, et al. Renal function and anaemia in acute myocardial infarction. Int J Cardiol. 2013. Jan. 7. [pmid: 23305857].
614 Pitsavos C, Kourlaba G, Panagiotakos DB, et al. Association of creatinine clearance and in-hospital mortality in patients with acute coronary syndromes: the GREECS study. Circ J. Jan. 2007;71(1):9-14. [pmid: 17186971].
615 Pitsavos C, Kurlaba G, Panagiotakos DB, et al. Association of creatinine clearance and in-hospital mortality in patients with acute coronary syndromes - The GREECS study. Circulation Journal. 2007;71(1):9-14. [pmid: 17186971].
616 Podolecki TS, Lenarczyk R, Kowalczyk J, et al. The incidence and risk factors of stroke in patients with acute myocardial infarction treated invasively and concomitant impaired renal function. Cardiol J. 2013. Aug. 30. [pmid: 23677725].
617 Podolecki TS, Lenarczyk RK, Kowalczyk JP, et al. The risk of stroke in patients with acute myocardial infarction treated invasively. Coron Artery Dis. Jan. 2012;23(1):9-15. [pmid: 22064650].
618 Ponniah JP, Shamsul AS, Adam BM. Predictors of mortality in patients with Acute Coronary Syndrome (ACS) undergoing Percutaneous Coronary Intervention (PCI): Insights from National Cardiovascular Disease Database (NCVD), Malaysia. Med J Malaysia. Dec. 2012;67(6):601-5. [pmid: 23770953].
619 Racki S, Zaputovic L, Vujicic B, et al. Comparison of survival between diabetic and non-diabetic patients on maintenance hemodialysis: a single-centre experience. Diabetes Res Clin Pract. Feb. 2007;75(2):169-75. [pmid: 16824639].
620 Racki S, Zaputovic L, Vujicic B, et al. Cardiovascular risk factors and diseases strongly predict hemodialysis treatment outcome in maintenance hemodialysis patients. Croat Med J. Dec. 2005;46(6):936-41. [pmid: 16342347].
621 Rakhit DJ, Armstrong KA, Beller E, et al. Risk stratification of patients with chronic kidney disease: results of screening strategies incorporating clinical risk scoring and dobutamine stress echocardiography. Am Heart J. Aug. 2006;152(2):363-70. [pmid: 16875924].
622 Rakhit DJ, Marwick TH, Armstrong KA, et al. Effect of aggressive risk factor modification on cardiac events and myocardial ischaemia in patients with chronic kidney disease. Heart. Oct. 2006;92(10):1402-8. [pmid: 16606867].
623 Rasty S, Borzak S, Tisdale JE. Bleeding associated with eptifibatide targeting higher risk patients with acute coronary syndromes: incidence and multivariate risk factors. J Clin Pharmacol. Dec. 2002;42(12):1366-73. [pmid: 12463732].
624 Reddan DN, Szczech L, Bhapkar MV, et al. Renal function, concomitant medication use and outcomes following acute coronary syndromes. Nephrol Dial Transplant. Oct. 2005;20(10):2105-12. [pmid: 16030030].
625 Reibis R, Herbstleb J, Kamke W, et al. Renal and cardiac functions as prognostic factors after revascularization for myocardial infarction. Dtsch Med Wochenschr. Jun. 8. 2007;132(23):1259-63. [pmid: 17541867].
626 Rocha S, Nabais S, Magalhaes S, et al. Heart failure after acute coronary syndrome: identify to treat better!. Rev Port Cardiol. Apr. 2007;26(4):349-59. [pmid: 17695730].
627 Rutherford E, Leslie SJ, Soiza RL. Creatinine and eGFR are similarly predictive of outcome of acute coronary syndrome. Int J Cardiol. May. 14. 2010;141(1):118-20. [pmid: 19111358].
628 Rutten JHW, Korevaar JC, Boeschoten EW, et al. B-type natriuretic peptide and amino-terminal atrial natriuretic peptide predict survival in peritoneal dialysis. Peritoneal Dialysis International. 2006;26(5):598-602. [pmid: 16973518].
629 Sachdeva S, Singh NP, Saha R. Impact of renal dysfunction on the outcome of acute myocardial infarction. Journal, Indian Academy of Clinical Medicine. 2010;11(4):277-81.
630 Sadeghi HM, Stone GW, Grines CL, et al. Impact of renal insufficiency in patients undergoing primary angioplasty for acute myocardial infarction. Circulation. Dec. 2. 2003;108(22):2769-75. [pmid: 14638545].
631 Sakai K, Nagayama S, Ihara K, et al. Primary percutaneous coronary intervention for acute myocardial infarction in the elderly aged >/=75 years. Catheter Cardiovasc Interv. Jan. 1. 2012;79(1):50-6. [pmid: 22215567].
632 Saltzman AJ, Stone GW, Claessen BE, et al. Long-term impact of chronic kidney disease in patients with ST-segment elevation myocardial infarction treated with primary percutaneous coronary intervention: the HORIZONS-AMI (Harmonizing Outcomes With Revascularization and Stents in Acute Myocardial Infarction) trial. JACC Cardiovasc Interv. Sep. 2011;4(9):1011-9. [pmid: 21939942].
633 Sanger S, Knorig J. Perioperative outcome and management of patients with dialysis-dependent renal insufficiency undergoing cardiac surgery. Zeitschrift fur Herz-, Thorax- und Gefasschirurgie. 2004;18(4):194-7.
634 Santolucito PA, Tighe DA, McManus DD, et al. Management and outcomes of renal disease and acute myocardial infarction. Am J Med. Sep. 2010;123(9):847-55. [pmid: 20800154].
635 Santopinto JJ, Fox KA, Goldberg RJ, et al. Creatinine clearance and adverse hospital outcomes in patients with acute coronary syndromes: findings from the global registry of acute coronary events (GRACE). Heart. Sep. 2003;89(9):1003-8. [pmid: 12923009].
636 Savic L, Mrdovic I, Perunicic J, et al. Impact of the combined left ventricular systolic and renal dysfunction on one-year outcomes after primary percutaneous coronary intervention. J Interv Cardiol. Apr. 2012;25(2):132-9. [pmid: 22103669].
637 Schiele F, Seronde MF, Descotes-Genon V, et al. Impact of renal dysfunction and glucometabolic status on one month mortality after acute myocardial infarction. Acute Card Care. 2007;9(1):34-42. [pmid: 17453537].
638 Schneider CA, Ferrannini E, Defronzo R, et al. Effect of pioglitazone on cardiovascular outcome in diabetes and chronic kidney disease. J Am Soc Nephrol. Jan. 2008;19(1):182-7. [pmid: 18057215].
639 Schouten O, Hoeks SE, Goei D, et al. Plasma N-terminal pro-B-type natriuretic peptide as a predictor of perioperative and long-term outcome after vascular surgery. J Vasc Surg. Feb. 2009;49(2):435-41. discussion 41-2. [pmid: 19028043].
640 Segev A, Matetzky S, Danenberg H, et al. Contemporary use and outcome of percutaneous coronary interventions in patients with acute coronary syndromes: insights from the 2010 ACSIS and ACSIS-PCI surveys. EuroIntervention. Aug. 2012;8(4):465-9. [pmid: 22917730].
641 Selvarajah S, Fong AY, Selvaraj G, et al. An Asian validation of the TIMI risk score for ST-segment elevation myocardial infarction. PLoS One. 2012;7(7):e40249. [pmid: 22815733].
642 Sendra JM, Sarria-Santamera A, Inigo J, et al. Factors associated with acute myocardial infarction in-hospital mortality. Results of an observational study. Med Clin (Barc). Nov. 12. 2005;125(17):641-6. [pmid: 16324492].
643 Serra A, Izzo A, Tomasi L, et al. Mortality triplicates in acute myocardial infarction patients affected by chronic renal failure. G Ital Nefrol. Mar-Apr. Suppl 45. 2009;26:S12-5. [pmid: 19382088].
644 Seyfarth M, Kastrati A, Mann JF, et al. Prognostic value of kidney function in patients with ST-elevation and non-ST-elevation acute myocardial infarction treated with percutaneous coronary intervention. Am J Kidney Dis. Nov. 2009;54(5):830-9. [pmid: 19592145].
645 Sezai A, Nakata KI, Hata M, et al. Long-Term Results of Dialysis Patients with Chronic Kidney Disease Undergoing Coronary Artery Bypass Grafting. Ann Thorac Cardiovasc Surg. 2013. Feb. 15. [pmid: 23411841].
646 Shao CL, Qiao SB, Zhu J, et al. Impact of timing of intervention on prognosis of non-ST segment elevation acute coronary syndrome patients with renal dysfunction. Zhonghua Yi Xue Za Zhi. Sep. 14. 2010;90(34):2380-4. [pmid: 21092504].
647 Shaw JA, Andrianopoulos N, Duffy S, et al. Renal impairment is an independent predictor of adverse events post coronary intervention in patients with and without drug-eluting stents. Cardiovasc Revasc Med. Oct-Dec. 2008;9(4):218-23. [pmid: 18928945].
648 Shaya FT, Gu A, Yan X. Effect of Persistence with Drug Therapy On the Risk of Myocardial Re-infarction. P T. May. 2008;33(5):288-95. [pmid: 19561792].
649 Shibui T, Nakagomi A, Kusama Y, et al. Impact of statin therapy on renal function and long-term prognosis in acute coronary syndrome patients with chronic kidney disease. Int Heart J. 2010;51(5):312-8. [pmid: 20966602].
650 Shiga T, Kasanuki H, Hagiwara N, et al. Angiotensin receptor blocker-based therapy and cardiovascular events in hypertensive patients with coronary artery disease and impaired renal function. Blood Press. Dec. 2010;19(6):359-65. [pmid: 20491606].
651 Shiraishi J, Kohno Y, Sawada T, et al. Prognostic impact of pulse pressure at admission on in-hospital outcome after primary percutaneous coronary intervention for acute myocardial infarction. Heart Vessels. 2012. Aug. 28. [pmid: 22926409].
652 Shiraishi J, Kohno Y, Sawada T, et al. Prognostic impact of systolic blood pressure at admission on in-hospital outcome after primary percutaneous coronary intervention for acute myocardial infarction. J Cardiol. Aug. 2012;60(2):139-44. [pmid: 22521431].
653 Shlipak MG, Simon JA, Grady D, et al. Renal insufficiency and cardiovascular events in postmenopausal women with coronary heart disease. J Am Coll Cardiol. Sep. 2001;38(3):705-11. [pmid: 11527621].
654 Simms AD, Reynolds S, Pieper K, et al. Evaluation of the NICE mini-GRACE risk scores for acute myocardial infarction using the Myocardial Ischaemia National Audit Project (MINAP) 2003-2009: National Institute for Cardiovascular Outcomes Research (NICOR). Heart. Jan. 2013;99(1):35-40. [pmid: 23002253].
655 Skali H, Uno H, Levey AS, et al. Prognostic assessment of estimated glomerular filtration rate by the new Chronic Kidney Disease Epidemiology Collaboration equation in comparison with the Modification of Diet in Renal Disease Study equation. Am Heart J. Sep. 2011;162(3):548-54. [pmid: 21884875].
656 Smith GL, Masoudi FA, Shlipak MG, et al. Renal impairment predicts long-term mortality risk after acute myocardial infarction. J Am Soc Nephrol. Jan. 2008;19(1):141-50. [pmid: 18003773].
657 Solak Y, Yilmaz MI, Sonmez A, et al. Neutrophil to lymphocyte ratio independently predicts cardiovascular events in patients with chronic kidney disease. Clin Exp Nephrol. Aug. 2013;17(4):532-40. [pmid: 23180042].
658 Son J, Hur SH, Kim IC, et al. The impact of moderate to severe renal insufficiency on patients with acute myocardial infarction. Korean Circ J. Jun. 2011;41(6):308-12. [pmid: 21779283].
659 Sooklim K, Srimahachota S, Boonyaratavej S, et al. Renal dysfunction as an independent predictor of total mortality after acute coronary syndrome: the Thai ACS Registry. J Med Assoc Thai. Oct. Suppl 1. 2007;90:32-40. [pmid: 18431884].
660 Steffenino G, Chinaglia A, Noussan P, et al. Care of acute myocardial infarction in the coronary care units of Piedmont in 2007: results from the ‘PRIMA_sweet’ region-wide survey. J Cardiovasc Med (Hagerstown). May. 2013;14(5):354-63. [pmid: 23941892].
661 Suzuki M, Seike F, Miyoshi A, et al. Critical role of systemic inflammation in patients with ST-segment elevation myocardial infarction complicated with renal dysfunction. Int J Cardiol. 2013. Apr. 30. [pmid: 23642593].
662 Szczech LA, Reddan DN, Owen WF, et al. Differential survival after coronary revascularization procedures among patients with renal insufficiency. Kidney Int. Jul. 2001;60(1):292-9. [pmid: 11422764].
663 Szummer K, Lundman P, Jacobson SH, et al. Influence of renal function on the effects of early revascularization in non-ST-elevation myocardial infarction: data from the Swedish Web-System for Enhancement and Development of Evidence-Based Care in Heart Disease Evaluated According to Recommended Therapies (SWEDEHEART). Circulation. Sep. 8. 2009;120(10):851-8. [pmid: 19704097].
664 Szummer K, Lundman P, Jacobson SH, et al. Relation between renal function, presentation, use of therapies and in-hospital complications in acute coronary syndrome: data from the SWEDEHEART register. J Intern Med. Jul. 2010;268(1):40-9. [pmid: 20210836].
665 Takahashi A, Takase H, Toriyama T, et al. Candesartan, an angiotensin II type-1 receptor blocker, reduces cardiovascular events in patients on chronic haemodialysis--a randomized study. Nephrol Dial Transplant. Sep. 2006;21(9):2507-12. [pmid: 16766543].
666 Takamura T, Takahashi N, Ishigami T, et al. Combining chronic kidney disease with 201thallium/123iodine beta methyliodophenyl pentadecanoic acid dual myocardial single-photon emission computed tomography findings is useful for the evaluation of cardiac event risk. Nucl Med Commun. Jan. 2009;30(1):54-61. [pmid: 19306514].
667 Takeuchi I, Moriguchi M, Imaki R, et al. Hemodialysis is an independent predictor of coronary in-stent restenosis after paclitaxel eluting stent implantation. Internal Medicine. 2010;49(22):2379-84. [pmid: 21088337].
668 Tanaka Y, Joki N, Hase H. History of acute coronary events during the predialysis phase of chronic kidney disease is a strong risk factor for major adverse cardiac events in patients initiating haemodialysis. Nephrology Dialysis Transplantation. 2007;22(10):2917-23.
669 Tang WH, Iqbal N, Wu Y, et al. Usefulness of cardiac biomarker score for risk stratification in stable patients undergoing elective cardiac evaluation across glycemic status. Am J Cardiol. Feb. 15. 2013;111(4):465-70. [pmid: 23219176].
670 Tang WH, Wu Y, Nicholls SJ, et al. Subclinical myocardial necrosis and cardiovascular risk in stable patients undergoing elective cardiac evaluation. Arterioscler Thromb Vasc Biol. Mar. 2010;30(3):634-40. [pmid: 20032289].
671 Tay ELW, Chan M, Tan V, et al. Relation between combining evidence-based medications on mortality following myocardial infarction in patients with and without renal impairment. Acta Cardiol. 2010;65(2):211-6. [pmid: 20458829].
672 Teixeira R, Lourenco C, Baptista R, et al. Invasive versus conservative strategy in non-sT elevation acute coronary syndromes: data from a single Portuguese center. Rev Port Cardiol. Apr. 2009;28(4):355-73. [pmid: 19634494].
673 Thiele H, Zeymer U, Neumann FJ, et al. Intraaortic balloon support for myocardial infarction with cardiogenic shock. N Engl J Med. Oct. 4. 2012;367(14):1287-96. [pmid: 22920912].
674 Timoteo AT, Fiarresga A, Feliciano J, et al. The prognostic impact of renal failure in patients with ST-segment elevation acute myocardial infarction. Kardiol Pol. Oct. 2005;63(4):373-8. discussion 9-80. [pmid: 16273475].
675 Tobbia P, Brodie BR, Witzenbichler B, et al. Adverse event rates following primary PCI for STEMI at US and non-US hospitals: three-year analysis from the HORIZONS-AMI trial. EuroIntervention. Feb. 22. 2013;8(10):1134-42. [pmid: 23425539].
676 Tomaszuk-Kazberuk A, Kozuch M, Malyszko J, et al. Which method of GFR estimation has the best prognostic value in patients treated with primary PCI: Cockcroft-Gault formula, MDRD, or CKD-EPI equation?--A 6-year follow-up. Ren Fail. 2011;33(10):983-9. [pmid: 22013931].
677 Tong PC, Kong AP, So WY, et al. Hematocrit, independent of chronic kidney disease, predicts adverse cardiovascular outcomes in chinese patients with type 2 diabetes. Diabetes Care. Nov. 2006;29(11):2439-44. [pmid: 17065681].
678 Trespalacios FC, Taylor AJ, Agodoa LY, et al. Incident acute coronary syndromes in chronic dialysis patients in the United States. Kidney Int. Nov. 2002;62(5):1799-805. [pmid: 12371982].
679 Tsagalis G, Akrivos T, Alevizaki M, et al. Renal dysfunction in acute stroke: an independent predictor of long-term all combined vascular events and overall mortality. Nephrol Dial Transplant. Jan. 2009;24(1):194-200. [pmid: 18728156].
680 Valentijn TM, Hoeks SE, Martienus KA, et al. Impact of haemoglobin concentration on cardiovascular outcome after vascular surgery: A retrospective observational cohort study. Eur J Anaesthesiol. 2013. Jun. 1. [pmid: 23736094].
681 Vasaiwala S, Cannon CP, Fonarow GC, et al. Quality of care and outcomes among patients with acute myocardial infarction by level of kidney function at admission: report from the get with the guidelines coronary artery disease program. Clin Cardiol. Sep. 2012;35(9):541-7. [pmid: 22744797].
682 Vasu S, Gruberg L, Brown DL. The impact of advanced chronic kidney disease on in-hospital mortality following percutaneous coronary intervention for acute myocardial infarction. Catheter Cardiovasc Interv. Nov. 1. 2007;70(5):701-5. [pmid: 17932900].
683 Vis MM, Engstrom AE, Sjauw KD, et al. Plasma glucose and not hemoglobin or renal function predicts mortality in patients with STEMI complicated with cardiogenic shock. J Cardiovasc Med (Hagerstown). Nov. 2010;11(11):827-31. [pmid: 20686421].
684 Vis MM, VdS RJ, Sjauw KD, et al. Creatinine clearance is independently associated with one year mortality in a primary PCI cohort with cardiogenic shock. Acute Card Care. 2009;11(2):107-12. [pmid: 19449237].
685 Vogt A, Schoelmerich A, Pollner F, et al. Comparison of outcome in 1809 patients treated with drug-eluting stents or bare-metal stents in a real-world setting. Vasc Health Risk Manag. 2011;7:693-9. [pmid: 22174579].
686 Wallmann R, Llorca J, Gomez-Acebo I, et al. Prediction of 30-day cardiac-related-emergency-readmissions using simple administrative hospital data. Int J Cardiol. Apr. 5. 2013;164(2):193-200. [pmid: 21775001].
687 West AJ, Dixon SR, Kahn JK, et al. Effectiveness of primary angioplasty for acute myocardial infarction in patients on dialysis. Am J Cardiol. Feb. 15. 2004;93(4):468-70. [pmid: 14969626].
688 Wetmore JB, Sankaran S, Jones PG, et al. Association of decreased glomerular filtration rate with racial differences in survival after acute myocardial infarction. Clin J Am Soc Nephrol. Apr. 2011;6(4):733-40. [pmid: 21310822].
689 Williams ES, Thompson VP, Chiswell KE, et al. Rate versus rhythm control and outcomes in patients with atrial fibrillation and chronic kidney disease: Data from the GUSTO-III Trial. Cardiol J. 2013;20(4):439-46. [pmid: 23913464].
690 Wison S, Foo K, Cunningham J, et al. Renal function and risk stratification in acute coronary syndromes. Am J Cardiol. May. 1. 2003;91(9):1051-4. [pmid: 12714145].
691 Wodzig KW, Kragten JA, Hermens WT, et al. Estimation of myocardial infarct size from plasma myoglobin or fatty acid-binding protein. Influence of renal function. Eur J Clin Chem Clin Biochem. Mar. 1997;35(3):191-8. [pmid: 9127740].
692 Wohrle J, Nusser T, Mayer C, et al. Intracoronary application of abciximab in patients with ST-elevation myocardial infarction. EuroIntervention. Jan. 2008;3(4):465-9. [pmid: 19736089].
693 Wong JA, Goodman SG, Yan RT, et al. Temporal management patterns and outcomes of non-ST elevation acute coronary syndromes in patients with kidney dysfunction. Eur Heart J. Mar. 2009;30(5):549-57. [pmid: 19201761].
694 Wong PN, Mak SK, Lo KY, et al. Adverse prognostic indicators in continuous ambulatory peritoneal dialysis patients without obvious vascular or nutritional comorbidities. Perit Dial Int. Dec. Suppl 2. 2003;23:S109-15. [pmid: 17986527].
695 Woo J, Lacbawan FL, Sunheimer R, et al. Is myoglobin useful in the diagnosis of acute myocardial infarction in the emergency department setting?. Am J Clin Pathol. Jun. 1995;103(6):725-9. [pmid: 7785657].
696 Woo YM, McLean D, Kavanagh D, et al. The influence of pre-operative electrocardiographic abnormalities and cardiovascular risk factors on patient and graft survival following renal transplantation. J Nephrol. Jul-Aug. 2002;15(4):380-6. [pmid: 12243367].
697 Wright RS, Reeder GS, Herzog CA, et al. Acute myocardial infarction and renal dysfunction: a high-risk combination. Ann Intern Med. Oct. 1. 2002;137(7):563-70. [pmid: 12353943].
698 Wu X, Yang D, Zhao Y, et al. Effectiveness of percutaneous coronary intervention within 12 hours to 28 days of ST-elevation myocardial infarction in a real-world Chinese population. PLoS One. 2013;8(3):e58382. [pmid: 23554888].
699 Yamaguchi J, Kasanuki H, Ishii Y, et al. Serum creatinine on admission predicts long-term mortality in acute myocardial infarction patients undergoing successful primary angioplasty: data from the Heart Institute of Japan Acute Myocardial Infarction (HIJAMI) Registry. Circ J. Sep. 2007;71(9):1354-9. [pmid: 17721010].
700 Yamaguchi J, Kasanuki H, Ishii Y, et al. Prognostic significance of serum creatinine concentration for in-hospital mortality in patients with acute myocardial infarction who underwent successful primary percutaneous coronary intervention (from the Heart Institute of Japan Acute Myocardial Infarction [HIJAMI] Registry). Am J Cardiol. Jun. 15. 2004;93(12):1526-8. [pmid: 15194026].
701 Yan AT, Yan RT, Tan M, et al. Treatment and one-year outcome of patients with renal dysfunction across the broad spectrum of acute coronary syndromes. Can J Cardiol. Feb. 2006;22(2):115-20. [pmid: 16485045].
702 Yan AT, Yan RT, Tan M, et al. Optimal medical therapy at discharge in patients with acute coronary syndromes: temporal changes, characteristics, and 1-year outcome. Am Heart J. Dec. 2007;154(6):1108-15. [pmid: 18035083].
703 Yano H, Horinaka S, Yagi H, et al. Comparison of inflammatory response after implantation of sirolimus- and paclitaxel-eluting stents in patients on hemodialysis. Heart Vessels. 2013;28(3):308-15. [pmid: 22526379].
704 Yoda S, Nakanishi K, Tano A, et al. Risk stratification of cardiovascular events in patients at all stages of chronic kidney disease using myocardial perfusion SPECT. J Cardiol. Nov. 2012;60(5):377-82. [pmid: 22890072].
705 Young Altahan R, Goldenberg I, Kimron L, et al. Timing of coronary angiography and outcome in patients with non-ST elevation acute coronary syndromes and kidney disease: real-world data from the acute coronary syndromes Israeli survey. Cardiology. 2011;119(4):224-34. [pmid: 22041637].
706 Zahn R, Hamm CW, Schneider S, et al. Predictors of death or myocardial infarction during follow-up after coronary stenting with the sirolimus-eluting stent. Results from the prospective multicenter German Cypher Stent Registry. Am Heart J. Dec. 2006;152(6):1146-52. [pmid: 17161068].
707 Zdzienicka J, Siudak Z, Zawislak B, et al. Patients with non-ST-elevation myocardial infarction and without chest pain are treated less aggressively and experience higher in-hospital mortality. Kardiol Pol. Jul. 2007;65(7):769-75. discussion 76-7. [pmid: 17694458].
708 Zeman K, Pohludkova L, Spinar J, et al. Short-term prognosis and treatment of patients hospitalized for acute heart failure in a regional hospital without a cardiocentre. Vnitr Lek. Apr. 2012;58(4):273-9. [pmid: 22559800].
709 Zhang Q, Shen WF, Zhang JS, et al. Coronary stenting in patients with acute coronary syndrome and renal dysfunction. Zhonghua Nei Ke Za Zhi. Feb. 2004;43(2):106-8. [pmid: 15059406].
710 Zhang Q, Zhang RY, Shen J, et al. Impact of admission creatinine level on clinical outcomes of patients with acute ST-elevation myocardial infarction undergoing primary percutaneous coronary intervention with drug-eluting stent implantation. Chin Med J (Engl). Dec. 5. 2008;121(23):2379-83. [pmid: 19102952].
711 Zhao FH, Chen YD, Song XT, et al. Predictive factors of recurrent angina after acute coronary syndrome: the global registry acute coronary events from China (Sino-GRACE). Chin Med J (Engl). Jan. 5. 2008;121(1):12-6. [pmid: 18208658].
712 Zhao WS, Li KB, Zhang Y, et al. The in-hospital mortality and its determinants for very elderly patients with acute myocardial infarction. Zhonghua Nei Ke Za Zhi. Dec. 2011;50(12):1023-5. [pmid: 22333170].
713 Zhu HN, Huo Y, Jiang J, et al. Analysis of prognostic patients with non-ST-segment elevation acute myocardial infarction and clinical characteristics of those with renal dysfunction. Beijing Da Xue Xue Bao. Oct. 18. 2008;40(5):533-7. [pmid: 18931720].
714 Zouaoui W, Ouldzein H, Boudou N, et al. Factors predictive for in-hospital mortality following percutaneous coronary intervention. Arch Cardiovasc Dis. Jul-Aug. 2008;101(7-8):443-8. [pmid: 18848686].

## Troponin or CKD Not Reported Separately

715 Ahmed E, El-Menyar A, Singh R, et al. Effect of Age on Clinical Presentation and Outcome of Patients Hospitalized with Acute Coronary Syndrome: A 20-Year Registry in a Middle Eastern Country. Open Cardiovasc Med J. 2012;6:60-7. [pmid: 22670161].
716 Akerblom A, Wallentin L, Larsson A, et al. Cystatin C- and Creatinine-Based Estimates of Renal Function and Their Value for Risk Prediction in Patients with Acute Coronary Syndrome: Results from the PLATelet Inhibition and Patient Outcomes (PLATO) Study. Clin Chem. Sep. 2013;59(9):1369-75. [pmid: 23698074].
717 Alcock RF, Kouzios D, Naoum C, et al. Perioperative myocardial necrosis in patients at high cardiovascular risk undergoing elective non-cardiac surgery. Heart. May. 2012;98(10):792-8. [pmid: 22543837].
718 Alfaleh HF, Alsuwaida AO, Ullah A, et al. The prognostic impact of in-hospital worsening of renal function in patients with acute coronary syndrome. Int J Cardiol. 2012. Feb. 18. [pmid: 22349044].
719 Alfaleh HF, Alsuwaida AO, Ullah A, et al. The prognostic impact of in-hospital worsening of renal function in patients with acute coronary syndrome. Int J Cardiol. Aug. 10. 2013;167(3):866-70. [pmid: 22349044].
720 Al-Rasadi K, Al-Zakwani I, Zubaid M, et al. Prevalence, Predictors, and Impact of Low High-Density Lipoprotein Cholesterol on in-Hospital Outcomes Among Acute Coronary Syndrome Patients in the Middle East. Open Cardiovasc Med J. 2011;5:203-9. [pmid: 21966331].
721 Amin AP, Spertus JA, Reid KJ, et al. The prognostic importance of worsening renal function during an acute myocardial infarction on long-term mortality. Am Heart J. Dec. 2010;160(6):1065-71. [pmid: 21146659].
722 Andrews N, Jenkins J, Andrews G, et al. Using postoperative cardiac Troponin-I (cTi) levels to detect myocardial ischaemia in patients undergoing vascular surgery. Cardiovasc Surg. Jun. 2001;9(3):254-65. [pmid: 11336849].
723 Apple FS, Ler R, Chung AY, et al. Point-of-care i-STAT cardiac troponin I for assessment of patients with symptoms suggestive of acute coronary syndrome. Clin Chem. Feb. 2006;52(2):322-5. [pmid: 16449217].
724 Apple FS, Pearce LA, Chung A, et al. Multiple biomarker use for detection of adverse events in patients presenting with symptoms suggestive of acute coronary syndrome. Clin Chem. May. 2007;53(5):874-81. [pmid: 17384009].
725 Audimooolam VK, McPhail MJ, Sherwood R, et al. Elevated troponin I and its prognostic significance in acute liver failure. Crit Care. Nov. 28. 2012;16(6):R228. [pmid: 23190744].
726 Azzazy HM, Duh SH, Fitzgerald RL, et al. Multisite study of a second generation whole blood rapid assay for cardiac troponin T. Ann Clin Biochem. Jul. 1999;36(Pt 4):438-46. [pmid: 10456205].
727 Bargnoux AS, Morena M, Jaussent I, et al. A combined index of cardiac biomarkers as a risk factor for early cardiovascular mortality in hemodialysis patients. Clin Chem Lab Med. Sep. 1. 2013;51(9):1865-74. [pmid: 23399590].
728 Barra S, Providencia R, Lourenco Gomes P, et al. Prediction of cerebrovascular event risk following myocardial infarction. Rev Port Cardiol. Jul. 2011;30(7-8):655-63. [pmid: 22005309].
729 Biegus J, Zymlinski R, Szachniewicz J, et al. Clinical characteristics and predictors of in-hospital mortality in 270 consecutive patients hospitalised due to acute heart failure in a single cardiology centre during one year. Kardiol Pol. 2011;69(10):997-1005. [pmid: 22006596].
730 Blasco L, Sanjuan R, Carbonell N, et al. Estimated Glomerular Filtration Rate in Short-Risk Stratification in Acute Myocardial Infarction. Cardiorenal Med. 2011;1(2):131-8. [pmid: 22258400].
731 Bonnefoy E, Godon P, Kirkorian G, et al. Significance of serum troponin I elevation in patients with acute aortic dissection of the ascending aorta. Acta Cardiol. Apr. 2005;60(2):165-70. [pmid: 15887472].
732 Brizuela Sanz JA, Gonzalez Fajardo JA, Fuentes LM, et al. Mortality in patients undergoing open aortoiliac surgery: prognostic value of troponin T in the immediate postoperative period. Ann Vasc Surg. Aug. 2010;24(6):747-51. [pmid: 20472389].
733 Burton JO, Jefferies HJ, Selby NM, et al. Hemodialysis-induced cardiac injury: determinants and associated outcomes. Clin J Am Soc Nephrol. May. 2009;4(5):914-20. [pmid: 19357245].
734 Cabrerizo Garcia JL, Zalba Etayo B, Perez Calvo JI. Prognostic value of occult renal failure in the acute coronary syndrome. Rev Clin Esp. Apr. 2010;210(4):204-6. [pmid: 20304391].
735 Cakar MA, Gunduz H, Vatan MB, et al. The effect of admission creatinine levels on one-year mortality in acute myocardial infarction. ScientificWorldJournal. 2012;2012:186495. [pmid: 22619619].
736 Calzavacca P, Licari E, Tee A, et al. Point-of-care testing during medical emergency team activations: a pilot study. Resuscitation. Sep. 2012;83(9):1119-23. [pmid: 22353639].
737 Cauliez B, Hue G, Lavoinne A. Assay of cardiac troponin T on Elecsys 2010: comparison with cardiac troponin I. Ann Biol Clin (Paris). Nov-Dec. 1998;56(6):711-5. [pmid: 9853030].
738 Chang AM, Edwards M, Matsuura AC, et al. Relationship between renal dysfunction and outcomes in emergency department patients with potential acute coronary syndromes. Emerg Med J. Feb. 2013;30(2):101-5. [pmid: 22396383].
739 Chang SN, Hwang JJ, Chen YS, et al. Clinical experience with intra-aortic balloon counterpulsation over 10 years: a retrospective cohort study of 459 patients. Resuscitation. Jun. 2008;77(3):316-24. [pmid: 18314247].
740 Chen RZ, Bu LP, Yu Y, et al. Relationship between serum cTnI/cTnT in patients with chronic heart failure and different cardiovascular diseases. Fudan University Journal of Medical Sciences. 2005;32(6):653-6.
741 Chiostri M, Valente S, Crudeli E, et al. A new post-PCI scoring system for in-hospital mortality in STEMI patients. J Cardiovasc Med (Hagerstown). Oct. 2010;11(10):733-8. [pmid: 20479658].
742 Choi JS, Kim CS, Park JW, et al. Renal dysfunction as a risk factor for painless myocardial infarction: results from Korea Acute Myocardial Infarction Registry. Clin Res Cardiol. Oct. 2012;101(10):795-803. [pmid: 22555520].
743 Choi SY, Lee JE, Jang EH, et al. Association between changes in N-terminal pro-brain natriuretic peptide levels and changes in left ventricular mass index in stable hemodialysis patients. Nephron Clin Pract. 2008;110(2):c93-100. [pmid: 18815449].
744 Chong C, Lam Q, Ryan J, et al. Impact of troponin 1 on long-term mortality after emergency orthopaedic surgery in older patients. Intern Med J. Nov. 2010;40(11):751-6. [pmid: 19811558].
745 Chow GV, Hirsch GA, Spragg DD, et al. Prognostic significance of cardiac troponin I levels in hospitalized patients presenting with supraventricular tachycardia. Medicine (Baltimore). May. 2010;89(3):141-8. [pmid: 20453600].
746 Christenson RH, Duh SH, Newby LK, et al. Cardiac troponin T and cardiac troponin I: relative values in short-term risk stratification of patients with acute coronary syndromes. GUSTO-IIa Investigators. Clin Chem. Mar. 1998;44(3):494-501. [pmid: 9510853].
747 Chrysohoou C, Pitsavos C, Aggelopoulos P, et al. Brain natriuretic peptide mediates the effect of creatinine clearance on development of left ventricular systolic dysfunction in patients with acute coronary syndrome. Hellenic J Cardiol. Sep-Oct. 2010;51(5):413-20. [pmid: 20876054].
748 Clark GH, Kennon SR, Price CP. Evaluation of a new troponin I method on the Bayer Immuno 1 immunoassay analyser. J Immunoassay. Nov. 1999;20(4):253-73. [pmid: 10595858].
749 Damman P, Kikkert WJ, Woudstra P, et al. Gender difference in the prognostic value of estimated glomerular filtration rate at admission in ST-segment elevation myocardial infarction: a prospective cohort study. BMJ Open. 2012;2(2):e000322. [pmid: 22389358].
750 de Lemos JA, Drazner MH, Omland T, et al. Association of troponin T detected with a highly sensitive assay and cardiac structure and mortality risk in the general population. JAMA. Dec. 8. 2010;304(22):2503-12. [pmid: 21139111].
751 De Mauri A, Bellomo G, Navino C, et al. Plasma B-type natriuretic peptide in dialyzed patients: marker of cardiovascular disease or link to plasma refilling. J Nephrol. Jul-Aug. 2011;24(4):507-14. [pmid: 21240867].
752 DeFilippi CR, Fink JC, Nass CM, et al. N-terminal pro-B-type natriuretic peptide for predicting coronary disease and left ventricular hypertrophy in asymptomatic CKD not requiring dialysis. Am J Kidney Dis. Jul. 2005;46(1):35-44. [pmid: 15983955].
753 deFilippi CR, Thorn EM, Aggarwal M, et al. Frequency and cause of cardiac troponin T elevation in chronic hemodialysis patients from study of cardiovascular magnetic resonance. Am J Cardiol. Sep. 1. 2007;100(5):885-9. [pmid: 17719339].
754 Dragu R, Behar S, Sandach A, et al. Should primary percutaneous coronary intervention be the preferred method of reperfusion therapy for patients with renal failure and ST-elevation acute myocardial infarction?. Am J Cardiol. Apr. 15. 2006;97(8):1142-5. [pmid: 16616015].
755 Eggers KM, Dellborg M, Oldgren J, et al. Risk prediction in chest pain patients by biochemical markers including estimates of renal function. Int J Cardiol. Aug. 18. 2008;128(2):207-13. [pmid: 17662484].
756 Ekart R, Kanic V, Pecovnik Balon B, et al. Prognostic value of 48-hour ambulatory blood pressure measurement and cardiovascular mortality in hemodialysis patients. Kidney Blood Press Res. 2012;35(5):326-31. [pmid: 22398387].
757 Eubanks A, Raza F, Alkhouli M, et al. Clinical significance of troponin elevations in acute decompensated diabetes without clinical acute coronary syndrome. Cardiovasc Diabetol. 2012;11.
758 Everett BM, Cook NR, Magnone MC, et al. Sensitive cardiac troponin T assay and the risk of incident cardiovascular disease in women with and without diabetes mellitus: the Women's Health Study. Circulation. Jun. 21. 2011;123(24):2811-8. [pmid: 21632491].
759 Fernandez-Reyes MJ, Heras M, Sanchez R, et al. Value of troponin T in patients with advanced chronic kidney failure. Clinical course after beginning hemodialysis. Nefrologia. 2005;25(5):574-5. [pmid: 16392311].
760 Fox CS, Muntner P, Chen AY, et al. Use of evidence-based therapies in short-term outcomes of ST-segment elevation myocardial infarction and non-ST-segment elevation myocardial infarction in patients with chronic kidney disease: a report from the National Cardiovascular Data Acute Coronary Treatment and Intervention Outcomes Network registry. Circulation. Jan. 26. 2010;121(3):357-65. [pmid: 20065168].
761 Furuhashi M, Ura N, Hasegawa K, et al. Serum ratio of heart-type fatty acid-binding protein to myoglobin. A novel marker of cardiac damage and volume overload in hemodialysis patients. Nephron Clin Pract. 2003;93(2):C69-74. [pmid: 12616033].
762 Garcia Acuna JM, Gonzalez-Babarro E, Grigorian Shamagian L, et al. Cystatin C provides more information than other renal function parameters for stratifying risk in patients with acute coronary syndrome. Rev Esp Cardiol. May. 2009;62(5):510-9. [pmid: 19406065].
763 Goicoechea M, de Vinuesa SG, Gomez-Campdera F, et al. Predictive cardiovascular risk factors in patients with chronic kidney disease (CKD). Kidney Int Suppl. Jan. 2005;(93):S35-8. [pmid: 15613066].
764 Greenberg G, Assali A, Assa-Vaknin H, et al. Outcome of patients presenting with ST elevation myocardial infarct and cardiogenic shock: a contemporary single center's experience. Cardiology. 2012;122(2):83-8. [pmid: 22739496].
765 Greenslade JH, Cullen L, Kalinowski L, et al. Examining renal impairment as a risk factor for acute coronary syndrome: a prospective observational study. Ann Emerg Med. Jul. 2013;62(1):38-46 e1. [pmid: 23541630].
766 Hafner G, Peetz D, Dati F, et al. Analytical and clinical evaluation of troponin I determination on dimension RXL-HM. Clin Chem Lab Med. Apr. 2000;38(4):355-61. [pmid: 10928657].
767 Hanna EB, Chen AY, Roe MT, et al. Characteristics and in-hospital outcomes of patients presenting with non-ST-segment elevation myocardial infarction found to have significant coronary artery disease on coronary angiography and managed medically: stratification according to renal function. Am Heart J. Jul. 2012;164(1):52-7 e1. [pmid: 22795282].
768 Hanna EB, Chen AY, Roe MT, et al. Characteristics and in-hospital outcomes of patients with non-ST-segment elevation myocardial infarction and chronic kidney disease undergoing percutaneous coronary intervention. JACC Cardiovasc Interv. Sep. 2011;4(9):1002-8. [pmid: 21939940].
769 Harada RK, Eagle KA, Kline-Rogers EM, et al. Low utilization of secondary preventive medications and its potential impact in patients with chronic kidney disease and acute coronary syndromes. Indian Heart J. May-Jun. 2006;58(3):222-9. [pmid: 19033620].
770 Heitner JF, Curtis JP, Haq SA, et al. The significance of elevated troponin T in patients with nondialysis-dependent renal insufficiency: a validation with coronary angiography. Clin Cardiol. Jul. 2005;28(7):333-6. [pmid: 16075826].
771 Hermsen D, Apple F, Garcia-Beltran L, et al. Results from a multicenter evaluation of the 4th generation Elecsys Troponin T assay. Clin Lab. 2007;53(1-2):1-9. [pmid: 17323819].
772 Hoiseth A, Neukamm A, Brekke PH, et al. Prognostic value of troponin T in COPD exacerbation. Am J Respir Crit Care Med. 2010;181(1).
773 Hollander JE, Levitt MA, Young GP, et al. Effect of recent cocaine use on the specificity of cardiac markers for diagnosis of acute myocardial infarction. Am Heart J. Feb. 1998;135(2 Pt 1):245-52. [pmid: 9489972].
774 Hossein-Nia M, Anderson JR, Corbishley C, et al. Cardiac troponin T release following cardiac transplantation. European Journal of Laboratory Medicine. 1995;3(3):239-43.
775 Hudson MP, O'Connor CM, Gattis WA, et al. Implications of elevated cardiac troponin T in ambulatory patients with heart failure: a prospective analysis. Am Heart J. Mar. 2004;147(3):546-52. [pmid: 14999208].
776 Hur SJ, Kim DM, Lim KH, et al. Vitamin D levels and their relationship with cardiac biomarkers in chronic hemodialysis patients. J Korean Med Sci. Jan. Suppl. 2009;24:S109-14. [pmid: 19194538].
777 Ilva TJ, Eskola MJ, Nikus KC, et al. The etiology and prognostic significance of cardiac troponin I elevation in unselected emergency department patients. J Emerg Med. Jan. 2010;38(1):1-5. [pmid: 18687565].
778 Jacob J, Martin-Sanchez FJ, Herrero P, et al. Prognostic value of troponin in patients with acute heart failure attended in Spanish Emergency Departments: TROPICA study (TROPonin in acute heart failure). Med Clin (Barc). 2012. Oct. 30. [pmid: 23122607].
779 James S, Budaj A, Aylward P, et al. Ticagrelor versus clopidogrel in acute coronary syndromes in relation to renal function: results from the Platelet Inhibition and Patient Outcomes (PLATO) trial. Circulation. Sep. 14. 2010;122(11):1056-67. [pmid: 20805430].
780 James SK, Lindahl B, Siegbahn A, et al. N-terminal pro-brain natriuretic peptide and other risk markers for the separate prediction of mortality and subsequent myocardial infarction in patients with unstable coronary artery disease: a Global Utilization of Strategies To Open occluded arteries (GUSTO)-IV substudy. Circulation. Jul. 22. 2003;108(3):275-81. [pmid: 12847065].
781 Januzzi Jr JL, Rehman S, Mueller T, et al. Importance of biomarkers for long-term mortality prediction in acutely dyspneic patients. Clin Chem. 2010;56(12):1814-21. [pmid: 20921266].
782 Jensen JK, Kristensen SR, Bak S, et al. Frequency and significance of troponin T elevation in acute ischemic stroke. Am J Cardiol. Jan. 1. 2007;99(1):108-12. [pmid: 17196472].
783 Jensen JK, Ueland T, Aukrust P, et al. Highly sensitive troponin T in patients with acute ischemic stroke. Eur Neurol. 2012;68(5):287-93. [pmid: 23051820].
784 Kalla C, Raveh D, Algur N, et al. Incidence and significance of a positive troponin test in bacteremic patients without acute coronary syndrome. Am J Med. Oct. 2008;121(10):909-15. [pmid: 18823863].
785 Kang YU, Jeong MH, Kim SW. Impact of renal dysfunction on clinical outcomes of acute coronary syndrome. Yonsei Med J. Aug. 31. 2009;50(4):537-45. [pmid: 19718403].
786 Kiatchoosakun S, Sahasthas D, Wongvipaporn C, et al. Cardiac troponin-T in pre-end stage kidney disease. J Med Assoc Thai. Dec. 2008;91(12):1806-11. [pmid: 19133513].
787 Kilic T, Oner G, Ural E, et al. Comparison of the long-term prognostic value of cystatin C to other indicators of renal function, markers of inflammation and systolic dysfunction among patients with acute coronary syndrome. Atherosclerosis. Dec. 2009;207(2):552-8. [pmid: 19523634].
788 Kim BS, Jeon DS, Shin MJ, et al. Persistent elevation of C-reactive protein may predict cardiac hypertrophy and dysfunction in patients maintained on hemodialysis. Am J Nephrol. May-Jun. 2005;25(3):189-95. [pmid: 15863980].
789 Kirtane AJ, Leder DM, Waikar SS, et al. Serum blood urea nitrogen as an independent marker of subsequent mortality among patients with acute coronary syndromes and normal to mildly reduced glomerular filtration rates. J Am Coll Cardiol. Jun. 7. 2005;45(11):1781-6. [pmid: 15936606].
790 Klein G, Kampmann M, Baum H, et al. Clinical performance of the new cardiac markers troponin T and CK-MB on the Elecsys 2010. A multicentre evaluation. Wien Klin Wochenschr. Suppl 3. 1998;110:40-51. [pmid: 9677671].
791 Knafelj R, Radsel P, Ploj T, et al. Primary percutaneous coronary intervention and mild induced hypothermia in comatose survivors of ventricular fibrillation with ST-elevation acute myocardial infarction. Resuscitation. Aug. 2007;74(2):227-34. [pmid: 17383070].
792 Komarov AL, Iliushenko TA, Shakhmatova OO, et al. Comparative efficacy of conservative and invasive treatment of patients with stable form of ischemic heart disease (according to results of five year prospective study). Kardiologiia. 2012;52(8):4-14. [pmid: 23098392].
793 Kontos MC, Jamal S, Tatum JL, et al. Predictive power of systolic function and congestive heart failure in patients with patients admitted for chest pain without ST elevation in the troponin era. Am Heart J. Aug. 2008;156(2):329-35. [pmid: 18657664].
794 Kratz A, Januzzi JL, Lewandrowski KB, et al. Positive predictive value of a point-of-care testing strategy on first-draw specimens for the emergency department-based detection of acute coronary syndromes. Arch Pathol Lab Med. Dec. 2002;126(12):1487-93. [pmid: 12456209].
795 Kristen AV, Giannitsis E, Lehrke S, et al. Assessment of disease severity and outcome in patients with systemic light-chain amyloidosis by the high-sensitivity troponin T assay. Blood. Oct. 7. 2010;116(14):2455-61. [pmid: 20581312].
796 Lambert ND, Sacrinty MT, Ketch TR, et al. Chronic kidney disease and dipstick proteinuria are risk factors for stent thrombosis in patients with myocardial infarction. Am Heart J. Apr. 2009;157(4):688-94. [pmid: 19332197].
797 Landesberg G, Shatz V, Akopnik I, et al. Association of cardiac troponin, CK-MB, and postoperative myocardial ischemia with long-term survival after major vascular surgery. J Am Coll Cardiol. Nov. 5. 2003;42(9):1547-54. [pmid: 14607436].
798 Lankeit M, Jimenez D, Kostrubiec M, et al. Predictive value of the high-sensitivity troponin T assay and the simplified Pulmonary Embolism Severity Index in hemodynamically stable patients with acute pulmonary embolism: a prospective validation study. Circulation. Dec. 13. 2011;124(24):2716-24. [pmid: 22082681].
799 Lasocki S, Provenchere S, Benessiano J, et al. Cardiac troponin I is an independent predictor of in-hospital death after adult cardiac surgery. Anesthesiology. Aug. 2002;97(2):405-11. [pmid: 12151931].
800 Lavoinne A, Cauliez B, Eltchaninoff H, et al. Analytical and clinical performance of the Immulite cardiac troponin I assay. Clin Chem. Dec. 2000;46(12):1989-90. [pmid: 11106332].
801 Lazzeri C, Valente S, Chiostri M, et al. Microalbuminuria in non-diabetic stemi: an independent predictor for acute kidney injury. Scand Cardiovasc J. Dec. 2012;46(6):324-9. [pmid: 22694718].
802 Lazzeri C, Valente S, Chiostri M, et al. Uric acid in the early risk stratification of ST-elevation myocardial infarction. Intern Emerg Med. Feb. 2012;7(1):33-9. [pmid: 21234713].
803 Li JP, Momin M, Huo Y, et al. Renal insufficiency is an independent predictor of in-hospital mortality for patients with acute myocardial infarction receiving primary percutaneous coronary intervention. J Zhejiang Univ Sci B. Aug. 2012;13(8):638-44. [pmid: 22843184].
804 Lim SY, Bae EH, Choi JS, et al. Effect on short- and long-term major adverse cardiac events of statin treatment in patients with acute myocardial infarction and renal dysfunction. Am J Cardiol. May. 15. 2012;109(10):1425-30. [pmid: 22356794].
805 Lim W, Whitlock R, Khera V, et al. Etiology of troponin elevation in critically ill patients. J Crit Care. Jun. 2010;25(2):322-8. [pmid: 19781898].
806 Linnemann B, Sutter T, Herrmann E, et al. Elevated Cardiac Troponin T is Associated with Higher Mortality and Amputation Rates in Patients with Peripheral Arterial Disease. J Am Coll Cardiol. 2013. Jun. 20. [pmid: 23792625].
807 Loeb HS, Liu JC. Frequency, risk factors, and effect on long-term survival of increased troponin I following uncomplicated elective percutaneous coronary intervention. Clin Cardiol. Dec. 2010;33(12):E40-4. [pmid: 21184543].
808 Lowbeer C, Gustafsson SA, Seeberger A, et al. Serum cardiac troponin T in patients hospitalized with heart failure is associated with left ventricular hypertrophy and systolic dysfunction. Scand J Clin Lab Invest. 2004;64(7):667-76. [pmid: 15513324].
809 Manzano-Fernndez S, Januzzi Jr JL, Boronat-Garcia M, et al. (beta)-trace protein and cystatin C as predictors of long-term outcomes in patients with acute heart failure. J Am Coll Cardiol. 2011;57(7):849-58. [pmid: 21310322].
810 Masson S, Anand I, Favero C, et al. Serial measurement of cardiac troponin T using a highly sensitive assay in patients with chronic heart failure: data from 2 large randomized clinical trials. Circulation. Jan. 17. 2012;125(2):280-8. [pmid: 22139751].
811 Matsumori R, Shimada K, Kiyanagi T, et al. Clinical significance of the measurements of urinary liver-type fatty acid binding protein levels in patients with acute coronary syndrome. J Cardiol. Sep. 2012;60(3):168-73. [pmid: 22658694].
812 McCann CJ, Glover BM, Menown IB, et al. Novel biomarkers in early diagnosis of acute myocardial infarction compared with cardiac troponin T. Eur Heart J. Dec. 2008;29(23):2843-50. [pmid: 18682444].
813 Metra M, Bettari L, Pagani F, et al. Troponin T levels in patients with acute heart failure: clinical and prognostic significance of their detection and release during hospitalisation. Clin Res Cardiol. Aug. 2012;101(8):663-72. [pmid: 22407461].
814 Metra M, Cotter G, Davison BA, et al. Effect of Serelaxin on Cardiac, Renal, and Hepatic Biomarkers in the Relaxin in Acute Heart Failure (RELAX-AHF) Development Program: Correlation With Outcomes. J Am Coll Cardiol. Jan. 15. 2013;61(2):196-206. [pmid: 23273292].
815 Meune C, Balmelli C, Twerenbold R, et al. Patients with acute coronary syndrome and normal high-sensitivity troponin. Am J Med. Dec. 2011;124(12):1151-7. [pmid: 22014790].
816 Mueller C, Neumann FJ, Perruchoud AP, et al. Renal function and long term mortality after unstable angina/non-ST segment elevation myocardial infarction treated very early and predominantly with percutaneous coronary intervention. Heart. Aug. 2004;90(8):902-7. [pmid: 15253964].
817 Muller-Bardorff M, Hallermayer K, Schroder A, et al. Improved troponin T ELISA specific for cardiac troponin T isoform: Assay development and analytical and clinical validation. Clin Chem. 1997;43(3):458-66. [pmid: 9068589].
818 Munzer T, Heim C, Riesen W. Incidence of perioperative myocardial infarction and cardiac events after noncardiac surgery patients with prior myocardial infarction. III: Cardiac troponin T in the diagnosis of perioperative myocardial reinfarction. Anaesthesist. 1996;45(3):225-30. [pmid: 8919894].
819 Nagele P, Brown F, Gage BF, et al. High-sensitivity cardiac troponin T in prediction and diagnosis of myocardial infarction and long-term mortality after noncardiac surgery. Am Heart J. 2013;166(2):325-32.e1. [pmid: 23895816].
820 Nanda N, Sen SK, Arokiaraj MC. Ejection fraction at the first attack of myocardial infarction and postinfarction survival in South Indian population. Indian J Physiol Pharmacol. Jan-Mar. 2012;56(1):21-7. [pmid: 23029960].
821 Nunes JP, Faria Mdo S, Garcia JM, et al. Glomerular filtration rate and coronary artery disease burden in patients with acute coronary syndrome. Clin Cardiol. Sep. 2007;30(9):464-8. [pmid: 17803203].
822 Nunes JPL, Faria MDS, Garcia JMM, et al. Glomerular filtration rate and coronary artery disease burden in patients with acute coronary syndrome. Clin Cardiol. 2007;30(9):464-8. [pmid: 17803203].
823 Ohman EM, Armstrong PW, Christenson RH, et al. Cardiac troponin T levels for risk stratification in acute myocardial ischemia. GUSTO IIA Investigators. N Engl J Med. Oct. 31. 1996;335(18):1333-41. [pmid: 8857016].
824 Osherov AB, Roguin A, Aronson D, et al. Impact of platelet glycoprotein IIb/IIIa receptor inhibitors on renal function in patients with ST-segment elevation myocardial infarction treated with primary or rescue percutaneous coronary intervention. EuroIntervention. Nov. 2009;5(5):604-9. [pmid: 20142182].
825 Paparella D, Scrascia G, Paramythiotis A, et al. Preoperative cardiac troponin I to assess midterm risks of coronary bypass grafting operations in patients with recent myocardial infarction. Ann Thorac Surg. Mar. 2010;89(3):696-702. [pmid: 20172112].
826 Patil A, Aronow WS, Alexa M, et al. Causes of increased cardiac troponin I levels in hospitalized patients without coronary artery disease. Open Journal of Cardiology. 2012;2(1).
827 Patti G, Pasceri V, D'Antonio L, et al. Comparison of safety and efficacy of bivalirudin versus unfractionated heparin in high-risk patients undergoing percutaneous coronary intervention (from the Anti-Thrombotic Strategy for Reduction of Myocardial Damage During Angioplasty-Bivalirudin vs Heparin study). Am J Cardiol. Aug. 15. 2012;110(4):478-84. [pmid: 22583760].
828 Pervae S, Anderson FP, Lohmann TP, et al. Comparative analysis of cardiac troponin I and creatine kinase-MB as markers of acute myocardial infarction. Clin Cardiol. 1997;20(3):269-71. [pmid: 9068915].
829 Pitsavos C, Kourlaba G, Panagiotakos DB, et al. Characteristics and in-hospital mortality of diabetics and nondiabetics with an acute coronary syndrome; the GREECS study. Clin Cardiol. May. 2007;30(5):239-44. [pmid: 17492678].
830 Prellwitz W, Hafner G, Rupprecht HJ, et al. Diagnostic and differential diagnostic value of troponins. Med Klin (Munich). Jun. 15. 1996;91(6):336-42. [pmid: 8767305].
831 Reznichenko NE, Panphilova E, Evdokimova MA, et al. Cystatin C level is independently related to risk of unfavorable outcome after acute coronary syndrome in individuals with normal or moderately reduced renal function. Kardiologiia. 2011;51(6):4-10. [pmid: 21878063].
832 Rittger H, Schnupp S, Sinha AM, et al. Predictors of treatment in acute coronary syndromes in the elderly: impact on decision making and clinical outcome after interventional versus conservative treatment. Catheter Cardiovasc Interv. Nov. 1. 2012;80(5):735-43. [pmid: 22121113].
833 Roe MT, Peterson ED, Li Y, et al. Relationship between risk stratification by cardiac troponin level and adherence to guidelines for non-ST-segment elevation acute coronary syndromes. Arch Intern Med. Sep. 12. 2005;165(16):1870-6. [pmid: 16157831].
834 Sanchez Hidalgo A, Pou M, Leiro R, et al. Renal failure stages as predictors of mortality following acute coronary syndrome. Nefrologia. 2009;29(1):53-60. [pmid: 19240772].
835 Sanchez-Diaz CJ, Garcia-Badillo E, Sanchez-Ramirez CJ, et al. Clinical characteristics, process of care and outcomes among Mexican, Hispanic and non-Hispanic white patients presenting with non-ST elevation acute coronary syndromes: Data from RENASICA and CRUSADE registries. Arch Cardiol Mex. Jan. 2012;82(1):14-21. [pmid: 22452861].
836 Sandhu KS, Singh A, Nadar SK. Management of elderly patients with troponin positive chest pain in a district general hospital. Cardiol J. 2012;19(4):395-401. [pmid: 22825901].
837 Santos JC, Rocha Mde S, Araujo Mda S. Prognostic factors in patients with acute coronary syndrome without ST segment elevation. Arq Bras Cardiol. May. 2013;100(5):412-21. [pmid: 23579621].
838 Scheitz JF, Endres M, Mochmann HC, et al. Frequency, determinants and outcome of elevated troponin in acute ischemic stroke patients. Int J Cardiol. May. 31. 2012;157(2):239-42. [pmid: 22326514].
839 Sciahbasi A, Rizzello V, Gonzini L, et al. Chronic aspirin and statin therapy in patients with impaired renal function and acute coronary syndromes: results from the IN-ACS Outcome Registry. Eur J Prev Cardiol. 2012. Sep. 5. [pmid: 22952286].
840 Sharma R, Pellerin D, Gaze DC, et al. Mitral annular calcification predicts mortality and coronary artery disease in end stage renal disease. Atherosclerosis. Apr. 2007;191(2):348-54. [pmid: 16647710].
841 Skelding KA, Boga G, Sartorius J, et al. Frequency of Coronary Angiography and Revascularization among Men and Women with Myocardial Infarction and Their Relationship to Mortality at One Year: An Analysis of the Geisinger Myocardial Infarction Cohort. J Interv Cardiol. 2013.
842 Stromme JH, Halvorsen S, Frederichsen P. Diagnoses and increased levels of troponin T among discharged patients. Tidsskr Nor Laegeforen. Oct. 30. 2001;121(26):3041-5. [pmid: 11757436].
843 Szummer K, Lindahl B, Sylven C, et al. Relationship of plasma erythropoietin to long-term outcome in acute coronary syndrome. Int J Cardiol. Aug. 20. 2010;143(2):165-70. [pmid: 19269703].
844 Urso S, Garozzo M, Milone F, et al. Cardiovascular risk markers in hemodialysis patients. Int J Artif Organs. Dec. 2004;27(12):1083-90. [pmid: 15645620].
845 Verouden NJ, Haeck JD, Kuijt WJ, et al. Comparison of the usefulness of N-terminal pro-brain natriuretic peptide to other serum biomarkers as an early predictor of ST-segment recovery after primary percutaneous coronary intervention. Am J Cardiol. Apr. 15. 2010;105(8):1047-52. [pmid: 20381651].
846 Wallace TW, Abdullah SM, Drazner MH, et al. Prevalence and determinants of troponin T elevation in the general population. Circulation. Apr. 25. 2006;113(16):1958-65. [pmid: 16618821].
847 Wang CP, Lu LF, Tsai IT, et al. Roles of serum total P-cresylsulfate and chronic kidney disease in coronary atherosclerotic burden in acute coronary syndrome patients. Acta Cardiologica Sinica. 2012;28(4):297-305.
848 Waxman DA, Hecht S, Schappert J, et al. A model for troponin I as a quantitative predictor of in-hospital mortality. J Am Coll Cardiol. Nov. 7. 2006;48(9):1755-62. [pmid: 17084245].
849 Wong PS, Jones JD, Ashrafi R, et al. Early and late mortality in hospitalised patients with raised cardiac troponin T. Postgrad Med J. Aug. 2012;88(1042):437-42. [pmid: 22543243].
850 Wood FO, Leonowicz NA, Vanhecke TE, et al. Mortality in patients with ST-segment elevation myocardial infarction who do not undergo reperfusion. Am J Cardiol. Aug. 15. 2012;110(4):509-14. [pmid: 22633204].
851 Young Altahan R, Goldenberg I, Kimron L, et al. Timing of coronary angiography and outcome in patients with non-ST elevation acute coronary syndromes and kidney disease: real-world data from the acute coronary syndromes Israeli survey. Cardiology. 2011;119(4):224-34. [pmid: 22041637].
852 Zahid M, Good CB, Singla I, et al. Clinical significance of borderline elevated troponin I levels across different assays in patients with suspected acute coronary syndrome. Am J Cardiol. Jul. 15. 2009;104(2):164-8. [pmid: 19576340].
853 Zaninotto M, Altinier S, Lachin M, et al. Strategies for the early diagnosis of acute myocardial infarction using biochemical markers. Am J Clin Pathol. Mar. 1999;111(3):399-405. [pmid: 10078116].
854 Zethelius B, Berglund L, Sundstrom J, et al. Use of multiple biomarkers to improve the prediction of death from cardiovascular causes. N Engl J Med. May. 15. 2008;358(20):2107-16. [pmid: 18480203].

## No Comparison of Interest

855 Badero OJ, Salifu MO. Prediction of hemodynamically significant coronary artery disease using troponin I in hemodialysis patients presenting with chest pain: A case-control study. Cardiology. 2009;114(4):292-7. [pmid: 19696481].
856 Barthelemy O, Helft G, Berman E, et al. Primary PCI in patients with impaired renal function. Eur Heart J. 2012;33:387.
857 Beciani M, Tedesco A, Azzarito M, et al. Cardiac troponin I in chronic hemodialysis. Comparison of methods and results after 3 months. Recenti Prog Med. Nov. 2001;92(11):660-2. [pmid: 11765657].
858 Christenson RH, Fitzgerald RL, Ochs L, et al. Characteristics of a 20-minute whole blood rapid assay for cardiac troponin T. Clin Biochem. Feb. 1997;30(1):27-33. [pmid: 9056106].
859 Colombani JC. Clinical interest of cardiac troponin T in a general hospital. Comparison with cardiac troponin I. Immuno-Analyse et Biologie Specialisee. 1998;13(1):26-30.
860 Croitoru M, Taegtmeyer H. Spurious rises in troponin T in end-stage renal disease. Lancet. Oct. 7. 1995;346(8980):974. [pmid: 7564765].
861 Davis GK, Labugger R, Van Eyk JE, et al. Cardiac troponin T is not detected in Western blots of diseased renal tissue. Clin Chem. Apr. 2001;47(4):782-3. [pmid: 11274043].
862 Escalon JC, Wong SS. False-positive cardiac troponin T levels in chronic hemodialysis patients. Cardiology. May-Jun. 1996;87(3):268-9. [pmid: 8725327].
863 Finsterer J, Stollberger C, Krugluger W. Positive troponin-T in noncompaction is associated with neuromuscular disorders and poor outcome. Clin Res Cardiol. Feb. 2007;96(2):109-13. [pmid: 17146603].
864 Heeschen C, Goldmann BU, Moeller RH, et al. Analytical performance and clinical application of a new rapid bedside assay for the detection of serum cardiac troponin I. Clin Chem. Sep. 1998;44(9):1925-30. [pmid: 9732978].
865 Jernberg T, Lindahl B, James S, et al. Cystatin C: a novel predictor of outcome in suspected or confirmed non-ST-elevation acute coronary syndrome. Circulation. Oct. 19. 2004;110(16):2342-8. [pmid: 15477399].
866 Karwowski D, Kalinaczuk L, Majewski K, et al. Impaired renal function in patients with myocardial infarction treated with primary angioplasty and the risk for failed myocardial tissue reperfusion and thus worse long-term outcomes. Postepy w Kardiologii Interwencyjnej. 2012;8(1):18-24.
867 Lazaros G, Tsiachris D, Tousoulis D, et al. In-hospital worsening renal function is an independent predictor of one-year mortality in patients with acute myocardial infarction. Int J Cardiol. Feb. 23. 2012;155(1):97-101. [pmid: 21078526].
868 Lee MG, Jeong MH, Lee KH, et al. Comparison of chronic kidney disease and risk for presenting with painless versus nonpainless acute myocardial infarction. Am J Cardiol. Sep. 15. 2012;110(6):790-4. [pmid: 22657394].
869 Lourenco C, Teixeira R, Antonio N, et al. Impact of renal function on mortality and incidence of major adverse cardiovascular events following acute coronary syndromes. Rev Port Cardiol. Sep. 2010;29(9):1331-52. [pmid: 21179976].
870 McLaurin MD, Apple FS, Voss EM, et al. Cardiac troponin I, cardiac troponin T, and creatine kinase MB in dialysis patients without ischemic heart disease: evidence of cardiac troponin T expression in skeletal muscle. Clin Chem. Jun. 1997;43(6 Pt 1):976-82. [pmid: 9191549].
871 Panteghini M, Bonora R, Pagani F. Rapid and specific immunoassay for cardiac troponin I in the diagnosis of myocardial damage. Int J Clin Lab Res. 1997;27(1):60-4. [pmid: 9144029].
872 Park SH, Lee SW, Lee SJ, et al. The association between left ventricular hypertrophy and biomarkers in patients on continuous ambulatory peritoneal dialysis. Korean Circ J. Nov. 2009;39(11):488-93. [pmid: 19997545].
873 Petrovic D, Stojimirovic B. Cardiovascular morbidity and mortality in patients treated with hemodialysis--epidemiological analysis. Vojnosanit Pregl. Dec. 2008;65(12):893-900. [pmid: 19160983].
874 Sahinarslan A, Guz G, Mutluay R, et al. The impact of dialysis type on biomarkers for cardiovascular diseases. Turk Kardiyol Dern Ars. Sep. 2011;39(6):456-62. [pmid: 21918314].
875 Steen H, Madadi-Schroeder M, Lehrke S, et al. Staged cardiovascular magnetic resonance for differential diagnosis of troponin T positive patients with low likelihood for acute coronary syndrome. J Cardiovasc Magn Reson. 2010;12:51. [pmid: 20840783].
876 Wu AHB. Interpretation of high sensitivity cardiac troponin I results: Reference to biological variability in patients who present to the emergency room with chest pain: Case report series. Clinica Chimica Acta. 2009;401(1-2):170-4.
877 Ziebig R, Lun A, Hocher B, et al. Renal elimination of troponin T and troponin I. Clin Chem. Jul. 2003;49(7):1191-3. [pmid: 12816921].

## No Outcome of Interest

878 Adams JE 3rd, Bodor GS, Davila-Roman VG, et al. Cardiac troponin I. A marker with high specificity for cardiac injury. Circulation. Jul. 1993;88(1):101-6. [pmid: 8319322].
879 Adhyapak SM, Iyengar SS. Characteristics of a subset of patients with reversible systolic dysfunction in chronic kidney disease. Congest Heart Fail. May-Jun. 2011;17(3):120-6. [pmid: 21609385].
880 Afsar B, Elsurer R, Akgul A, et al. Factors related to silent myocardial damage in hemodialysis patients. Ren Fail. 2009;31(10):933-41. [pmid: 20030529].
881 Akagi M, Nagake Y, Ichikawa H, et al. Myocardial troponin T levels in patients with diabetic nephropathy. Nihon Jinzo Gakkai Shi. Mar. 1996;38(3):136-40. [pmid: 8721335].
882 Akagi M, Nagake Y, Makino H, et al. A comparative study of myocardial troponin T levels in patients undergoing hemodialysis. Nihon Jinzo Gakkai Shi. Nov. 1995;37(11):639-43. [pmid: 8583700].
883 Aksoy N, Ozer O, Sari I, et al. Contribution of renal function impairment to unexplained troponin T elevations in congestive heart failure. Ren Fail. 2009;31(4):272-7. [pmid: 19462275].
884 Al Badr W, Mukherjee D, Kline-Rogers E, et al. Clinical association between renal insufficiency and positive troponin I in patients with acute coronary syndrome. Cardiology. 2004;102(4):215-9. [pmid: 15452394].
885 Al-Hadi HA, William B, Fox KA. Serum level of heart-type Fatty Acid-binding protein in patients with chronic renal failure. Sultan Qaboos Univ Med J. Dec. 2009;9(3):311-4. [pmid: 21509315].
886 Apple FS, Ricchiuti V, Voss EM, et al. Expression of cardiac troponin T isoforms in skeletal muscle of renal disease patients will not cause false-positive serum results by the second generation cardiac troponin T assay. Eur Heart J. Nov. Suppl N. 1998;19:N30-3. [pmid: 9857936].
887 Arroyo D, Quiroga B, Panizo N, et al. High-sensitivity troponin T levels in kidney transplant recipients. Transplant Proc. Nov. 2012;44(9):2545-7. [pmid: 23146449].
888 Balamuthusamy S, Khosla S, Meka S, et al. Clinical utility of cardiac troponin I in the diagnosis of acute coronary syndrome in patients with renal failure. Am J Ther. Jul-Aug. 2007;14(4):356-60. [pmid: 17667211].
889 Barthelemy O, Cayla G, Silvain J, et al. Optimal time for catheterization in NSTE-ACS patients with impaired renal function: Insights from the ABOARD Study. Int J Cardiol. Sep. 10. 2013;167(6):2646-52. [pmid: 22795712].
890 Bolasco P, Ghezzi PM, Serra A, et al. Effects of acetate-free haemodiafiltration (HDF) with endogenous reinfusion (HFR) on cardiac troponin levels. Nephrol Dial Transplant. Jan. 2011;26(1):258-63. [pmid: 20601367].
891 Boulier A, Bosc JY, Boularan AM, et al. So the reference values for cTroponin I must be modified in end stage renal disease?. Immuno-Analyse et Biologie Specialisee. 2004;19(2):101-4.
892 Braun SL, Baum H, Neumeier D, et al. Troponin T and troponin I after coronary artery bypass grafting: discordant results in patients with renal failure. Clin Chem. May. 1996;42(5):781-3. [pmid: 8653914].
893 Breidthardt T, Burton JO, Odudu A, et al. Troponin T for the detection of dialysis-induced myocardial stunning in hemodialysis patients. Clin J Am Soc Nephrol. Aug. 2012;7(8):1285-92. [pmid: 22822013].
894 Caliskan Y, Ozkok A, Akagun T, et al. Cardiac biomarkers and noninvasive predictors of atherosclerosis in chronic peritoneal dialysis patients. Kidney Blood Press Res. 2012;35(5):340-8. [pmid: 22473007].
895 Cauliez B, Hue G, Lavoinne A. Cardiac troponin T on Elecsys 2010: Comparison with cardiac troponin I. Ann Biol Clin (Paris). 1998;56(6):711-5. 23. [pmid: 9853030].
896 Charytan DM, Setoguchi S, Solomon DH, et al. Clinical presentation of myocardial infarction contributes to lower use of coronary angiography in patients with chronic kidney disease. Kidney Int. May. 2007;71(9):938-45. [pmid: 17342183].
897 Collado S, Coll E, Deulofeu R, et al. Prevalence of cardiovascular disease in uraemia and relevance of cardiovascular risk factors. Nefrologia. 2010;30(3):342-8. [pmid: 20514101].
898 Collinson PO, Hadcocks L, Foo Y, et al. Cardiac troponins in patients with renal dysfunction. Ann Clin Biochem. May. 1998;35(Pt 3):380-6. [pmid: 9635103].
899 Coritsidis G, Sutariya D, Stern A, et al. Does timing of dialysis in patients with ESRD and acute myocardial infarcts affect morbidity or mortality?. Clin J Am Soc Nephrol. Aug. 2009;4(8):1324-30. [pmid: 19590061].
900 Correia LC, Barbosa CE, Cerqueira T, et al. Moderate renal dysfunction is not associated with elevated Troponin T in acute coronary syndromes. Arq Bras Cardiol. Oct. 2010;95(5):600-5. [pmid: 21225113].
901 Desai AS, Toto R, Jarolim P, et al. Association between cardiac biomarkers and the development of ESRD in patients with type 2 diabetes mellitus, anemia, and CKD. Am J Kidney Dis. Nov. 2011;58(5):717-28. [pmid: 21820220].
902 Diris JH, Hackeng CM, Kooman JP, et al. Impaired renal clearance explains elevated troponin T fragments in hemodialysis patients. Circulation. Jan. 6. 2004;109(1):23-5. [pmid: 14691043].
903 Donnino MW, Karriem-Norwood V, Rivers EP, et al. Prevalence of elevated troponin I in end-stage renal disease patients receiving hemodialysis. Acad Emerg Med. Sep. 2004;11(9):979-81. [pmid: 15347551].
904 Fahie-Wilson MN, Carmichael DJ, Delaney MP, et al. Cardiac troponin T circulates in the free, intact form in patients with kidney failure. Clin Chem. Mar. 2006;52(3):414-20. [pmid: 16410339].
905 Falaknazi K, Bagheri N, Taziki O. Assessment of inflammatory factors and cardiac troponin T in hemodialysis patients. Saudi J Kidney Dis Transpl. Mar. 2009;20(2):219-22. [pmid: 19237807].
906 Farah R, Hahiashvilli A, Shurtz-Swirski R, et al. The significance of troponin T in hemodialysis patients. Harefuah. Dec. 2006;145(12):875-8. 943. [pmid: 17220023].
907 Flisinski M, Strozecki P, Stefanska A, et al. Cardiac troponin I in patients with chronic kidney disease treated conservatively or undergoing long-term haemodialysis. Kardiol Pol. Sep. 2007;65(9):1068-75. discussion 76-8. [pmid: 17975754].
908 Ford ML, Smith ER, Tomlinson LA, et al. FGF-23 and osteoprotegerin are independently associated with myocardial damage in chronic kidney disease stages 3 and 4. Another link between chronic kidney disease-mineral bone disorder and the heart. Nephrol Dial Transplant. Feb. 2012;27(2):727-33. [pmid: 21750158].
909 Fredericks S, Chang R, Gregson H, et al. Circulating cardiac troponin-T in patients before and after renal transplantation. Clin Chim Acta. Aug. 20. 2001;310(2):199-203. [pmid: 11498086].
910 Gabr AE, Ibrahim IA, Aloulou SM, et al. Cardiac troponin T and end stage renal disease. Saudi Med J. Aug. 2004;25(8):1015-9. [pmid: 15322590].
911 Guz G, Sahinarslan A, Dhondt AW, et al. Elevated cardiac troponin T in hemodialysis patients receiving more intravenous iron sucrose. Ren Fail. Nov. 2004;26(6):663-72. [pmid: 15600258].
912 Hafner G, Peetz D, Erbes H, et al. Comparison of diagnostic performance of cardiac troponin I on the IMMULITE system with other automated troponin I assays in minor myocardial damage. Scand J Clin Lab Invest. May. 2001;61(3):227-35. [pmid: 11386609].
913 Hafner G, Thome-Kromer B, Schaube J, et al. Cardiac troponins in serum in chronic renal failure. Clin Chem. Sep. 1994;40(9):1790-1. [pmid: 8070099].
914 Haller C, Zehelein J, Remppis A, et al. Cardiac troponin T in patients with end-stage renal disease: absence of expression in truncal skeletal muscle. Clin Chem. May. 1998;44(5):930-8. [pmid: 9590364].
915 Hausken J, Klingenberg O, Morkrid L, et al. Elevated troponin I and NT-proBNP at the time of transplantation may predict a major adverse cardiac event in the early postoperative period after renal transplantation. Transplantation. Jul. 27. 2012;94(2):e15-6. [pmid: 22820562].
916 Hayashi T, Obi Y, Kimura T, et al. Cardiac troponin T predicts occult coronary artery stenosis in patients with chronic kidney disease at the start of renal replacement therapy. Nephrol Dial Transplant. Sep. 2008;23(9):2936-42. [pmid: 18403432].
917 Ho JE, Hwang SJ, Wollert KC, et al. Biomarkers of Cardiovascular Stress and Incident Chronic Kidney Disease. Clin Chem. 2013. Jul. 19. [pmid: 23873716].
918 Iliou MC, Fumeron C, Benoit MO, et al. Factors associated with increased serum levels of cardiac troponins T and I in chronic haemodialysis patients: Chronic Haemodialysis And New Cardiac Markers Evaluation (CHANCE) study. Nephrol Dial Transplant. Jul. 2001;16(7):1452-8. [pmid: 11427640].
919 Ishii J, Ishikawa T, Yukitake J, et al. Clinical specificity of a second-generation cardiac troponin T assay in patients with chronic renal failure. Clin Chim Acta. Feb. 23. 1998;270(2):183-8. [pmid: 9544455].
920 Jacobs LH, van de Kerkhof J, Mingels AM, et al. Haemodialysis patients longitudinally assessed by highly sensitive cardiac troponin T and commercial cardiac troponin T and cardiac troponin I assays. Ann Clin Biochem. Jul. 2009;46(Pt 4):283-90. [pmid: 19454537].
921 Jacobs LH, van de Kerkhof JJ, Mingels AM, et al. Inflammation, overhydration and cardiac biomarkers in haemodialysis patients: a longitudinal study. Nephrol Dial Transplant. Jan. 2010;25(1):243-8. [pmid: 19692417].
922 Jaroszynski A, Czekajska-Chechab E, Drelich-Zbroja A, et al. Spatial QRS-T angle in peritoneal dialysis patients: association with carotid artery atherosclerosis, coronary artery calcification and troponin T. Nephrol Dial Transplant. Mar. 2009;24(3):1003-8. [pmid: 18978067].
923 Jefferies HJ, Virk B, Schiller B, et al. Frequent hemodialysis schedules are associated with reduced levels of dialysis-induced cardiac injury (myocardial stunning). Clin J Am Soc Nephrol. Jun. 2011;6(6):1326-32. [pmid: 21597028].
924 Jung HH, Ma KR, Han H. Elevated concentrations of cardiac troponins are associated with severe coronary artery calcification in asymptomatic haemodialysis patients. Nephrol Dial Transplant. Dec. 2004;19(12):3117-23. [pmid: 15546893].
925 Kandil ME, Hussein G, Bazaraa HM, et al. Left ventricular hypertrophy and cardiac troponin I in pediatric hemodialysis. Journal of Clinical and Basic Cardiology. 2009;12(1-4):5-10.
926 Koehnlein T, Schmidt A, Moesenthin M, et al. Increased cardiac troponin T and C-reactive protein levels in end-stage renal disease are associated with obstructive sleep apnea. Clin Nephrol. Jan. 2009;71(1):50-8. [pmid: 19203550].
927 Korkmaz H, Sasak G, Celik A, et al. The comparison of cardiac biomarkers positivities in hemodialysis patients without acute coronary syndrome. Ren Fail. 2011;33(6):578-81. [pmid: 21663388].
928 Kostrubiec M, Labyk A, Pedowska-Wloszek J, et al. Impaired renal function predicts short term prognosis in patients with acute pulmonary embolism. Eur Heart J. 2010;31:915.
929 Lazzeri C, Valente S, Chiostri M, et al. ST-elevation myocardial infarction with preserved ejection fraction: the impact of worsening renal failure. Int J Cardiol. Feb. 23. 2012;155(1):170-2. [pmid: 22188989].
930 Leowattana W, Ong-Ajyooth L, Taruangsri P, et al. Circulating N-terminal pro-brain natriuretic peptide and cardiac troponin T in chronic dialysis patients. J Med Assoc Thai. May. Suppl 1. 2003;86:S52-8. [pmid: 12866769].
931 Levin A, Rigatto C, Brendan B, et al. Cohort profile: Canadian study of prediction of death, dialysis and interim cardiovascular events (CanPREDDICT). BMC Nephrol. 2013;14:121. [pmid: 23758910].
932 Linnemann B, Sutter T, Sixt S, et al. Elevated cardiac troponin T contributes to prediction of worse in-hospital outcomes after endovascular therapy for acute limb ischemia. J Vasc Surg. Mar. 2012;55(3):721-9. [pmid: 22277685].
933 Lippi G, Tessitore N, Montagnana M, et al. Influence of sampling time and ultrafiltration coefficient of the dialysis membrane on cardiac troponin I and T. Arch Pathol Lab Med. Jan. 2008;132(1):72-6. [pmid: 18181677].
934 Liu YW, Su CT, Wang SP, et al. Application of speckle-tracking echocardiography in detecting coronary artery disease in patients with maintenance hemodialysis. Blood Purif. 2011;32(1):38-42. [pmid: 21293120].
935 Lowbeer C, Ottosson-Seeberger A, Gustafsson SA, et al. Increased cardiac troponin T and endothelin-1 concentrations in dialysis patients may indicate heart disease. Nephrol Dial Transplant. Aug. 1999;14(8):1948-55. [pmid: 10462276].
936 Lubas A, Ryczek R, Kade G, et al. Impact of cardiovascular organ damage on cortical renal perfusion in patients with chronic renal failure. Biomed Res Int. 2013;2013:137868. [pmid: 23853766].
937 Macsai E, Szell J, Ladanyi E, et al. Determining factors of cardiac biomarkers in hemodialysed diabetic and non-diabetic patients. Orv Hetil. Mar. 18. 2007;148(11):483-8. [pmid: 17350919].
938 Mallamaci F, Zoccali C, Parlongo S, et al. Diagnostic value of troponin T for alterations in left ventricular mass and function in dialysis patients. Kidney Int. Nov. 2002;62(5):1884-90. [pmid: 12371993].
939 Marjani A, Moradi A, Veghari G. Comparison of plasma cardiac Troponin I and cardiac enzymes in haemodialysis patients of Gorgan (south east of Iran). Pak J Biol Sci. Nov. 1. 2007;10(21):3915-8. [pmid: 19090253].
940 Mekontso Dessap A, Lellouche N, Audard V, et al. Effect of renal failure on peak troponin Ic level in patients with acute myocardial infarction. Cardiology. 2008;109(4):217-21. [pmid: 17873484].
941 Melanson SE, Conrad MJ, Mosammaparast N, et al. Implementation of a highly sensitive cardiac troponin I assay: test volumes, positivity rates and interpretation of results. Clin Chim Acta. Sep. 2008;395(1-2):57-61. [pmid: 18515084].
942 Mielniczuk LM, Pfeffer MA, Lewis EF, et al. Acute decline in renal function, inflammation, and cardiovascular risk after an acute coronary syndrome. Clin J Am Soc Nephrol. Nov. 2009;4(11):1811-7. [pmid: 19820133].
943 Mishra RK, Li Y, Defilippi C, et al. Association of Cardiac Troponin T With Left Ventricular Structure and Function in CKD. Am J Kidney Dis. 2013. Jan. 3. [pmid: 23291148].
944 Mnif O, Belhadj R, Zerelli L, et al. Variation of C troponin T in chronic hemodialysis patients: Study about 52 cases. Tunisie Medicale. 2009;87(4):285-8. [pmid: 19835288].
945 Mongeon FP, Dorais M, Lorier JL, et al. Effect of hemodialysis, coronary artery disease and diabetes on cardiac troponin T: a prospective survey over one year. Open Cardiovasc Med J. 2009;3:69-77. [pmid: 19590593].
946 Montagnana M, Lippi G, Tessitore N, et al. Effect of hemodialysis on traditional and innovative cardiac markers. J Clin Lab Anal. 2008;22(1):59-65. [pmid: 18200568].
947 Mutluay R, Konca C, Erten Y, et al. Predictive markers of asymptomatic atherosclerosis in end-stage renal disease patients. Ren Fail. May. 2010;32(4):448-54. [pmid: 20446782].
948 Nakai K, Nagane Y, Obara W, et al. Serum levels of cardiac troponin I and other marker proteins in patients with chronic renal failure. Clin Exp Nephrol. Mar. 2004;8(1):43-7. [pmid: 15067515].
949 Negishi K, Kobayashi M, Ochiai I, et al. Association between fibroblast growth factor 23 and left ventricular hypertrophy in maintenance hemodialysis patients. Comparison with B-type natriuretic peptide and cardiac troponin T. Circ J. Nov. 2010;74(12):2734-40. [pmid: 21041973].
950 Ninan VT, Hilali N, Ali JH, et al. Baseline cardiac troponin I in patients on maintenance dialysis. Transplant Proc. Jul-Aug. 2004;36(6):1829-30. [pmid: 15350489].
951 Obialo CI, Sharda S, Goyal S, et al. Ability of troponin T to predict angiographic coronary artery disease in patients with chronic kidney disease. Am J Cardiol. Sep. 15. 2004;94(6):834-6. [pmid: 15374805].
952 Ooi DS, House AA. Cardiac troponin T in hemodialyzed patients. Clin Chem. Jul. 1998;44(7):1410-6. [pmid: 9665417].
953 Ortega O, Rodriguez I, Gracia C, et al. Strict volume control and longitudinal changes in cardiac biomarker levels in hemodialysis patients. Nephron Clin Pract. 2009;113(2):c96-103. [pmid: 19602905].
954 Popowska-Drojecka J, Muszytowski M, Sobilo-Jarek L, et al. Increased serum levels of troponin I and lesions in coronary angiography in hemodialysed patients. Rocz Akad Med Bialymst. 2005;50:311-3. [pmid: 16358990].
955 Porter GA, Norton TL, Lindsley J, et al. Relationship between elevated serum troponin values in end-stage renal disease patients and abnormal isotopic cardiac scans following stress. Ren Fail. Jan. 2003;25(1):55-65. [pmid: 12617333].
956 Quiroga B, Goicoechea M, Garcia de Vinuesa S, et al. Cardiac markers in different degrees of chronic kidney disease: influence of inflammation and previous heart disease. Med Clin (Barc). Jun. 30. 2012;139(3):98-102. [pmid: 21807382].
957 Rammos C, Hendgen-Cotta UB, Sobierajski J, et al. Macrophage migration inhibitory factor is associated with vascular dysfunction in patients with end-stage renal disease. Int J Cardiol. 2013. Aug. 14. [pmid: 23978362].
958 Roberts MA, MacMillan N, Hare DL, et al. Cardiac troponin levels in asymptomatic patients on the renal transplant waiting list. Nephrology (Carlton). Oct. 2006;11(5):471-6. [pmid: 17014564].
959 Rumenjak V, Brajkovic-Bralic M, Varlaj-Knobloch V, et al. N-terminal proBNP and high sensivity cardiac troponin I concentrations in haemodialysis patients. Acta Med Croatica. Oct. Suppl 3. 2011;65:36-40. [pmid: 23120813].
960 Ryu DR, Park JT, Chung JH, et al. A more appropriate cardiac troponin T level that can predict outcomes in end-stage renal disease patients with acute coronary syndrome. Yonsei Med J. Jul. 2011;52(4):595-602. [pmid: 21623601].
961 Sahinarslan A, Guz G, Okyay K, et al. Brain natriuretic peptide correlates with troponin T in patients with renal failure. Acta Cardiol. Apr. 2007;62(2):171-6. [pmid: 17536606].
962 Seco Garcia ML, Borque de Larrea L, Rus Martinez A, et al. Cardiac troponins and other myocardial markers in patients with renal disease. Quimica Clinica. 2000;19(5):390-4.
963 Seino Y, Hori M, Sonoda T. Multicenter prospective investigation on cardiovascular adverse effects of tacrolimus in kidney transplantations. Cardiovasc Drugs Ther. Mar. 2003;17(2):141-9. [pmid: 12975596].
964 Sezer S, Karakan S, Ozdemir N. Increased cardiac troponin T levels are related to inflammatory markers and various indices of renal function in chronic renal disease patients. Ren Fail. 2012;34(4):454-9. [pmid: 22320145].
965 Shroff GR, Frederick PD, Herzog CA. Renal failure and acute myocardial infarction: clinical characteristics in patients with advanced chronic kidney disease, on dialysis, and without chronic kidney disease. A collaborative project of the United States Renal Data System/National Institutes of Health and the National Registry of Myocardial Infarction. Am Heart J. Mar. 2012;163(3):399-406. [pmid: 22424010].
966 Sommerer C, Heckele S, Schwenger V, et al. Cardiac biomarkers are influenced by dialysis characteristics. Clin Nephrol. Dec. 2007;68(6):392-400. [pmid: 18184522].
967 Su CT, Liu YW, Lin JW, et al. Increased procollagen type I C-terminal peptide levels indicate diastolic dysfunction in end-stage renal disease patients undergoing maintenance dialysis therapy. J Am Soc Echocardiogr. Aug. 2012;25(8):895-901. [pmid: 22658561].
968 Sutidze M, Kajrishvili M, Tsimakuridze M, et al. Factors associated with increased serum levels of specific markers of myocardial injury--cardiac troponins T and I in chronic haemodialysis patients. Georgian Med News. Apr. 2009;(169):39-43. [pmid: 19430042].
969 Sutidze M, Sulakvelidze M, Kochiashvili D, et al. Creatine kinase mb, cardiac troponin T and cardiac troponin I as the markers of rhabdomyolysis in chronic hemodialysis patients. Georgian Med News. Mar. 2006;(132):68-71. [pmid: 16636385].
970 Taki K, Tsuruta Y, Niwa T. Cardiac troponin T and advanced glycation end-products in hemodialysis patients. Am J Nephrol. 2008;28(5):701-6. [pmid: 18431051].
971 Taskapan MC, Taskapan H, Ulutas O, et al. Relationships between brain natriuretic peptide, troponin I and QT dispersion in asymptomatic dialysis patients. Ren Fail. 2007;29(2):221-5. [pmid: 17365940].
972 Trimarchi H, Muryan A, Campolo-Girard V, et al. Elevated pro-brain natriuretic peptide, troponin T and malnutrition inflammatory score in chronic hemodialysis patients with overt cardiovascular disease. Nephron Clin Pract. 2011;117(3):c198-205. [pmid: 20805692].
973 Trimarchi H, Muryan A, Dicugno M, et al. Proteinuria: an ignored marker of inflammation and cardiovascular disease in chronic hemodialysis. Int J Nephrol Renovasc Dis. 2012;5:1-7. [pmid: 22334794].
974 Trinquier S, Flecheux O, Bullenger M, et al. Highly specific immunoassay for cardiac troponin I assessed in noninfarct patients with chronic renal failure or severe polytrauma. Clin Chem. Nov. 1995;41(11):1675-6. [pmid: 7586570].
975 Tsutamoto T, Kawahara C, Yamaji M, et al. Relationship between renal function and serum cardiac troponin T in patients with chronic heart failure. Eur J Heart Fail. Jul. 2009;11(7):653-8. [pmid: 19502379].
976 Tun A, Khan IA, Win MT, et al. Specificity of cardiac troponin I and creatine kinase-MB isoenzyme in asymptomatic long-term hemodialysis patients and effect of hemodialysis on these cardiac markers. Cardiology. 1998;90(4):280-5. [pmid: 10085490].
977 Ulas T, Apucu G, Paksoy F, et al. Comparison of troponin-I levels before and after haemodialysis in diabetic and nondiabetic chronic kidney disease patients. Duzce Medical Journal. 2012;14(3):11-4.
978 Urso S, Milone F, Garozzo M, et al. Cardiovascular risk markers in hemodialysis. G Ital Nefrol. Nov-Dec. Suppl 30. 2004;21:S212-6. [pmid: 15750988].
979 Wang AY, Lam CW, Wang M, et al. Diagnostic potential of serum biomarkers for left ventricular abnormalities in chronic peritoneal dialysis patients. Nephrol Dial Transplant. Jun. 2009;24(6):1962-9. [pmid: 19237403].
980 Wang F, Ye P, Luo L, et al. Association of glomerular filtration rate with high-sensitivity cardiac troponin T in a community-based population study in Beijing. PLoS One. 2012;7(5):e38218. [pmid: 22675450].
981 Wanic-Kossowska M, Kobelski M, Pawliczak E, et al. Cardiac troponin I (cTnl) serum concentration in patients with chronic renal failure treated by hemodialysis. Pol Arch Med Wewn. Nov. 2003;110(5):1309-16. [pmid: 16737001].
982 Wiessner R, Hannemann-Pohl K, Ziebig R, et al. Impact of kidney function on plasma troponin concentrations after coronary artery bypass grafting. Nephrol Dial Transplant. Jan. 2008;23(1):231-8. [pmid: 17898023].
983 Willging S, Keller F, Steinbach G. Specificity of cardiac troponins I and T in renal disease. Clin Chem Lab Med. Feb. 1998;36(2):87-92. [pmid: 9594044].
984 Wong CK, Szeto CC, Chan MH, et al. Elevation of pro-inflammatory cytokines, C-reactive protein and cardiac troponin T in chronic renal failure patients on dialysis. Immunol Invest. 2007;36(1):47-57. [pmid: 17190649].
985 Wrenn K, Blair R, Parl FF, et al. Calcium-phosphorus product and troponin-T values in renal failure. Am J Emerg Med. Nov. 2006;24(7):836-8. [pmid: 17098107].
986 Wu AH, Feng YJ, Roper L, et al. Cardiac troponins T and I before and after renal transplantation. Clin Chem. Feb. 1997;43(2):411-2. [pmid: 9023153].
987 Yamashita T, Seino Y, Ogawa A, et al. N-terminal pro-BNP is a novel biomarker for integrated cardio-renal burden and early risk stratification in patients admitted for cardiac emergency. J Cardiol. May. 2010;55(3):377-83. [pmid: 20350516].
988 Zaman Z, De Spiegeleer S, Gerits M, et al. Analytical and clinical performance of two cardiac troponin I immunoassays. Clin Chem Lab Med. Sep. 1999;37(9):889-97. [pmid: 10596955].
989 Zand Parsa AF, Abdolahi A, Mahdavimazdeh M. Is cardiac biomarkers and left ventricular function affected by chronic kidney disease?. Indian Heart J. Sep-Oct. 2012;64(5):479-83. [pmid: 23102386].
990 Zaninotto M, Altinier S, Lachin M, et al. Fluoroenzymometric method to measure cardiac troponin I in sera of patients with myocardial infarction. Clin Chem. Sep. 1996;42(9):1460-6. [pmid: 8787705].
991 Zumrutdal A, Baltali M, Micozkadioglu H, et al. Determinants of coronary artery disease in nondiabetic hemodialysis patients: a matched case-control study. Ren Fail. 2007;29(1):67-71. [pmid: 17365912].

## No Key Question Addressed

992 Abeygunasekara SC, Horner CW. High prevalence of undiagnosed kidney disease in those presenting with troponin positive acute coronary syndrome. Ren Fail. 2012;34(7):845-8. [pmid: 22680915].
993 Ahmed K, Jeong MH, Chakraborty R, et al. Coronary Stents in Patients with ST-Elevation Myocardial Infarction and Chronic Kidney Disease Undergoing Primary Percutaneous Coronary Intervention. Korean Circ J. Dec. 2012;42(12):830-8. [pmid: 23323121].
994 Bae EH, Lim SY, Cho KH, et al. GFR and cardiovascular outcomes after acute myocardial infarction: results from the Korea Acute Myocardial Infarction Registry. Am J Kidney Dis. Jun. 2012;59(6):795-802. [pmid: 22445708].
995 Birnbaum Y, Strasberg B, Rechavia E, et al. Acute renal failure following intravenous streptokinase infusion for acute myocardial infarction. Western Journal of Medicine. 1993;158(4):406-7. [pmid: 8317134].
996 Chapelle JP, Dubois B, Bovy C, et al. Comparison of plasma cardiac troponins T and I in chronically hemodialyzed patients in relation to cardiac status and age. Clin Chem Lab Med. Mar. 2002;40(3):240-5. [pmid: 12005213].
997 Ellis K, Dreisbach AW, Lertora JL. Plasma elimination of cardiac troponin I in end-stage renal disease. South Med J. Oct. 2001;94(10):993-6. [pmid: 11702827].
998 Fredericks S, Bainbridge K, Fenske CD, et al. Cardiac troponin-I content of skeletal muscle in patients with renal failure. Clin Biochem. Jul. 2002;35(5):421-3. [pmid: 12270775].
999 Fredericks S, Murray JF, Bewick M, et al. Cardiac troponin T and creatine kinase MB are not increased in exterior oblique muscle of patients with renal failure. Clin Chem. Jun. 2001;47(6):1023-30. [pmid: 11375287].
1000 Gagliardi GM, Rossi S, Manes MT, et al. Impact of left ventricular patterns and diastolic dysfunction on hemodialysis patients. G Ital Nefrol. Jan-Feb. 2004;21(1):45-50. [pmid: 15356847].
1001 Hill SA, Cleve R, Carlisle E, et al. Intra-individual variability in troponin T concentration in dialysis patients. Clin Biochem. Jul. 2009;42(10-11):991-5. [pmid: 19362083].
1002 Hussein MM, Mooij JM, Al Malki N, et al. Troponin-I is not falsely elevated in asymptomatic dialysis patients. Saudi J Kidney Dis Transpl. Jan. 2013;24(1):48-53. [pmid: 23354191].
1003 Irfan A, Twerenbold R, Reiter M, et al. Determinants of high-sensitivity troponin T among patients with a noncardiac cause of chest pain. Am J Med. May. 2012;125(5):491-8 e1. [pmid: 22482847].
1004 Jacobs L, Van De Kerkhof J, Mingels A, et al. Cardiac biomarkers in dialysis patients: Variations during a six month follow up. Nederlands Tijdschrift voor Klinische Chemie en Laboratoriumgeneeskunde. 2008;33(3):176-8.
1005 Jeon DS, Lee MY, Kim CJ, et al. Clinical findings in patients with cardiac troponin T elevation and end-stage renal disease without acute coronary syndrome. Am J Cardiol. Sep. 15. 2004;94(6):831-4. [pmid: 15374804].
1006 Keddis MT, El-Zoghby ZM, El Ters M, et al. Cardiac troponin T before and after kidney transplantation: determinants and implications for posttransplant survival. Am J Transplant. Feb. 2013;13(2):406-14. [pmid: 23137067].
1007 Kim SB, Lee SK, Min WK, et al. Lack of effects of low-dose aspirin on high-sensitivity C-reactive protein, hemostatic factors, and troponin T in CAPD patients. Perit Dial Int. Nov-Dec. 2002;22(6):721-3. [pmid: 12556076].
1008 Li D, Jialal I, Keffer J. Greater frequency of increased cardiac troponin T than increased cardiac troponin I in patients with chronic renal failure. Clin Chem. Jan. 1996;42(1):114-5. [pmid: 8565211].
1009 Nakamura T, Ushiyama C, Osada S, et al. Effect of dilazep dihydrochloride on serum cardiac troponin T levels in hemodialysis patients. Kidney Blood Press Res. 2002;25(1):50-4. [pmid: 11834877].
1010 Nakamura T, Ushiyama C, Shoji H, et al. Effects of hemoperfusion on serum cardiac troponin T concentrations using polymyxin B-immobilized fibers in septic patients undergoing hemodialysis. ASAIO J. Jan-Feb. 2002;48(1):41-4. [pmid: 11814097].
1011 Okura H, Suzuki R, Azuma Y, et al. The basic research on the high-sensitive troponin I assay, and the application to evaluation of chronic heart failure. Rinsho Byori. May. 2013;61(5):375-81. [pmid: 23947174].
1012 Resic H, Ajanovic S, Kukavica N, et al. Plasma levels of brain natriuretic peptides and cardiac troponin in hemodialysis patients. Bosn J Basic Med Sci. May. 2009;9(2):137-41. [pmid: 19485946].
1013 Selby NM, Fluck RJ, Taal MW, et al. Effects of acetate-free double-chamber hemodiafiltration and standard dialysis on systemic hemodynamics and troponin T levels. ASAIO J. Jan-Feb. 2006;52(1):62-9. [pmid: 16436892].
1014 van der Putten RF, te Velthuis HT, de Zwaan C, et al. State and diagnostic value of plasma tissue factor in early-hospitalised patients with chest pain. Br J Haematol. Oct. 2005;131(1):91-9. [pmid: 16173968].
1015 Wohrle J, Nusser T, Mayer C, et al. Intracoronary application of abciximab in patients with ST-elevation myocardial infarction. EuroIntervention. Jan. 2008;3(4):465-9. [pmid: 19736089].
1016 Wong CK, Szeto CC, Chan MH, et al. Elevation of pro-inflammatory cytokines, C-reactive protein and cardiac troponin T in chronic renal failure patients on dialysis. Immunol Invest. 2007;36(1):47-57. [pmid: 17190649].
1017 Woo YM, McLean D, Kavanagh D, et al. The influence of pre-operative electrocardiographic abnormalities and cardiovascular risk factors on patient and graft survival following renal transplantation. J Nephrol. Jul-Aug. 2002;15(4):380-6. [pmid: 12243367].
1018 Wood FO, Leonowicz NA, Vanhecke TE, et al. Mortality in patients with ST-segment elevation myocardial infarction who do not undergo reperfusion. Am J Cardiol. Aug. 15. 2012;110(4):509-14. [pmid: 22633204].
1019 Young PJ, Dalley P, Garden A, et al. A pilot study investigating the effects of remote ischemic preconditioning in high-risk cardiac surgery using a randomised controlled double-blind protocol. Basic Res Cardiol. 2012;107(3):256. [pmid: 22406977].
1020 Zahid M, Good CB, Singla I, et al. Clinical significance of borderline elevated troponin I levels across different assays in patients with suspected acute coronary syndrome. Am J Cardiol. Jul. 15. 2009;104(2):164-8. [pmid: 19576340].
1021 Zeman K, Pohludkova L, Spinar J, et al. Short-term prognosis and treatment of patients hospitalized for acute heart failure in a regional hospital without a cardiocentre. Vnitr Lek. Apr. 2012;58(4):273-9. [pmid: 22559800].
1022 Zumrutdal A, Bakinen O, Ucan H, et al. Relationship between uremic myopathy and false-positive cardiac troponin T test. Nephron. Dec. 2000;86(4):522-3. [pmid: 11124612].

## Other Reason for Exclusion

1023 McNeil AR. Implications of a rapid decrease in serum Troponin T levels after renal transplantation. Australian and New Zealand Journal of Medicine. 2000;30(5):638-9. [pmid: 11108079].
1024 Rinat C, Becker-Cohen R, Nir A, et al. B-type natriuretic peptides are reliable markers of cardiac strain in CKD pediatric patients. Pediatr Nephrol. Apr. 2012;27(4):617-25. [pmid: 22038201].