# Forms

Title Review

The title review form is shown from the Distiller SR online software program. A title and its authors are displayed with the choice of yes or no in a radio checkbox to the question “Is this article potentially relevant to our review.

Abstract Review

The abstract review form is shown from the Distiller SR online software program. The abstract, title, and authors are displayed. Next to them are exclusion and inclusion criteria to checkbox, as well as unclear, pull for handsearch, and a comment box.

Article Review

The article review form is shown from the Distiller SR online software program. The abstract, title, and authors are displayed and a hyperlink to the pdf. Next to them are exclusion and inclusion criteria to checkbox, as well as unclear, pull for handsearch, mark for background information, and a comment box.

Study Design

The study design form is shown from the Distiller SR online software program for data abstraction. There are various checkboxes, fill ins, and comments boxes to answer questions that describe the study design of the article being reviewed.

Population characteristics

The population characteristics form is shown from the Distiller SR online software program for data abstraction. There are various checkboxes, fill ins, and comments boxes to answer questions that describe the population characteristics of the article being reviewed. All groups are on a single form.

Key Question 1 Outcomes

The Key Question 1 outcomes form is shown from the Distiller SR online software program for data abstraction. There are various checkboxes, fill ins, and comments boxes to answer questions that describe the outcomes pertaining to Key Question 1 of the article being reviewed. One outcomes form is filled out per outcome.

Key Question 2-4 Outcomes

The Key Question 2-4 outcomes form is shown from the Distiller SR online software program for data abstraction. There are various checkboxes, fill ins, and comments boxes to answer questions that describe the outcome information such as incidence of outcome and measures of association if applicable of the article being reviewed. One outcomes form is filled out per outcome and timepoint.

Study Quality

The study quality form is shown from the Distiller SR online software program for data abstraction. The form is an adaptation of the Downs and Black Checklist for Measuring Study quality.