# Detailed Electronic Database Search Strategies

PubMed Strategy

Search | String
#1 | “kidney failure, chronic”[mh]
#2 | Renal[tiab]
#3 | Kidney[tiab]
#4 | Dialysis[tiab]
#5 | Hemodialysis[tiab]
#6 | Haemodialysis[tiab]
#7 | #1 OR #2 OR #3 OR #4 OR #5 OR #6
#8 | “acute coronary syndrome”[mh]
#9 | “acute coronary syndrome”[tiab] OR “acute coronary syndromes”[tiab]
#10 | “angina, unstable”[mh]
#11 | “unstable angina”[tiab]
#12 | “myocardial infarction”[tiab]
#13 | “Non-ST-segment elevation”[tiab] OR “non-ST-elevation”[tiab] OR “non-ST elevation”[tiab] OR “ST-segment elevation”[tiab] OR “ST-elevation”[tiab] OR “ST elevation”[tiab] OR (elevation[tiab] AND (ST[tiab] OR “S-T”[tiab] OR “ST-segment”[tiab]))
#14 | Acute[tiab]
#15 | #12 AND (#13 OR #14)
#16 | #8 OR #9 OR #10 OR #11 OR #15
#17 | “Troponin I”[mh] OR “Troponin T”[mh]
#18 | Troponin*[tiab]
#19 | #17 OR #18
#20 | (#7 AND #16) OR (#7 AND #19)
#21 | (animal[mh] NOT human [mh])
#22 | Addresses[pt] OR Autobiography[pt] OR Bibliography[pt] OR Biography[pt] OR “Case Reports”[pt] OR “Classical Article”[pt] OR “Clinical Conference”[pt] OR “Collected Works”[pt] OR Comment[pt] OR Congresses[pt] OR “Consensus Development Conference”[pt] OR “Consensus Development Conference, NIH”[pt] OR Dictionary[pt] OR Directory[pt] OR Editorial[pt] OR “Legal Cases”[pt] OR Legislation[pt] OR News[pt] OR “Newspaper Article”[pt] OR Portraits[pt]
#23 | #20 NOT #21 NOT #22
| Publication date from 1990/01/01

EMBASE Strategy

Search | String
#1 | ‘chronic kidney failure’/exp
#2 | “Renal”:ti,ab
#3 | “Kidney”:ti,ab
#4 | “Dialysis”:ti,ab
#5 | “Hemodialysis”:ti,ab
#6 | “Haemodialysis”:ti,ab
#7 | #1 OR #2 OR #3 OR #4 OR #5 OR #6
#8 | ‘acute coronary syndrome’/exp
#9 | “acute coronary syndrome”:ti,ab OR “acute coronary syndromes”:ti,ab
#10 | ‘unstable angina pectoris’/exp
#11 | “unstable angina”:ti,ab
#12 | “myocardial infarction”:ti,ab
#13 | “Non-ST-segment elevation”:ti,ab OR “non-ST-elevation”:ti,ab OR “non-ST elevation”:ti,ab OR “ST-segment elevation”:ti,ab OR “ST-elevation”:ti,ab OR “ST elevation”:ti,ab OR (“elevation”:ti,ab AND (“ST”:ti,ab OR “S-T”:ti,ab OR “ST-segment”:ti,ab))
#14 | “acute”:ti,ab
#15 | #12 AND (#13 OR #14)
#16 | #8 OR #9 OR #10 OR #11 OR #15
#17 | ‘Troponin i’/exp OR ‘Troponin T’/exp
#18 | Troponin*:ti,ab
#19 | #17 OR #18
#20 | (#7 AND #16) OR (#7 AND #19)
#21 | ([animals]/lim NOT [humans]/lim)
#22 | ‘conference abstracts’:it OR ‘conference paper’:it OR ‘conference reviews’:it OR editorial:it OR erratum:it OR letter:it OR note:it
#23 | #20 NOT #21 NOT #22
#24 | Publication date from 1990

Cochrane Strategy

Search | String
#1 | “kidney failure, chronic”:ti,ab,kw
#2 | Renal:ti,ab,kw
#3 | Kidney:ti,ab,kw
#4 | Dialysis:ti,ab,kw
#5 | Hemodialysis:ti,ab,kw
#6 | Haemodialysis:ti,ab,kw
#7 | #1 OR #2 OR #3 OR #4 OR #5 OR #6
#8 | “acute coronary syndrome”:ti,ab,kw
#9 | “acute coronary syndrome”:ti,ab,kw OR “acute coronary syndromes”:ti,ab,kw
#10 | “angina, unstable”:ti,ab,kw
#11 | “unstable angina”:ti,ab,kw
#12 | “myocardial infarction”:ti,ab,kw
#13 | “Non-ST-segment elevation”:ti,ab,kw OR “non-ST-elevation”:ti,ab,kw OR “non-ST elevation”:ti,ab,kw OR “ST-segment elevation”:ti,ab,kw OR “ST-elevation”:ti,ab,kw OR “ST elevation”:ti,ab,kw OR (elevation:ti,ab,kw AND (ST:ti,ab,kw OR “S-T”:ti,ab,kw OR “ST-segment”:ti,ab,kw))
#14 | Acute:ti,ab,kw
#15 | #12 AND (#13 OR #14)
#16 | #8 OR #9 OR #10 OR #11 OR #15
#17 | “Troponin I”:ti,ab,kw OR “Troponin T”:ti,ab,kw
#18 | Troponin*:ti,ab,kw
#19 | #17 OR #18
#20 | (#7 AND #16) OR (#7 AND #19)
| Publication date from 1990/01/01 and only trials