# Results

## Results of Literature Searches

Results of our searches appear in Figure 2. We included 167 published articles reporting on 135 studies. Of the included studies, 124 were randomized controlled trials, 5 were observational studies, and 6 were systematic reviews. Additional details describing the included studies are provided in the relevant sections of this results chapter.

Figure 2 Literature flow diagram

Figure 2 is titled, “Literature flow diagram” The figure is a flow chart that summarizes the search and selection of articles: There were 5,390 citations of randomized trials identified by searchingPubMed® (N=1,225), EMBASE (N=1,730), the Cochrane Library (N=958), CINAHL®(N=467) and PsycINFO®(N=1,010). In addition, 305 trials were identified in ClinicalTrials.gov, 130 trials were found in the World Health Organization's International Clinical Trials Registry Platform, 1 report from the National Institute for Clinical Excellence was found, 5 unique references were identified from a handsearch of 23 references, and 12 references were suggested by peer reviewers. After removal of duplicate citations, titles and abstracts of 3,460 references were screened for potential inclusion. Of these, 536 were deemed appropriate for full-text review to determine eligibility. After full-text review, 371 were excluded: 11 were in a language other than English; 23 were the wrong type of publication; 38 dealt with the wrong population; 72 had either the wrong intervention or wrong comparator; 66 did not report an outcome of intrest; 18 were not in an outpatient setting; 90 were excluded for wrong study design; 46 were trials of treatment shorter than 12 weeks, and 7 were outdated systematic reviews. One hundred sixty-five articles representing 140 studies are included in this report's qualitative synthesis, and 91 studies are included in quantitative analyses.

## Key Question 1 Efficacy and Comparative Effectiveness for Improving Consumption Outcomes

For this Key Question (KQ), we describe the characteristics of included trials and then results for alcohol consumption outcomes (return to any drinking, return to heavy drinking, drinking days, heavy drinking days, drinks per drinking day) for medications for which we included multiple trials. For medications with just 1 eligible trial, we graded the strength of evidence (SOE) as insufficient (because evidence was imprecise, unknown consistency, and medium or high risk of bias); information on the characteristics and results for medications with just 1 eligible trial is provided in Appendix E.

Throughout this KQ, we include headers and sections only for consumption outcomes with sufficient data for synthesis. Negative effect sizes favor medication over placebo. Positive effect sizes favor placebo. Studies typically included psychosocial co-interventions; thus, effect sizes reflect the added benefits of medications beyond those of psychosocial interventions. We describe the results of sensitivity analyses that included studies rated as high or unclear risk of bias only if they changed the effect size significantly. Results of all such sensitivity analyses are provided in Appendix F.

### Detailed Synthesis: Placebo-Controlled Trials of FDA-Approved Medications for Treating Alcohol Dependence

#### Acamprosate

##### Characteristics of Trials

Table 5 summarizes characteristics of the 22 trials meeting our inclusion criteria. The majority were parallel two-arm trials comparing acamprosate with placebo. Doses ranged from 1,000 to 3,000 mg per day; 1,998 mg per day (divided into 3 doses) was the most frequently used dose. Duration of treatment ranged from 12 to 52 weeks; most (18 trials) treated subjects for 12 to 26 weeks; 4 trials treated subjects for longer periods, 48 to 52 weeks. Followup to 1 year or longer was available for 8 trials.

Table 5 Characteristics of included double-blind randomized placebo-controlled trials of acamprosate

Author, Year Trial Name | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Country | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Anton, 2006^65^ Donovan, 2008^68^ COMBINE | ACA 3,000 + CBI + MM (151) ACA 3,000 + MM (152) NTX 100 + CBI + MM (155) NTX 100 + MM (154) Placebo + CBI + MM (156) Placebo + MM (153)^a^ | 16 (68) | U.S. | 11 U.S. academic sites | Ads, community resources, clinical referrals at 11 academic sites | 44 | 23 | 31 | NR | As randomized; Community support group participation (like AA) encouraged | Low
Baltieri, 2004^63^ | ACA 1,998 (40) Placebo (35) | 12 (24) | Brazil | Outpatient | Patients seeking treatment at an outpatient clinic for treatment of drug dependence | 18-60 | NR | 0 | 0 | AA encouraged | Medium
Berger, 2013^69^ | ACA 1,998 (51) Placebo (49) | 12 | U.S. | 2 outpatient primary care clinics | Provider referral and ads | 48 | 9 | 38 | NR | Brief structured behavioral intervention from primary care physician | Medium
Besson, 1998^70^ | ACA 1,300 to 1,998 (55) Placebo (55) | 52 (108) | Switzerland | Outpatient; 3 psychiatric treatment centers | From inpatient treatment unit | 42 | NR | 20 | 0 | Routine counseling 100% Voluntary disulfiram 22-24% | Medium
Chick, 2000^71^ | ACA 1,998 (289) Placebo (292) | 24 | U.K. | Outpatient | Recruited from treatment programs | 43 | NR | 16 | 0 | Usual psychosocial outpatient treatment program | Medium
Geerlings, 1997^72^ | ACA 1,332 to 1,998 (128) Placebo (134) | 26 (52) | Belgium, the Netherlands, and Luxembourg | Outpatient substance abuse treatment centers | Recruited from detoxification patients in same centers | 40-42 | NR | 24 | NR | ACA: benzodiazepines 5% Placebo: benzodiazepines 6% | Medium
Gual, 2001^73^ | ACA 1,998 (148) Placebo (148) | 26 | Spain | Outpatient; multicenter; hospitals | NR | 41 | NR | 20 to 21 | NR | NR | Medium
Kiefer, 2003^74^ Kiefer, 2004^75^ Kiefer, 2005^76^ | ACA 1,998 (40) NTX 50 (40) Placebo (40) ACA 1,998 + NTX 50 (40) | 12 | Germany | 1 site, Hamburg outpatient | Inpatient withdrawal treatment | 46 | NR | 26 | 0 | Group therapy | Low
Lhuintre, 1985^77^ | ACA 1,000 to 2,250 (42) Placebo (43) | 13 | France | Outpatient; methadone maintenance clinics | Recruited as inpatients within 48 hours of admission | 40 to 43 | NR | 11 | NR | Meprobamate 100% for first month | High
Lhuintre, 1990^78^ | ACA 1,332 (279) Placebo (290) | 12 | France | Outpatient; multicenter | Recruited within 48 hours of hospitalization for alcohol withdrawal | 42 to 43 | NR | 18 | NR | Psychotherapy allowed | Unclear
Mann, 2012^79^ PREDICT | ACA 1,998 (172) NTX 50 (169) Placebo (86) | 12 | Germany | NR | Recruited from inpatient facilities of 5 academic medical centers plus 2 state-run psychiatric hospitals | 45 | NR | 23 | NR | Medical management | Medium
Mason, 2006^66^ | ACA 2,000 (258) ACA 3,000 (83) Placebo (260) | 24 (32) | U.S. | 21 outpatient clinics^b^ | Primarily by newspaper ads | 44 to 45 | 14 to 15 | 29 to 36 | NR | Brief abstinence-oriented protocol-specific counseling and self-help materials 100% | Low
Morley, 2006^61^ Morley, 2010^80^ | ACA 1,998 (55) NTX 50 (53) Placebo (61) | 12 | Australia | 3 treatment centers with “medical care typically available at hospital based drug and alcohol treatment services” | Patients who had attended an inpatient detoxification program, outpatient treatment or followup or who responded to live or print ads | 45 | NR | 30 | Severe concurrent illness (psychiatric or other) –NOS 3 | All offered 4-6 sessions of manualized compliance therapy Up-take / attendance NR | Low
Paille, 1995^81^ | ACA 1.3 g (188) ACA 2 g (173) Placebo (177) | 52 (78) | France | NR^c^ | Referral from alcohol specialist centers | 43 | NR | 20 | NR | Supportive psychotherapy 100% Hypnotics 6 to 7% Anxiolytics 8 to 12% Antidepressants 8 to 9% | Medium
Pelc, 1996^82^; Pelc, 1992^83^ | ACA 1,332 to 1,998 (55) Placebo (47) | 26 | Belgium | Outpatient; multicenter | Post-inpatient detoxification | 43 | NR | 31 | NR | Supportive psychotherapy 100% | High
Pelc, 1997^64^ | ACA 1,332 (63) ACA 1,998 (63) Placebo (62) | 13 | Belgium, France | Outpatient; after inpatient detoxification | Inpatient referral | NR | NR | NR | NR | Counseling, social support when needed 100% | Medium
Poldrugo, 1997^84^ | ACA 1,332 to 1,998 (122) Placebo (124) | 26 (52) | Italy | Inpatient for 1-2 weeks then outpatient; multicenter community based alcohol rehabilitation program | From acute inpatient withdrawal treatment | 43 to 45 | NR | 23 to 31 | 0 | Community-based rehabilitation program with group sessions, alcohol education, community meetings 100% | Medium
Ralevski, 2011^62^; Ralevski, 2011^85^ | ACA 1,998 (12) Placebo (11) | 12 | U.S. | Outpatient; university and VA health centers | From community and through referrals from treatment facilities at a university and a VA facility | 51 | 65 | 17 | Schizophrenia spectrum disorders 100 | Weekly skills training that incorporated CB drug relapse prevention strategies 100% | High
Sass, 1996^86^ | ACA 1,332 to 1,998 (136) Placebo (136) | 48 (96) | Germany | Psychiatric outpatient | Outpatient referral | 41 to 42 | NR | 22 | NR | Counseling / psychotherapy 100% | Medium
Tempesta, 2000^87^ | ACA 1,998 (164) Placebo (166) | 26 (39) | Italy | Outpatient | Recruited from outpatient internal medicine, neurology and addiction treatment programs | 46 | NR | 17 | 0 | Medical and behavioral counseling | Medium
Whitworth, 1996^88^ | ACA 1,332 or 1,998 (224) Placebo (224) | 52 (104) | Austria | Outpatient specialty | Inpatient recruitment | 42 | NR | 21 | NR | NR | Medium
Wolwer, 2011^89^ | ACA 1,998 + IBT (124) ACA 1,998 + TAU (122)^d^ Placebo + IBT (125) | 24 (52) | Germany | Outpatient; 4 university hospitals 1 non-academic clinic | Recruited after inpatient detoxification | 46 | NR | 29 | NR | NR | Medium

AA = Alcoholics Anonymous; ACA = acamprosate; CB = cognitive behavioral; CBI = combined behavioral intervention; COMBINE = Combined Pharmacotherapies and Behavioral Intervention; IBT = integrative behavior therapy; mg = milligram; MM = medical management; N = number; NOS = not otherwise specified; NR = not reported; NTX = naltrexone; TAU = treatment as usual; U.K. = United Kingdom; U.S. = United States; VA = Veterans Affairs

Note: Age, Years is the mean age in years, unless otherwise stated.

a Three additional treatment arms were included in COMBINE but were not relevant to our Key Questions: ACA + NTX + CBI + MM, ACA + NTX + MM, and CBI only (no pills).

b Clinics were affiliated with academic medical centers and had investigators experienced in alcoholism treatment.

c The article was not explicit about the setting, but patients received psychotherapy and psychiatric medication management suggesting a psychiatric outpatient setting.

d Treatment as usual, seen once per week in an individual setting; MI techniques allowed.

The majority were conducted in Europe (16 trials); 4 were conducted in the United States, 1 in Brazil, and 1 in Australia. Recruitment methods varied, with trials typically identifying patients through treatment programs (e.g., inpatient detoxification, outpatient treatment), advertisements, referrals, or some combination of those.

Mean age was very similar across trials, usually in the early to mid-40s. All subjects met criteria for alcohol dependence in 21 trials; 1 trial did not report the proportion with alcohol dependence, but most subjects likely had alcohol dependence.61 Most studies did not report information on race; 1 trial reported enrolling a majority (65 percent) of nonwhite subjects.62 Most trials enrolled between 11 and 36 percent females; 1 trial enrolled all males,63 and 1 did not report information on sex.64 Just 4 trials reported information on smoking history at baseline; those trials had 46 to 81 percent smokers enrolled.61,65-67

The majority of trials either did not report information about how many subjects had co-occurring psychiatric conditions or excluded subjects with other psychiatric disorders; 1 trial enrolled subjects with alcohol dependence and schizophrenia spectrum disorders.62 Trials often included or encouraged psychological or psychosocial co-interventions.

##### Return to Any Drinking

Nineteen of the 22 trials reported sufficient data for meta-analysis. All but 1 study66 had point estimates trending in favor of acamprosate. Our meta-analysis of low and medium risk of bias trials found that 9 percent fewer subjects treated with acamprosate returned to any drinking than with placebo (risk difference [RD], -0.09; 95% CI, -0.14 to -0.04). Statistical heterogeneity was considerable (I^2^ 80.8 percent).

Differences in country and duration of treatment seem to explain much of the heterogeneity. The only 3 U.S.-based trials contributing data found no difference between acamprosate and placebo.65,66,69 Stratifying our meta-analysis by U.S. and non-U.S. studies found no difference for the 3 U.S.-based trials (RD, 0.03; 95% CI, -0.03 to 0.09), but found 12 percent fewer subjects treated with acamprosate returned to any drinking than with placebo for trials conducted in other countries (RD, -0.12; 95% CI, -0.16 to -0.08), and statistical heterogeneity decreased to the moderate range. Stratifying by duration of treatment (which corresponds to timing of outcome assessment used in analyses) found low heterogeneity among studies treating patients for 48 to 52 weeks, with an 11 percent absolute reduction in return to any drinking (RD, -0.11; 95% CI, -0.16 to -0.06; 4 trials).

##### Return to Heavy Drinking

Our meta-analysis found no significant difference between acamprosate and placebo (RD, -0.01; 95% CI, -0.04 to 0.03; I^2^ 0 percent; 7 trials).

##### Drinking Days

Patients treated with acamprosate had 8.8 percent fewer drinking days than those treated with placebo (weighted mean difference [WMD], -8.8; 95% CI, -12.8 to -4.8; 13 trials).

Three U.S.-based trials contributed data.65,66,69 Stratifying our meta-analysis by U.S. and non-U.S. studies found no difference for the 3 U.S.-based trials (WMD, -2.1; 95% CI, -6.4 to 2.1), but found that patients treated with acamprosate had 11.2 percent fewer drinking days than those treated with placebo for trials conducted in other countries (WMD, -11.2; 95% CI, -15.8 to -6.6). Stratifying by duration of treatment (which corresponds to timing of outcome assessment used in our analyses) found that patients treated with acamprosate had 12.2 percent fewer drinking days than those treated with placebo over 48 to 52 weeks (WMD, -12.2; 95% CI, -16.4 to -8.0; I^2^ 0 percent).

##### Heavy Drinking Days

Only 1 trial rated as low or medium risk of bias69 reported data for heavy drinking days. The trial found no significant difference between acamprosate and placebo (WMD, -2.6; 95% CI, -11.4 to 6.2)

##### Drinks per Drinking Day

Just 1 trial rated as low or medium risk of bias reported data. It found no statistically significant difference between acamprosate and placebo (WMD, 0.4; 95% CI, -1.8 to 2.6).61

#### Disulfiram

##### Characteristics of Trials

Table 6 summarizes characteristics of the four trials meeting our inclusion criteria. All four were conducted in Veterans Administration Medical Centers. Three compared disulfiram with placebo or riboflavin (which was intended as placebo); one compared disulfiram with naltrexone, placebo, and the combination of naltrexone and disulfiram.90 Doses for the intended active disulfiram arms were the same (250 mg per day) in all four trials. Two of the four trials were rated as high risk of bias, either primarily for high risk of attrition bias and inadequate handling of missing data,91 or primarily for high risk of ascertainment bias90; see Appendix C for details.

Table 6 Characteristics of included double-blind randomized placebo-controlled trials of disulfiram

Author, Year Trial Name | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Country | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Additional Condition | Co-intervention | Risk of Bias
Fuller, 1979^93^ | DIS 250 (43) DIS 1 (43) RIB 50 (42) | 52 | U.S. | Outpatient; VA hospital | Patients presenting to VA hospital requesting treatment for alcoholism or patients admitted for alcohol-related illness | 43 | 61 | 0 | NR | Counseling (unspecified) 100% | Medium
Fuller, 1986^92^ | DIS 250 (202) DIS 1 (204) RIB 50 (199) | 52 | U.S. | Outpatient; 9 VAMCs | Screened as inpatients in 7 centers and outpatients at 2 | 41 to 42 | 47 | 0 | NR | Counseling (loosely defined) % NR | Medium
Ling, 1983^91^ | DIS 250 (41) Placebo (41) | 37 | U.S. | Outpatient; VA | Unclear | 39 | NR | NR | Heroin use 80 Marijuana use 36 Other drug use 67 Depression 83 Moderate to high depression 50 | Methadone 100% | High
Petrakis, 2005^90^ Ralevski, 2007^94^ Petrakis, 2007^95^ Petrakis, 2006^96^ VA MIRECC | DIS 250 (66) NTX 50 (59) Placebo (64) NTX 50 + DIS 250 (65) | 12 | U.S. | Outpatient; VA | Recruited as outpatients or ad | 47 | 26 | 3 | Axis I disorder 100 | Psychiatric treatment as usual 100% | High for DIS vs. placebo

DIS = disulfiram; mg = milligram; MIRECC = Mental Illness Research, Education and Clinical Center; N = number; NR = not reported; NTX = naltrexone; RIB = riboflavin; U.S. = United States; VA = Veterans Affairs; VAMC = Veterans Administration Medical Center.

Note: Age, Years is the mean age in years, unless otherwise stated.

Duration of treatment ranged from 12 to 52 weeks. Three of the four trials followed subjects for 9 to 12 months. All four were conducted in the United States. Mean age was very similar across trials, ranging from 39 to 47 years. All subjects likely met criteria for alcohol dependence. Very few female subjects were enrolled (0 to 3 percent in the 3 trials reporting). None of the trials reported information on smoking history at baseline. One trial enrolled subjects with alcoholism who were also in methadone maintenance programs.91 Another enrolled subjects with co-occurring psychiatric disorders.90 Neither of the trials rated as medium risk of bias reported information on how many subjects had co-occurring psychiatric conditions.

##### Return to Any Drinking

Three of the four trials reported data. Our meta-analysis found no statistically significant difference between disulfiram 250 mg per day and disulfiram 1 mg per day or placebo, both without (RD, 0.04; 95% CI, -0.03 to 0.11) and with inclusion of the studies rated as high risk of bias (RD, -0.00; 95% CI, -0.10 to 0.09). Both medium risk of bias studies found point estimates favoring placebo/disulfiram 1 mg, but differences between groups were not statistically significant.

Our meta-analysis found no statistically significant difference between disulfiram 250 mg per day and riboflavin (i.e., no disulfiram) (RD, -0.04; 95% CI, -0.11 to 0.03). Both medium risk of bias studies found point estimates favoring disulfiram 250 mg per day, but differences between groups were not statistically significant.

The largest trial (N=605)92 reported a significant relationship between adherence and complete abstinence in all groups (disulfiram 250 mg, disulfiram 1 mg, and no disulfiram/riboflavin). The other trial assessed as medium risk of bias similarly reported that complete abstinence correlated significantly with adherence.93

##### Drinking Days

Both medium risk of bias trials reported some information about the percentage of drinking days. The smaller trial (N=128) reported no statistically significant differences among the three groups in percentage of drinking days (31 percent versus 32 percent versus 37 percent, for disulfiram 500/250, disulfiram 1, and riboflavin, respectively, p NR). The larger trial (N=605) reported this outcome only for the subset of subjects who drank and had a complete set of assessment interviews (N=162). It found that patients among this subset treated with disulfiram reported fewer drinking days than those given disulfiram 1 mg or those given riboflavin (49 percent versus 75.4 percent versus 86.5 percent, respectively, p=0.05).

#### Naltrexone

##### Characteristics of Trials

Table 7 summarizes characteristics of the 44 trials meeting our inclusion criteria. Less than half were parallel two-arm trials comparing naltrexone with placebo; most had three or more study arms. Four trials evaluated long-acting, injectable naltrexone, at doses from 150 to 400 mg per month.97-100 The rest administered oral naltrexone—32 trials used a dose of 50 mg per day, 6 used 100 mg per day,65,101-105 1 used 150 mg per day,106 and 1 used 100 mg on Mondays and Wednesdays and 150 mg on Fridays (weekly average of 50 mg per day).107 Duration of treatment ranged from 12 to 52 weeks; most (38 trials) treated subjects for 12 to 17 weeks; 6 trials included treatment with naltrexone for longer periods—24 to 52 weeks.97,103,108-111 Two of the latter groups included comparisons of different treatment durations for 50 mg per day, either comparing 12 versus 24 weeks111 or comparing 12 versus 52 weeks.110

Table 7 Characteristics of included double-blind randomized placebo-controlled trials of naltrexone

Author, Year Trial Name | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Country | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Additional Condition | Cointervention | Risk of Bias
Ahmadi, 2002^123^; Ahmadi, 2004^124^ | NTX 50 (58) Placebo (58) | 12 | Iran | Outpatient treatment | Self-referral | 43 | NR | 0 | NR | Individual counseling 100% | Unclear
Anton, 1999^125^; Anton, 2001^126^ | NTX 50 (68) Placebo (63) | 12 | U.S. | Outpatient academic research center | Ads, referrals for treatment-seekers | 41 to 44 | 11 to 18 | 27 to 31 | 0 | CBT 100% | Medium
Anton, 2005^127^ | NTX 50 + CBT (39) NTX 50 + MET (41) Placebo + CBT (41) Placebo + MET (39) | 12 | U.S. | Outpatient | Ads, referred to clinical service | 43 to 45 | 8 to 23 | 21 to 27 | NR | CBT and MET as randomized | Medium
Anton, 2006^65^ Donovan, 2008^68^ COMBINE | ACA^a^ 3,000 + CBI + MM (151) ACA 3,000 + MM (152) NTX 100 + CBI + MM (155) NTX 100 + MM (154) Placebo + CBI + MM (156) Placebo + MM (153) | 16 (68) | U.S. | 11 U.S. academic sites | Ads, community resources, clinical referrals at 11 academic sites | 44 | 23 | 31 | NR | As randomized; community support group participation (like AA) encouraged | Low
Anton, 2011^118^ | NTX 50 (50) Placebo (50) NTX 50 + 6 weeks gabapentin, with 1,200 maximum dose (50) | 16 | U.S. | Outpatient | NR | 43 to 47 | 13 | 18 | NR | Used COMBINE's manual (CBT + MM + 12-step techniques) 100% | Medium
Balldin, 2003^108^ | NTX 50 + CBT (25) NTX 50 +ST (31) Placebo + CBT (30) Placebo + ST (32) | 26 | Sweden | 10 sites outpatient | Newspaper, outpatient treatment | 48 to 51 | NR | 9 to 23 | 0 | None | Low
Baltieri, 2008^119^; Baltieri, 2009^128^ | TOP target 200, maximum 400 (52) NTX 50 (49) Placebo (54) | 12 | Brazil | Outpatient | NR | 44 to 45 | 29 | 0 | NR | Psychosocial 100% | High
Brown, 2009^120^ | NTX 50 (20) Placebo (23) | 12 | U.S. | Outpatient; university health center | Newspaper ads, physician referral, flyers and brochures at clinics | 41 | 26 | 49 | Bipolar (current depressed or mixed mood) 100 Cannabis abuse 21 Cocaine abuse 12 Amphetamine abuse 7 | CBT 100% | High
Chick, 2000^129^ | NTX 50 (90) Placebo (85) | 12 | U.K. | Outpatient | From patients starting outpatient alcohol rehabilitation program | 43 | NR | 25 | 0 | “Usual psychosocial treatment program” | Medium
Fogaca, 2011^130^ | NTX 50 (20) Placebo (20) NTX 50 + PUFA (20) PUFA (20) | 12 | Brazil | Outpatient | Newspaper and radio ads | NR | NR | 0 | NR | None | High
Garbutt, 2005^97^; Pettinati, 2009^131^; Lucey, 2008^132^ | NTX inj 380 every 4 weeks (208) NTX inj 190 every 4 weeks (210) Placebo (209) | 26 | U.S. | Inpatient and outpatient, private and VA | NR | 45 | 17 | 32 | NR | BRENDA^b^ standardized ST 100% | Medium
Gastpar, 2002^133^ | NTX 50 (84) Placebo (87) | 12 | Germany | 7 centers; outpatient | Outpatient and inpatient recruitment | 43 | 0 | 28 | 0 | Psychosocial treatment | Medium
Guardia, 2002^134^ | NTX 50 (101) Placebo (101) | 12 | Spain | 7 centers, outpatient | Recruited treatment-seeking patients | NR | NR | 25 | NR | Psychosocial | Medium
Heinala, 2001^109^ | NTX 50 daily for 12 weeks then targeted + CS (34) Placebo + CS (33) NTX 50 daily for 12 weeks then targeted + ST (29) Placebo + ST (25) | 32 | Finland | Outpatient | Ads | 46 | NR | 29 | 0 | None | High
Huang, 2005^112^ | NTX 50 (20) Placebo (20) | 14 | Taiwan | Alcoholism treatment unit of an inpatient psychiatric hospital; 1 week inpatient, remainder outpatient | Recruited as inpatients after admission for detoxification | 38 to 43 | 100 | 0 | NR | Weekly individual psychotherapy sessions 100% | High
Johnson, 2004^98^ | NTX inj 400 every 28 days (25) Placebo inj (5) | 17 | U.S., France, the Netherlands | 4 centers; outpatient | NR | 43 | 37 | 27 | NR | Psychosocial support 100% | High
Kiefer, 2003^74^ Kiefer, 2004^75^ Kiefer, 2005^76^ | ACA 1,998 (40) NTX 50 (40) Placebo (40) ACA 1,998 + NTX 50 (40) | 12 | Germany | 1 site; outpatient | Inpatient withdrawal treatment | 46 | NR | 26 | 0 | Group therapy | Low
Killeen, 2004^122^ | NTX 50 + TAU (54) Placebo + TAU(43) TAU alone (48) | 12 | U.S. | Outpatient community substance abuse treatment center | Clinic treatment seekers | 37 | 24 | 37 | Comorbid psychiatric disorder 51 Additional substance use disorder 35 | Several types and intensities | Medium
Kranzler, 2004^99^ | NTX inj once a month 150 (185) Placebo inj (157) | 12 | U.S. | Outpatient | Ads, recruited as outpatients | 44 | 17 to 18 | 33 to 37 | NR | MET 100% | Medium
Kranzler, 2009^135^ | NTX 50 targeted (38) NTX 50 once daily (45) Placebo targeted (39) Placebo once daily (41) | 12 | U.S. | Outpatient | Media ads, local provider referral | 49 | 3 | 42 | Drug use disorder <1 Social phobia 3 Antisocial personality disorder 3 Dysthymic disorder <1 Agoraphobia without panic disorder <1 OCD <1 GAD <1 | Brief coping skills training 100% | Medium
Krystal, 2001^110^ VACS 425 | NTX 50 for 12 months (209) NTX 50 for 3 months then placebo (209) Placebo (209) | 12 or 52 | U.S. | Multicenter, outpatient | VA clinics | 49 | 37 | 3 | 0 | 12-step facilitation | Medium
Latt, 2002^136^ | NTX 50 (56) Placebo (51) | 12 (26) | Australia | 4 hospitals ; outpatient | NR | 45 | NR | 30 | 0 | No extensive psychosocial interventions | Medium
Lee, 2001^113^ | NTX 50 (35) Placebo (18) | 12 | Singapore | Mixed: initially inpatient, discharged after 1 month from substance abuse treatment center | Direct recruitment from inpatient facility | 45 | ≥88 | 0 | NR | Intensive inpatient rehabilitation program; postdischarge therapy encouraged 100% | High
Longabaugh, 2009^111^ | NTX 50 for 24 weeks + BST (36) NTX 50 for 12 weeks then placebo for 12 weeks + BST (35) NTX 50 for 24 weeks + MET (33) NTX 50 for 12 weeks then placebo for 12 weeks + MET (38)^c^ | 12-24 (72) | U.S. | Outpatient | Newspaper ads | 44 to 46 | 6 to 14 | 33 to 43 | NR | None^d^ | Medium
Mann, 2012^79^ PREDICT | ACA 1,998 (172) NTX 50 (169) Placebo (86) | 12 | Germany | NR | Recruited from inpatient facilities of 5 academic medical centers plus 2 state-run psychiatric hospitals | 45 | NR | 23 | NR | Medical Management | Medium
Monterosso, 2001^101^ | NTX 100 (121) Placebo (62) | 12 | U.S. | Outpatient | Ads | 46 | 27 | 27 | NR | BRENDA^b^ | Medium
Monti, 2001^137^; Rohsenow, 2007^138^; Rohsenow, 2000^139^ | NTX 50 (64) Placebo (64) | 12 (52) | U.S. | 2 weeks partial hospital (pre-medication); 52 weeks outpatient | Recruited from partial hospital program in an urban private psychiatric hospital | 39 | 3 | 24 | Cocaine use 23 Sedative use 8 Opiate use 4 | Brief physician outpatient contacts (intensive therapy occurred prior to medication portion of trial) | Medium
Morgenstern, 2012^102^ | NTX 100 + MBSCT (51) NTX 100 (51) Placebo + MBSCT (50) Placebo (48) | 12 | U.S. | NR | Ads, community outreach | 40 | 26 | 0 | HIV 15 Any drug use 67 | BBCET 100% | Medium
Morley, 2006^61^ Morley, 2010^80^ | ACA 1,998 (55) NTX 50 (53) Placebo (61) | 12 | Australia | 3 treatment centers with “medical care typically available at hospital based drug and alcohol treatment services” | Patients who had attended an inpatient detoxification program, outpatient treatment, or followup or who responded to live or print ads | 45 | NR | 30 | Severe concurrent illness (psychiatric or other) –NOS 3 | All offered 4 to 6 sessions of manualized compliance therapy Up-take / attendance NR | Low
Morris, 2001^140^ | NTX 50 (55) Placebo (56) | 12 | Australia | Outpatient | Outpatient, self-referral | 47 | NR | 0 | PTSD 23 GAD 32 Panic disorder 4 MDD 6 BPD 1 | Group psychoeducation and social support | Medium
O'Malley, 1992^141^;O'Malley, 1996^142^ | NTX 50 + CS (29) NTX 50 + ST (23) Placebo + CS (25) Placebo + ST (27) | 12 (38) | U.S. | Outpatient; university alcohol treatment unit | Ads and those seeking treatment at unit | 41 | 7 | 26 | NR | See arms | Medium
O'Malley, 2007^117^ | NTX 50 (57) Placebo (50) Randomization stratified by presence of eating disorder | 12 | U.S. | University mental health center | Newspaper ads and patients seeking substance abuse treatment | 40 | 11 | 100 | Eating disorder 28 | CBCST 100%, based on manualized approach used in Project MATCH | Medium
O'Malley, 2008^42^ | NTX 50 (34) Placebo (34) NTX 50 + SERT 100 (33) | 16 | U.S. | Outpatient | Direct community recruitment, health clinic referral, local ads | 40 | 70 | 34 | NR | MM 100% | Medium
Oslin, 1997^107^ | NTX 100 on Monday and Wednesday, 150 on Friday (21) Placebo (23) | 12 | U.S. | Outpatient substance abuse clinic and VAMC | From a VA hospital | 58 | 64 | NR | 0 | Group therapy and case manager 100% | Medium
Oslin, 2008^103^ | NTX 100 + CBT (40) NTX 100 + BRENDA^b^ (39) NTX 100 + doctor only (41) Placebo + CBT (40) Placebo + BRENDA^b^ (40) Placebo + doctor only (40) | 24 | U.S. | Outpatient psychiatry clinic | Ads in local media | 41 | 27 | 27 | NR | None | Medium
Petrakis, 2004^121^; Ralevski, 2006^143^ | NTX 50 (16) Placebo (15) | 12 | U.S. | At least 3 outpatient centers—MIRECC clinics | Direct recruitment from participating centers | 46 | 19 | 0 | Schizophrenia or schizo-affective disorder 100 | CBT + psychiatric TAU Neuroleptics 52% Benzodiazepines 16% Thymoleptics 39% | Medium
Petrakis, 2005^90^ Ralevski, 2007^94^ Petrakis, 2007^95^ Petrakis, 2006^96^ VA MIRECC DBRCT | DIS 250 (66) NTX 50 (59) Placebo (64) NTX 50 + DIS 250 (65) | 12 | U.S. | Outpatient VA | Recruited as outpatient or ads | 47 | 26 | 3 | Axis I disorder 100 | Psychiatric TAU 100% | Medium for NTX vs. placebo
Pettinati, 2008^106^ | NTX 150 (82) Placebo (82) Subjects also randomized to either CBT or BRENDA^b^ (2×2 design)^e^ | 12 | U.S. | University-affiliated outpatient substance abuse treatment research facility | Those seeking treatment at the facility | 39 | 76 | 29 | Cocaine dependence 100 | NR | Medium
Pettinati, 2010^104^ | SERT 200 (40) NTX 100 (49) Placebo (39) SERT 200 + NTX 100 (42) | 14 | U.S. | Outpatient | Newspaper ads, referrals from local professional or friends/family | 43 | 35 | 38 | Depression 100 | CBT 100% | Medium
Schmitz, 2004^114^ | NTX 50 + RPT (20) NTX 50 + DC (20) Placebo + RPT (20) Placebo + DC (20) | 12 | U.S. | Outpatient | Ads | 36 | 71 | 16 | Cocaine dependence 100 | RPT or DC as randomized | High
Schmitz, 2009^105^ | NTX 100 + CBT (20) NTX 100 + CBT and CM (25) Placebo + CBT (27) Placebo + CBT and CM (14) | 12 | U.S. | Outpatient substance abuse clinic | Media ads | 34 | 84 to 93 | 13 | Cocaine use disorder 100 | CBT 100% | High
Volpicelli, 1995^115^ Volpicelli, 1992^144^ | NTX 50 (54) Placebo (45)^f^ | 12 | U.S. | Substance abuse treatment unit of a VAMC | Patients in the substance abuse treatment program of a VAMC | NR | ≥78 | 0 | NR | Outpatient treatment program and group therapy 100% | Unclear
Volpicelli, 1997^116^ | NTX 50 (48) Placebo (49) | 12 | U.S. | Outpatient substance abuse treatment, university/VA treatment research center | Receiving outpatient treatment | 38 to 39 | 60 to 65 | 18 to 26 | NR | Counseling 100% | Medium
ALK21-014, 2011^100^ | NTX inj 380 every 4 weeks (152) Placebo (148) | 12 | Germany, Austria | Outpatient | NR | 46 | NR | 20 | NR | NR | Medium

AA = Alcoholics Anonymous; ACA = acamprosate; BBCET = brief behavioral compliance enhancement treatment; BPD = bipolar disorder; BRENDA = BRENDA is an acronym based on the components of the intervention: (B)iopsychosocial evaluation, (R)eport to the patient on assessment, (E)mpathic understanding of the patient's situation, (N)eeds collaboratively identified by the patient and treatment provider, (D)irect advice to the patient on how to meet those needs, (A)ssess reaction of the patient to advice and adjust as necessary for best care; BST = broad spectrum treatment; CB = cognitive behavioral; CBCST = cognitive behavioral coping skills therapy; CBI = combined behavioral intervention; CBT = cognitive behavioral therapy; CS = coping skills; COMBINE = Combined Pharmacotherapies and Behavioral Intervention; DC = drug counseling; GAD = generalized anxiety disorder; HIV = human immunodeficiency virus; inj = injectable; MATCH = Matching Alcoholism Treatments to Client Heterogeneity; MBSCT = modified behavioral self-control therapy; MDD = major depressive disorder; MET = motivational enhancement therapy; mg = milligram; MIRECC = Mental Illness Research, Education and Clinical Center; MM = medical management; N = number; NOS = not otherwise specified; NR = not reported; NTX = naltrexone; OCD = obsessive-compulsive disorder; PTSD = post-traumatic stress disorder; PUFA = polyunsaturated fatty acid; RPT = relapse prevention therapy; SERT = sertraline; ST = supportive therapy; TAU = treatment as usual; TOP = topiramate; U.K. = United Kingdom; U.S. = United States; VA = Veterans Affairs; VACS = Veterans Affairs Cooperative Study; VAMC = Veterans Administration Medical Center.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Three additional treatment arms were included in COMBINE but were not relevant to our Key Questions: ACA + NTX + CBI + MM, ACA + NTX + MM, and CBI only (no pills).

b BRENDA is a psychosocial program designed to enhance medication and treatment compliance. The approach has six components: biopsychosocial evaluation, giving the patient a report of findings from the evaluation, empathy, addressing patient needs, providing direct advice, and assessing patient reaction to advice and adjusting the treatment plan as needed.

c Ns are numbers analyzed, numbers randomized to each group NR. Total number randomized was 174.

d This study is not focused on NTX versus placebo comparison; it is a different design and has 4 arms, aiming to compare 12 versus 24 weeks of NTX and to compare MET versus BST (to determine whether the type of psychosocial treatment delivered in combination with duration of NTX may partially explain inconsistent findings regarding efficacy of NTX).

e Study stratified randomization by sex and reports the results overall and separately by sex.

f Data are from Volpicelli 1995,^115^ which reported pooled results of 99 subjects. Data from a smaller subset (N=70) of this sample was reported in Volpicelli 1992.^144^ For our data analyses, we used data from Volpicelli 1995 to use the larger, more complete sample and did not use data from Volpicelli 1992 to avoid double counting.

The majority were conducted in the United States only (27 trials); 8 were conducted in Europe, 3 in Australia, 2 in Brazil, 1 multinational (United States, France, and the Netherlands), and 1 each in Singapore, Iran, and Taiwan. Recruitment methods varied, with trials typically identifying patients through treatment programs (e.g., inpatient detoxification, outpatient treatment), advertisements, referrals, or some combination of those.

Mean age was very similar across trials, usually in the 40s (34 trials) or 30s (6 trials); 3 trials did not report mean age, and 1 trial enrolled older subjects (mean age 58).107 All subjects met criteria for alcohol dependence in the vast majority of trials. Nine trials enrolled a majority of nonwhite subjects (60 to 100 percent).42,105-107,112-116 Most trials enrolled a third or fewer females; 1 trial enrolled all women.117 Just 9 trials reported information on smoking history at baseline, with most of those reporting a majority of smokers (55 to 77 percent) enrolled in those trials42,61,65,110,118-120 and 2 reporting a minority (17 and 47 percent).97,104

Eight trials reported enrolling all or a majority of subjects with co-occurring psychiatric disorders, including bipolar disorder,120 schizophrenia or schizoaffective disorder,121 cocaine use disorders,105,106,114 depression,104 another Axis I disorder,90 or any comorbid psychiatric disorder.122 Trials generally included or encouraged psychological or psychosocial co-interventions.

##### Return to Any Drinking

Our meta-analysis of low and medium risk of bias trials found that 4 percent fewer subjects treated with naltrexone returned to any drinking than with placebo (RD, -0.04; 95% CI, -0.07 to -0.01; 21 trials). Separating U.S.- and non-U.S.-based trials found no difference in point estimates by country (both found RD, -0.04), but the effect did not reach statistical significance for the non-U.S. trials (95% CI, -0.11 to 0.03; 7 trials). Stratifying by dose and delivery method found similar effect sizes for 50 mg per day orally (RD, -0.05), 100 mg per day orally (RD, -0.03), and injectable naltrexone (RD, -0.04), although the effect did not reach statistical significance for 100 mg per day or for injectable naltrexone.

##### Return to Heavy Drinking

Our meta-analysis of low and medium risk of bias trials found that 7 percent fewer subjects treated with naltrexone returned to heavy drinking than with placebo (RD, -0.07; 95% CI, -0.11 to -0.03; 23 trials). Including studies rated as high risk of bias resulted in a slightly larger effect size (RD, -0.09; 95% CI, -0.13 to -0.05; 27 trials). Separating U.S.- and non-U.S.-based trials found a small difference in point estimates by country (U.S. RD, -0.08; non-U.S. RD, -0.05), and the effect did not reach statistical significance for the non-U.S. trials (95% CI, -0.12 to 0.01; 10 trials). Stratifying by dose and delivery method found a trend toward greater effect sizes for 50 mg per day (RD, -0.09) than for 100 mg per day (RD, -0.05) or injectable naltrexone (RD, -0.01). The effect did not reach statistical significance for 100 mg per day or for injectable naltrexone, but those analyses had many fewer studies and subjects (and thus less precision) and confidence intervals overlapped for all three dose categories.

##### Drinking Days

Subjects treated with naltrexone had 4.6 percent fewer drinking days than those treated with placebo (WMD, -4.6; 95% CI, -6.6 to -2.5; 19 trials). All point estimates (of the individual studies) favored naltrexone over placebo. Stratifying our meta-analysis by U.S. and non-U.S. studies found similar effect sizes for U.S-based (WMD, -4.5) and non-U.S.-based trials (WMD, -4.7). The effect did not reach statistical significance for non-U.S.-based trials, but the analysis had fewer studies and subjects (and thus less precision) and confidence intervals overlapped.

Stratifying by dose and delivery method found a trend toward greater effect sizes for 50 mg per day (WMD, -5.4) than for 100 mg per day (WMD, -0.86); the single study of injectable naltrexone found a larger effect size (WMD, -8.6). The effect did not reach statistical significance for 100 mg per day (95% CI, -4.2 to 2.5).

##### Heavy Drinking Days

Subjects treated with naltrexone had 3.8 percent fewer heavy drinking days than those treated with placebo (WMD, -3.8; 95% CI, -5.8 to -1.8; 11 trials). Separating by U.S.- and non-U.S.-based trials found that the effect remained statistically significant for U.S.-based trials (WMD, -3.7; 95% CI, -5.8 to -1.6; 9 trials) but the pooled effect size did not reach statistical significance for the 2 non-U.S.-based studies (WMD, -5.8; 95% CI, -16.7 to 5.2).

##### Drinks per Drinking Day

Subjects treated with naltrexone had 0.5 percent fewer drinks per drinking day than those treated with placebo (WMD, -0.54; 95% CI, -1.01 to -0.07; 11 trials). Stratifying our meta-analysis by U.S. and non-U.S. studies found similar effect sizes for U.S.- and non-U.S.-based trials.

### Detailed Synthesis: Placebo-Controlled Trials of Medications Used Off-Label or Those Under Investigation

We found no studies meeting inclusion criteria for amitriptyline. We found 1 placebo-controlled trial for each of the following medications: aripiprazole, atomoxetine, desipramine, fluvoxamine, imipramine, olanzapine, ondansetron, paroxetine, and varenicline. We found insufficient evidence to support the efficacy of these medications. We provide additional details about the individual trials evaluating each of these medications in Appendix E.

We found multiple placebo-controlled trials for baclofen (2), buspirone (5), citalopram (2), fluoxetine (3), nalmefene (7), quetiapine (3), sertraline (7), topiramate (4), and valproic acid (2).

#### Baclofen

##### Characteristics of Baclofen Trials

Two trials met our inclusion criteria (Table 8). Both were parallel two-arm trials comparing baclofen with placebo for 12 weeks. Mean age was 49 years in both trials. All subjects met criteria for alcohol dependence. The trials enrolled 27 percent145 and 45 percent females.146 Neither trial reported information on smoking history at baseline. All patients included in 1 trial had liver cirrhosis.145 Both trials included psychological co-interventions.

Table 8 Characteristics of included double-blind randomized placebo-controlled trials of baclofen

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Additional Condition | Cointervention | Risk of Bias
Addolorato, 2007^145^ | BAC 30 (42) Placebo (42) | 12 | Italy; university treatment and research center | People contacting alcohol treatment unit | 49 | NR | 24 to 31 | Liver cirrhosis 100 Hepatitis B 15 Hepatitis C 29 | Routine psychological support 100% | Medium
Garbutt, 2010^146^ | BAC 30 (40) Placebo (40) | 12 | U.S.; outpatient, details NR | Newspaper and radio ads | 49 | 4 | 45 | NR | BRENDA 100% | Medium

BAC = baclofen; BRENDA = BRENDA is an acronym based on the components of the intervention: (B)iopsychosocial evaluation, (R)eport to the patient on assessment, (E)mpathic understanding of the patient's situation, (N)eeds collaboratively identified by the patient and treatment provider, (D)irect advice to the patient on how to meet those needs, (A)ssess reaction of the patient to advice and adjust as necessary for best care; mg = milligram; N = number; NR = not reported; U.S. = United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

##### Return to Any Drinking

The trial conducted in Italy reported that a lower percentage of patients treated with baclofen returned to any drinking than with placebo (29 percent [12 of 42 patients] versus 71 percent [30 of 42]; odds ratio [OR], 6.3; 95% CI, 2.4 to 16.1).145 The trial conducted in the United States did not report numbers for rates of return to any drinking, but reported no difference between groups for time to first usage (p=0.13), and included a figure for percentage abstinent that shows over 90 percent of subjects returned to any drinking over the course of the trial.146

##### Return to Heavy Drinking

The trial conducted in Italy reported a greater proportion of patients in the placebo group relapsing to heavy drinking than in the baclofen group (data not reported, shown in figure only, p=0.0062). Relapse was defined as a daily alcohol intake of more than 4 drinks or an overall consumption of 14 drinks or more per week during at least 4 weeks.145

The trial conducted in the United States found no significant difference between groups for the proportion of patients returning to heavy drinking (hazard ratio [HR], 0.924; p=0.76).146

##### Drinking Days

Only the U.S.-based trial reported data for percentage of drinking days. The trial found no significant difference between groups (baclofen versus placebo: 50.1 versus 49.4, p=0.50).146

##### Heavy Drinking Days

Only the U.S.-based trial reported data for percentage of heavy drinking days. The trial found no significant difference between groups (baclofen versus placebo: 25.9 versus 25.5, p=0.73).146

#### Buspirone

##### Characteristics of Buspirone Trials

We included 5 trials comparing buspirone with placebo (Table 9). Doses ranged from 40 to 60 mg per day. Duration of treatment ranged from 12 to 52 weeks. Four trials were conducted in the United States and 1 was conducted in Canada. Mean age was very similar across trials, in the early 40s. All subjects met criteria for alcohol dependence. Two studies did not report information on race; 3 reported enrolling between 0 and 18 percent nonwhite subjects across study arms. Three trials included no women; 2 included a minority of women (18 to 26 percent across study arms). None of the trials reported information on smoking history at baseline.

Table 9 Characteristics of included double-blind randomized placebo-controlled trials of buspirone

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Fawcett, 2000^149^ | Buspirone 40 (48) Placebo (52) Lithium 1,200 (56) | 26 | U.S.; Outpatient | Ad, referral, inpatient/outpatient programs | 40 | 16 | 0 | Depression 48 | Supportive therapy | Medium
George, 1999^151^ | Buspirone 60 (25) Placebo (24) | 52 | U.S.; Outpatient | Recruited from inpatient research unit at NIAAA | 42 | NR | 0 | 0 | Care of psychiatrist and nurse at posthospital clinic 100% | High
Kranzler, 1994^147^ | Buspirone 15-60, mean 52.5 (31) Placebo (30) | 12 (38) | U.S.; Outpatient; university health center | Ads | 39 to 40 | 0 to 10 | 20 to 26 | GAD 37 to 46 Anxiety disorder 50 to 52 MDD 25 to 27 | CBT 100% | Medium
Malcolm, 1992^148^ | Buspirone target 60, mean 52 (33) Placebo (34) | 26 | U.S.; 1-2 weeks inpatient, then outpatient; VAMC alcohol dependence treatment unit | Screened during inpatient stay for alcohol dependence treatment | 42 to 44 | 15 to 18 | 0 | GAD 100 | None | Medium
Malec, 1996^150^ | Buspirone 40 (28) Placebo (29) | 12 | Canada; hospital research center | Media ad | 42 | NR | 18 | NR | None prescribed but 37% received additional treatment: AA 7% Individual psychotherapy 3% | High

AA = Alcoholics Anonymous; CBT = cognitive behavioral therapy; GAD = generalized anxiety disorder; MDD = major depressive disorder; mg = milligram; N = number; NIAAA = National Institute on Alcohol Abuse and Alcoholism; NR = not reported; U.S. = United States; VAMC = Veterans Administration Medical Center.

Note: Age, Years is the mean age in years, unless otherwise stated.

Two trials enrolled a majority of subjects147 or all subjects148 with anxiety disorders; 1 included almost half with depression.149 Most trials included or encouraged psychological or psychosocial co-interventions.

##### Return to Any Drinking

Just 2 of the 5 trials reported data for return to any drinking;148,150 1 of them was rated as high risk of bias.150 Neither trial found a statistically significant difference between groups, and point estimates favored placebo in both trials.

##### Drinking Days

Two trials rated as medium risk of bias reported data.147,149 One trial (N=61) enrolling anxious alcoholics reported fewer drinking days for subjects treated with buspirone than for those who received placebo (at 12 weeks: 3.6 versus 13.3, p<0.10; at posttreatment follow up 26 weeks later: 9.5 versus 24.8, p<0.01).147 One trial comparing buspirone, lithium, and placebo found no significant difference between groups (over months 1 to 3: 7 percent versus 10 percent versus 8 percent, respectively).149 Our meta-analysis found no difference between buspirone and placebo (WMD, -3.4; 95% CI, -9.2 to 2.4; 2 trials).

##### Drinks per Drinking Day

Just 1 trial (N=61) enrolling anxious alcoholics reported drinks per day.147 It found no statistically significant difference between subjects treated with buspirone and those who received placebo over 12 weeks (0.7 versus 2.1, p NS), or at posttreatment follow up 26 weeks later (0.9 versus 4.8, p<0.10).

#### Citalopram

##### Characteristics of Citalopram Trials

We included 2 trials comparing citalopram 40 mg per day with placebo for 12 to 13 weeks (Table 10). Mean age was in the mid-40s for both trials. All subjects met criteria for alcohol dependence. Neither trial reported information on race. One trial enrolled all males152 and 1 enrolled 44 percent females.153 One did not report information on smoking history;152 1 included 34 percent smokers.153 Both trials included psychological or psychosocial co-interventions. We rated both trials as high risk of bias, primarily for high risk of attrition bias and inadequate handling of missing data (see Appendix C for details).

Table 10 Characteristics of included double-blind randomized placebo-controlled trials of citalopram

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Setting | Recruitment Method | Age, Years | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Naranjo, 1995^153^ | Citalopram 40 (53) Placebo (46) | 12 (20) | Canada; outpatient research center | Newspaper ad | 45 | 44 | NR | Brief psychosocial intervention 100% | High
Tiihonen, 1996^152^ | Citalopram 40 (31) Placebo (31) | 13 (17) | Finland; outpatient; community-based alcohol rehabilitation center | Inpatient / outpatient referral | 45 to 47 | 0 | 0 | Supportive psychotherapy intervention 100% | High

mg = milligram; N = number; NR = not reported.

Note: Age, Years is the mean age in years, unless otherwise stated.

##### Return to Any Drinking

The trial conducted in Finland reported 25 of 31 citalopram-treated patients and 28 of 31 placebo-treated patients returned to any drinking (p=0.10).152

##### Drinking Days

The trial conducted in Canada found similar proportions of drinking days for those who received citalopram and those who received placebo over the 12 weeks of treatment (72.7 percent versus 76.5 percent, p NS).153

##### Drinks per Drinking Day

The trial conducted in Canada found similar reductions in drinks per drinking day for those who received citalopram and those who received placebo over the 12 weeks of treatment (26.1 percent versus 26.4 percent, p NS).153

#### Fluoxetine

##### Characteristics of Fluoxetine Trials

We included 3 trials comparing fluoxetine with placebo (Table 11). Doses ranged from 20 to 60 mg per day. Duration of treatment ranged from 12 to 15 weeks. All 3 trials were conducted in the United States. Mean age ranged from 35 to 47. All subjects met criteria for alcohol dependence. For 2 trials, about half of enrolled subjects were nonwhite;154,155 1 enrolled 5 percent nonwhite subjects.156 One trial enrolled all males;155 the other 2 enrolled 20 percent156 or 49 percent154 females. None of the trials reported information on smoking history at baseline. One trial only enrolled subjects with major depressive disorder and alcohol dependence.154 Two trials included or encouraged psychological or psychosocial co-interventions.

Table 11 Characteristics of included double-blind randomized placebo-controlled trials of fluoxetine

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Cornelius, 1997^154^; Cornelius, 1995^157^ | Fluoxetine 20-40 (25) Placebo (26) | 12 | U.S.; inpatient psychiatric institute | Recruited as inpatient | 35 | 53 | 49 | MDD 100% | Usual care: psychotherapy 100% | Medium
Kabel, 1996^155^ | Fluoxetine 20-60 (15) Placebo (13) | 15 | U.S.; inpatient substance abuse treatment | Inpatient recruitment | 47 | 46 | 0 | Cocaine use 14% | NR | High
Kranzler, 1995^156^ | Fluoxetine 20-60, mean 47 (51) Placebo (50) | 12 (38) | U.S.; outpatient clinic | Ads | 40 | 5 | 20 | Major depression 14% | Group psychotherapy 79% Individual psychotherapy 21% | Medium

MDD = major depressive disorder; mg = milligram; N = number; NR = not reported; U.S. = United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

##### Return to Any Drinking

Two small trials, 1 rated as medium risk of bias (N=51) and 1 rated as high risk of bias (N=28), reporting return to any drinking found no statistically significant difference between fluoxetine and placebo.154,155

##### Drinking Days

Both medium risk of bias trials reported drinking days. Our meta-analysis of these 2 trials found no statistically significant difference between fluoxetine and placebo (WMD, -3.2; 95% CI, -18.2 to 11.9), but statistical heterogeneity was considerable (I^2^ 82.7 percent). The trial enrolling subjects who all had major depressive disorder (N=51) found that subjects treated with fluoxetine had fewer drinking days than those who received placebo (WMD, -11.6; 95% CI, -22.7 to -0.5). The trial enrolling a population with 14 percent of subjects with major depression found no difference between groups, and a point estimate trending in favor of placebo (WMD, 3.8; 95% CI, -2.1 to 9.7).

##### Heavy Drinking Days

The trial enrolling subjects who all had major depressive disorder (N=51) reported fewer heavy drinking days for subjects treated with fluoxetine than for those who received placebo (cumulative number of days of heavy drinking: 4.8 versus 16, p=0.04).

##### Drinks per Drinking Day

Both medium risk of bias trials reported this outcome. Similar to the analysis for drinking days, our meta-analysis of these 2 trials found no statistically significant difference between fluoxetine and placebo (WMD, -1.2; 95% CI, -4.6 to 2.2), but statistical heterogeneity was considerable (I^2^ 78.3 percent). The trial enrolling subjects who all had major depressive disorder (N=51) found that subjects treated with fluoxetine had fewer drinks per drinking day than those who received placebo (WMD, -3.0; 95% CI, -5.4 to -0.6). The trial enrolling a population with 14 percent of subjects with major depression found no difference between groups, and a point estimate trending in favor of placebo (WMD, 0.5; 95% CI, -1.6 to 2.6).

#### Nalmefene

##### Characteristics of Nalmefene Trials

We included 7 trials comparing nalmefene with placebo (Table 12). Doses ranged from 5 to 80 mg per day. Four trials assessed targeted dosing, instructing patients to take the medication when they believed drinking to be imminent, rather than as a daily scheduled medication.158-161 Duration of treatment ranged from 12 to 52 weeks. Three trials were conducted in the United States, 1 in Finland, and 3 were multi-national. Mean age was in the 40s in all but 1 trial. All subjects met criteria for alcohol dependence in 6 trials; 1 trial reported that 93 percent met criteria for alcohol dependence.158 The trials enrolled 0 to 19 percent nonwhite subjects and from 19 to 37 percent females across study arms. None of the trials reported information on smoking history at baseline. The proportion of subjects with co-occurring psychiatric conditions was either zero or was not reported.

Table 12 Characteristics of included double-blind randomized placebo-controlled trials of nalmefene

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Anton, 2004^164^ | NALM 5 (68) NALM 20 (66) NALM 40 (68) Placebo (68) | 12 | U.S.; outpatient | Ads, recruited as outpatients | 44 to 46 | 6 to 15 | 22 to 33 | NR | MET 100% | Medium
Gual, 2013^160^ ESENSE 2 | NALM 20 as-needed (358) Placebo (360) | 24 | Belgium, Czech Republic, France, Italy, Poland, Portugal, Spain; 57 sites | Referrals and ads | 44 to 45 | 1 | 26 to 29 | 0 | BRENDA | Medium
Karhuvaara, 2007^158^ | NALM 10 to 40 Targeted dose^a^ (242) Placebo (161) | 28^b^ | Finland; 15 sites^c^ | Mainly by newspaper ads | 49 | 0 | 19 | NR | Some elements of BRENDA | Medium
Mann, 2013^159^ ESENSE 1 | NALM 20 as-needed (306) Placebo (298) | 24 | Austria, Finland, Germany, Sweden; 39 sites | Referrals and ads | 52 | <1 | 32 to 33 | 0 | BRENDA | Medium
Mason, 1994^163^ | NALM 10 (7) NALM 40 (7) Placebo (7) | 12 | U.S.; NR | Ads | 42 | 10 | 29 | 0 | Group therapy 0 to 14% AA 0 to 29% | High
Mason, 1999^162^ | NALM 20 or 80 (70) Placebo (35) | 12 | U.S.; outpatient substance abuse treatment; academic research center | Ads, press releases, other non-specified sources | 42 | 17 to 19 | 31 to 37 | 0 | CBT (used in MATCH) 100% | Medium
SENSE, 2013^161^ | NALM 20 as-needed (509) Placebo (166) | 52 (56) | Czech Republic, Estonia, Hungary, Latvia, Lithuania, Poland, Russian Federation, Slovakia, Ukraine, U.K. | NR | 44 | NR | 23 | NR | NR | High

AA = Alcoholics Anonymous; BRENDA = BRENDA is an acronym based on the components of the intervention: (B)iopsychosocial evaluation, (R)eport to the patient on assessment, (E)mpathic understanding of the patient's situation, (N)eeds collaboratively identified by the patient and treatment provider, (D)irect advice to the patient on how to meet those needs, (A)ssess reaction of the patient to advice and adjust as necessary for best care; CBT = cognitive behavioral therapy; ESENSE/SENSE = Safety and Efficacy of Nalmefene in Patients With Alcohol Dependence; MATCH = Matching Alcoholism Treatments to Clinical Heterogeneity; MET = motivational enhancement therapy; mg = milligram; N = number; NALM = nalmefene; NR = not reported; U.K. = United Kingdom; U.S. = United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Targeted dosing; medication was taken when subjects believed drinking to be imminent, rather than as a daily scheduled medication.

b 52 weeks total (28 weeks of initial nalmefene vs. placebo, then another randomization for nalmefene responders).

c Sites included 5 specialist treatment clinics, 6 private general practices, 2 occupational health care offices, and 2 outpatient clinical research facilities.

##### Return to Heavy Drinking

Two trials, 1 rated as medium risk of bias (N=105)162 and 1 pilot study rated as high risk of bias (N=21),163 reported return to heavy drinking. The former found that 23 percent fewer patients treated with nalmefene returned to heavy drinking than with placebo (RD, -0.23; 95% CI, -0.43 to -0.03). The pilot study found no difference between groups (RD, -0.05; 95% CI, -0.51 to 0.41).

##### Drinking Days

Our meta-analysis of 2 trials,158,162 both rated as medium risk of bias, that reported data for this outcome found no significant difference between nalmefene and placebo (WMD, -1.1; 95% CI, -7.6 to 5.4).

##### Heavy Drinking Days

The trial conducted in Finland (N=403)158 that assessed targeted dosing reported a lower percentage of heavy drinking days for patients treated with targeted nalmefene than for those who received placebo (18.1 percent versus 29.7 percent, p=0.024). The ESENSE1 trial (N analyzed=365)159 reported a greater reduction from baseline to month 6 in number of monthly heavy drinking days in patients treated with as-needed nalmefene than for those who received placebo (mean difference, -2.3; 95% CI, -3.8 to -0.8). Similarly, the ESENSE2 trial (N analyzed =441)160 reported a difference favoring nalmefene at month 6 (mean difference, -1.7; 95% CI, -3.1 to -0.3). The SENSE trial (N analyzed=430) did not find a difference in monthly heavy drinking days between the 2 treatments at month 6, but did report a difference at month 13 (mean difference, -1.6; 95% CI, -2.9 to -0.2). Our meta-analysis of the 2 medium risk of bias studies159,160 found a statistically significant difference between nalmefene and placebo for change in heavy drinking days over the past month (WMD, -1.98; 95% CI, -3.0 to -0.96).

##### Drinks per Drinking Day

Three of the trials rated as medium risk of bias reported data.158,162,164 Our meta-analysis found that subjects treated with nalmefene had 1 fewer drink per drinking day than those who received placebo (WMD, -1.0; 95% CI, -1.8 to -0.3).

#### Quetiapine

##### Characteristics of Quetiapine Trials

We included 3 trials comparing quetiapine with placebo for 12 weeks (Table 13). All 3 trials were conducted in the United States. Mean age ranged from late 30s to late 40s. All subjects met criteria for alcohol dependence in 2 trials; 1 reported that 97 percent of subjects met criteria.165 Just 1 trial reported information on smoking history at baseline, with 56 percent smokers enrolled.166 For 2 trials, all subjects had co-occurring bipolar disorder.165,166 We rated all 3 trials as high risk of bias, primarily for high risk of attrition bias, high risk of selection bias, and inadequate handling of missing data (see Appendix C for details).

Table 13 Characteristics of included double-blind randomized placebo-controlled trials of quetiapine

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Brown, 2008^165^ | QUET titrated from 25 to 600 over 6 weeks (52) Placebo (50) | 12 | U.S.; NR | From community | 38 | 39 | 37 | Bipolar 100 | NR | High
Kampman, 2007^167^ | QUET 400 (29) Placebo (32) | 12 | U.S.; outpatient | Community referrals, media ads | 47 | 46 | 23 | MDD 15 Antisocial personality disorder 11 PTSD 8 Panic disorder 5 Social phobia 5 GAD 3 OCD 2 | BRENDA 100% | High
Stedman, 2010^166^ | QUET 300-800 (175) Placebo (186) | 12 | U.S.; outpatient; multicenter | NR | 39 | 12 | 37 | Bipolar 100 | None | High

BRENDA = BRENDA is an acronym based on the components of the intervention: (B)iopsychosocial evaluation, (R)eport to the patient on assessment, (E)mpathic understanding of the patient's situation, (N)eeds collaboratively identified by the patient and treatment provider, (D)irect advice to the patient on how to meet those needs, (A)ssess reaction of the patient to advice and adjust as necessary for best care; GAD = generalized anxiety disorder; MDD = major depressive disorder; mg = milligram; N = number; NR = not reported; OCD = obsessive-compulsive disorder; PTSD = post-traumatic stress disorder; QUET = quetiapine; U.S. = United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

##### Return to Any Drinking

The trial that did not enroll subjects with co-occurring bipolar disorder reported that more subjects treated with quetiapine achieved complete abstinence (9 of 29 patients versus 2 of 32, p=0.012)—that is, fewer subjects treated with quetiapine returned to any drinking (20 of 29 versus 30 of 32).

##### Drinking Days

All 3 trials reported this outcome. Our meta-analysis of the 3 trials found no difference between patients treated with quetiapine and those who received placebo (WMD, -2.7; 95% CI, -12.8 to 7.5).

##### Heavy Drinking Days

All 3 trials reported this outcome. Our meta-analysis of the 3 trials found no difference between patients treated with quetiapine and those who received placebo (WMD, -3.1; 95% CI, -10.1 to 4.0).

#### Sertraline

##### Characteristics of Sertraline Trials

We included 7 trials comparing sertraline with placebo (Table 14). Doses ranged from 50 to 200 mg per day. Duration of treatment ranged from 12 to 26 weeks. The majority were conducted in the United States (5 trials); 1 was conducted in Turkey and 1 in Spain. Mean age was very similar across trials, usually in the 40s. All subjects met criteria for alcohol dependence in 6 trials; 1 trial reported that 99 percent of subjects met criteria for alcohol dependence.168 The percentage of nonwhite subjects enrolled was not reported by 3 trials, was a small minority (1 to 8 percent) in 2 trials, was about a third in 1 trial, and was the majority (80 percent) in 1 trial. Six trials enrolled between 19 and 48 percent females; 1 enrolled all men.169 Just 1 trial reported information on smoking history at baseline, with 17 percent smokers enrolled.104 Most trials enrolled subjects with comorbidities—3 only included patients with depressive disorders;104,168,170 1 only included those with post-traumatic stress disorder (PTSD);171 and 1 reported that about half of subjects had depression.172 Trials typically included or encouraged psychological or psychosocial co-interventions.

Table 14 Characteristics of included double-blind randomized placebo-controlled trials of sertraline

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Brady, 2005^171^ | SERT 150 (49) Placebo (45) | 12 | U.S.; outpatient | Ads, outpatient substance abuse treatment programs | 37 | NR | 43 to 49 | PTSD 100 Depressive disorder 51 Anxiety disorder 38 | CBT 100% | Medium
Coskunol, 2002^169^ | SERT 100 (30) Placebo (29) | 26 | Turkey; inpatient (mean 1 month) followed by 6 months outpatient; substance abuse treatment unit | NR | 44 | NR | 0 | For eligibility, required no concurrent Axis I disorders | Thiamine 500 mg per day 100% Pyridoxone 500 mg per day 100% AA during inpatient 100% | Medium
Gual, 2003^170^ | SERT 50-150 (44) Placebo (39) | 24 | Spain; 1 center; outpatient | Outpatient alcohol dependence treatment | 47 | NR | 47 | Depression/ dysthymia 100 | NR | Medium
Kranzler, 2011^173^; Kranzler, 2012^174^ | SERT 50-200 (63) Placebo (71) | 12 (26) | U.S.; outpatient; university health center | Primarily ads, some clinician referrals | 48 | 8 | 19 | Cannabis use disorder 17.2 Cocaine use disorder 19.4 Past MDD 20.9 | Coping skills training 100% | Medium
Moak, 2003^168^ | SERT 50-200 (38) Placebo (44) | 12 | U.S.; 1 site; outpatient | Newspaper, outpatient treatment | 41 | 1 | 39 | Depression/ dysthymia 100 | CBT | Medium
Pettinati, 2001^172^ | SERT 200 (50) Placebo (50) | 14 | U.S.; outpatient | Ads and referral | 44 | 80 | 48 | Depression 47 | 12-step facilitation | Unclear
Pettinati, 2010^104^ | SERT 200 (40) NTX 100 (49) Placebo (39) SERT 200 + NTX 100 (42) | 14 | U.S.; outpatient | Newspaper ads and referrals | 43 | 35 | 38 | Depression 100 | CBT 100% | Medium

CBT = cognitive behavioral therapy; MDD = major depressive disorder; mg = milligram; N = number; NR = not reported; NTX = naltrexone; PTSD = post-traumatic stress disorder; SERT = sertraline; U.S. = United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

##### Return to Any Drinking

Just 1 trial reported this outcome—the trial that compared sertraline, naltrexone, sertraline plus naltrexone, and placebo.104 It found similar proportions of patients treated with sertraline returning to any drinking as with placebo (29 of 40 patients versus 30 of 39, p NS).

##### Return to Heavy Drinking

Two of the trials reported this outcome—the trials conducted in Turkey and Spain.169,170 Our meta-analysis found no difference between patients treated with sertraline and those who received placebo (RD, -0.04; 95% CI, -0.31 to 0.23).

##### Drinking Days

Four of the trials reported this outcome—the trial conducted in Spain,170 the 2 trials conducted in the United States rated as medium risk of bias,168,173 and the U.S.-based trial rated as unclear risk of bias.172 Our meta-analysis found no significant difference between patients treated with sertraline and those who received placebo, both without (WMD, 1.8; 95% CI, -6.3 to 9.9) and with inclusion of the trial rated as unclear risk of bias (WMD, 0.6; 95% CI, -5.7 to 7.0).

##### Heavy Drinking Days

Two trials reported this outcome.171,173 One trial enrolled patients with PTSD and alcohol dependence (N=94),171 and the other did not require a co-occurring condition for study entry (N=134). Both trials reported numerically more heavy drinking days for patients treated with sertraline than for those who received placebo.171Our meta-analysis found a statistically significant difference in favor of placebo (WMD, 1.9; 95% CI, 0.7 to 3.0)—i.e., more heavy drinking days for those who received sertraline.

##### Drinks per Drinking Day

Two of the trials reported this outcome—the trial conducted in South Carolina (N=82)168 and the U.S.-based trial that enrolled patients with PTSD and alcohol dependence (N=94).171 Our meta-analysis found no significant difference between patients treated with sertraline and those who received placebo (WMD, -0.9; 95% CI, -2.2 to 0.5).

#### Topiramate

##### Characteristics of Topiramate Trials

We included 4 trials comparing topiramate with placebo for 12 to 14 weeks (Table 15). Two trials were conducted in the United States, 1 in Brazil, and 1 in Spain. Mean age was in the 40s in all 4 trials. All subjects met criteria for alcohol dependence in 3 trials; 1 trial did not report the proportion with alcohol dependence, but most subjects likely had alcohol dependence.175 Two trials enrolled all males;119,176 the other 2 included from 26 to 40 percent females across study arms. The 2 non-U.S.-based trials reported information on smoking history at baseline, with 66 to 80 percent smokers enrolled in those trials.119,176 Three of the 4 trials offered or included psychological or psychosocial co-interventions.

Table 15 Characteristics of included double-blind randomized placebo-controlled trials of topiramate

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Baltieri, 2008^119^; Baltieri, 2009^128^ | TOP target 200, maximum 400 (52) NTX 50 (49) Placebo (54) | 12 | Brazil; outpatient | NR | 44 to 45 | 29 | 0 | NR | Psychosocial 100% | High
Johnson, 2003^175^ Ma, 2006^177^; Johnson, 2004^178^ | TOP 25-300 (75) Placebo (75) | 12 | U.S.; 1 site; outpatient | Newspaper | 41 | NR | 28 to 40 | 0 | None | Medium
Johnson, 2007^179^ Johnson, 2008^180^ | TOP 50-300, mean 171 (183) Placebo (188) | 14 | U.S.; 17 academic sites | From academic sites; by newspaper, radio, television ads | 47 to 48 | 15 | 26 to 28 | NR | BBCET 100% | Low
Rubio, 2009^176^ | TOP 250 (31) Placebo (32)^a^ | 12 | Spain; outpatient | NR | 42 | NR | 0 | NR | Supportive group therapy offered | High

BBCET = brief behavioral compliance enhancement treatment; mg = milligram; N = number; NR = not reported; NTX = naltrexone; TOP = topiramate; U.S. = United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Numbers entered are those analyzed; 76 total were randomized, but dropouts were not reported by arm.

##### Return to Any Drinking

Just 1 trial reported this outcome—the trial conducted in Brazil that was rated as high risk of bias.119 It reported that more patients treated with topiramate returned to any drinking than with placebo (24 of 52 patients versus 15 of 54).

##### Drinking Days

Three of the trials reported this outcome—2 U.S.-based trials rated as low (N=371)179 or medium risk of bias (N=150)175 and the trial conducted in Spain (N=63) that was rated as high risk of bias.176 The trial rated as low risk of bias found a lower percentage of drinking days for patients treated with topiramate than for those who received placebo (WMD, -8.5; 95% CI, -15.9 to -1.1); meta-analysis combining this trial with the trial rated as high risk of bias found a lower percentage of drinking days for patients treated with topiramate than for those who received placebo (WMD, -9.7; 95% CI, -16.4 to -3.1). We were unable to include the smaller U.S.-based trial (N=150) in the meta-analysis due to differences in the type of data reported—it reported that subjects treated with topiramate had a greater percentage of days abstinent than those who received placebo (mean difference -11.6, 95% CI, -3.98 to -19.3).

##### Heavy Drinking Days

Three of the trials reported this outcome—2 U.S.-based trials rated as low (N=371)179 or medium risk of bias (N=150)175 and the trial conducted in Spain (N=63) that was rated as high risk of bias.176 Our meta-analysis found a lower percentage of heavy drinking days for patients treated with topiramate than for those who received placebo both without (WMD, -11.5; 95% CI, -18.3 to -4.8) and with inclusion of the trial rated as high risk of bias (WMD, -12.5; 95% CI, -17.9 to -7.2).

##### Drinks per Drinking Day

Three of the trials reported this outcome—2 U.S.-based trials rated as low (N=371)179 or medium risk of bias (N=150)175 and the trial conducted in Spain (N=63) that was rated as high risk of bias.176 Our meta-analysis found that patients treated with topiramate had fewer drinks per drinking day than those treated with placebo both without (WMD, -1.1; 95% CI, -1.7 to -0.4) and with inclusion of the trial rated as high risk of bias (WMD, -1.2; 95% CI, -1.8 to -0.6).

#### Valproic Acid

##### Characteristics of Valproic Acid Trials

We included 2 trials comparing valproic acid with placebo (Table 16). Duration of treatment ranged from 12 to 24 weeks. Both trials were conducted in the United States. Mean age was very similar across trials, 38 to 40. All subjects met criteria for alcohol dependence. The trials enrolled from 25 percent181 to 54 percent182 nonwhite subjects, and from 29 percent181 to 62 percent182 women. Just 1 of the trials reported information on smoking history at baseline, reporting that 71 percent of subjects were smokers.181 One trial only enrolled subjects with bipolar disorder.181 Both trials included co-interventions—1 with lithium and weekly dual diagnosis (alcohol dependence and bipolar disorder) recovery counseling,181 and 1 with cognitive behavioral therapy.182

Table 16 Characteristics of included double-blind randomized placebo-controlled trials of valproic acid

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Brady, 2002^182^ | Valproic acid 1,500 (14) Placebo (15) | 12 | U.S.; outpatient | Newspaper; several treatment settings | 40 | 54 | 62 | 0 | CBT | Medium
Salloum, 2005^181^ | Valproate 750+ (29) Placebo (30) | 24 | U.S.; outpatient substance abuse service at university clinic | Treatment seekers | 38 | 25 | 29 | Bipolar I disorder 100 Mixed bipolar subtype 58 Manic 21 Depressed 21 Cannabis abuse or dependence 29 Cocaine abuse 29 | Lithium and weekly individual dual diagnosis recovery counseling 100% | Medium

CBT = cognitive behavioral therapy; mg = milligram; N = number; U.S. = United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

##### Return to Any Drinking

One trial (N=29) reported no significant difference in the percentage of subjects who returned to any drinking over 12 weeks (valproic acid versus placebo: 81 versus 83, p NS).182

##### Return to Heavy Drinking

Our meta-analysis found that 32 percent fewer subjects treated with valproic acid returned to heavy drinking than with placebo (RD, -0.32; 95% CI, -0.52 to -0.11; 2 trials).

##### Drinking Days

One trial (N=29) reported no significant difference in the percentage of drinking days over 12 weeks between subjects treated with valproic acid and those who received placebo (15.9 versus 19.6, p NS).182

##### Heavy Drinking Days

Our meta-analysis found a lower percentage of heavy drinking days for patients treated with valproic acid than for those who received placebo (WMD, -8.5; 95% CI, -15.9 to -1.1; 2 trials).

##### Drinks per Drinking Day

Our meta-analysis found that subjects treated with valproic acid had 2.6 fewer drinks per drinking day than those who received placebo (WMD, -2.6; 95% CI, -5.0 to -0.2; 2 trials).

### Detailed Synthesis: Head-to-Head Trials

#### Acamprosate Versus Disulfiram

##### Characteristics of Trials

We found no studies meeting our inclusion criteria. Our searches did identify some studies comparing acamprosate with disulfiram that did not meet our inclusion criteria for this section because they were open-label studies.183,184

#### Acamprosate Versus Naltrexone

##### Characteristics of Trials

We included 4 trials comparing acamprosate with naltrexone (Table 17). Three used 50 mg per day doses for naltrexone;61,74,79 1 used 100 mg per day.65 Three used 1,998 mg per day doses for acamprosate;61,74,79 1 used 3,000 mg per day.65 Duration of treatment ranged from 12 to 16 weeks. One trial was conducted in the United States, 2 in Germany, and 1 in Australia. Mean age was in the mid-40s for all 4 trials. All subjects met criteria for alcohol dependence in 3 trials; 1 trial did not report the proportion with alcohol dependence, but most subjects likely had alcohol dependence.61 Three studies did not report information on race; 1 trial reported enrolling 23 percent nonwhite subjects.65 The trials enrolled a similar proportion of women (23 to 31 percent). Two trials reported information on smoking history at baseline—1 reported that 55 percent of pill-taking subjects were smokers;65 1 reported that 72 to 81 percent of subjects were smokers across study arms.61 Trials included or encouraged psychological or psychosocial co-interventions.

Table 17 Characteristics of double-blind head-to-head randomized controlled trials of acamprosate versus naltrexone

Author, Year Trial Name | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Anton, 2006^65^ Donovan, 2008^68^ COMBINE | ACA 3,000 + CBI + MM (151) ACA 3,000 + MM (152) NTX 100 + CBI + MM (155) NTX 100 + MM (154) Placebo + CBI + MM (156) Placebo + MM (153)^a^ | 16 (68) | U.S.; 11 academic sites | Ads, community resources, clinical referrals | 44 | 23 | 31 | NR | Community support group participation (like AA) encouraged | Low
Kiefer, 2003^74^ Kiefer, 2004^75^ Kiefer, 2005^76^ | ACA 1,998 (40) NTX 50 (40) Placebo (40) ACA 1.998 + NTX 50 (40) | 12 | Germany; 1 site in Hamburg; outpatient | From inpatient withdrawal treatment | 46 | NR | 26 | 0 | Group therapy | Low
Mann, 2012^79^ PREDICT | ACA 1,998 (172) NTX 50 (169) Placebo (86) | 12 | Germany; NR | Recruited from inpatient facilities of 5 academic medical centers plus 2 state-run psychiatric hospitals | 45 | NR | 23 | NR | Medical Management | Medium
Morley, 2006^61^ Morley, 2010^80^ | ACA 1,998 (55) NTX 50 (53) Placebo (61) | 12 | Australia; 3 treatment centers in Sydney | Patients who had attended an inpatient detoxification program, outpatient treatment, or followup, or who responded to live or print ads | 45 | NR | 30 | Severe concurrent illness (psychiatric or other) –NOS 3 | All offered 4-6 sessions of manualized compliance therapy | Low

AA = Alcoholics Anonymous; ACA = acamprosate; CBI = combined behavioral intervention; COMBINE = Combined Pharmacotherapies and Behavioral Intervention; mg = milligram; MM = medical management; N = number; NA = not applicable; NOS = not otherwise specified; NTX = naltrexone; U.S. = United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Three additional treatment arms were included in COMBINE but were not relevant to our Key Questions: ACA + NTX + CBI + MM, ACA + NTX + MM, and CBI only (no pills).

##### Return to Any Drinking

Our meta-analysis found no statistically significant difference between naltrexone and acamprosate (RD, 0.02; 95% CI, -0.03 to 0.08; 3 trials).

##### Return to Heavy Drinking

Our meta-analysis found no statistically significant difference between naltrexone and acamprosate (RD, 0.01; 95% CI, -0.05 to 0.06; 4 trials).

##### Drinking Days

Two of the 4 trials reported sufficient data for meta-analysis for drinking days; neither found a statistically significant difference between treatments.61,65 Our meta-analysis found no statistically significant difference between naltrexone and acamprosate (WMD, -2.98; 95% CI, -13.4 to 7.5).

##### Heavy Drinking Days

The COMBINE study reported that analyses of alternative summary measures of drinking, including heavy drinking days per month (p=0.006) were consistent with those for the coprimary end points (percentage of days abstinent from alcohol and time to first heavy drinking day), all showing a significant naltrexone by combined behavioral intervention (CBI) interaction.

##### Drinks per Drinking Day

Two of the trials reported some information about drinks per drinking day, but not enough data for us to conduct quantitative synthesis. The trial conducted in Australia reported no statistically significant difference between acamprosate and naltrexone (mean [SD], 7.5 [6.1] versus 5.9 [6.1]; p not reported). The COMBINE study reported that analyses of alternative summary measures of drinking, including drinks per drinking day (p=0.03), were consistent with those for the coprimary end points (percentage of days abstinent from alcohol and time to first heavy drinking day), all showing a significant naltrexone by CBI interaction.

#### Disulfiram Versus Naltrexone

##### Characteristics of Trials

We included 1 trial comparing disulfiram with naltrexone (Table 18). It compared disulfiram, naltrexone, placebo, and the combination of disulfiram plus naltrexone for 12 weeks in Veterans Administration outpatient settings. All subjects met criteria for alcohol dependence and had co-occurring Axis I psychiatric disorders. Almost all subjects were male. The trial did not report information on smoking history at baseline.

Table 18 Characteristics of double-blind head-to-head randomized controlled trials of disulfiram versus naltrexone

Author, Year Trial Name | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Petrakis, 2005^90^ Ralevski, 2007^94^ Petrakis, 2007^95^ Petrakis, 2006^96^ VA MIRECC | DIS 250 (66) NTX 50 (59) Placebo (64) NTX 50 + DIS 250 (65) | 12 | U.S.; outpatient VA | Recruited as outpatients or by ads | 47 | 26 | 3 | Axis I disorder 100 | Psychiatric treatment as usual 100% | High^a^

DIS = disulfiram; mg = milligram; MIRECC = Mental Illness Research, Education and Clinical Center; N = number; NTX = naltrexone; U.S. = United States; VA = Veterans Administration.

Note: Age, Years is the mean age in years, unless otherwise stated.

a High risk of bias for disulfiram versus naltrexone; medium for naltrexone versus placebo.

The study used a double-blind design for the comparison between naltrexone and placebo, but not for disulfiram (which was given open label). We rated the trial as high risk of bias for the comparison between disulfiram and naltrexone, primarily for high risk of ascertainment bias (see Appendix C for details; we rated it as medium risk of bias for naltrexone versus placebo).

Other studies that did not meet our inclusion criteria for this section comparing disulfiram with naltrexone were either open-label studies184-186 or were conducted in adolescents.187

##### Return to Any Drinking

The trial reported no statistically significant difference between disulfiram and naltrexone for number of subjects achieving total abstinence (51 versus 38, p=0.11).

##### Drinking Days

The trial reported no statistically significant difference between disulfiram and naltrexone for the percentage of days abstinent (96.6 versus 95.4, p=0.55).

##### Heavy Drinking Days

The trial reported no statistically significant difference between disulfiram and naltrexone for the percentage of heavy drinking days (3.2 versus 4, p=0.65).

#### Head-to-Head Trials Including Medications Used Off-Label or Those Under Investigation

##### Characteristics of Trials

We found 4 eligible trials (Table 19). All 4 utilized naltrexone; none treated subjects with acamprosate or disulfiram. Off-label medications evaluated included aripiprazole, desipramine, paroxetine, sertraline, and topiramate. No 2 trials assessed the same head-to-head comparison. Duration of treatment ranged from 12 to 16 weeks. Two were conducted in the United States, 1 in Brazil, and 1 in Italy. Mean age of subjects was similar across trials (in the 40s). All subjects met criteria for alcohol dependence. One trial enrolled all males,119 and 1 did not report information on sex.188 The other 2 included 9 to 38 percent women.104,189 One trial only included subjects with both PTSD and alcohol dependence;189 1 only included those with depression and alcohol dependence.104 Trials typically included or encouraged psychological or psychosocial co-interventions.

Table 19 Characteristics of double-blind head-to-head randomized controlled trials including medications used off-label, or those under investigation

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Setting | Recruitment method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Baltieri, 2008^119^; Baltieri, 2009^128^ | Topiramate target 200, maximum 400 (52) NTX 50 (49) Placebo (54) | 12 | Brazil; outpatient | NR | 44 to 45 | 29 | 0 | NR | Psychosocial 100% | High
Martinotti, 2009^188^ | Aripiprazole 5-15 (29) NTX 50 (28) | 16 | Italy; outpatient; university hospital day clinic | Direct recruitment from local facility | 40 | NR | NR | Mood disorder 19 Anxiety disorder 11^a^ | None required | Medium
Petrakis, 2012^189^ | Desipramine 200 + placebo (24)^b^ Paroxetine 40 + placebo (20) Desipramine 200 + NTX 50 (22) Paroxetine 40 + NTX 50 (22) | 12 | U.S.; outpatient; multiple mental illness centers, most from VAs | Local advertising (nonveterans); mental illness centers (veterans) | 47 | 25 | 9 | PTSD 100 | Clinical management/ compliance enhancement therapy 100% | High
Pettinati, 2010^104^ | Sertraline 200 (40) NTX 100 (49) Placebo (39) Sertraline 200 + NTX 100 (42) | 14 | U.S.; outpatient | Newspaper ads, referrals | 43 | 35 | 38 | Depression 100 | CBT 100% | Medium

CBT = cognitive behavioral therapy; mg = milligram; N = number; NR = not reported; NTX = naltrexone; PTSD = post-traumatic stress disorder; U.S. = United States; VA = Veterans Affairs.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Study also reported the following percentages of subjects with co-occurring disorders: impulse control disorder 5%, eating disorder 1%, somatoform disorder 1%. Personality disorders: borderline 8%, antisocial 4%, avoidant 4%, histrionic 1%, paranoid 1%, dependent 1%, passive-aggressive 1%, schizoid 1%, cannabis abuse 12%, cocaine abuse 8%, benzodiazepine abuse 1%, MDMA abuse 1%.

b Because 2 of the 4 arms are combinations, they are not eligible/not comparisons of interest; only the head-to-head comparison of paroxetine + placebo and desipramine + placebo is eligible.

#### Aripiprazole Compared With Naltrexone

The only included trial reported no significant differences between groups for number of subjects who remained abstinent, number of subjects who relapsed, mean number of abstinent days, and heavy drinking days.188

#### Desipramine Compared With Paroxetine

One included trial, rated as high risk of bias, randomized patients with PTSD and alcohol dependence to desipramine, paroxetine, desipramine plus naltrexone, or paroxetine plus naltrexone.189 The trial found that patients treated with desipramine had fewer heavy drinking days (p=0.009) and drinks per drinking day (p=0.027) than those who received paroxetine.

#### Sertraline Compared With Naltrexone

The only included trial reported a higher abstinence rate for patients (all had alcohol dependence and co-occurring depression) who received the combination of sertraline and naltrexone than for those who received either naltrexone, sertraline, or placebo only (53.7 percent versus 21.3 percent versus 27.5 percent versus 23.1 percent; p=0.001).104 The difference between naltrexone and sertraline given alone was not significant.

#### Topiramate Compared With Naltrexone

The only included trial, rated as high risk of bias, reported no significant differences between topiramate and naltrexone for proportion of abstinent subjects, cumulative abstinence duration, time to first relapse, or heavy drinking weeks.119 Significantly more subjects in the topiramate group participated in AA than in the naltrexone group (19.2 percent versus 4.1 percent, p=0.04).

### Systematic Reviews

We included 5 systematic reviews for this KQ.37,38,190-192 Two were reviews from the Cochrane Collaboration assessing acamprosate37 or opioid antagonists (naltrexone and nalmefene).38 One assessed the efficacy of disulfiram,190 1 was a sex-specific individual patient data meta-analysis of response to acamprosate,191 and 1 was for the United Kingdom's National Institute for Clinical Excellence (NICE) guidelines on alcohol-use disorders.192 All 5 were rated as low or medium risk of bias. In general, the 5 systematic reviews did not report findings that conflict with our results, so we describe them only briefly in this report. None of the reviews included publications from the past few years, as literature searches were typically completed 3 or more years ago.

The Cochrane Collaboration review of acamprosate for people with alcohol dependence (literature searches through January 2009) found acamprosate to be effective.37 It reported a 14 percent reduction in return to any drinking compared with placebo (relative risk [RR], 0.86; 95% CI, 0.81 to 0.91; number needed to treat [NNT], 9.1; 95% CI, 6.7 to 14.3). The Cochrane Collaboration review of opioid antagonists (literature searches through January 2010) reported that naltrexone reduced the risk of heavy drinking (RR, 0.83; 95% CI, 0.76 to 0.90; NNT, 9.1), decreased drinking days (WMD, -3.89; 95% CI, -5.75 to -2.04), and decreased heavy drinking days (WMD, -3.25; 95% CI, -5.51 to -0.99) compared with placebo.38 Effects of naltrexone on return to any drinking were not statistically significant (RR, 0.96; 95% CI, 0.92 to 1.00).

The sex-specific individual patient data meta-analysis (N=6,111) of response to acamprosate found a significant effect of acamprosate compared with placebo for improving rates of abstinence and no heavy drinking in both women and men.191 Men and women did not differ on any measure of acamprosate efficacy.

The review for the NICE guidelines found that the evidence for both acamprosate and naltrexone supports their efficacy for improving alcohol consumption outcomes.192 It reported a significant effect of acamprosate in promoting abstinence when compared with placebo (RR, 0.83; 95% CI, 0.77 to 0.88) and for the number of individuals relapsing to heavy drinking (RR, 0.90; 95% CI, 0.81 to 0.99). It found that oral naltrexone reduced rates of relapse to heavy drinking (RR, 0.83; 95% CI, 0.75 to 0.91), reduced mean drinks per drinking day (standardized mean difference [SMD], -0.28; 95% CI, -0.44 to -0.11), and reduced days of heavy drinking (SMD -0.43; 95% CI, -0.82 to -0.03) compared with placebo. Oral disulfiram was not significantly different from placebo in preventing participants from lapsing to alcohol consumption (RR, 1.05; 95% CI, 0.96 to 1.15).

## Key Question 2 Health Outcomes

For this Key Question (KQ), we describe the characteristics of included studies and then results for the included health outcomes (accidents, injuries, quality of life [QoL], function, and mortality). Throughout this KQ, we include headers and sections only for outcomes reported by the included studies.

### Detailed Synthesis: Placebo-Controlled Trials of FDA-Approved Medications for Treating Alcohol Dependence

We found no placebo-controlled trials of disulfiram that reported a health outcome of interest. Below we describe 10 placebo-controlled trials of acamprosate and 9 placebo-controlled trials of naltrexone that reported a health outcome of interest (including the COMBINE study, which has comparisons between placebo and both medications). These represent a subset of the trials included in KQ 1.

#### Acamprosate

##### Characteristics of Trials

Ten placebo-controlled RCTs reported a health outcome (Table 20). Sample sizes ranged from 100 to 612 participants in acamprosate plus placebo arms. Duration of treatment ranged from 12 to 52 weeks. Followup to 1 year or longer was available for 6 trials. No studies identified a health outcome as their primary outcome.

Table 20 Characteristics of included double-blind randomized placebo-controlled trials of acamprosate that report a health outcome

Author, Year Trial Name Design | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Setting | Recruitment Method | Age, Years | % Non-White | % Female | Cointervention | Risk of Bias
Anton, 2006^65^ Donovan, 2008^68^ LoCastro, 2009^193^ COMBINE | ACA 3,000 + CBI + MM (151) ACA 3,000 + MM (152) NTX 100 + CBI + MM (155) NTX 100 + MM (154) Placebo + CBI + MM (156) Placebo + MM (153)^a^ | 16 (68) | U.S.; 11 academic sites | Ads, community resources, clinical referrals | 44 | 23 | 31 | As randomized; community support group participation (like AA) encouraged | Low
Berger, 2013^69^ | ACA 1,998 (51) Placebo (49) | 12 | U.S.; 2 outpatient primary care clinics | Provider referral and ads | 48 | 9 | 38 | Brief structured behavioral intervention from primary care physician | Medium
Besson, 1998^70^ | ACA 1,300 to 1,998 (55) Placebo (55) | 52 (108) | Switzerland; Outpatient; 3 psychiatric treatment centers | From inpatient treatment unit | 42 | NR | 20 | Routine counseling 100% Voluntary disulfiram 22% to 24% | Medium
Geerlings, 1997^72^ | ACA 1,332 to 1,998 (128) Placebo (134) | 26 (52) | Belgium, the Netherlands, and Luxembourg; Outpatient substance abuse treatment centers | Recruited from detoxification patients in same centers | 40 to 42 | NR | 24 | ACA: benzodiazepines 5% Placebo: benzodiazepines 6% | Medium
Lhuintre, 1990^78^ | ACA 1,332 (279) Placebo (290) | 12 (12) | France; Outpatient substance abuse treatment centers | Inpatient treatment centers (30 centers across France) | 42 to 43 | NR | 18 | None | Unclear
Mason, 2006^66^ | ACA 2,000 (258) ACA 3,000 (83) Placebo (260) | 24 (32) | U.S.; 21 outpatient clinics^b^ | Primarily by newspaper ads | 44 to 45 | 14 to 15 | 29 to 36 | Brief abstinence-oriented protocol-specific counseling and self-help materials 100% | Low
Paille, 1995^81^ | ACA 1.3 g (188) ACA 2 g (173) Placebo (177) | 52 (78) | France; NR^c^ | Referral from alcohol specialist centers | 43 | NR | 20 | Supportive psychotherapy 100% Hypnotics 6 to 7% Anxiolytics 8 to 12% Antidepressants 8 to 9% | Medium
Poldrugo, 1997^84^ | ACA 1,332 to 1,998 (122) Placebo (124) | 26 (52) | Italy; Inpatient for 1-2 weeks then outpatient; multicenter community-based alcohol rehabilitation program | From acute inpatient withdrawal treatment | 43 to 45 | NR | 23 to 31 | Community-based rehabilitation program with group sessions, alcohol education, community meetings 100% | Medium
Sass, 1996^86^ | ACA 1,332 to 1,998 (136) Placebo (136) | 48 (96) | Germany; Psychiatric outpatient | Outpatient referral | 41 to 42 | NR | 22 | Counseling / psychotherapy 100% | Medium
Whitworth, 1996^88^ | ACA 1,332 or 1,998 (224) Placebo (224) | 52 (52) | Austria; Outpatient specialty | Recruited after inpatient detoxification | 42 | NR | 21 | NR | Medium

AA = Alcoholics Anonymous; ACA = acamprosate; CBI = combined behavioral intervention; COMBINE = Combined Pharmacotherapies and Behavioral Intervention; mg = milligram; MM = medical management; N = number; NR = not reported; NTX = naltrexone; U.S. = United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Three additional treatment arms were included in COMBINE but were not relevant to our Key Questions: ACA + NTX + CBI + MM, ACA + NTX + MM, and CBI only (no pills).

b Clinics were affiliated with academic medical centers and had investigators experienced in alcoholism treatment.

c The article was not explicit about the setting, but patients received psychotherapy and psychiatric medication management suggesting a psychiatric outpatient setting.

The mean age of patients ranged from 40 to 48. All patients enrolled in the trials had alcohol dependence. Two trials reported on race: 9 to 15 percent of patients were nonwhite.66,69 Females made up 18 to 38 percent of the patients across studies. Three trials65,66,69 reported smoking status at baseline, from 44 percent to 55 percent.65 No trials specified the percentage of patients who had a co-existing medical or psychiatric condition.

There was minor variation in the dosing of acamprosate across trials. Most studies used doses from 1,332 to 1,998 mg per day and determined dosing based on weight. Two studies included an arm who received 3 g per day.65,66 Three studies commented on the use of other pharmacotherapy to address alcohol or comorbid psychiatric disorders. One trial allowed the use of disulfiram on a voluntary basis.70 Two other trials reported that 5 to 6 percent of patients in either treatment group were prescribed benzodiazepines.72, and 1 trial allowed the use of “hypnotics, anxiolytics or antidepressants” in either group.81

Three studies were conducted in the United States;65,66,69 all others were conducted in European countries. One study was conducted in a primary care setting;69 most of the others were conducted in outpatient substance abuse or psychiatric treatment centers. The majority of trials recruited patients during or shortly after discharge from an inpatient substance abuse treatment center. Two U.S. trials recruited patients via newspaper advertisement66 or a combination of advertisements and provider referrals.69 One German trial recruited patients from outpatient substance abuse treatment centers.86 The COMBINE study recruited patients by advertisement and referral from 11 academic centers.65

Eight trials were rated as low or medium risk of bias. One trial was rated as unclear risk of bias, primarily due to unclear handling of missing data and unclear masking of outcome assessors (see Appendix C for details).78

##### Accidents or Injuries

We identified 1 study, rated as unclear risk of bias, reporting that one patient in the placebo group died by “accident.” No other details on the cause or nature of the accident were provided.78

##### Quality of Life or Function

The COMBINE study assessed QoL using the World Health Organization Quality of Life (WHOQOL) and 12-item Short-Form Health Survey (SF-12v2) physical and mental health scores. Results were not presented for each treatment group separately.193 These results are discussed in detail in the acamprosate versus naltrexone section (below). Briefly, no clinically significant differences were found across the eight combinations of pharmacological and behavioral treatments for QoL for acamprosate compared with placebo.193

##### Mortality

Nine trials of acamprosate reported on mortality. Few deaths were reported; no study reported more than two deaths in any group. Table 21 shows the number of deaths in studies which report deaths per study arm. In the COMBINE trial, the authors reported that one fatal serious adverse event was reported during the 16-week treatment phase. Investigators classified this death as being unrelated to the study medication. No details were provided on which group the death occurred in, the nature of the adverse event, or the cause of death.65

Table 21 Mortality reported in placebo-controlled trials of acamprosate^a^

Author, Year | Study Duration, Weeks | N (Cause) Deaths, Placebo Arm | N (Cause) Deaths, Acamprosate Arm
Berger, 2013^69^ | 12 | 0 | 0
Besson, 1998^70^ | 52 | 1 (cardiac arrest) | 0
Geerlings, 1997^72^ | 26 | 0 | 0
Mason, 2006^66^ | 26 | 0 | 0
Paille, 1995^81^ | 51 | 2 (NR) | 4 (NR)^b^
Poldrugo, 1997^84^ | 26 | 1 (NR) | 0
Sass, 1996^86^ | 52 | 1 (suicide, by hanging) | 1 (suicide, by hanging)
Whitworth, 1996^88^ | 26 | 1 (NR) | 2 (NR)

N = number; NR = not reported.

a The table includes 8 of the 9 trials that reported on mortality. The other trial was the COMBINE trial (as described in the text, it did not report which group the death occurred in).

b The study reported 2 deaths in the arm receiving 1.3 grams daily and 2 deaths in the arm receiving 2 grams daily.

#### Naltrexone

##### Characteristics of Trials

Nine RCTs comparing naltrexone with placebo reported at least one health outcome of interest (Table 22). All 9 trials were rated as low or medium risk of bias. Sample sizes ranged from 31 to 618 participants in the naltrexone plus placebo arms. Duration of treatment ranged from 12 to 26 weeks.

Table 22 Characteristics of included double-blind randomized placebo-controlled trials of naltrexone that report a health outcome

Author, Year Trial Name | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Anton, 2006^65^ Donovan, 2008^68^ LoCastro, 2009^193^ COMBINE | ACA 3,000 + CBI + MM (151) ACA 3,000 + MM (152) NTX 100 + CBI + MM (155) NTX 100 + MM (154) Placebo + CBI + MM (156) Placebo + MM (153)^a^ | 16 (68) | U.S.; 11 academic sites | Ads, community resources, clinical referrals at 11 academic sites | 44 | 23 | 31 | NR | As randomized; community support group participation (like AA) encouraged | Low
Balldin, 2003^108^ | NTX 50 (56) Placebo (62) | 26 | Sweden; 10 sites outpatient | Ads, outpatient treatment center | 48 to 51 | NR | 9 to 23 | 0 | None | Low
Garbutt, 2005^97^; Pettinati, 2009^131^ | NTX inj 380 every 4 weeks (208) NTX inj 190 every 4 weeks (210) Placebo (209) | 26 | U.S.; Inpatient and outpatient, private and VA | NR | 45 | 17 | 32 | NR | BRENDA standardized supportive therapy 100% | Medium
Morgenstern, 2012^102^ | NTX 100 + MBSCT (51) NTX 100 (51) Placebo + MBSCT (50) Placebo (48) | 12 | U.S.; NR | Ads, community outreach | 40 | 26 | 0 | HIV 15 Any drug use 67 | BBCET 100% | Medium
O'Malley, 2008^42^ | NTX 50 (34) Placebo (34) NTX 50 + SER 100 (33) | 16 | U.S.; Outpatient | Direct community recruitment, health clinic referral, local ads | 40 | 70 | 34 | NR | MM 100% | Medium
Petrakis, 2004^121^; Ralevski, 2006^143^ | NTX 50 (16) Placebo (15) | 12 | U.S.; At least 3 outpatient centers—MIRECC clinics | Direct recruitment from participating centers | 46 | 19 | 0 | Schizophrenia or schizoaffective disorder 100 | CBT + psychiatric treatment as usual Neuroleptics 52% Benzodiazepines 16% Thymoleptics 39% | Medium
Pettinati, 2008^106^ | NTX 150 (82) Placebo (82) Subjects also randomized to either CBT or BRENDA (2×2 design) | 12 | U.S.; University-affiliated outpatient substance abuse treatment research facility | Those seeking treatment at the facility | 39 | 76 | 29 | Cocaine dependence 100 | NR | Medium
Pettinati, 2010^104^ | SER 200 (40) NTX 100 (49) Placebo (39) SER 200 + NTX 100 (42) | 14 | U.S.; Outpatient | Newspaper ads, referrals from local professional or friends / family | 43 | 35 | 38 | Depression 100 | CBT 100% | Medium
Petrakis, 2005^90^ Ralevski, 2007^94^ Petrakis, 2007^95^ Petrakis, 2006^96^ VA MIRECC | DIS 250 (66) NTX 50 (59) Placebo (64) NTX 50 + DIS 250 (65) | 12 | U.S.; Outpatient VA | Recruited as outpatients or ads | 47 | 26 | 3 | Axis I disorder 100 | Psychiatric treatment as usual 100% | Medium

AA = Alcoholics Anonymous; ACA = acamprosate; BRENDA = BRENDA is an acronym based on the components of the intervention: (B)iopsychosocial evaluation, (R)eport to the patient on assessment, (E)mpathic understanding of the patient's situation, (N)eeds collaboratively identified by the patient and treatment provider, (D)irect advice to the patient on how to meet those needs, (A)ssess reaction of the patient to advice and adjust as necessary for best care; CBI = combined behavioral intervention; CBT = cognitive behavioral therapy; COMBINE = Combined Pharmacotherapies and Behavioral Intervention; DIS = disulfiram; inj = injection; mg = milligram; MBSCT = modified behavioral self-control therapy; MIRECC = Mental Illness Research, Education and Clinical Center; MM = medical management; N = number; NR = not reported; NTX = naltrexone; SER = sertraline; U.S. = United States; VA = Veterans Affairs.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Three additional treatment arms were included in COMBINE but were not relevant to our Key Questions: ACA + NTX + CBI + MM, ACA + NTX + MM, and CBI only (no pills).

Mean age was similar across trials, ranging from 39 to 50. Two trials included only male patients;102,121 females made up 3 to 38 percent of patients in the other trials. One study did not report on the race of study participants108; most of the other trials enrolled a minority of nonwhite subjects (17 to 35 percent) and 2 enrolled a majority (70 to 76 percent).42,106 Three studies provided information on smoking status; approximately half of participants in those trials were smokers.42,65,97 All trials enrolled a vast majority (93 percent or more) of patients with alcohol dependence. Three trails did not specifically include (or describe) whether study participants had any co-existing medical or psychiatric disorders.97,106,108 One trial was conducted among men who have sex with men; 67 percent reported any other drug use and 15 percent had HIV.102 Four trials were conducted among populations who all had a specific psychiatric comorbidity: 1 among patients with either schizophrenia or schizoaffective disorder,121 1 among patients with cocaine dependence,106 1 among patients with at least one other psychiatric (Axis I) disorder,90 and 1 among patients with depression.104

One trial evaluated the efficacy of two doses of injectable naltrexone97 and the remainder randomized patients to oral naltrexone either at 50, 100,^102,104,193^ or 150 mg per day.106 Four trials described a specific behavioral or psychological co-intervention.97,102,108,131 Two trials conducted among those with a psychiatric comorbidity specified that patients continued medical management and usual psychiatric care90,121 and 1 included cognitive behavioral therapy for depressed patients.104 No specific co-intervention was described in the trial comparing naltrexone with placebo in patients with cocaine dependence.106

One trial was conducted in Sweden;108 all others were conducted in the United States. Most were conducted at an outpatient substance abuse or mental health center; none were conducted in primary care settings.

##### Mortality

Six placebo-controlled trials of naltrexone reported mortality rates; no study found more than one death in each treatment group. Three studies reported that there were no deaths in either group,104,106,131 1 reported one death in each study arm without providing additional details,90 and 1 study reported a death due to alcohol intoxication in the placebo group.108 In the COMBINE trial, the authors reported that one fatal serious adverse event was reported during the 16-week treatment phase. Investigators classified this death as being unrelated to the study medication. No details were provided on which group the death occurred in, the nature of the adverse event, or the cause of death.65

##### Quality of Life or Function

Four placebo-controlled trials of naltrexone measured QoL or some aspect of function, each trial using a different measure. One trial conducted among men who have sex with men102 measured QoL at 13 weeks using the Short Inventory of Problems,194 an alcohol-specific QoL measure used to assess negative consequences of drinking. No differences between naltrexone and placebo in end-of-treatment scores were found when using a last observation carried forward (LOCF) method to impute missing data (mean difference between groups at 13 weeks was -1.7, p<0.09).102

One study comparing injectable naltrexone with placebo measured QoL using the Medical Outcomes Study 36-item short-form health survey (SF-36).131,195 Data were reported separately for the overall physical and overall mental health summary scores of the SF-36. The study found no significant difference on either scale at 24 weeks between the placebo group and the injectable naltrexone 190 mg per month group. Patients receiving naltrexone 380 mg per month had greater improvement on the mental health summary score than those receiving placebo at 24 weeks (8.2 versus 6.2, p=0.044), but there was no difference in improvement found on the physical health summary score (0.2 versus -0.1, p=0.51).131

The COMBINE study assessed QoL using the WHOQOL and SF-12v2 physical and mental health scores. Results were not presented for each treatment group separately.193 See the section below on acamprosate versus naltrexone for details on these results. Briefly, the results indicate that the eight combinations of pharmacological and behavioral treatments did not show clinically significant differential effects on QoL for either scale.193

One placebo-controlled study of naltrexone 50 mg measured the Drinker Inventory of Consequences (DrInC) at 16 weeks.42 The DrInC is a 50-item questionnaire designed to measure adverse consequences of alcohol abuse in five areas: interpersonal, physical, social, impulsive, and intrapersonal.194 More patients in the placebo group reported one or more alcohol-related consequence than in the naltrexone group, as measured by the DrInC (76 versus 45%, p=0.02).42

### Detailed Synthesis: Placebo-Controlled Trials of Medications Used Off-Label or Those Under Investigation

As described in KQ 1, we found just 1 placebo-controlled trial meeting our inclusion criteria for each of the following medications: aripiprazole, atomoxetine, desipramine, fluvoxamine, imipramine, olanzapine, ondansetron, paroxetine, and varenicline. We found insufficient evidence to support the efficacy of these medications. Among these studies, just 2 reported a health outcome (number of deaths for fluvoxamine and placebo196 and varenicline and placebo, and QoL for varenicline and placebo).197 We provide additional details about these trials in Appendix E.

For the medications with multiple placebo-controlled trials (baclofen, buspirone, citalopram, fluoxetine, nalmefene, quetiapine, sertraline, topiramate, and valproic acid), 6 trials reported outcomes relevant to KQ 2 (Table 23): 2 placebo-controlled trials of as-needed nalmefene,159,160 1 trial of quetiapine in bipolar patients with alcohol dependence,166 2 placebo-controlled trials of sertraline in patients with co-existing depression or dysthymia,104,170 and 1 placebo-controlled trial of topiramate.179,180 Sample size ranged from 83 to 718. Duration of treatment ranged from 12 to 24 weeks.

Table 23 Characteristics of included double-blind randomized placebo-controlled trials of medications used off-label or those under investigation

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Gual, 2003^170^ | SER 50-150 (44) Placebo (39) | 24 | Spain; Outpatient | Outpatient alcohol dependence treatment | 47 | NR | 47 | Depression/ dysthymia 100 | NR | Medium
Gual,, 2013^160^ | NALM 20 as-needed (358) Placebo (360) | 24 | Belgium, Czech Republic, France, Italy, Poland, Portugal, Spain; 57 sites | Referrals and ads | 44 to 45 | 1 | 26 to 29 | 0 | BRENDA | Medium
Johnson, 2007^179^ Johnson, 2008^180^ | TOP 50-300^a^ (183) Placebo (188) | 14 | U.S.; 17 academic sites; outpatient | Academic sites and by newspaper, radio, television ads | 47 to 48 | 15 | 26 to 28 | NR | BBCET 100% | Low
Mann, 2013^159^ | NALM 20 as-needed (306) Placebo (298) | 24 | Austria, Finland, Germany, Sweden; 39 sites | Referrals and ads | 52 | <1 | 32 to 33 | 0 | BRENDA | Medium
Pettinati, 2010^104^ | SER 200 (40) NTX 100 (49) Placebo (39) SER 200 + NTX 100 (42) | 14 | U.S.; Outpatient | Newspaper ads, referrals | 43 | 35 | 38 | Depression 100 | CBT 100% | Medium
Stedman, 2010^166^ | Quetiapine 300-800 (175) Placebo (186) | 12 | U.S.; Outpatient; 43 centers | NR | 39 | 12 | 37 | Bipolar 100 | None | High

BBCET, brief behavioral compliance enhancement treatment; BRENDA = BRENDA is an acronym based on the components of the intervention: (B)iopsychosocial evaluation, (R)eport to the patient on assessment, (E)mpathic understanding of the patient's situation, (N)eeds collaboratively identified by the patient and treatment provider, (D)irect advice to the patient on how to meet those needs, (A)ssess reaction of the patient to advice and adjust as necessary for best care; CBT, cognitive behavioral therapy; mg = milligram; N = number; NR, not reported; NTX = naltrexone; SER, sertraline; TOP, topiramate; U.S., United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Dose titrated over a 5-week period from 25 to a maximum of 300 mg; mean 171.

The mean age of participants was similar across trials—39 to 52 years. Twenty-six to 47 percent of patients were female, and from less than 1 to 35 percent of patients were nonwhite in the 5 trials reporting information on race; 1 did not report information on race.159,160,170 Two trials reported smoking status: 1 placebo-controlled trial of sertraline enrolled 14 to 20 percent smokers,104 and the trial of quetiapine enrolled 56 percent smokers.166 Five of the trials were conducted in those with alcohol dependence; the trial of topiramate did not specify the percentage who met criteria for alcohol dependence.179 Three trials were conducted in the United States, 1 in Spain,170 and 2 were multinational European.159,160

The placebo-controlled trial of quetiapine was rated as high risk of bias, primarily for high risk of attrition bias and methods of handling of missing data (see Appendix C for details).166

#### Nalmefene

##### Mortality

Two placebo-controlled trials of as-needed nalmefene reported deaths in at least one treatment group over 24 weeks. In one (N=598),159 no patients in the nalmefene group died, but two patients in the placebo group died. Both deaths were due to suicide. In the other trial (N=655),160 one patient randomized to placebo died of hepatocellular carcinoma and one patient randomized to nalmefene experienced sudden death of unknown cause (assessed by the investigator as not being related to the study medication).

#### Quetiapine

##### Mortality

Two deaths (one in each treatment group) were reported in the placebo-controlled trial of quetiapine rated as high risk of bias; one after a skull fracture caused by blunt trauma in the quetiapine group and one attributed to myocardial ischemia more than 30 days after treatment in the placebo group.166 Both deaths were judged to be unrelated to the study medications by the study investigators.

##### Quality of Life or Function

No difference was found between the quetiapine and placebo groups in health-related QoL assessed by the Quality of Life Enjoyment and Satisfaction Questionnaire (Q-LES-Q)198 at 12 weeks (mean score 46.9 versus 47.7, p=0.63). Functional impairment was assessed using the Sheehan Disability Score (SDS),199 a questionnaire that aims to assess the relationship between symptoms and impairment in work, social, and family life. No statistically significant differences between quetiapine and placebo groups were found for mean total SDS score (11.03 versus 9.17), mean SDS number of lost work days per week (1.1 versus 0.7), and SDS number of underproductive days per week over 12 weeks (1.8 versus 1.3).166

#### Sertraline

##### Mortality

One placebo-controlled trial of sertraline in patients with co-existing alcohol dependence and depression reported no deaths in either treatment group at 13 weeks.104

##### Quality of Life or Function

One study of patients with co-existing depression measured QoL using the SF-36 at 24 weeks. Scores were presented in a figure only (bar graph, data not reported). QoL improved during treatment for both the placebo and sertraline groups; the authors noted that the sertraline group improved more than placebo in only the mental health summary score of the SF-36 (p=0.031).170

#### Topiramate

##### Accident or Injury

One placebo-controlled trial of topiramate reported injury in a list of adverse events occurring during treatment (over 12 weeks).179 Eight patients (4.4 percent) in the topiramate group and 22 patients in the placebo group (11.7 percent) had an injury (p=0.01). The authors note that three separate individuals in the placebo group experienced a tibial plateau fracture. No other information is provided on the cause or nature of the injuries.179

##### Mortality

The placebo-controlled trial of topiramate reported one death in the placebo group following a cardiac arrest associated with gastrointestinal tract bleeding and seizures.179 According to the investigators, the precipitating incident could not be determined. There was no mention of deaths in the topiramate group.179

### Detailed Synthesis: Head-to-Head Trials Including FDA-Approved Medications

We identified 3 RCTs (Table 24) that reported at least one health outcome of interest. Two of these were rated as high risk of bias for the head-to-head comparison—one three-arm study comparing naltrexone with disulfiram or placebo,90 and one four-arm open-label trial comparing acamprosate, disulfiram, and naltrexone.184 Both trials had high risk of ascertainment bias; one did not adequately handle missing data for QoL outcomes (see Appendix C for additional details about risk of bias ratings).

Table 24 Characteristics of head-to-head randomized controlled trials reporting a health outcome

Author, Year Trial Name Design | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Setting | Recruitment Method | Age, Years | % Non-White | % Female | Cointervention | Risk of Bias
Anton, 2006^65^ LoCastro, 2009^193^ COMBINE DBRCT | ACA 3,000 + CBI + MM (151) ACA 3,000 + MM (152) NTX 100 + CBI + MM (155) NTX 100 + MM (154) Placebo + CBI + MM (156) Placebo + MM (153)^a^ | 68 | U.S.; 11 sites | Ads, community resources, clinical referrals at 11 academic sites | 44 | 23 | 31 | Community support group participation encouraged (e.g., AA) | Low
Laaksonen, 2008^184^ OLRCT | ACA 1,998 or 1,333 (81) DIS 100 to 200 (81) NTX 50 (81) | Up to 52 (119) | Finland; 6 sites in 5 cities | Volunteers seeking outpatient treatment for alcohol problems | 43 | 0 | 29 | Manual-based CBT^b^ | High for quality of life / KQ 2
Petrakis, 2005^90^ Ralevski, 2007^94^ Petrakis, 2007^95^ Petrakis, 2006^96^ VA MIRECC DBRCT | DIS 250 (66) NTX 50 (59) Placebo (64) NTX 50 + DIS 250 (65) | 12 | U.S.; Outpatient VA | Recruited as outpatients or via ads | 47 | 26 | 3 | Psychiatric treatment as usual 100% | High for DIS vs. NTX

AA = Alcoholics Anonymous; ACA = acamprosate; CBI = combined behavioral intervention; COMBINE = Combined Pharmacotherapies and Behavioral Intervention; DBRCT = double-blind randomized controlled trial; DIS = disulfiram; mg = milligram; MIRECC = Mental Illness Research, Education and Clinical Center; MM = medical management; N = number; NR = not reported; NTX = naltrexone; OLRCT = open-label randomized controlled trial; U.S. = United States; VA = Veterans Affairs.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Three additional treatment arms were included in COMBINE but were not relevant to our Key Questions: ACA + NTX + CBI + MM, ACA + NTX + MM, and CBI only (no pills).

b Co-intervention included a “Winning at last--defeating the drinking problem” booklet targeted to match medication goals (i.e., reduction in drinking or abstinence for ACA and NTX; abstinence for DIS).

One study (COMBINE), rated as low risk of bias, reported mortality and QoL. COMBINE is a multicenter nine-arm trial that compared eight groups of patients receiving medical management with 16 weeks of naltrexone (100 mg per day) or acamprosate (3 g per day), both, and/or both placebos, with or without a combined behavioral intervention (CBI). The ninth group received CBI only and no drug or placebo. Mean age was 44 years; all patients met criteria for alcohol dependence.

#### Acamprosate Versus Naltrexone

##### Mortality

In the COMBINE trial, the authors reported that one fatal serious adverse event was reported during the 16-week treatment phase. This was classified by investigators as not related to the study medication. No details were provided on which group the death occurred in, the nature of the adverse event, or the cause of death.

One study, rated as high risk of bias, reported that one person committed suicide and two persons drowned in the acamprosate group but reported no events in the naltrexone group.184

##### Quality of Life or Functional Status

The COMBINE study assessed QoL using the WHOQOL and SF-12v2 physical and mental health scores. Results were not presented for each treatment group separately.193 To analyze the treatment effects of specific pharmacological and behavior treatment combinations on QoL, a mixed-effects general linear model was used to examine the main and interaction effects of three treatments (acamprosate, naltrexone, and CBIs) from baseline to 26 weeks and from baseline to 52 weeks (20 ANOVAs were conducted unadjusted and 20 were adjusted for percentage heavy drinking days). The results indicate that the eight combinations of pharmacological and behavioral treatments did not show differential effects on QoL for either scale. The only two significant effects reaching a p value of <0.001 (to account for multiple tests) were the two-way interaction of naltrexone by CBI for the SF-12v2 physical health score at 52 weeks for both the adjusted and unadjusted analyses. The authors conclude that this suggests CBI and naltrexone combined have a greater impact than either alone for the SF-12v2 physical health scale; however, the difference between groups was no larger than 2.1, and unlikely to suggest a clinically meaningful difference (the 95% confidence interval for the SF-12v2 physical health scale is 6.6).193

One study rated as high risk of bias measured QoL with the European Quality of Life Scale (EQ-5),200 Koskenvuo Quality of Life Scale (KQL),201 and Visual Analogue Scale (VAS).202 QoL improved for both groups over the 52-week followup compared with baseline with no difference between the acamprosate or naltrexone groups.184

#### Acamprosate Versus Disulfiram

##### Accident or Injury

One study, rated as high risk of bias, reported one traffic accident in the disulfiram group and none in the acamprosate group over 52 weeks.184 No details of the event were described; the study coordinator determined that the event was not related to the study treatment.

##### Mortality

One study, rated as high risk of bias, reported that one person committed suicide and two persons drowned in the acamprosate group and reported no events in the disulfiram group.184

##### Quality of Life

QoL was measured in one study rated high risk of bias with the EQ-5, KQL, and VAS. QoL improved for both groups over the 52-week followup compared with baseline with no difference between the acamprosate or disulfiram groups.184

#### Disulfiram Versus Naltrexone

##### Accident or Injury

One study, rated as high risk of bias, reported one traffic accident in the disulfiram group and no accident or injuries in the naltrexone group.184 No details of the event were described; the study coordinator determined that the event was not related to the study treatment.

##### Mortality

In 1 study rated high risk of bias that compared disulfiram and naltrexone among patients with co-existing depression, one person died in the naltrexone group and no deaths were reported in the disulfiram group.90

##### Quality of Life

QoL was measured in 1 study rated high risk of bias with the EQ-5, KQL, and VAS. QoL improved for both groups over the 52-week followup compared with baseline with no difference between the disulfiram or naltrexone groups.184

### Detailed Synthesis: Head-to-Head Trials Including Medications Used Off-Label or Those Under Investigation

We identified 3 head-to-head trials of off-label medications that measured an eligible health outcome (Table 25). One compared sertraline with naltrexone; 2 compared topiramate with naltrexone. Sample size ranged from 89 to 182 within the relevant head-to-head arms. All subjects met criteria for alcohol dependence, the average age of participants was similar across trials (43 to 48), and females made up 15 to 38 percent of participants. The trial comparing sertraline with naltrexone was conducted among patients with co-occurring depression.104 The trials comparing topiramate with naltrexone enrolled about a quarter of subjects with personality disorders.203,204 Only the study comparing sertraline with naltrexone reported on smoking rates: 14 to 20 percent of participants were smokers. All studies included a psychological co-intervention.

Table 25 Characteristics of head-to-head randomized controlled trials including medications used off-label or those under investigation

Author, Year Design | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Florez, 2008^205^ OLRCT | TOP intended 200^a^ (51) NTX 50 (51) | 26 | Spain; Outpatient substance abuse clinic, referrals | Recruited when presenting for treatment | 47 | 0 | 15 | Personality disorders 27 | Therapy based on Relapse Prevention Model 100% | High
Florez, 2011^204^ OLRCT | TOP 200 (91) NTX 50 (91) | 26 | Spain; Outpatient substance abuse clinic, referrals | Recruited and screened when presenting for treatment | 47 to 48 | NR | 15 | Personality disorders 23 | BRENDA 100% At least monthly meeting with psychiatrist 100% | High
Pettinati, 2010^104^ DBRCT | SER 200 (40) NTX 100 (49) Placebo (39) SER 200 + NTX 100 (42) | 14 | U.S.; Outpatient | Newspaper ads, referrals | 43 | 35 | 38 | Depression 100 | CBT 100% | Medium

BRENDA = BRENDA is an acronym based on the components of the intervention: (B)iopsychosocial evaluation, (R)eport to the patient on assessment, (E)mpathic understanding of the patient's situation, (N)eeds collaboratively identified by the patient and treatment provider, (D)irect advice to the patient on how to meet those needs, (A)ssess reaction of the patient to advice and adjust as necessary for best care; CBT = cognitive behavioral therapy; DBRCT = double-blind randomized controlled trial; mg = milligram; N = number; OLRCT = open-label randomized controlled trial; TOP = topiramate; U.S., United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Actual dosing: increased by 50 mg per day up to 300 or 400 mg based on consumption control or cravings.

One double-blind RCT compared sertraline 200 mg per day with naltrexone 100 mg per day104 and 2 open-label RCTs compared topiramate 200 mg per day to naltrexone 50 mg per day.203,204 One study was conducted within the United States104 and 2 were conducted in Spain.203,204 The trial comparing sertraline to naltrexone was rated as medium risk of bias and the 2 studies comparing topiramate to naltrexone were rated as high risk of bias.203,204 One study allowed titration of topiramate from 200 mg per day up to 300 to 400 mg per day based on continued alcohol consumption or craving.203

#### Sertraline Versus Naltrexone

##### Mortality

One trial comparing sertraline with naltrexone among patients with co-occurring depression and alcohol dependence reported no deaths in either group.104

#### Topiramate Versus Naltrexone

##### Quality of Life or Function

One unblinded study rated as high risk of bias used the World Health Organization Psychiatric Disability Assessment Schedule (WHO/DAS) to assess alcohol dependence-related disability at 3 and 6 months.204 No significant changes were found in most domains of the WHO/DAS at 3 months (personal, family, social), with one exception: patients taking topiramate had a lower disability score on the employment domain (1.64 versus 2.2, p=0.047). At 6 months, the topiramate group had lower disability scores for the family (0.58 versus 1.05, p=0.035) and social domains (0.46 versus 0.83, p=0.154); there was no difference between the two groups in the employment or personal domains at 6 months.204 A similar study (by the same author), which dosed topiramate based on continued alcohol intake or craving, found no difference between the topiramate and naltrexone groups on any of the WHO/DAS domains at 3 or 6 months.203

This same study measured QoL using the EQ-5D at 3 and 6 months.204 At 3 months, the topiramate group had a small, but statistically significant, greater improvement in QoL compared with the naltrexone group (96.10 versus 94.16, p=0.014); there was no difference between the two groups at 6 months.204 A similar study (by the same author), which dosed topiramate based on continued alcohol intake or craving, found that patients treated with topiramate had better QoL at 3 months compared with naltrexone (96.88 versus 95.21, p=0.014) but no statistically significant difference was found between the two groups at 6 months.203

## Key Question 3 Adverse Effects of Medications

For this question, we evaluated trials included in Key Questions (KQs) 1 and 2. In addition, we searched for nonrandomized controlled trials (non-RCTs), open-label trials, single-blind trials, prospective cohort studies, and case-control studies otherwise meeting the eligibility criteria. We ultimately included 105 double-blind RCTs, eight open-label or single-blind RCTs, and one prospective cohort study. Throughout this KQ, we often describe risks of various adverse events—risks reported are absolute risk differences (RDs) between intervention and control. Because the studies were not primarily focused on harms, the reporting of harms varied across studies significantly. Limited information was reported for most of the off-label medications—insufficient for synthesis of specific adverse events or for making definitive conclusions. We therefore focus here on the Food and Drug Administration (FDA)-approved medications and those with moderate or better evidence supporting efficacy. We do not include information on medications with insufficient evidence to support their efficacy (i.e., efficacy as determined in KQ 1).

### Key Points

- Adverse events were often not collected using standardized measures, and methods for systematically capturing adverse events were often not reported.
- Selective outcome reporting could impact our results. Reporting varied across studies, with some studies only reporting adverse effects that were significantly different from placebo (or control) group, some reporting effects observed in more than some percentage of patients (e.g., 5 percent or more), and others listing effects that were considered in the study.
- While major harms were rarely reported in the studies, some minor harms (e.g., diarrhea) were reported more consistently.
- For many serious harms, the evidence was insufficient to determine comparative rates of adverse events — very little data were available.
- Suicidality, or self-harmful behaviors: evidence was insufficient to determine whether risk was increased with any of the medications. Evidence from studies of FDA-approved drugs was limited to 3 cases of suicide attempts or suicidal ideation reported in acamprosate arms and 3 in placebo arms. In studies that compared nalmefene with placebo, there were 4 cases of suicide attempts or suicidal ideation in nalmefene arms and 9 in placebo arms.
- Withdrawals due to adverse events: In head-to-head studies, the risk of withdrawals due to adverse events was not significantly different between acamprosate and naltrexone.
- Specific adverse events: Compared with placebo, patients treated with acamprosate had a higher risk of anxiety, diarrhea, and vomiting; those treated with naltrexone had a higher risk of dizziness, nausea, and vomiting; those treated with nalmefene had a higher risk of dizziness, headache, insomnia, nausea, and vomiting. Trials of topiramate reported increased risks of many adverse events, including paresthesias, taste perversion, anorexia, difficulty with concentration/attention, nervousness, dizziness, pruritis, psychomotor slowing, and weight loss. In head-to-head studies, patients treated with acamprosate had a slightly lower risk of headache and vomiting than those treated with naltrexone.

### Detailed Synthesis

In this section, we have considered harms associated with acamprosate, disulfiram, naltrexone, nalmefene, topiramate, and valproic acid. Our main meta-analyses included studies of low and medium risk of bias reporting results for the specific adverse event. We conducted sensitivity analyses that also included studies rated as high or unclear risk of bias. Insufficient data were available to conduct meta-analyses of results from studies that compared disulfiram with placebo, acamprosate, naltrexone, or other controls. Therefore, we described and summarized these qualitatively when possible.

### Characteristics of Included Studies

The vast majority of the included RCTs are described in KQs 1 and 2, and we do not describe them again in this KQ. Ten studies not described in KQs 1 or 2 were eligible for inclusion in this KQ. These included 7 open-label183,185,186,203,204,206 or single-blind RCTs,207 2 double-blind RCTs,208-210 and 1 prospective cohort study.211 Of those 10, 6 focused on comparisons addressed in this KQ (Table 26); the other 4 focused on comparisons with medications used off-label—either topiramate203,204,206 or buspirone.208,209 All but 1 of the studies210 listed in Table 26 were rated as high risk of bias, primarily due to concerns with selection bias, attrition bias, measurement bias, confounding, or selective outcome reporting bias (see Appendix C for details).

Table 26 Characteristics of studies included for Key Question 3 that were not in Key Question 1 or 2

Author, Year Design | Arm Dose, mg/Day (N) | Rx Duration, Weeks | Country Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Additional Condition | Cointer-vention | Risk of Bias
Anton, 2003^210^ COMBINE pilot DBRCT | ACA 3,000 + CBI + MM (9) ACA 3,000 + MM (9) NTX 100 + CBI + MM (9) NTX 100 + MM (9) Placebo + CBI + MM (9) Placebo + MM (8)^b^ | 16 | 11 U.S. academic sites | Ads, community resources, clinical referrals at 11 academic sites | 38 to 42 | 17 to 22 | 22 to 33 | NR | As randomized | Med
De Sousa, 2005^183^ OLRCT | ACA 1,998 (50) DIS 250 (50) | 35 | India; outpatient, private psychiatric hospital | Patients undergoing detoxification | 42 to 43 | 100 | 0 | NR | Weekly supportive group psychotherapy offered | High
De Sousa, 2004^185^ OLRCT | DIS 250 (50) NTX 50 (50) | 52 | India; outpatient | Recruited as inpatients | 43 to 47 | NR | 0 | NR | Supportive group psychotherapy | High
Narayama, 2008 211 Prospective cohort | ACA 1,332 to 1,998 (28) NTX 50 (26) TOP 100 to 125 (38) | 52 | India; military, outpatient | Members of the Armed Forces | 38 | 100 | 0 | NR | Various psychotherapies were offered | High
Nava, 2006^186^ OLRCT | GHB 50 a (28) NTX 50 (24) DIS 200 (28) | 52 | Italy; outpatient | Advertisements, word of mouth, press release | 38.5 to 42.7 | NR | 15% | 0 | Cognitive behavioral therapy | High
Rubio, 2001^207^ SBRCT | ACA 1,665-1,998 (80) NTX 50 (77) | 52 | Spain; outpatient | Patients presenting to hospital for detoxification | 44 | NR | 0 | 0 | Supportive group therapy weekly; weekly visits with a psychiatrist for 3 months, then biweekly until end of study | High

ACA = acamprosate; CBI = combined behavioral intervention; COMBINE = Combined Pharmacotherapies and Behavioral Intervention; DIS = disulfiram; DBRCT = double-blind randomized controlled trial; FDA = U.S. Food and Drug Administration; GHB = γ-Hydroxybuteric acid; med = medium; mg = milligrams; MM = medical management; N = number; NR = not reported; NTX = naltrexone; OLRCT = open-label randomized controlled trial; SBRCT = single-blind randomized controlled trial; TOP = topiramate; U.S. = United States.

Notes: Age, Years is the mean age in years, unless otherwise stated.

The following studies also met the inclusion criteria, but assessed harms of an off-label medication (compared with placebo) without evidence of efficacy, or compared an off-label medication without evidence of efficacy with an FDA-approved medication, and are therefore not described further in this Key Question: Florez, 2011,^204^, Florez, 2008^203^, De Sousa, 2008,^206^ and Tollefson, 1991.^208,209^

a Dose is 50 mg per kg of body weight 3 times a day.

b Three additional treatment arms were included in COMBINE pilot study but were not relevant to our Key Questions: ACA + NTX + CBI + MM, ACA + NTX + MM, and CBI only (no pills).

For the 6 studies not described elsewhere that focused on comparisons addressed in this KQ, 2 compared acamprosate with naltrexone,207,211 1 was the multiarm COMBINE pilot study,210 2 compared naltrexone with disulfiram,185,186 and 1 compared acamprosate with disulfiram.183 Study duration ranged from 35 to 52 weeks. Three of the studies were conducted in India, 1 in the United States, 1 in Spain, and 1 in Italy. For 3 trials, study participants were recruited as inpatients. For the other trials, recruitment methods included advertisements, word of mouth, clinical referrals, and a press release.186 The prospective cohort study211 followed members of the armed forces. Mean age ranged from 38 to 47 years. Two of the studies included women.186,210 In 2 studies,183,211 all participants were nonwhite; 1 study enrolled 17 to 22 percent nonwhite subjects;210 race and ethnicity was not reported in the other 3 studies.

#### Acamprosate Compared With Placebo

Table 27 summarizes the main results of our meta-analyses. The only statistically significant findings for harms from our main analyses were for anxiety, diarrhea, and vomiting. Statistical heterogeneity was considerable for the diarrhea analysis (I^2^ 88.9 percent), with some studies finding much higher rates of diarrhea than with placebo (with absolute risks increased as much as 33 percent). Sensitivity analyses for withdrawals due to adverse events, anxiety, diarrhea, and vomiting were also statistically significant (finding higher risk with acamprosate).

Table 27 Results of meta-analyses and risk difference calculations for adverse events: acamprosate compared with placebo

Outcome | N Trials | N Subjects | RD | 95% CI | Heterogeneity I^2^
Withdrawal due to adverse events | 13 | 4,653 | 0.01 | -0.00 to 0.02 | 8.5%
Withdrawal due to adverse events—SA | 16 | 5,480 | 0.01 | 0.00 to 0.01 | 0.0%
Anxiety | 1 | 601 | 0.16 | 0.10 to 0.23 | NA
Anxiety—SA | 2 | 624 | 0.16 | 0.09 to 0.22 | 0.0%
Diarrhea | 12 | 3,299 | 0.10 | 0.03 to 0.17 | 88.9%
Diarrhea—SA | 14 | 4,118 | 0.09 | 0.04 to 0.15 | 85.8%
Dizziness | 2 | 151 | 0.08 | -0.22 to 0.38 | 80.3%
Headache | 6 | 1,074 | 0.001 | -0.05 to 0.05 | 67.0%
Headache—SA | 7 | 1,643 | 0.002 | -0.04 to 0.04 | 60.2%
Insomnia | 3 | 251 | 0.02 | -0.10 to 0.14 | 73.5%
Insomnia—SA | 4 | 820 | 0.02 | -0.06 to 0.09 | 63.8%
Nausea | 7 | 1,758 | 0.01 | -0.01 to 0.02 | 0.3%
Nausea—SA | 8 | 1,828 | 0.01 | -0.01 to 0.03 | 12.5%
Numbness | 1 | 262 | 0.01 | -0.01 to 0.03 | NA
Numbness—SA | 2 | 831 | 0.01 | -0.01 to 0.03 | 0.0%
Rash | 1 | 35 | 0.11 | -0.07 to 0.29 | NA
Rash—SA | 2 | 105 | 0.07 | -0.01 to 0.16 | 0.0%
Suicide attempts or suicidal ideation | 1 | 581 | 0.007 | -0.005 to 0.019 | NA
Suicide attempts or suicidal ideation—SA | 2 | 1,173 | 0.002 | -0.008 to 0.011 | 14.6%
Vomiting | 4 | 1,817 | 0.02 | 0.01 to 0.04 | 0.0%
Vomiting – SA | 5 | 1,840 | 0.02 | 0.01 to 0.04 | 0.0%

CI = confidence interval; N = number of trials or subjects contributing data; NA = not applicable; RD = risk difference; SA = sensitivity analysis.

Note: Positive risk differences favor placebo. Sensitivity analyses include studies rated as high risk of bias.

#### Disulfiram Compared With Placebo or Control

Four included studies compared disulfiram with placebo or control.90-93 One of these did not report results for adverse events.93 The other 3 did not yield sufficient quantitative data to conduct meta-analyses.

One study of disulfiram compared with placebo in patients who were all taking methadone reported that “there were no deaths, serious adverse reactions, or illnesses that could be attributed to the combined use of the drugs [disulfiram and methadone]” but did not provide details about the incidence of specific adverse events in the study population.91

In another study, patients who received 250 mg per day of disulfiram reported “moderate or severe” drowsiness more often than those not given disulfiram (8 versus 2 percent, p=0.03). There was no significant difference in the incidence of drowsiness between the 250 and 1 mg per day disulfiram groups.92 In this same study, disulfiram was discontinued by 3 patients in the 250 mg per day group and 1 patient in the 1 mg per day group because of increased serum alkaline phosphatase or aspartate aminotransferase. Psychiatric problems were observed in 11 patients with no statistically significant difference between the three groups.92

Results from a four-arm study comparing disulfiram combined with naltrexone, disulfiram combined with placebo, naltrexone alone, and placebo alone showed that patients on any study medication experienced aftertaste, blurred vision, confusion, constipation, drowsiness, dry mouth, loss of appetite, nausea, or tremors more often than patients who received placebo. There were no statistically significant between-group differences for other adverse events.90 Six of the 14 serious adverse events reported in this study occurred in the disulfiram with placebo group (4 psychiatric hospitalizations—2 for a change in mental status and 2 for suicidal ideation, 1 cardiac event, and 1 hospitalization for acute axonal neuropathy) and 3 occurred in the placebo group (1 death, 1 drug and alcohol overdose, and 1 hospitalization for pneumonia).90

#### Naltrexone Compared With Placebo

Table 28 summarizes the main results of our meta-analyses. We found statistically significant increased risk of withdrawal due to adverse events, dizziness, nausea, and vomiting.

Table 28 Results of meta-analyses and risk difference calculations for adverse events: naltrexone compared with placebo

Outcome | N Trials | N Subjects | RD | 95% CI | Heterogeneity I^2^
Withdrawal due to adverse events | 17 | 2,743 | 0.02 | 0.01 to 0.03 | 0.0%
Withdrawal due to adverse events - SA | 20 | 2,899 | 0.02 | 0.01 to 0.03 | 0.0%
Anxiety | 7 | 1,461 | 0.01 | -0.02 to 0.04 | 0.0%
Anxiety—SA | 9 | 1,676 | 0.01 | -0.02 to 0.04 | 0.0%
Diarrhea | 11 | 2,358 | 0.01 | -0.01 to 0.04 | 21.9%
Diarrhea – SA | 12 | 2,461 | 0.01 | -0.02 to 0.03 | 30.2%
Dizziness | 13 | 2,675 | 0.06 | 0.04 to 0.09 | 37.4%
Dizziness - SA | 17 | 2,977 | 0.06 | 0.04 to 0.08 | 27.1%
Headache | 17 | 3,347 | 0.01 | -0.02 to 0.03 | 8.0%
Headache - SA | 22 | 3,799 | 0.00 | -0.02 to 0.03 | 20.9%
Insomnia | 8 | 1,637 | 0.03 | -0.003 to 0.06 | 0.0%
Insomnia - SA | 12 | 2,030 | 0.03 | 0.001 to 0.05 | 0.0%
Nausea | 24 | 4,655 | 0.11 | 0.07 to 0.15 | 69.6%
Nausea - SA | 31 | 5,263 | 0.10 | 0.07 to 0.13 | 65.9%
Numbness | 1 | 123 | -0.01 | -0.19 to 0.17 | NA
Numbness - SA | 2 | 226 | -0.02 | -0.08 to 0.04 | 0.0%
Rash | 4 | 469 | -0.01 | -0.06 to 0.04 | 41.6%
Rash – SA | 5 | 522 | -0.02 | -0.06 to 0.02 | 21.5%
Blurred vision | 2 | 133 | 0.08 | -0.17 to 0.33 | 46.3%
Vomiting | 9 | 2,438 | 0.04 | 0.02 to 0.06 | 0.0%
Vomiting - SA | 11 | 2,567 | 0.04 | 0.02 to 0.06 | 1.1%

Note: Positive risk differences favor placebo. Sensitivity analyses include studies rated as high risk of bias.

Abbreviations: CI = confidence interval; N = number of trials or subjects contributing data; NA = not applicable; RD = risk difference; SA = sensitivity analysis.

#### Acamprosate Compared With Disulfiram

Both studies reporting results for adverse events for this comparison were rated as high risk of bias; both reported no statistically significant differences between the acamprosate and disulfiram groups.183,184

One of the studies reported that six patients who received disulfiram experienced elevated alanine transaminase (ALAT) levels. Subsequently, three of the patients discontinued the medication, and three continued to receive a half dose; ALAT levels normalized within 2 to 3 weeks.184 The most common adverse events reported in the study for patients treated with acamprosate were diarrhea and dermatological problems; for patients treated with disulfiram—tiredness and headache.

#### Acamprosate Compared With Naltrexone

Table 29 summarizes the main results of our meta-analyses. The risks of headache, nausea, and vomiting were slightly higher for those treated with naltrexone in either the main analyses or in sensitivity analyses that included studies rated as high or unclear risk of bias.

Table 29 Results of meta-analyses for adverse events: acamprosate compared with naltrexone

Outcome | N Trials | N Subjects | RD | 95% CI | Heterogeneity I^2^
Withdrawal due to adverse events | 2 | 953 | 0.01 | -0.04 to 0.07 | 73.4%
Withdrawal due to adverse events—SA | 3 | 1,110 | 0.00 | -0.04 to 0.04 | 64.5%
Diarrhea | 4 | 836 | 0.18 | -0.02 to 0.37 | 89.3%
Diarrhea—SA | 5 | 993 | 0.14 | -0.07 to 0.35 | 96.0%
Dizziness | 2 | 144 | 0.08 | -0.23 to 0.39 | 81.7%
Dizziness—SA | 3 | 306 | -0.03 | -0.19 to 0.13 | 82.4%
Headache | 3 | 301 | -0.06 | -0.12 to 0.01 | 0.0%
Headache—SA | 4 | 463 | -0.09 | -0.16 to -0.01 | 36.3%
Insomnia | 2 | 144 | 0.07 | -0.20 to 0.34 | 65.5%
Nausea | 4 | 836 | -0.08 | -0.18 to 0.02 | 72.8%
Nausea—SA | 6 | 1,155 | -0.10 | -018 to -0.02 | 71.6%
Vomiting | 2 | 648 | -0.06 | -0.11 to -0.01 | 0.0%

CI = confidence interval; N = number of trials or subjects contributing data; NA, not applicable; RD = risk difference; SA = sensitivity analysis.

Note: Positive risk differences favor naltrexone. Table only includes rows for outcomes with sufficient data for meta-analyses.

A prospective cohort study rated as high risk of bias comparing acamprosate with naltrexone reported that adverse events were uncommon, mild, and temporary in both groups. The most common adverse events in the naltrexone group (N=26) were anxiety (23.07 percent), nervousness (23.07 percent), and insomnia (15.4 percent); these were not reported in the acamprosate group. The most common adverse events in the acamprosate group (N=28) were nausea (25.0 percent) and diarrhea (21.42 percent); 11 percent of those in the naltrexone group experienced nausea, but none reported diarrhea.211

#### Disulfiram Compared With Naltrexone

We found 4 studies comparing disulfiram with naltrexone and reporting on adverse events; all 4 were rated as high risk of bias.90,184-186 One of these reported no statistically significant difference in the incidence of adverse events between groups;184 another stated that no serious adverse events occurred during the study and reported the incidence of adverse events only among those who withdrew because of adverse events.186

In 1 of the studies, nausea, drowsiness, abdominal pain, and diarrhea were more common among patients receiving naltrexone than among those receiving disulfiram, but statistical significance was not reported.185

A four-arm study comparing disulfiram combined with naltrexone, disulfiram combined with placebo, naltrexone alone, and placebo alone found that fever was more common in the disulfiram group than in the naltrexone group (p=0.03); nervousness (p=0.005) and restlessness (p=0.03) were more common in the naltrexone group than in the disulfiram group.90

#### Nalmefene Compared With Placebo

Table 30 summarizes the main results of our meta-analyses. Considering outcomes with multiple low or medium risk of bias studies, our main meta-analyses found that patients treated with nalmefene had a higher risk of withdrawal due to adverse events, dizziness, headache, insomnia, nausea, and vomiting, compared with patients who received placebo. Sensitivity analyses including studies rated as high or unclear risk of bias found similar results. Nalmefene was associated with a lower risk of diarrhea than placebo.

Table 30 Results of meta-analyses and risk difference calculations for adverse events: nalmefene compared with placebo

Outcome | N Trials | N Subjects | RD | 95% CI | Heterogeneity I^2^
Withdrawal due to adverse events | 5 | 2,054 | 0.08 | 0.02 to 0.15 | 86.4%
Withdrawal due to adverse events—SA | 7 | 2,750 | 0.08 | 0.04 to 0.12 | 79.5%
Cognitive dysfunction | 1 | 265 | 0.05 | 0.01 to 0.09 | NA
Cognitive dysfunction—SA | 2 | 830 | 0.03 | -0.03 to 0.08 | 81.9%
Diarrhea | 2 | 1,081 | -0.03 | -0.06 to -0.01 | 0.0%
Dizziness | 4 | 1,944 | 0.16 | 0.11 to 0.21 | 58.4%
Dizziness—SA | 6 | 2,630 | 0.14 | 0.10 to 0.18 | 53.5%
Headache | 3 | 1,401 | 0.04 | 0.01 to 0.07 | 0.0%
Headache—SA | 4 | 2,066 | 0.04 | 0.01 to 0.07 | 0.0%
Insomnia | 5 | 2,049 | 0.10 | 0.06 to 0.14 | 47.3%
Insomnia—SA | 6 | 2,714 | 0.09 | 0.06 to 0.12 | 34.9%
Nausea | 5 | 2,049 | 0.16 | 0.10 to 0.22 | 75.8%
Nausea—SA | 6 | 2,714 | 0.16 | 0.11 to 0.21 | 69.8%
Suicide attempts or suicidal ideation | 2 | 1,253 | -0.01 | -0.02 to 0.00 | 0.0%
Suicide attempts or suicidal ideation—SA | 3 | 1,918 | -0.00 | -0.01 to 0.01 | 39.2%
Vomiting | 3 | 1,679 | 0.06 | 0.02 to 0.10 | 68.1%
Vomiting—SA | 4 | 2,344 | 0.07 | 0.03 to 0.11 | 76.2%

CI = confidence interval; N = number of trials or subjects contributing data; NA = not applicable; RD = risk difference; SA = sensitivity analysis.

Note: Positive risk differences favor placebo. Sensitivity analyses include studies rated as high risk of bias.

#### Topiramate Compared With Placebo

Trials of topiramate reported increased risk of many adverse events, including paresthesias, taste perversion, anorexia, difficulty with concentration/attention, nervousness, dizziness, pruritis, psychomotor slowing, and weight loss.175,179 Table 31 summarizes the main results of our meta-analyses; few studies of topiramate contributed adverse events data.

Table 31 Results of meta-analyses and risk difference calculations for adverse events: topiramate compared with placebo

Outcome | N Trials | N Subjects | RD | 95% CI | Heterogeneity I^2^
Withdrawal due to adverse events | 2 | 521 | 0.06 | -0.12 to 0.25 | 93.4%
Withdrawal due to adverse events—SA | 3 | 599 | 0.06 | -0.06 to 0.18 | 86.9%
Anorexia | 1 | 371 | 0.13 | 0.06 to 0.20 | NA
Cognitive dysfunction | 2 | 521 | 0.08 | 0.01 to 0.16 | 38.5%
Diarrhea | 1 | 371 | 0.04 | -0.03 to 0.10 | NA
Diarrhea—SA | 2 | 477 | 0.00 | -0.07 to 0.08 | 61.1%
Dizziness | 2 | 521 | 0.10 | -0.01 to 0.22 | 65.0%
Dizziness—SA | 3 | 627 | 0.08 | 0.01 to 0.14 | 51.5%
Headache | 1 | 371 | -0.08 | -0.17 to 0.01 | NA
Insomnia | 1 | 371 | 0.03 | -0.05 to 0.11 | NA
Insomnia—SA | 2 | 477 | 0.03 | -0.03 to 0.10 | 0.0%
Nausea | 1 | 371 | -0.06 | -0.13 to 0.01 | NA
Nausea—SA | 2 | 477 | -0.02 | -0.11 to 0.06 | 62.0%
Numbness/tingling/paresthesias | 2 | 521 | 0.40 | 0.32 to 0.47 | 0.0%
Numbness/tingling/paresthesias—SA | 3 | 627 | 0.29 | 0.05 to 0.52 | 93.1%
Taste abnormalities | 1 | 371 | 0.18 | 0.11 to 0.25 | NA

CI = confidence interval; N = number of trials or subjects contributing data; NA = not applicable; RD = risk difference; SA = sensitivity analysis.

Note: Positive risk differences favor placebo. Sensitivity analyses include studies rated as high risk of bias.

#### Valproic Acid Compared With Naltrexone

A single trial that reported adverse effects for valproic acid compared with placebo found a higher rate of nausea for patients treated with valproic acid (Table 32).

Table 32 Results of risk difference calculations for adverse events: valproic acid compared with placebo

Outcome | N Trials | N Subjects | RD | 95% CI | Heterogeneity I^2^
Withdrawal due to adverse events | 1 | 52 | 0.04 | -0.07 to 0.14 | NA
Diarrhea | 1 | 52 | 0.10 | -0.12 to 0.32 | NA
Headache | 1 | 52 | 0.05 | -0.20 to 0.30 | NA
Nausea | 1 | 52 | 0.25 | 0.05 to 0.46 | NA
Vision changes | 1 | 52 | -0.02 | -0.26 to 0.22 | NA

CI = confidence interval; N = number of trials or subjects contributing data; NA = not applicable; RD = risk difference.

Note: Positive risk differences favor placebo. Sensitivity analyses include studies rated as high risk of bias.

## Key Question 4 Evidence From Primary Care Settings

### Characteristics of Included Trials

We identified 1 eligible trial conducted completely in primary care settings.69 It compared acamprosate 1,998 milligrams per day with placebo for 12 weeks and was based in two U.S. primary care clinics. Primary care providers also delivered a brief structured behavioral intervention. Mean age of patients was 48, 9 percent of patients were non-White, and almost 40 percent were female.

One additional included trial compared targeted nalmefene with placebo for 28 weeks in 15 sites in Finland—5 of the sites were specialist treatment clinics, 6 were private general practice offices, 2 were offices for occupational health, and 2 were specialized in conducting outpatient clinical research (Table 33).158 For targeted nalmefene dosing, patients were instructed to take the medication when they believed drinking to be imminent, rather than as a daily scheduled medication. The trial reported that 93 percent of subjects met criteria for alcohol dependence. It did not report information on smoking history at baseline. The study did not include any formal manualized psychosocial treatment, but did include some elements of BRENDA,212 including biopsychosocial assessment, feedback to subjects about assessments, simple advice to reduce drinking, and monitoring of treatment progress—with the emphasis on correct use of the study medication.

Table 33 Characteristics of included randomized controlled trials of FDA-approved medications for treating alcohol dependence in primary care settings

Author, Year | Arm Dose, mg/Day (N) | Rx Duration, Weeks (Followup) | Setting | Recruitment Method | Age, Years | % Non-White | % Female | % With Co-occurring Condition | Cointervention | Risk of Bias
Berger, 2013^69^ | ACA 1,998 (51) Placebo (49) | 12 | U.S.; 2 primary care sites | Provider referral and ads | 48 | 9 | 38 | NR | Brief structured behavioral intervention from primary care physician | Medium
Karhuvaara, 2007^158^ | Nalmefene 10 to 40 targeted dose (242) Placebo (161) | 28 (52)^a^ | Finland; 15 sites | Mainly by newspaper ads | 49 | 0 | 19 | NR | Some elements of BRENDA | Medium

BRENDA = BRENDA is an acronym based on the components of the intervention: (B)iopsychosocial evaluation, (R)eport to the patient on assessment, (E)mpathic understanding of the patient's situation, (N)eeds collaboratively identified by the patient and treatment provider, (D)irect advice to the patient on how to meet those needs, (A)ssess reaction of the patient to advice and adjust as necessary for best care; FDA = U.S. Food and Drug Administration; mg = milligram; N = number; NR = not reported; U.S. = United States.

Note: Age, Years is the mean age in years, unless otherwise stated.

a After 28 weeks, nalmefene responders were invited to continue in a double-blind randomized controlled trial for an additional 24 weeks.

Several other published studies, including some in other sections of this report, may have implications for or some applicability to primary care settings, an issue addressed in the report Discussion.

### Results for Consumption Outcomes

The trial conducted completely in primary care settings (N=100)69 found no significant treatment effect of acamprosate on drinking days (effect size, 0.14; 95% CI, -0.26 to 0.53) or heavy drinking days (effect size, 0.27; 95% CI, -0.12 to 0.67).

The Finnish trial (N=403) found no significant difference in percentage of drinking days between nalmefene and placebo (WMD, -3.8; 95% CI, -9.3 to 1.7), but reported a lower percentage of heavy drinking days for patients treated with targeted nalmefene (18.1 percent versus 29.7 percent, p=0.024) and 1 fewer drink per drinking day for patients treated with nalmefene (WMD, -1.0; 95% CI, -2.0 to -0.02) than for those who received placebo.

## Key Question 5 Subgroups

We evaluated evidence on whether any of the medications were more or less effective than other medications for the following subgroups: men or women, older adults, young adults, racial or ethnic minorities, smokers, or those with co-occurring disorders. Only studies that compared at least two medications with each other were eligible for this Key Question (KQ). Throughout this KQ, we include headers and sections only for subgroups reported by the included studies.

### Detailed Synthesis

#### Characteristics of Included Studies

Eleven RCTs and 1 observational study addressed this KQ (Table 34). Studies included FDA-approved (acamprosate, disulfiram, naltrexone, topiramate) and non-FDA-approved (desipramine, paroxetine, sertraline, topiramate) medications. Treatment durations ranged from 12 weeks (7 studies) to 68 weeks. All but 1 of the studies reported concurrent psychiatric care, psychotherapy, or other psychosocial support. Studies were conducted in Australia, Brazil, Germany, and India in addition to the United States.

Table 34 Characteristics of head-to-head medication studies that evaluated subgroups

Author, Year Trial Name Design | Arm Dose, mg/Day (N) | Subgroup(s) | Rx Duration, Weeks | Setting | Age, Years | % Non-White | % Female | Cointervention | Risk of Bias
Baltieri, 2008^119^; Baltieri, 2009^128^ NA DBRCT | TOP target 200, maximum 400 (52) NTX 50 (49) Placebo (54) | Smokers | 12 | Brazil; outpatient | 44 to 45 | 29 | 0 | Psychosocial 100% | High
Carroll, 1993^213^ NA OLRCT | DIS 250 (9) NTX 50 (9) | Cocaine dependence | 12 | U.S.; outpatient substance abuse | 32 | 39 | 72 | Weekly individual psychotherapy 100% | High
De Sousa, 2004^185^ NA OLRCT | DIS 250 (50) NTX 50 (50) | Men | 52 | India; outpatient | 43 to 47 | NR | 0 | Supportive group psychotherapy 100% | High
De Sousa, 2005^183^ NA OLRCT | ACA 1,998 (50) DIS 250 (50) | Men | 35 | India; outpatient; private psychiatric hospital | 42 to 43 | 100 | 0 | Weekly supportive group psychotherapy offered | High
De Sousa, 2008^206^ NA OLRCT | TOP 150 (50) DIS 250 (50) | Men | 39 | India; center with facilities for both in- and outpatient treatment of alcohol dependence and substance abuse | 43 | 100 | 0 | Offered weekly supporting group psychotherapy – % NR | High
Greenfield, 2010^214^ Fucito, 2012^67^ COMBINE DBRCT | ACA 3,000 + CBI + MM (151) ACA 3,000 + MM (152) NTX 100 + CBI + MM (155) NTX 100 + MM (154) Placebo + CBI + MM (156) Placebo + MM (153) | Men/women; smokers | 68 | 11 U.S. academic sites | 44 | 23 | 31 | As randomized; community support group participation (like AA) encouraged | Low
Kiefer, 2005^76^ NA DBRCT | ACA 1,998 (40) NTX 50 (40) Placebo (40) ACA 1,998 + NTX 50 (40) | Somatic distress, depression, anxiety | 12 | Germany; 1 site, outpatient | 46 | NR | 26 | Group therapy | Low
Morley, 2006^61^ Morley, 2010^80^ NA DBRCT | ACA 1,998 (55) NTX 50 (53) Placebo (61) | Depression | 12 | Australia; 3 treatment centers with “medical care typically available at hospital based drug and alcohol treatment services” | 45 | NR | 30 | All offered 4-6 sessions of manualized compliance therapy Up-take / attendance NR | Low
Narayana, 2008^211^ Prospective cohort | ACA 1,332 to 1,998 (28) NTX 50 (26) TOP 100 to 125 (38) | Men | 52 | Indian military, outpatient | 38 | 100 | 0 | NR | High
Petrakis, 2005^90^ Ralevski, 2007^94^ Petrakis, 2007^95^ Petrakis, 2006^96^ VA MIRECC DBRCT | DIS 250 (66) NTX 50 (59) Placebo (64) NTX 50 + DIS 250 (65) | Axis I disorders | 12 | U.S.; outpatient VA | 47 | 26 | 3 | Psychiatric treatment as usual 100% | High for DIS vs. NTX
Petrakis, 2012^189^ NA DBRCT | DES 200 + placebo (24) PAR 40 + placebo (20) PAR 40 + NTX 50 (22) DES 200 + NTX 50 (22) | PTSD, depression | 12 | U.S.; outpatient; multiple mental illness centers, most subjects from VAs | 47 | 25 | 9 | Clinical management/ compliance enhancement therapy 100% | High
Pettinati, 2010^104^ NA DBRCT | SER 200 (40) NTX 100 (49) Placebo (39) SER 200 + NTX 100 (42) | Depression | 14 | U.S.; outpatient | 43 | 35 | 38 | CBT 100% | Medium

AA = Alcoholics Anonymous; ACA = acamprosate; CBI = combined behavioral intervention; CBT = cognitive behavioral therapy; COMBINE = Combined Pharmacotherapies and Behavioral Intervention; DBRCT = double-blind randomized controlled trial; DES = desipramine; DIS = disulfiram; mg = milligram; MIRECC = Mental Illness Research, Education and Clinical Center; MM = medical management; N = number; NR = not reported; NTX = naltrexone; OLRCT = open-label randomized controlled trial; PAR = paroxetine; PTSD = post-traumatic stress disorder; SER = sertraline; TOP = topiramate; U.S. = United States; VA = Veterans Affairs.

Note: Age, Years is the mean age in years, unless otherwise stated.

Mean age ranged from 32 to 47, the reported proportion nonwhite ranged from 23 to 100 percent, and the reported proportion female ranged from 0 to 72 percent. In 11 of the studies, all participants had alcohol dependence; in 1 it was not reported. Smoking rates were high (55 to 81 percent of participants) in 3 studies;61,67,80,119,128 all patients in 1 study213 had cocaine dependence. Three studies included only participants with psychiatric comorbidities (Axis I disorders, depression, or PTSD).90,94-96,104,189 Participants were recruited from the community as well as from outpatient and inpatient contacts. Three of these studies were rated low risk of bias, 3 were rated medium, and the rest were rated high risk of bias, primarily due to concerns with attrition bias, inadequate handling of missing data, or measurement bias (see Appendix C for details).

##### Sex

Five studies—4 trials and 1 prospective cohort—provided evidence about the effectiveness of medications by sex.183,185,206,211,214

Subgroup analyses from the COMBINE study,214 the only study among this group rated as low risk of bias, found no significant association between sex and the impact of acamprosate or naltrexone treatment on percentage of days abstinent, time to heavy drinking, or percentage of heavy drinking days.

Three trials, all open-label and from the same group of investigators, and all rated as high risk of bias, found that naltrexone and topiramate have a greater impact than disulfiram and disulfiram has a greater impact than acamprosate on reducing drinking for men.183,185,206

The prospective cohort study, rated as high risk of bias, found that treatment with topiramate had a greater impact than acamprosate or naltrexone on any drinking for men.211

##### Smokers

Two studies provided evidence about the effectiveness of medications by smoking status. Subgroup analyses from the COMBINE study67 found that smokers who received naltrexone had more days abstinent (78 percent versus 72 percent, p=0.004) and fewer heavy drinking days (14 percent versus 20 percent, p=0.003) than smokers who received placebo. No data were reported on the effectiveness of acamprosate among smokers—only that smokers did not benefit differentially from acamprosate. Subgroup analyses from a trial comparing naltrexone, topiramate, and placebo found no association between the number of cigarettes smoked per day at the start of the trial and the effect of naltrexone or topiramate on any drinking outcomes.119,128

##### People With Co-Occurring Disorders

Six studies provided evidence about the effectiveness of medications on individuals with co-occurring psychiatric disorders or other substance use disorders. Five studies addressed co-occurring psychiatric disorders, including depression or anxiety,61,80,104 Axis I disorders,90,94-96 PTSD and depression,189 and somatic distress/depression/anxiety;76 1 addressed co-occurring cocaine dependence.213 Two were rated low risk of bias, 1 as medium risk of bias, and 3 as high risk of bias. Four were conducted in the United States, 1 in Germany,76 and 1 in Australia.61,80

The German study addressing patients with co-occurring somatic distress/depression/anxiety76 evaluated the effects of naltrexone and acamprosate in patients with scores above and below the median on the Symptom Checklist-90 ( SCL-90) and its subscales.215 In patients with total SCL-90 scores above the median, naltrexone was associated with a longer time to lapse compared with acamprosate (51.3 versus 30.1 days, p NR). Similar differences between naltrexone and acamprosate were found for the above-median scores for somatic distress (45.5 versus 20.3), depression (53.4 versus 28.1), and anxiety (47.3 versus 24.4), though none reached statistical significance. Results for time to relapse were similar, and were not statistically significantly different.

In 1 U.S.-based study of patients with co-occurring alcohol dependence and depression,104 patients treated with naltrexone reported numerically longer time to relapse than patients treated with sertraline (45.2 versus 39.9 days, p NR). A slightly higher percent of patients treated with sertraline (27.5 percent) remained abstinent during treatment compared with naltrexone (21.3 percent, p NR).

Another U.S.-based study compared disulfiram (plus placebo) with naltrexone in a population of veterans with comorbid Axis I disorders.90 There were no significant differences between disulfiram and naltrexone in percentage of days abstinent (97 percent versus 95 percent, respectively, p=0.55), percentage of heavy drinking days (3.2 percent versus 4.0 percent, p=0.65), or percentage remaining abstinent (77.3 percent versus 64.4 percent, p=0.11). This study was rated high risk of bias. When subgroups of the Axis I disorders were examined, results were similar, with no significant differences in alcohol use outcomes by treatment for patients diagnosed with depression,95 borderline personality disorder,94 antisocial personality disorder,94 or post-traumatic stress disorder.96

The Australian study examined acamprosate and naltrexone in patients with and without depression or anxiety.61,80 It did not find a naltrexone or acamprosate by depression interaction when assessing predictors of abstinence (no lapse)—odds ratios (ORs) were 0.78 (95% CI, 0.60 to 1.01) and 0.95 (95% CI, 0.81 to 1.12), respectively. It also reported no anxiety by naltrexone or acamprosate interaction when assessing predictors of abstinence (OR for acamprosate by anxiety interaction, 0.92; 95% CI, 0.74 to 1.15; OR for naltrexone by anxiety, 1.06; 95% CI, 0.83 to 1.35). When assessing predictors of no relapse (at least 4 drinks for females and at least 6 drinks for males), the study found a significant naltrexone by depression interaction—OR, 0.77 (95% CI, 0.63 to 0.95) but no significant interactions for acamprosate by depression, naltrexone by anxiety, or acamprosate by anxiety.

In the U.S.-based study of patients with PTSD and alcohol dependence,189 desipramine was associated with a lower percentage of heavy drinking days (p=0.009) and fewer drinks per drinking day (p=0.027) compared with paroxetine, but specific alcohol use data were not reported and the study was rated high risk of bias.

In the U.S.-based study of patients with both alcohol and cocaine dependence,213 disulfiram was associated with a significantly lower percentage of drinking days compared with naltrexone (4.0 percent versus 26.3 percent, respectively, p<0.01).This study was rated high risk of bias.

## Key Question 6 Genetic Polymorphisms

For this KQ, we describe the characteristics of included studies and then evidence on whether any of the medications are more or less effective for adults with specific genotypescompared with adults with different genotypes. The most commonly evaluated polymorphisms were those of the mu-opioid receptor gene. For most polymorphism-medication pairs, we found just 1 eligible study, and we graded the SOE as insufficient (because evidence was imprecise, had unknown consistency, and had medium or high risk of bias)—information on the study characteristics and results for polymorphism-medication pairs with just 1 eligible study is provided in Appendix G. These included 1 study each for the following: nalmefene and opioid receptor gene polymorphisms; topiramate or naltrexone and DRD2, DRD3, HTR2A, or SLC6A gene polymorphisms; olanzapine and DRD4 gene polymorphisms; acamprosate or naltrexone and GATA4 polymorphisms; sertraline and 5-HTTLPR polymorphisms; and disulfiram and DBH polymorphisms.

### Characteristics of Included Studies

We found no studies that assessed the clinical utility of genotype-guided dosing strategies or genotype-guided medication selection, and none randomized by genotype; all included studies assessed the association between genotype and response to medication. We found 7 eligible studies assessing variation in naltrexone response related to polymorphisms of the opioid receptor gene (Table 35). Four studies were analyses of subjects from U.S.-based randomized controlled trials; 3 were prospective cohort studies conducted in Australia,216 South Korea,217 or Spain.43 All 7 studies assessed mu-opioid receptor gene (OPRM1) polymorphisms; 1 also assessed polymorphisms of the genes that encode the delta- and kappa-opioid receptors (OPRD1 and OPRK1, respectively). The main polymorphism tested is in exon 1 of the OPRM1 gene (118A>G), resulting in an asparagine to aspartate substitution at position 40 of the amino acid sequence (Asn40Asp) of the mu-opioid receptor.

Table 35 Characteristics of included studies that assessed the association between opioid receptor gene polymorphisms and naltrexone response

Author, Year | Arm Dose, mg/Day (N) | Genotypes Assessed | Rx Duration, Weeks | Setting | Age, Years | % Non-White | % Female | Cointer-vention | Risk of Bias
Anton, 2008^40^ | Naltrexone 100 (301) Placebo (303) | OPRM1 | 16 | U.S.; Outpatient 11 sites | 45 to 46 | 0 | 30 | MM 100% CBI 49% ACA % NR | Medium
Coller, 2011^216^ | Naltrexone 50 (100) | OPRM1 | 12 | Australia; substance abuse treatment, outpatient | 43 | NR | 43 | CBI 100% | Medium
Gelernter, 2007^218^ | Naltrexone 50 (149) Placebo (64) | OPRM1 OPRD1 OPRK1 | 13 | U.S.; Multisite VAMCs | 50 | 26 | 0 | NR | High
Kim, 2009^217^ | Naltrexone 50 (32) | OPRM1 | 12 | South Korea; Multiple hospitals | 46 to 49 | 100 | 0 | CBT 100% | High
Kranzler, 2013^41^ | Naltrexone 50—daily or targeted (81) Placebo (77) | OPRM1 | 12 | U.S.; Outpatient; university health center | 49 | 3 | 42 | Coping skills therapy 100% | Medium
O'Malley, 2008^42^ | Naltrexone 50 (34) Placebo (34) Naltrexone 50 + Sertraline 100 (33)^a^ | OPRM1 | 16 | U.S.; Native and non-native Alaskans, outpatient | 40 | 70 | 34 | MM 100% | Medium
Rubio, 2002^43^ | Naltrexone 50 (45) | OPRM1 | 12 | Spain; outpatient | NR | NR | 0 | NR | Unclear

mg = milligram; MM = medical management; N = number; NR = not reported; OPRM1 = the mu-opioid receptor gene; U.S. = United States; VAMC = Veterans Administration Medical Center.

Note: Age, Years is the mean age in years, unless otherwise stated.

a Usable DNA was available for 92 of the 101 participants in the randomized controlled trial. Of those, 17 had one or more copies of the Asp40 allele (9 placebo, 3 NTX only, and 5 NTX + sertraline), so the authors restricted statistical analyses to the participants who were homozygous for the Asn40 allele.

Most of the studies used naltrexone 50 mg; 1 used 100 mg.40 Duration of treatment ranged from 12 to 16 weeks. Mean age was very similar across studies, from 40 to 50 years. All subjects met criteria for alcohol dependence in 6 of the studies; 1 study reported that 95 percent of subjects met criteria for alcohol dependence.41 Three studies enrolled all males43,217,218; the others enrolled between 30 and 43 percent females. Information on race was not reported in 2 studies;43,216 2 reported including a majority of non-white subjects;42,217 and 3 reported including zero40 or a small percentage41,218 of nonwhite subjects. The study that reported including zero non-white subjects40 restricted analyses to Caucasians because the main polymorphism tested for (118A>G) is rare in African Americans. Three studies reported consistency of genotype frequencies with Hardy-Weinberg equilibrium; the others did not report checking for it.

One additional study (Oslin et al., 2003) was identified that did not meet inclusion criteria.219 It pooled data for a subset of subjects from 3 separate trials, 1 of which was less than 12 weeks in treatment duration. Because this study may include useful information, and has been included in previous reviews, we conducted sensitivity analyses that include this study (see below in the Overview of Results section).

### Overview of Results

Three of the studies reported some positive associations between polymorphisms and response to naltrexone (Table 36).40,41,217

Table 36 Results of included studies that assessed the association between mu-opioid receptor gene polymorphisms and naltrexone response

Author, year | Reported a Significant Positive Association? | AA, N | AA, Return to Any Drinking | AA, Return to Heavy Drinking—Relapse | AG/GG, N | AG/GG, Return to Any Drinking | AG/GG, Return to Heavy Drinking—Relapse
Anton, 2008^40^ | Yes^a^ | 115^b^ | NR | 52 | 31^b^ | NR | 4
Coller, 2011^216^ | No | NR | NR | NR | NR | NR | NR
Gelernter, 2007^218^ | No | 98 | NR | 35 | 33 | NR | 12
Kim, 2009^217^ | Mixed^c^ | 16 | 8 | 6 | 16 | 9 | 3
Kranzler, 2013^41^ | Yes | 59 | NR | NR | 22 | NR | NR
O'Malley, 2008^42^ | No^d^ | 25 | 16 | 16 | 3 | 2 | 2
Rubio, 2002^43^ | No | 29 | 9 | 9 | 16 | 4 | 4

CBI = combined behavioral intervention; N = number; NR = not reported.

Note: Table only includes data for subjects who received naltrexone; it does not include data for those who received placebo or who received naltrexone plus sertraline.

a Statistically significant difference between groups for return to heavy drinking.

b Data are for those who received naltrexone and medical management, and do not include those who received naltrexone + medical management + CBI. The study found no gene by medication by time interactions for the latter group for percentage of days abstinent or heavy drinking days, and did not report specific numbers by genotype for the outcomes.

c Yes for time to first relapse (p=0.014); no for abstinent rate (p=0.656) and relapse rate (p=0.072).

d Study authors restricted analyses to A-allele homozygotes because they had only 17 of 92 genotyped participants with at least one G allele. The results for the 75 A-allele homozygotes were similar to the results for the total sample, indicating that treatment efficacy was not dependent on the presence of the G allele.

Our meta-analyses for return to any drinking found no significant difference between A-allele homozygotes and those with at least one G allele among patients treated with naltrexone, both without (RD, -0.03; 95% CI, -0.6 to 0.5) and with inclusion of the studies rated as high or unclear risk of bias (RD, 0.01; 95% CI, -0.2 to 0.2). Sensitivity analyses including the Oslin 2003 study also found no difference for return to any drinking.219

Similarly, our meta-analyses for return to heavy drinking found no statistically significant difference between A-allele homozygotes and those with at least one G allele among patients treated with naltrexone, both without (RD, 0.26; 95% CI, -0.01 to 0.53) and with inclusion of the studies rated as high or unclear risk of bias (RD, 0.14; 95% CI, -0.03 to 0.3). Sensitivity analyses including the Oslin 2003 study,219 along with all other studies regardless of risk of bias rating, found that a lower percentage of patients with a G allele returned to heavy drinking than A-allele homozygotes (RD, 0.16; 95% CI, 0.02 to 0.29).

### Detailed Results of Individual Studies

Subgroup analysis from the COMBINE study found no gene by medication by time interactions for patients treated with medical management plus CBI, but reported an interaction between treatment and genotype for the time trend of percentage of days abstinent and for percentage of heavy drinking days for patients who received medical management (with no CBI).40 Among those who received medical management, patients with at least one Asp40 allele and treated with naltrexone had a higher proportion of good clinical outcomes (87.1 percent) than patients homozygous for Asn40 treated with naltrexone (54.8 percent) and those who received placebo who did and did not have an Asp40 allele (48.6 percent and 54 percent, respectively).

The study conducted in Australia reported a significant decrease in alcohol use over time, but no genotype by time interaction and no difference between the two genotypic groups (median grams per week: AA, 48.0 versus AG or GG, 37.5, p=0.78).216 It also reported no difference between genotypic groups (AA versus AG or GG) for time to first relapse (11 versus 10 days, p=0.40) and for mean number of drinking days (17.6 versus 21.9, p=0.56).

One U.S.-based study, a subgroup analysis of data from a trial conducted in Veteran's Affairs Medical Centers, reported no association between the OPRM1 genotype and naltrexone response.218 Patients who were A-allele homozygotes had about the same rate of relapse as those who carried a G allele (35.7 versus 36.0). The larger trial (N=627) that the study sample (N=220) was drawn from did not show a positive effect of naltrexone. The authors explained that the lack of an overall treatment effect of naltrexone in the larger trial might suggest that this was a sub-optimal sample in which to evaluate pharmacogenomic predictors of treatment. However, the subsample for which genotype information was available did show a positive naltrexone treatment effect, which would seem to diminish this problem.

The cohort study conducted in South Korea provided outcome information only for the subjects who were adherent to naltrexone for 12 weeks (32 of 63 subjects who initiated treatment).217 Among those, it reported longer time to relapse for patients with a G allele than for A-allele homozygotes (73.3 versus 59.9 days, p=0.014), but no statistically significant difference between groups for abstinent rate (43.8 percent versus 50 percent, p=0.656) or for relapse rate (18.8 percent versus 37.5 percent, p=0.072).

Another U.S.-based study, an analysis of data from a trial conducted in a university-based center, reported that neither genotype nor medication significantly predicted mean daily drinking levels.41 However, it found a positive desire by genotype by medication condition interaction, with a significant desire by genotype interaction for the placebo group (p=0.001) but not for the naltrexone group (p=0.74). In other words, when the evening desire to drink was high, G allele carriers were at greater risk to drink than A-allele homozygotes, except when treated with naltrexone.41

One U.S.-based study, an analysis of data from a trial conducted with Alaskans, restricted its analyses to A-allele homozygotes.42 The authors reported that this was because they had only 17 of 92 genotyped participants with at least one G allele. They found that the results for the 75 A-allele homozygotes were similar to the results for the total sample (for percentage abstinent and percentage relapsed to a heavy drinking day), indicating that treatment efficacy was not dependent on the presence of the G allele.

The cohort study conducted in Spain (N=45) was reported as an abstract only, with very little details about the methods.43 We assessed the risk of bias of this study as unclear due to very limited reporting of information. The study did not find a significant difference in consumption outcomes (abstinence/return to any drinking, or relapse) between patients who were A-allele homozygotes and those with a G allele.