# References

1 Saitz R. Clinical practice. Unhealthy alcohol use. N Engl J Med. Feb. 10. 2005;352(6):596-607. [pmid: 15703424].
2 Whitlock EP, Green CA, Polen MR. Behavioral Counseling Interventions in Primary Care to Reduce Risky/Harmful Alcohol Use. Systematic Evidence Review No. 30. AHRQ Publication No. 04-0533B. (Prepared by Oregon Evidence-based Practice Center under Contract No. 290-97-0018, Task Order No. 2). Rockville, MD. Agency for Healthcare Research and Quality. April. 2004.
3 U.S. Department of Veterans Affairs. AUDIT-C Frequently Asked Questions. Updated April 28, 2010 www.queri.research.va.gov/tools/alcohol-misuse/alcohol-faqs.cfm. June 27, 2011.
4 Mokdad AH, Marks JS, Stroup DF, et al. Actual causes of death in the United States, 2000. JAMA. Mar. 10. 2004;291(10):1238-45. [pmid: 15010446].
5 Whitlock EP, Polen MR, Green CA, et al. Behavioral counseling interventions in primary care to reduce risky/harmful alcohol use by adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Apr. 6. 2004;140(7):557-68. [pmid: 15068985].
6 Bouchery EE, Harwood HJ, Sacks JJ, et al. Economic costs of excessive alcohol consumption in the U.S., 2006. Am J Prev Med. Nov. 2011;41(5):516-24. [pmid: 22011424].
7 Harwood HJ, Fountain D, Fountain G. Economic cost of alcohol and drug abuse in the United States, 1992: a report. Addiction. May. 1999;94(5):631-5. [pmid: 10563025].
8 Centers for Disease Control and Prevention. FastStats: Alcohol Use. Updated January 27, 2012. www.cdc.gov/nchs/fastats/alcohol.htm. May 21, 2012.
9 Isaac M, Janca A, Sartorius N. ICD-10 symptom glossary for mental disorders. Geneva. Division of Mental Health, World Health Organization. 1994.
10 Janca A, Ustun TB, van Drimmelen J, et al. ICD-10 symptom checklist for mental disorders, version 1.1. Geneva. Division of Mental Health, World Health Organization. 1994.
11 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 4th ed. Text rev. Washington, DC. American Psychiatric Publishing, Inc. 2000.
12 American Psychiatric Association. Diagnostic and statistical manual of mental disorders. 5th ed. Arlington, VA. American Psychiatric Publishing. 2013.
13 Jonas DE, Garbutt JC, Amick HR, et al. Behavioral counseling after screening for alcohol misuse in primary care: a systematic review and meta-analysis for the U.S. Preventive Services Task Force. Ann Intern Med. Nov. 6. 2012;157(9):645-54. [pmid: 23007881].
14 Evidence-based Practice Center Systematic Review Protocol: Pharmacotherapy for Adults With Alcohol-Use Disorders in Outpatient Settings. 2013. http://effectivehealthcare.ahrq.gov/ehc/products/477/1483/Alcohol-misuse-drug-therapy-140326.pdf. Published April 26, 2013. January 24, 2014.
15 Schuckit MA. Alcohol-use disorders. Lancet. Feb. 7. 2009;373(9662):492-501. [pmid: 19168210].
16 National Collaborating Centre for Mental Health, National Institute for Health & Clinical Excellence. Alcohol-use Disorders: The NICE Guidelines on Diagnosis, Assessment and Management of Harmful Drinking and Alcohol Dependence. The British Psychological Society and The Royal College of Psychiatrists. 2011. http://www.nice.org.uk/nicemedia/live/13337/53190/53190.pdf.
17 Hasin DS, Stinson FS, Ogburn E, et al. Prevalence, correlates, disability, and comorbidity of DSM-IV alcohol abuse and dependence in the United States: results from the National Epidemiologic Survey on Alcohol and Related Conditions. Arch Gen Psychiatry. Jul. 2007;64(7):830-42. [pmid: 17606817].
18 Mertens JR, Weisner C, Ray GT, et al. Hazardous drinkers and drug users in HMO primary care: prevalence, medical conditions, and costs. Alcohol Clin Exp Res. Jun. 2005;29(6):989-98. [pmid: 15976525].
19 Teesson M, Baillie A, Lynskey M, et al. Substance use, dependence and treatment seeking in the United States and Australia: a cross-national comparison. Drug Alcohol Depend. Feb. 1. 2006;81(2):149-55. [pmid: 16043307].
20 Hasin DS, Grant BF. The co-occurrence of DSM-IV alcohol abuse in DSM-IV alcohol dependence: results of the National Epidemiologic Survey on Alcohol and Related Conditions on heterogeneity that differ by population subgroup. Arch Gen Psychiatry. Sep. 2004;61(9):891-6. [pmid: 15351767].
21 Mann K, Schafer DR, Langle G, et al. The long-term course of alcoholism, 5, 10 and 16 years after treatment. Addiction. Jun. 2005;100(6):797-805. [pmid: 15918810].
22 Norstrom T. Per capita alcohol consumption and all-cause mortality in Canada, 1950-98. Addiction. Oct. 2004;99(10):1274-8. [pmid: 15369565].
23 Rivara FP, Garrison MM, Ebel B, et al. Mortality attributable to harmful drinking in the United States, 2000. J Stud Alcohol. Jul. 2004;65(4):530-6. [pmid: 15376828].
24 Corrao G, Bagnardi V, Zambon A, et al. A meta-analysis of alcohol consumption and the risk of 15 diseases. Prev Med. May. 2004;38(5):613-9. [pmid: 15066364].
25 Cherpitel CJ, Ye Y. Alcohol-attributable fraction for injury in the U.S. general population: data from the 2005 National Alcohol Survey. J Stud Alcohol Drugs. Jul. 2008;69(4):535-8. [pmid: 18612569].
26 Alcohol-attributable deaths and years of potential life lost--United States, 2001. MMWR Morb Mortal Wkly Rep. Sep. 24. 2004;53(37):866-70. [pmid: 15385917].
27 Moos RH, Moos BS. Rates and predictors of relapse after natural and treated remission from alcohol use disorders. Addiction. Feb. 2006;101(2):212-22. [pmid: 16445550].
28 Rumpf HJ, Bischof G, Hapke U, et al. Stability of remission from alcohol dependence without formal help. Alcohol Alcohol. May-Jun. 2006;41(3):311-4. [pmid: 16490790].
29 Bodin MC, Romelsjo A. Predictors of abstinence and nonproblem drinking after 12-step treatment in Sweden. J Stud Alcohol. Jan. 2006;67(1):139-46. [pmid: 16536138].
30 Cox WM, Rosenberg H, Hodgins CH, et al. United Kingdom and United States healthcare providers' recommendations of abstinence versus controlled drinking. Alcohol Alcohol. Mar-Apr. 2004;39(2):130-4. [pmid: 14998830].
31 Dawson DA, Grant BF, Stinson FS, et al. Recovery from DSM-IV alcohol dependence: United States, 2001-2002. Addiction. Mar. 2005;100(3):281-92. [pmid: 15733237].
32 Maisto SA, Clifford PR, Stout RL, et al. Drinking in the year after treatment as a predictor of three-year drinking outcomes. J Stud Alcohol. Nov. 2006;67(6):823-32. [pmid: 17060998].
33 Schuckit MA. Drug and Alcohol Abuse: A Clinical Guide to Diagnosis and Treatment. 6th ed. New York. Springer. 2005.
34 O'Malley SS, O'Connor PG. Medications for unhealthy alcohol use: across the spectrum. Alcohol Res Health. 2011;33(4):300-12. [pmid: 23580015].
35 Miller WR, Walters ST, Bennett ME. How effective is alcoholism treatment in the United States?. J Stud Alcohol. Mar. 2001;62(2):211-20. [pmid: 11327187].
36 O'Brien CP, McLellan AT. Myths about the treatment of addiction. Lancet. Jan. 27. 1996;347(8996):237-40. [pmid: 8551886].
37 Rosner S, Hackl-Herrwerth A, Leucht S, et al. Acamprosate for alcohol dependence. Cochrane Database Syst Rev. 2010;(9):CD004332. [pmid: 20824837].
38 Rösner S, Hackl-Herrwerth A, Leucht S, et al. Opioid antagonists for alcohol dependence. Cochrane Database Syst Rev. 2010;(12):CD001867. [pmid: 21154349].
39 Kranzler HR, Van Kirk J. Efficacy of naltrexone and acamprosate for alcoholism treatment: a meta-analysis. Alcohol Clin Exp Res. Sep. 2001;25(9):1335-41. [pmid: 11584154].
40 Anton RF, Oroszi G, O'Malley S, et al. An evaluation of mu-opioid receptor (OPRM1) as a predictor of naltrexone response in the treatment of alcohol dependence: results from the Combined Pharmacotherapies and Behavioral Interventions for Alcohol Dependence (COMBINE) study. Arch Gen Psychiatry. Feb. 2008;65(2):135-44. [pmid: 18250251].
41 Kranzler HR, Armeli S, Covault J, et al. Variation in OPRM1 moderates the effect of desire to drink on subsequent drinking and its attenuation by naltrexone treatment. Addiction Biology. 2013;18(1):193-201. [pmid: 22784013].
42 O'Malley SS, Robin RW, Levenson AL, et al. Naltrexone alone and with sertraline for the treatment of alcohol dependence in Alaska natives and non-natives residing in rural settings: a randomized controlled trial. Alcohol Clin Exp Res. Jul. 2008;32(7):1271-83. [pmid: 18482155].
43 Rubio G, Ponce G, Jiménez-Arriero MA, et al. Polymorphism for m-opioid receptor (+118) as a prognostic variable of naltrexone in alcohol dependence treatment: Preliminary results. Eur Neuropsychopharmacol. 2002;12:397. [pmid: 12208557].
44 Harris AH, Kivlahan DR, Bowe T, et al. Pharmacotherapy of alcohol use disorders in the Veterans Health Administration. Psychiatric Services. Apr. 2010;61(4):392-8. [pmid: 20360279].
45 Harris AH, Oliva E, Bowe T, et al. Pharmacotherapy of alcohol use disorders by the Veterans Health Administration: patterns of receipt and persistence. Psychiatr Serv. Jul. 2012;63(7):679-85. [pmid: 22549276].
46 U.S. Department of Veterans Affairs, U.S. Department of Defense. VA/DoD Clinical Practice Guideline for Management of Substance Use Disorders (SUD). 2009. www.healthquality.va.gov/sud/sud_full_601f.pdf.
47 Pettinati HM, Weiss RD, Miller WR, et al. COMBINE Monograph Series, Volume 2. Medical Management Treatment Manual: A Clinical Research Guide for Medically Trained Clinicians Providing Pharmacotherapy as Part of the Treatment for Alcohol Dependence. DHHS Publication No. (NIH) 04–5289. Bethesda, MD. National Institute on Alcohol Abuse and Alcoholism. 2004.
48 Center for Substance Abuse and Treatment. Incorporating alcohol pharmacotherapies into medical practice. (Treatment improvement protocol (TIP); no. 49). Substance Abuse and Mental Health Services Administration (SAMHSA). Rockville, MD. 2009.
49 West SL, Garbutt JC, Carey TS, et al. Pharmacotherapy for Alcohol Dependence. Evidence report number 3. (Contract 290-97-0011 to Research Triangle Institute, University of North Carolina, Chapel Hill) AHCPR publication no. 99-E004. Rockville, MD. Agency for Health Care Policy and Research. January. 1999. www.ncbi.nlm.nih.gov/books/NBK32930/.
50 Garbutt JC, West SL, Carey TS, et al. Pharmacological treatment of alcohol dependence: a review of the evidence. JAMA. Apr. 14. 1999;281(14):1318-25. [pmid: 10208148].
51 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Agency for Healthcare Research and Quality. Rockville (MD). www.ncbi.nlm.nih.gov/books/NBK47095/.
52 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. AHRQ Publication No. 12-EHC047-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/.
53 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity. Methods Research Report. Prepared by RTI International -- University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I AHRQ Publication No. 10-EHC070-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2010.
54 Sutton AJ, Abrams KR, Jones DR, et al. Methods for Meta-Analysis in Medical Research. (Wiley Series in Probability and Statistics - Applied Probability and Statistics Section). London. Wiley. 2000.
55 Centers for Disease Control and Prevention. What is a standard drink in the United States?. 2013. www.cdc.gov/alcohol/faqs.htm#standDrink. August 20, 2013.
56 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. [pmid: 12111919].
57 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. [pmid: 12958120].
58 Higgins JP, Green ST, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011.
59 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
60 Atkins DC, Gartlehner G, et al. Chapter 6: Assessing the applicability of studies when comparing medical interventions. Agency for Healthcare Research and Quality. AHRQ Publication No. 11-EHC019-EF. Rockville, MD. 2011.
61 Morley KC, Teesson M, Reid SC, et al. Naltrexone versus acamprosate in the treatment of alcohol dependence: A multi-centre, randomized, double-blind, placebo-controlled trial. Addiction. Oct. 2006;101(10):1451-62. [pmid: 16968347].
62 Ralevski E, O'Brien E, Jane JS, et al. Effects of acamprosate on cognition in a treatment study of patients with schizophrenia spectrum disorders and comorbid alcohol dependence. J Nerv Ment Dis. Jul. 2011;199(7):499-505. [pmid: 21716064].
63 Baltieri DA, De Andrade AG. Acamprosate in alcohol dependence: a randomized controlled efficacy study in a standard clinical setting. J Stud Alcohol. Jan. 2004;65(1):136-9. [pmid: 15000513].
64 Pelc I, Verbanck P, Le Bon O, et al. Efficacy and safety of acamprosate in the treatment of detoxified alcohol-dependent patients. A 90-day placebo-controlled dose-finding study. Br J Psychiatry. Jul. 1997;171:73-7. [pmid: 9328500].
65 Anton RF, O'Malley SS, Ciraulo DA, et al. Combined pharmacotherapies and behavioral interventions for alcohol dependence: the COMBINE study: a randomized controlled trial. JAMA. May. 3. 2006;295(17):2003-17. [pmid: 16670409].
66 Mason BJ, Goodman AM, Chabac S, et al. Effect of oral acamprosate on abstinence in patients with alcohol dependence in a double-blind, placebo-controlled trial: the role of patient motivation. J Psychiatr Res. Aug. 2006;40(5):383-93. [pmid: 16546214].
67 Fucito LM, Park A, Gulliver SB, et al. Cigarette smoking predicts differential benefit from naltrexone for alcohol dependence. Biol Psychiatry. 2012;72(10):832-8. [pmid: 22541040].
68 Donovan DM, Anton RF, Miller WR, et al. Combined pharmacotherapies and behavioral interventions for alcohol dependence (The COMBINE Study): examination of posttreatment drinking outcomes. J Stud Alcohol Drugs. Jan. 2008;69(1):5-13. [pmid: 18080059].
69 Berger L, Fisher M, Brondino M, et al. Efficacy of acamprosate for alcohol dependence in a family medicine setting in the United States: A randomized, double-blind, placebo-controlled study. Alcohol. 2013;37(4):668-74. 2013-11440-015. First Author & Affiliation: Berger, Lisa. [pmid: 23134193].
70 Besson J, Aeby F, Kasas A, et al. Combined efficacy of acamprosate and disulfiram in the treatment of alcoholism: a controlled study. Alcohol Clin Exp Res. May. 1998;22(3):573-9. [pmid: 9622434].
71 Chick J, Howlett H, Morgan MY, et al. United Kingdom Multicentre Acamprosate Study (UKMAS): a 6-month prospective study of acamprosate versus placebo in preventing relapse after withdrawal from alcohol. Alcohol Alcohol. Mar-Apr. 2000;35(2):176-87. [pmid: 10787394].
72 Geerlings PJ, Ansoms C, Van Den Brink W. Acamprosate and prevention of relapse in alcoholics. Results of a randomized, placebo-controlled, double-blind study in out-patient alcoholics in the Netherlands, Belgium and Luxembourg. Eur Addict Res. 1997;3(3):129-37.
73 Gual A, Lehert P. Acamprosate during and after acute alcohol withdrawal: a double-blind placebo-controlled study in Spain. Alcohol Alcohol. 2001;36(5):413-8. CN-00367117. [pmid: 11524307].
74 Kiefer F, Jahn H, Tarnaske T, et al. Comparing and combining naltrexone and acamprosate in relapse prevention of alcoholism: a double-blind, placebo-controlled study. Arch Gen Psychiatry. Jan. 2003;60(1):92-9. [pmid: 12511176].
75 Kiefer F, Andersohn F, Otte C, et al. Long-term effects of pharmacotherapy on relapse prevention in alcohol dependence. Acta Neuropsychiatrica. 2004;18:233-8.
76 Kiefer F, Helwig H, Tarnaske T, et al. Pharmacological relapse prevention of alcoholism: clinical predictors of outcome. Eur Addict Res. 2005;11(2):83-91. [pmid: 15785069].
77 Lhuintre JP, Daoust M, Moore ND, et al. Ability of calcium bis acetyl homotaurine, a GABA agonist, to prevent relapse in weaned alcoholics. Lancet. May. 4. 1985;1(8436):1014-6. [pmid: 2859465].
78 Lhuintre JP, Moore N, Tran G, et al. Acamprosate appears to decrease alcohol intake in weaned alcoholics. Alcohol Alcohol. 1990;25(6):613-22. [pmid: 2085344].
79 Mann K, Lemenager T, Hoffmann S, et al. Results of a double-blind, placebo-controlled pharmacotherapy trial in alcoholism conducted in Germany and comparison with the US COMBINE study. Addict Biol. 2012. Dec. 12. [pmid: 23231446].
80 Morley KC, Teesson M, Sannibale C, et al. Clinical predictors of outcome from an Australian pharmacological relapse prevention trial. Alcohol Alcohol. Nov-Dec. 2010;45(6):520-6. [pmid: 20952764].
81 Paille FM, Guelfi JD, Perkins AC, et al. Double-blind randomized multicentre trial of acamprosate in maintaining abstinence from alcohol. Alcohol Alcohol. Mar. 1995;30(2):239-47. [pmid: 7662044].
82 Pelc I, Le Bon O, Lehert P, et al. Acamprosate in the Treatment of Alcohol Dependence: A 6-Month Postdetoxification Study. Soyka M, editor. Acamprosate in Relapse Prevention of Alcoholism. Springer Berlin Heidelberg. 1996:133-42.
83 Pelc I, Le Bon O, Verbanck P, et al. Calciumacetylhomotaurinate for maintaining abstinence in weaned alcoholic patients: a placebo-controlled double-blind multi-centre study. Naranjo CA, Sellers EM, editors. Novel Pharmacological Interventions for Alcoholism. New York. Springer-Verlag. 1992.
84 Poldrugo F. Acamprosate treatment in a long-term community-based alcohol rehabilitation programme. Addiction. Nov. 1997;92(11):1537-46. [pmid: 9519495].
85 Ralevski E, O'Brien E, Jane JS, et al. Treatment with acamprosate in patients with schizophrenia spectrum disorders and comorbid alcohol dependence. J Dual Diagn. 2011;7(1-2):64-73.
86 Sass H, Soyka M, Mann K, et al. Relapse prevention by acamprosate. Results from a placebo-controlled study on alcohol dependence. Arch Gen Psychiatry. Aug. 1996;53(8):673-80. [pmid: 8694680].
87 Tempesta E, Janiri L, Bignamini A, et al. Acamprosate and relapse prevention in the treatment of alcohol dependence: a placebo-controlled study. Alcohol Alcohol. Mar-Apr. 2000;35(2):202-9. [pmid: 10787398].
88 Whitworth AB, Fischer F, Lesch OM, et al. Comparison of acamprosate and placebo in long-term treatment of alcohol dependence. Lancet. May. 25. 1996;347(9013):1438-42. [pmid: 8676626].
89 Wolwer W, Frommann N, Janner M, et al. The effects of combined acamprosate and integrative behaviour therapy in the outpatient treatment of alcohol dependence: a randomized controlled trial. Drug Alcohol Depend. Nov. 1. 2011;118(2-3):417-22. [pmid: 21621929].
90 Petrakis IL, Poling J, Levinson C, et al. Naltrexone and disulfiram in patients with alcohol dependence and comorbid psychiatric disorders. Biol Psychiatry. May. 15. 2005;57(10):1128-37. [pmid: 15866552].
91 Ling W, Weiss DG, Charuvastra VC, et al. Use of disulfiram for alcoholics in methadone maintenance programs. A Veterans Administration Cooperative Study. Arch Gen Psychiatry. Aug. 1983;40(8):851-4. [pmid: 6347118].
92 Fuller RK, Branchey L, Brightwell DR, et al. Disulfiram treatment of alcoholism. A Veterans Administration cooperative study. JAMA. Sep. 19. 1986;256(11):1449-55. [pmid: 3528541].
93 Fuller RK, Roth HP. Disulfiram for the treatment of alcoholism. An evaluation in 128 men. Ann Intern Med. Jun. 1979;90(6):901-4. [pmid: 389121].
94 Ralevski E, Ball S, Nich C, et al. The impact of personality disorders on alcohol-use outcomes in a pharmacotherapy trial for alcohol dependence and comorbid Axis I disorders. Am J Addict. Nov-Dec. 2007;16(6):443-9. [pmid: 18058408].
95 Petrakis I, Ralevski E, Nich C, et al. Naltrexone and disulfiram in patients with alcohol dependence and current depression. J Clin Psychopharmacol. Apr. 2007;27(2):160-5. [pmid: 17414239].
96 Petrakis IL, Poling J, Levinson C, et al. Naltrexone and disulfiram in patients with alcohol dependence and comorbid post-traumatic stress disorder. Biol Psychiatry. Oct. 1. 2006;60(7):777-83. [pmid: 17008146].
97 Garbutt JC, Kranzler HR, O'Malley SS, et al. Efficacy and tolerability of long-acting injectable naltrexone for alcohol dependence: a randomized controlled trial. JAMA. Apr. 6. 2005;293(13):1617-25. [pmid: 15811981].
98 Johnson BA, Ait-Daoud N, Aubin HJ, et al. A pilot evaluation of the safety and tolerability of repeat dose administration of long-acting injectable naltrexone (Vivitrex) in patients with alcohol dependence. Alcohol Clin Exp Res. Sep. 2004;28(9):1356-61. [pmid: 15365306].
99 Kranzler HR, Wesson DR, Billot L. Naltrexone depot for treatment of alcohol dependence: a multicenter, randomized, placebo-controlled clinical trial. Alcohol Clin Exp Res. Jul. 2004;28(7):1051-9. [pmid: 15252291].
100 ALK21-014: Efficacy and Safety of Medisorb® Naltrexone (VIVITROL®) After Enforced Abstinence. 2011.
101 Monterosso JR, Flannery BA, Pettinati HM, et al. Predicting treatment response to naltrexone: the influence of craving and family history. Am J Addict. Summer. 2001;10(3):258-68. [pmid: 11579624].
102 Morgenstern J, Kuerbis AN, Chen AC, et al. A randomized clinical trial of naltrexone and behavioral therapy for problem drinking men who have sex with men. J Consult Clin Psychol. 2012;80(5):863-75. [pmid: 22612306].
103 Oslin DW, Lynch KG, Pettinati HM, et al. A placebo-controlled randomized clinical trial of naltrexone in the context of different levels of psychosocial intervention. Alcohol Clin Exp Res. Jul. 2008;32(7):1299-308. [pmid: 18540910].
104 Pettinati HM, Oslin DW, Kampman KM, et al. A double-blind, placebo-controlled trial combining sertraline and naltrexone for treating co-occurring depression and alcohol dependence. Am J Psychiatry. Jun. 2010;167(6):668-75. [pmid: 20231324].
105 Schmitz JM, Lindsay JA, Green CE, et al. High-dose naltrexone therapy for cocaine-alcohol dependence. Am J Addict. Sep-Oct. 2009;18(5):356-62. [pmid: 19874153].
106 Pettinati HM, Kampman KM, Lynch KG, et al. Gender differences with high-dose naltrexone in patients with co-occurring cocaine and alcohol dependence. J Subst Abuse Treat. Jun. 2008;34(4):378-90. [pmid: 17664051].
107 Oslin D, Liberto JG, O'Brien J, et al. Naltrexone as an adjunctive treatment for older patients with alcohol dependence. Am J Geriatr Psychiatry. Fall. 1997;5(4):324-32. [pmid: 9363289].
108 Balldin J, Berglund M, Borg S, et al. A 6-month controlled naltrexone study: combined effect with cognitive behavioral therapy in outpatient treatment of alcohol dependence. Alcohol Clin Exp Res. Jul. 2003;27(7):1142-9. [pmid: 12878920].
109 Heinala P, Alho H, Kiianmaa K, et al. Targeted use of naltrexone without prior detoxification in the treatment of alcohol dependence: a factorial double-blind, placebo-controlled trial. J Clin Psychopharmacol. Jun. 2001;21(3):287-92. [pmid: 11386491].
110 Krystal JH, Cramer JA, Krol WF, et al. Naltrexone in the treatment of alcohol dependence. N Engl J Med. Dec. 13. 2001;345(24):1734-9. [pmid: 11742047].
111 Longabaugh R, Wirtz PW, Gulliver SB, et al. Extended naltrexone and broad spectrum treatment or motivational enhancement therapy. Psychopharmacology (Berl). Oct. 2009;206(3):367-76. [pmid: 19639303].
112 Huang MC, Chen CH, Yu JM, et al. A double-blind, placebo-controlled study of naltrexone in the treatment of alcohol dependence in Taiwan. Addict Biol. Sep. 2005;10(3):289-92. [pmid: 16109592].
113 Lee A, Tan S, Lim D, et al. Naltrexone in the treatment of male alcoholics—An effectiveness study In Singapore. Drug and Alcohol Review. 2001;20(2):193-9.
114 Schmitz JM, Stotts AL, Sayre SL, et al. Treatment of cocaine-alcohol dependence with naltrexone and relapse prevention therapy. Am J Addict. Jul-Sep. 2004;13(4):333-41. [pmid: 15370932].
115 Volpicelli JR, Clay KL, Watson NT, et al. Naltrexone in the treatment of alcoholism: predicting response to naltrexone. J Clin Psychiatry. Suppl 7. 1995;56:39-44. [pmid: 7673104].
116 Volpicelli JR, Rhines KC, Rhines JS, et al. Naltrexone and alcohol dependence. Role of subject compliance. Arch Gen Psychiatry. Aug. 1997;54(8):737-42. [pmid: 9283509].
117 O'Malley SS, Sinha R, Grilo CM, et al. Naltrexone and cognitive behavioral coping skills therapy for the treatment of alcohol drinking and eating disorder features in alcohol-dependent women: a randomized controlled trial. Alcohol Clin Exp Res. Apr. 2007;31(4):625-34. [pmid: 17374042].
118 Anton RF, Myrick H, Wright TM, et al. Gabapentin combined with naltrexone for the treatment of alcohol dependence. Am J Psychiatry. Jul. 2011;168(7):709-17. [pmid: 21454917].
119 Baltieri DA, Daro FR, Ribeiro PL, et al. Comparing topiramate with naltrexone in the treatment of alcohol dependence. Addiction. Dec. 2008;103(12):2035-44. [pmid: 18855810].
120 Brown ES, Carmody TJ, Schmitz JM, et al. A randomized, double-blind, placebo-controlled pilot study of naltrexone in outpatients with bipolar disorder and alcohol dependence. Alcohol Clin Exp Res. Nov. 2009;33(11):1863-9. [pmid: 19673746].
121 Petrakis IL, O'Malley S, Rounsaville B, et al. Naltrexone augmentation of neuroleptic treatment in alcohol abusing patients with schizophrenia. Psychopharmacology (Berl). Mar. 2004;172(3):291-7. [pmid: 14634716].
122 Killeen TK, Brady KT, Gold PB, et al. Effectiveness of naltrexone in a community treatment program. Alcohol Clin Exp Res. Nov. 2004;28(11):1710-7. [pmid: 15547458].
123 Ahmadi J, Ahmadi N. A double blind, placebo-controlled study of naltrexone in the treatment of alcohol dependence. German Journal of Psychiatry. 2002;5(4):85-9.
124 Ahmadi J, Babaeebeigi M, Maany I, et al. Naltrexone for alcohol-dependent patients. Ir J Med Sci. Jan-Mar. 2004;173(1):34-7. [pmid: 15732235].
125 Anton RF, Moak DH, Waid LR, et al. Naltrexone and cognitive behavioral therapy for the treatment of outpatient alcoholics: results of a placebo-controlled trial. Am J Psychiatry. Nov. 1999;156(11):1758-64. [pmid: 10553740].
126 Anton RF, Moak DH, Latham PK, et al. Posttreatment results of combining naltrexone with cognitive-behavior therapy for the treatment of alcoholism. J Clin Psychopharmacol. Feb. 2001;21(1):72-7. [pmid: 11199951].
127 Anton RF, Moak DH, Latham P, et al. Naltrexone combined with either cognitive behavioral or motivational enhancement therapy for alcohol dependence. J Clin Psychopharmacol. Aug. 2005;25(4):349-57. [pmid: 16012278].
128 Baltieri DA, Daro FR, Ribeiro PL, et al. Effects of topiramate or naltrexone on tobacco use among male alcohol-dependent outpatients. Drug Alcohol Depend. Nov. 1. 2009;105(1-2):33-41. [pmid: 19595518].
129 Chick J, Anton R, Checinski K, et al. A multicentre, randomized, double-blind, placebo-controlled trial of naltrexone in the treatment of alcohol dependence or abuse. Alcohol Alcohol. Nov-Dec. 2000;35(6):587-93. [pmid: 11093966].
130 Fogaca MN, Santos-Galduroz RF, Eserian JK, et al. The effects of polyunsaturated fatty acids in alcohol dependence treatment--a double-blind, placebo-controlled pilot study. BMC Clin Pharmacol. 2011;11:10. [pmid: 21787433].
131 Pettinati HM, Gastfriend DR, Dong Q, et al. Effect of extended-release naltrexone (XR-NTX) on quality of life in alcohol-dependent patients. Alcohol Clin Exp Res. Feb. 2009;33(2):350-6. [pmid: 19053979].
132 Lucey MR, Silverman BL, Illeperuma A, et al. Hepatic safety of once-monthly injectable extended-release naltrexone administered to actively drinking alcoholics. Alcohol Clin Exp Res. Mar. 2008;32(3):498-504. [pmid: 18241321].
133 Gastpar M, Bonnet U, Boning J, et al. Lack of efficacy of naltrexone in the prevention of alcohol relapse: results from a German multicenter study. J Clin Psychopharmacol. Dec. 2002;22(6):592-8. [pmid: 12454559].
134 Guardia J, Caso C, Arias F, et al. A double-blind, placebo-controlled study of naltrexone in the treatment of alcohol-dependence disorder: results from a multicenter clinical trial. Alcohol Clin Exp Res. Sep. 2002;26(9):1381-7. [pmid: 12351933].
135 Kranzler HR, Tennen H, Armeli S, et al. Targeted naltrexone for problem drinkers. J Clin Psychopharmacol. Aug. 2009;29(4):350-7. [pmid: 19593174].
136 Latt NC, Jurd S, Houseman J, et al. Naltrexone in alcohol dependence: a randomised controlled trial of effectiveness in a standard clinical setting. Med J Aust. Jun. 3. 2002;176(11):530-4. [pmid: 12064984].
137 Monti PM, Rohsenow DJ, Swift RM, et al. Naltrexone and cue exposure with coping and communication skills training for alcoholics: treatment process and 1-year outcomes. Alcohol Clin Exp Res. Nov. 2001;25(11):1634-47. [pmid: 11707638].
138 Rohsenow DJ, Miranda R Jr., McGeary JE, et al. Family history and antisocial traits moderate naltrexone's effects on heavy drinking in alcoholics. Exp Clin Psychopharmacol. Jun. 2007;15(3):272-81. [pmid: 17563214].
139 Rohsenow DJ, Colby SM, Monti PM, et al. Pedictors of compliance with naltrexone among alcoholics. Alcohol. 2000;24(10):1542-9.
140 Morris PL, Hopwood M, Whelan G, et al. Naltrexone for alcohol dependence: a randomized controlled trial. Addiction. Nov. 2001;96(11):1565-73. [pmid: 11784454].
141 O'Malley SS, Jaffe AJ, Chang G, et al. Naltrexone and coping skills therapy for alcohol dependence. A controlled study. Arch Gen Psychiatry. Nov. 1992;49(11):881-7. [pmid: 1444726].
142 O'Malley SS, Jaffe AJ, Chang G, et al. Six-month follow-up of naltrexone and psychotherapy for alcohol dependence. Arch Gen Psychiatry. Mar. 1996;53(3):217-24. [pmid: 8611058].
143 Ralevski E, Balachandra K, Gueorguieva R, et al. Effects of naltrexone on cognition in a treatment study of patients with schizophrenia and comorbid alcohol dependence. J Dual Diagn. 2006;2(4):53-69.
144 Volpicelli JR, Alterman AI, Hayashida M, et al. Naltrexone in the treatment of alcohol dependence. Arch Gen Psychiatry. Nov. 1992;49(11):876-80. [pmid: 1345133].
145 Addolorato G, Leggio L, Ferrulli A, et al. Effectiveness and safety of baclofen for maintenance of alcohol abstinence in alcohol-dependent patients with liver cirrhosis: randomised, double-blind controlled study. Lancet. Dec. 8. 2007;370(9603):1915-22. [pmid: 18068515].
146 Garbutt JC, Kampov-Polevoy AB, Gallop R, et al. Efficacy and safety of baclofen for alcohol dependence: a randomized, double-blind, placebo-controlled trial. Alcohol Clin Exp Res. Nov. 2010;34(11):1849-57. [pmid: 20662805].
147 Kranzler HR, Burleson JA, Del Boca FK, et al. Buspirone treatment of anxious alcoholics. A placebo-controlled trial. Arch Gen Psychiatry. Sep. 1994;51(9):720-31. [pmid: 8080349].
148 Malcolm R, Anton RF, Randall CL, et al. A placebo-controlled trial of buspirone in anxious inpatient alcoholics. Alcohol Clin Exp Res. Dec. 1992;16(6):1007-13. [pmid: 1335217].
149 Fawcett J, Kravitz HM, McGuire M, et al. Pharmacological treatments for alcoholism: revisiting lithium and considering buspirone. Alcohol Clin Exp Res. May. 2000;24(5):666-74. [pmid: 10832908].
150 Malec E, Malec T, Gagne MA, et al. Buspirone in the treatment of alcohol dependence: a placebo-controlled trial. Alcohol Clin Exp Res. Apr. 1996;20(2):307-12. [pmid: 8730222].
151 George DT, Rawlings R, Eckardt MJ, et al. Buspirone treatment of alcoholism: age of onset, and cerebrospinal fluid 5-hydroxyindolacetic acid and homovanillic acid concentrations, but not medication treatment, predict return to drinking. Alcohol Clin Exp Res. Feb. 1999;23(2):272-8. [pmid: 10069556].
152 Tiihonen J, Ryynanen OP, Kauhanen J, et al. Citalopram in the treatment of alcoholism: a double-blind placebo-controlled study. Pharmacopsychiatry. Jan. 1996;29(1):27-9. [pmid: 8852531].
153 Naranjo CA, Bremner KE, Lanctot KL. Effects of citalopram and a brief psycho-social intervention on alcohol intake, dependence and problems. Addiction. Jan. 1995;90(1):87-99. [pmid: 7888983].
154 Cornelius JR, Salloum IM, Ehler JG, et al. Fluoxetine in depressed alcoholics. A double-blind, placebo-controlled trial. Arch Gen Psychiatry. Aug. 1997;54(8):700-5. [pmid: 9283504].
155 Kabel DI, Petty F. A placebo-controlled, double-blind study of fluoxetine in severe alcohol dependence: adjunctive pharmacotherapy during and after inpatient treatment. Alcohol Clin Exp Res. Jun. 1996;20(4):780-4. [pmid: 8800399].
156 Kranzler HR, Burleson JA, Korner P, et al. Placebo-controlled trial of fluoxetine as an adjunct to relapse prevention in alcoholics. Am J Psychiatry. Mar. 1995;152(3):391-7. [pmid: 7864265].
157 Cornelius JR, Salloum IM, Ehler JG, et al. Double-blind fluoxetine in depressed alcoholic smokers. Psychopharmacol Bull. 1997;33(1):165-70. [pmid: 9133770].
158 Karhuvaara S, Simojoki K, Virta A, et al. Targeted nalmefene with simple medical management in the treatment of heavy drinkers: a randomized double-blind placebo-controlled multicenter study. Alcohol Clin Exp Res. Jul. 2007;31(7):1179-87. [pmid: 17451401].
159 Mann K, Bladström A, Torup L, et al. Extending the treatment options in alcohol dependence: A randomized controlled study of as-needed nalmefene. Biol Psychiatry. 2013;73(8):706-13. 2013-12092-010. First Author & Affiliation: Mann, Karl. [pmid: 23237314].
160 Gual A, He Y, Torup L, et al. A randomised, double-blind, placebo-controlled, efficacy study of nalmefene, as-needed use, in patients with alcohol dependence. Eur Neuropsychopharmacol. 2013. Apr. 3. [pmid: 23562264].
161 Safety and Efficacy of Nalmefene in Patients with Alcohol Dependence (SENSE). 2013.
162 Mason BJ, Salvato FR, Williams LD, et al. A double-blind, placebo-controlled study of oral nalmefene for alcohol dependence. Arch Gen Psychiatry. 1999;56(8):719-24. [pmid: 10435606].
163 Mason BJ, Ritvo EC, Morgan RO, et al. A double-blind, placebo-controlled pilot study to evaluate the efficacy and safety of oral nalmefene HCl for alcohol dependence. Alcohol. 1994;18(5):1162-7.
164 Anton RF, Pettinati H, Zweben A, et al. A multi-site dose ranging study of nalmefene in the treatment of alcohol dependence. J Clin Psychopharmacol. Aug. 2004;24(4):421-8. [pmid: 15232334].
165 Brown ES, Garza M, Carmody TJ. A randomized, double-blind, placebo-controlled add-on trial of quetiapine in outpatients with bipolar disorder and alcohol use disorders. J Clin Psychiatry. May. 2008;69(5):701-5. [pmid: 18312058].
166 Stedman M, Pettinati HM, Brown ES, et al. A double-blind, placebo-controlled study with quetiapine as adjunct therapy with lithium or divalproex in bipolar I patients with coexisting alcohol dependence. Alcohol Clin Exp Res. Oct. 2010;34(10):1822-31. [pmid: 20626727].
167 Kampman KM, Pettinati HM, Lynch KG, et al. A double-blind, placebo-controlled pilot trial of quetiapine for the treatment of Type A and Type B alcoholism. J Clin Psychopharmacol. Aug. 2007;27(4):344-51. [pmid: 17632217].
168 Moak DH, Anton RF, Latham PK, et al. Sertraline and cognitive behavioral therapy for depressed alcoholics: results of a placebo-controlled trial. J Clin Psychopharmacol. Dec. 2003;23(6):553-62. [pmid: 14624185].
169 Coskunol H, Gökden O, Ercan ES, et al. Long-term efficacy of sertraline in the prevention of alcoholic relapses in alcohol-dependent patients: a single-center, double-blind, randomized, placebo-controlled, parallel-group study. Current Therapeutic Research. 2002;63(11):759-71.
170 Gual A, Balcells M, Torres M, et al. Sertraline for the prevention of relapse in detoxicated alcohol dependent patients with a comorbid depressive disorder: a randomized controlled trial. Alcohol Alcohol. Nov-Dec. 2003;38(6):619-25. [pmid: 14633652].
171 Brady KT, Sonne S, Anton RF, et al. Sertraline in the treatment of co-occurring alcohol dependence and posttraumatic stress disorder. Alcohol Clin Exp Res. Mar. 2005;29(3):395-401. [pmid: 15770115].
172 Pettinati HM, Volpicelli JR, Luck G, et al. Double-blind clinical trial of sertraline treatment for alcohol dependence. J Clin Psychopharmacol. Apr. 2001;21(2):143-53. [pmid: 11270910].
173 Kranzler HR, Armeli S, Tennen H, et al. A double-blind, randomized trial of sertraline for alcohol dependence: moderation by age of onset [corrected] and 5-hydroxytryptamine transporter-linked promoter region genotype. J Clin Psychopharmacol. Feb. 2011;31(1):22-30. [pmid: 21192139].
174 Kranzler HR, Armeli S, Tennen H. Post-treatment outcomes in a double-blind, randomized trial of sertraline for alcohol dependence. Alcohol Clin Exp Res. Apr. 2012;36(4):739-44. [pmid: 21981418].
175 Johnson BA, Ait-Daoud N, Bowden CL, et al. Oral topiramate for treatment of alcohol dependence: a randomised controlled trial. Lancet. May. 17. 2003;361(9370):1677-85. [pmid: 12767733].
176 Rubio G, Martinez-Gras I, Manzanares J. Modulation of impulsivity by topiramate: implications for the treatment of alcohol dependence. J Clin Psychopharmacol. Dec. 2009;29(6):584-9. [pmid: 19910725].
177 Ma JZ, Ait-Daoud N, Johnson BA. Topiramate reduces the harm of excessive drinking: implications for public health and primary care. Addiction. Nov. 2006;101(11):1561-8. [pmid: 17034435].
178 Johnson BA, Ait-Daoud N, Akhtar FZ, et al. Oral topiramate reduces the consequences of drinking and improves the quality of life of alcohol-dependent individuals: a randomized controlled trial. Arch Gen Psychiatry. Sep. 2004;61(9):905-12. [pmid: 15351769].
179 Johnson BA, Rosenthal N, Capece JA, et al. Topiramate for treating alcohol dependence: a randomized controlled trial. JAMA. Oct. 10. 2007;298(14):1641-51. [pmid: 17925516].
180 Johnson BA, Rosenthal N, Capece JA, et al. Improvement of physical health and quality of life of alcohol-dependent individuals with topiramate treatment: US multisite randomized controlled trial. Arch Intern Med. Jun. 9. 2008;168(11):1188-99. [pmid: 18541827].
181 Salloum IM, Cornelius JR, Daley DC, et al. Efficacy of valproate maintenance in patients with bipolar disorder and alcoholism: a double-blind placebo-controlled study. Arch Gen Psychiatry. Jan. 2005;62(1):37-45. [pmid: 15630071].
182 Brady KT, Myrick H, Henderson S, et al. The use of divalproex in alcohol relapse prevention: a pilot study. Drug Alcohol Depend. Aug. 1. 2002;67(3):323-30. [pmid: 12127203].
183 de Sousa A, de Sousa A. An open randomized study comparing disulfiram and acamprosate in the treatment of alcohol dependence. Alcohol Alcohol. Nov-Dec. 2005;40(6):545-8. [pmid: 16043433].
184 Laaksonen E, Koski-Jannes A, Salaspuro M, et al. A randomized, multicentre, open-label, comparative trial of disulfiram, naltrexone and acamprosate in the treatment of alcohol dependence. Alcohol Alcohol. Jan-Feb. 2008;43(1):53-61. [pmid: 17965444].
185 De Sousa A, De Sousa A. A one-year pragmatic trial of naltrexone vs disulfiram in the treatment of alcohol dependence. Alcohol Alcohol. Nov-Dec. 2004;39(6):528-31. [pmid: 15525790].
186 Nava F, Premi S, Manzato E, et al. Comparing treatments of alcoholism on craving and biochemical measures of alcohol consumptionst. J Psychoactive Drugs. Sep. 2006;38(3):211-7. [pmid: 17165363].
187 De Sousa A, De Sousa A. An open randomized trial comparing disulfiram and naltrexone in adolescents with alcohol dependence. J Subst Use. 2008;13(6):382-8.
188 Martinotti G, Di Nicola M, Di Giannantonio M, et al. Aripiprazole in the treatment of patients with alcohol dependence: a double-blind, comparison trial vs. naltrexone. J Psychopharmacol. Mar. 2009;23(2):123-9. [pmid: 18515460].
189 Petrakis IL, Ralevski E, Desai N, et al. Noradrenergic vs serotonergic antidepressant with or without naltrexone for veterans with PTSD and comorbid alcohol dependence. Neuropsychopharmacology. Mar. 2012;37(4):996-1004. [pmid: 22089316].
190 Jorgensen CH, Pedersen B, Tonnesen H. The efficacy of disulfiram for the treatment of alcohol use disorder. Alcohol Clin Exp Res. Oct. 2011;35(10):1749-58. [pmid: 21615426].
191 Mason BJ, Lehert P. Acamprosate for alcohol dependence: a sex-specific meta-analysis based on individual patient data. Alcohol Clin Exp Res. Mar. 2012;36(3):497-508. [pmid: 21895717].
192 National Collaborating Centre for Mental Health, National Institute for Health & Clinical Excellence. Alcohol-Use Disorders. Diagnosis, Assessment and Management of Harmful Drinking and Alcohol Dependence. National Clinical Practice Guideline 115. London. Psychiatrists TBPSaTRCo. 2011. http://guidance.nice.org.uk/CG115/Guidance/pdf/English.
193 LoCastro JS, Youngblood M, Cisler RA, et al. Alcohol treatment effects on secondary nondrinking outcomes and quality of life: the COMBINE study. J Stud Alcohol Drugs. Mar. 2009;70(2):186-96. [pmid: 19261230].
194 Miller WR, Tonigan JS, Longabaugh R. The Drinker Inventory of Consequences (DrInC): An instrument for assessing adverse consequences of alcohol abuse. Test manual. (Volume 4, Project MATCH Monograph Series). Rockville, MD. National Institute on Alcohol Abuse and Alcoholism. 1995.
195 Ware J, Kosinski M, Dewey J. How to Score Version 2 of the SF-36 Health Survey. Lincoln, RI. QualityMetric Incorporated. 2000.
196 Chick J, Aschauer H, Hornik K. Efficacy of fluvoxamine in preventing relapse in alcohol dependence: a one-year, double-blind, placebo-controlled multicentre study with analysis by typology. Drug Alcohol Depend. Apr. 9. 2004;74(1):61-70. [pmid: 15072808].
197 Litten RZ, Ryan ML, Fertig JB, et al. A double-blind, placebo-controlled trial assessing the efficacy of varenicline tartrate for alcohol dependence. J Addict Med. Jul-Aug. 2013;7(4):277-86. [pmid: 23728065].
198 Endicott J, Nee J, Harrison W, et al. Quality of Life Enjoyment and Satisfaction Questionnaire: a new measure. Psychopharmacol Bull. 1993;29(2):321-6. [pmid: 8290681].
199 Sheehan KH, Sheehan DV. Assessing treatment effects in clinical trials with the discan metric of the Sheehan Disability Scale. Int Clin Psychopharmacol. Mar. 2008;23(2):70-83. [pmid: 18301121].
200 EuroQol--a new facility for the measurement of health-related quality of life. The EuroQol Group. Health Policy. Dec. 1990;16(3):199-208. [pmid: 10109801].
201 Koskenvuo M. The Finnish Twin Registry Baseline Characteristics. Helsinki. Kansanterveystieteen laitokset: Helsingin yliopisto. 1979.
202 Scott J, Huskisson EC. Graphic representation of pain. Pain. Jun. 1976;2(2):175-84. [pmid: 1026900].
203 Florez G, Garcia-Portilla P, Alvarez S, et al. Using topiramate or naltrexone for the treatment of alcohol-dependent patients. Alcohol Clin Exp Res. Jul. 2008;32(7):1251-9. [pmid: 18482157].
204 Florez G, Saiz PA, Garcia-Portilla P, et al. Topiramate for the treatment of alcohol dependence: comparison with naltrexone. Eur Addict Res. 2011;17(1):29-36. [pmid: 20975274].
205 !!! INVALID CITATION !!!
206 De Sousa AA, De Sousa J, Kapoor H. An open randomized trial comparing disulfiram and topiramate in the treatment of alcohol dependence. J Subst Abuse Treat. Jun. 2008;34(4):460-3. [pmid: 17629442].
207 Rubio G, Jimenez-Arriero MA, Ponce G, et al. Naltrexone versus acamprosate: one year follow-up of alcohol dependence treatment. Alcohol Alcohol. Sep-Oct. 2001;36(5):419-25. [pmid: 11524308].
208 Tollefson GD, Lancaster SP, Montague-Clouse J. The association of buspirone and its metabolite 1-pyrimidinylpiperazine in the remission of comorbid anxiety with depressive features and alcohol dependency. Psychopharmacol Bull. 1991;27(2):163-70. [pmid: 1924664].
209 Tollefson GD, Montague-Clouse J, Tollefson SL. Treatment of comorbid generalized anxiety in a recently detoxified alcoholic population with a selective serotonergic drug (buspirone). J Clin Psychopharmacol. Feb. 1992;12(1):19-26. [pmid: 1552035].
210 Anton RF. Testing combined pharmacotherapies and behavioral interventions for alcohol dependence (the COMBINE study): A pilot feasibility study. Alcohol. 2003;27(7):1123-31.
211 Narayama PL, Gupta AK, Sharma PK. Use of anti-craving agents in soldiers with alcohol dependence syndrome. Medical Journal Armed Forces India. 2008;64(4):320-4.
212 Volpicelli JR, Pettinati HM, McLellan AT, et al. Combining medication and psychosocial Treatments for Addiction: The BRENDA Approach. New York, NY. The Guilford Press. 2001.
213 Carroll K, Ziedonis D, O'Malley SS, et al. Pharmacologic interventions for alcohol- and cocaine-abusing individuals: A pilot study of disulfiram vs. naltrexone. Am J Addict. 1993;2(1):77-9.
214 Greenfield SF, Pettinati HM, O'Malley S, et al. Gender differences in alcohol treatment: an analysis of outcome from the COMBINE study. Alcohol Clin Exp Res. Oct. 2010;34(10):1803-12. [pmid: 20645934].
215 Derogatis LR, Lipman RS, Covi L. SCL-90: an outpatient psychiatric rating scale--preliminary report. Psychopharmacol Bull. Jan. 1973;9(1):13-28. [pmid: 4682398].
216 Coller JK, Cahill S, Edmonds C, et al. OPRM1 A118G genotype fails to predict the effectiveness of naltrexone treatment for alcohol dependence. Pharmacogenet Genomics. Dec. 2011;21(12):902-5. [pmid: 21946895].
217 Kim SG, Kim CM, Choi SW, et al. A mu opioid receptor gene polymorphism (A118G) and naltrexone treatment response in adherent Korean alcohol-dependent patients. Psychopharmacology (Berl). 2009;201(4):611-8. [pmid: 18795264].
218 Gelernter J, Gueorguieva R, Kranzler HR, et al. Opioid receptor gene (OPRM1, OPRK1, and OPRD1) variants and response to naltrexone treatment for alcohol dependence: results from the VA Cooperative Study. Alcohol Clin Exp Res. Apr. 2007;31(4):555-63. [pmid: 17374034].
219 Oslin DW, Berrettini W, Kranzler HR, et al. A functional polymorphism of the mu-opioid receptor gene is associated with naltrexone response in alcohol-dependent patients. Neuropsychopharmacology. Aug. 2003;28(8):1546-52. [pmid: 12813472].
220 Rehm J, Baliunas D, Borges GL, et al. The relation between different dimensions of alcohol consumption and burden of disease: an overview. Addiction. May. 2010;105(5):817-43. [pmid: 20331573].
221 Bondy SJ, Rehm J, Ashley MJ, et al. Low-risk drinking guidelines: the scientific evidence. Can J Public Health. Jul-Aug. 1999;90(4):264-70. [pmid: 10489725].
222 Shalala DE. 10th Special Report to the U.S. Congress on Alcohol and Health: Highlights From Current Research: From the Secretary of Health and Human Services. Washington, DC. U.S. Department of Health and Human Services. 2000. http://pubs.niaaa.nih.gov/publications/10report/intro. 8 June 2012.
223 Rehm J, Shield KD, Gmel G, et al. Modeling the impact of alcohol dependence on mortality burden and the effect of available treatment interventions in the European Union. Eur Neuropsychopharmacol. Feb. 2013;23(2):89-97. [pmid: 22920734].
224 Zarkin GA, Bray JW, Aldridge A, et al. The effect of alcohol treatment on social costs of alcohol dependence: results from the COMBINE study. Med Care. May. 2010;48(5):396-401. [pmid: 20393362].
225 CAMPRAL® (acamprosate calcium). [package insert]. St. Louis, MO. Forest Pharmaceuticals, Inc. 2005.
226 REVIA® (naltrexone hydrochloride). [package insert]. Duramed Pharmaceuticals, Inc. Pomona, NY. 2009.
227 VIVITROL® (naltrexone for extended-release injectable suspension). [package insert]. Waltham, MA. Alkermes, Inc. 2010.
228 O'Malley SS, Rounsaville BJ, Farren C, et al. Initial and maintenance naltrexone treatment for alcohol dependence using primary care vs specialty care: a nested sequence of 3 randomized trials. Arch Intern Med. Jul. 28. 2003;163(14):1695-704. [pmid: 12885685].
229 Kiritze-Topor P, Huas D, Rosenzweig C, et al. A pragmatic trial of acamprosate in the treatment of alcohol dependence in primary care. Alcohol Alcohol. Nov-Dec. 2004;39(6):520-7. [pmid: 15304381].
230 Oslin DW, Lynch KG, Maisto SA, et al. A Randomized Clinical Trial of Alcohol Care Management Delivered in Department of Veterans Affairs Primary Care Clinics Versus Specialty Addiction Treatment. J Gen Intern Med. 2013. Sep. 20. [pmid: 24052453].
231 Saitz R, Cheng DM, Winter M, et al. Chronic care management for dependence on alcohol and other drugs: the AHEAD randomized trial. JAMA. Sep. 18. 2013;310(11):1156-67. [pmid: 24045740].
232 Jonas DE, Garbutt JC, Brown JM, et al. Screening Behavioral Counseling, and Referral in Primary Care to Reduce Alcohol Misuse. Comparative Effectiveness Review No. 64. (Prepared by the RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC055-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
233 D'Amico EJ, Paddock SM, Burnam A, et al. Identification of and guidance for problem drinking by general medical providers: results from a national survey. Med Care. Mar. 2005;43(3):229-36. [pmid: 15725979].
234 Kranzler HR, Armeli S, Tennen H, et al. Targeted naltrexone for early problem drinkers. J Clin Psychopharmacol. Jun. 2003;23(3):294-304. [pmid: 12826991].
235 Jonas DE, Wilt TJ, Taylor BC, et al. Chapter 11: challenges in and principles for conducting systematic reviews of genetic tests used as predictive indicators. J Gen Intern Med. Jun. Suppl 1. 2012;27:S83-93. [pmid: 22648679].
236 Polich JM, Armor DJ, Braiker HB. Stability and change in drinking patterns. The Course of Alcoholism: Four Years After Treatment. New York, NY. John Wiley & Sons. 1981:159-200.
237 Kissin B, Charnoff SM, Rosenblatt SM. Drug and placebo responses in chronic alcoholics. Psychiatr Res Rep Am Psychiatr Assoc. Mar. 1968;24:44-60. [pmid: 4889329].