# Methods

The methods for this comparative effectiveness review (CER) follow the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (http://www.effectivehealthcare.ahrq.gov/methodsguide.cfm).

## Topic Refinement and Review Protocol

This topic was nominated by a physician affiliated with the Substance Abuse and Mental Health Services Administration (SAMHSA), which works to improve the quality and availability of substance abuse prevention, alcohol and drug use disorder treatment, and mental health services. During the topic development and refinement processes, we engaged in a public process to develop a draft and final protocol for the CER process. We generated an analytic framework, preliminary Key Questions (KQs), and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, settings). The processes were guided by the information provided by the topic nominator, a scan of the literature, methods and content experts, and Key Informants. We worked with six Key Informants during the topic refinement, all of whom subsequently served on the Technical Expert Panel (TEP) for this report. The TEP consisted of a distinguished group of eight scientists and clinicians, including individuals with expertise in addiction medicine, psychiatry, pharmacotherapy, regulatory and medical education, and policy. Key Informants and TEP members participated in conference calls and discussions through email to review the scope, analytic framework, KQs, and PICOTS; provided input on the information and categories included in evidence tables; and provided input on the data analysis plan. A list of the Key Informants and TEP members is included in the front matter of this report.

The KQs were posted for public comment on AHRQ's Effective Health Care Web site from September 20 to October 18, 2012; we put them into final form after review of the comments and discussion with the TEP. The only comments we received were attempts to provide answers to the questions rather than to provide input about the draft scope, KQs, PICOTS, or analytic framework. Therefore, no changes were made based on public review. We then drafted a protocol for this CER and refined the protocol in consultation with AHRQ and the TEP before it was posted on the Effective Health Care Web site on April 29, 2013.

## Literature Search Strategy

### Search Strategy

To identify articles relevant to each KQ, we searched PubMed^®^, the Cochrane Library, PsycINFO^®^, CINAHL^®^, and Embase^®^. The full search strategy is presented in Appendix A. We used either Medical Subject Headings (MeSH) or major headings as search terms when available or key words when appropriate, focusing on terms to describe the relevant populations and interventions of interest. We reviewed our search strategy with the TEP and incorporated their input. Searches were run by an experienced information scientist serving as the Evidence-based Practice Center (EPC) librarian and were peer-reviewed by another information scientist/EPC librarian.

We limited the electronic searches to English-language, adult (18 and older), and human-only studies. Sources were searched from January 1, 1970, to October 11, 2013. This search date was selected based on the earliest publications found during the topic refinement process, the earliest study found in previous systematic reviews (which was from 1974), and expert opinion.

We manually searched reference lists of pertinent reviews, trials, and background articles on this topic to look for any relevant citations that our searches might have missed. We also reviewed references suggested by peer and public reviewers. We imported all citations into an EndNote^®^ X4 (Thomson Reuters, New York, NY) electronic database.

We also searched for unpublished studies relevant to this review using ClinicalTrials.gov, the World Health Organization International Clinical Trials Registry Platform, and the Web site for the U.S. Food and Drug Administration (FDA). In addition, AHRQ's Scientific Resource Center requested scientific information packets from relevant pharmaceutical companies, asking for any unpublished studies or data relevant to this CER. Scientific information packets allow pharmaceutical companies to provide the EPC with published or unpublished data that they believe should be considered for the review. Any additional studies identified from the packets will be included in the post-peer/public review report.

In cases in which relevant information was unclear or not reported, we contacted authors to get additional or unpublished information. When successful, this information was included in the findings.

### Inclusion and Exclusion Criteria

We developed eligibility (inclusion and exclusion) criteria with respect to PICOTS and study designs and durations for each KQ (Table 3).

Table 3 Eligibility criteria

Category | Inclusion | Exclusion
Population | Adults (age 18 years or older) with alcohol-use disorders (as defined in the Introduction). For KQ 5, co-occurring disorders include other mental health or substance use disorders (e.g., depression, cocaine use disorder) and acute or chronic medical conditions (e.g., cirrhosis). | Children and adolescents under 18
Interventions | Medications approved by FDA for treating alcohol dependence (acamprosate, disulfiram, naltrexone) and the following medications, which have been used off-label or are under investigation: amitriptyline, aripiprazole, atomoxetine, baclofen, buspirone, citalopram, desipramine, escitalopram, fluoxetine, fluvoxamine, gabapentin, imipramine, nalmefene, olanzapine, ondansetron, paroxetine, prazosin, quetiapine, sertraline, topiramate, valproate, varenicline, viloxazine. | Pharmacotherapy for alcohol withdrawal; any drugs not listed; combinations of medications (e.g., studies randomizing subjects to naltrexone plus ondansetron vs. placebo)
Comparators | For KQs 1 through 5, studies must compare one of the medications listed above with placebo or another medication. For KQ 6, studies must compare people who have a specific genotype or allele with people who have different genotypes or alleles. | No comparison; nonconcordant historical controls
Outcomes | Consumption outcomes: return to any drinking, return to heavy drinking, drinking days, heavy drinking days^a^, drinks per drinking day, time to lapse or relapse. Health outcomes: accidents, injuries^b^, quality of life, function, mortality. Adverse effects of intervention(s): withdrawals due to adverse events, nausea/vomiting, diarrhea, anorexia, palpitations, headache, dizziness, cognitive dysfunction, taste abnormalities, paresthesias (numbness, tingling), metabolic acidosis, glaucoma, vision changes, suicidal ideation, insomnia, anxiety, rash. | Craving; cue reactivity
Timing/length of followup | At least 12 weeks of followup from the time of medication initiation. | Less than 12 weeks
Settings | Outpatient health care (i.e., nonlaboratory) settings, including studies that begin in or recruit subjects from inpatient settings but then follow and assess subjects receiving pharmacotherapy as outpatients. KQ 4 applies to primary care settings only (i.e., internal medicine, family medicine, pediatrics, obstetrics/gynecology, or college and university health clinics). | All other settings; laboratory settings; inpatient settings (if most or all of the study followed inpatients)
Publication language | English | All other languages
Admissible evidence (study design and other criteria) | Original research; eligible study designs include the following:; - For KQs 1, 2, and 4, double-blind RCTs and recent systematic reviews were eligible.; - For KQ 2b (head-to-head studies reporting health outcomes), prospective cohort studies were also eligible.; - For KQ 3 (harms), double-blind RCTs and recent systematic reviews that compare medication with placebo or with another medication were eligible. The following designs were also eligible if they compared 2 or more drugs of interest: nonrandomized controlled trials, open-label trials, secondary analyses or subgroup analyses from trials, prospective cohort studies, and case-control studies.; - For KQ 5 (subgroups), double-blind RCTs, recent systematic reviews, nonrandomized controlled trials, open-label trials, secondary analyses or subgroup analyses from trials, prospective cohort studies, and case-control studies were eligible, as long as the studies compared 2 or more drugs.; - For KQ 6, double-blind RCTs, analyses of subjects from trials, and prospective cohort studies were eligible. | Case series Case reports Nonsystematic reviews Systematic reviews with searches that ended prior to 2007 Systematic reviews that had been updated Editorials Letters to the editor Studies with historical, rather than concurrent, control groups

FDA = U.S. Food and Drug Administration; KQ = Key Question; RCT = randomized controlled trial.

a Heavy drinking days were defined as 4 or more drinks per day for women and 5 or more drinks per day for men.

b Accidents typically refer to motor vehicle accidents. Injuries may be from a wide variety of alcohol-related problems (e.g., violence, falls). We did not use strict definitions for accidents and injuries. Knowing a priori that we would find very little evidence for these outcomes, we used definitions provided by studies and we included studies that did not provide definitions (but that only gave a number of injuries, for example).

### Study Selection

Two trained members of the research team independently reviewed each title and abstract (identified through searches) against our eligibility criteria. Studies marked for possible inclusion by either reviewer underwent a full-text review. For titles or abstracts that lacked adequate information to determine eligibility, we retrieved and reviewed the full text. Two trained members of the research team independently reviewed each full-text article and determined eligibility based on the criteria described above. If the reviewers disagreed, they resolved conflicts by discussion and consensus or by consulting a third, senior member of the team. We recorded the principal reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix B). All results in both review stages were tracked in an EndNote® database.

### Data Extraction

For studies that met our inclusion criteria, we extracted important information into evidence tables. We designed, pilot-tested, and used structured data extraction forms to gather pertinent information from each article; this included characteristics of study populations, settings, interventions, comparators, study designs, methods, and results. Trained reviewers extracted the relevant data from each included article. All data abstractions were reviewed for completeness and accuracy by a second member of the team. We recorded intention-to-treat (ITT) results if available. All data abstraction was performed using Microsoft Word^®^ or Excel^®^ software.

## Risk-of-Bias Assessment of Individual Studies

To assess the risk of bias (internal validity) of studies for major outcomes of interest, we used predefined criteria based on guidance from the AHRQ “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.” We assessed selection bias, confounding, performance bias, detection bias, and attrition bias; we included questions about adequacy of randomization, allocation concealment, similarity of groups at baseline, blinding, attrition, whether ITT analysis was used, methods of handling missing data, and fidelity. We rated the studies as low, medium, high, or unclear risk of bias.52

In general terms, studies categorized as low risk of bias imply high confidence that the results represent the true treatment effects. Studies with medium risk of bias are susceptible to some risk of bias but probably not enough to invalidate the results. Studies with a medium risk of bias did not meet all criteria required for low risk of bias. These studies had some flaws in design or execution (e.g., inadequate description of methods of randomization and allocation concealment) but they provided enough information to allow readers to determine that the flaws did not likely cause major bias. Missing information often led to ratings of medium as opposed to low risk of bias. Studies assessed as high risk of bias have significant flaws stemming from serious errors in design, conduct, or analysis that may invalidate the results (e.g., high overall or differential attrition without appropriate handling of missing data).

For systematic reviews, we assessed the review questions, the literature search strategy, the eligibility criteria, whether dual review was used, whether the internal validity of included studies was assessed, whether publication bias was assessed, whether heterogeneity was assessed and addressed, the data synthesis approach, and whether conclusions were supported by the data presented.

Two independent reviewers assessed the risk of bias for each study; one of the two reviewers was always an experienced EPC investigator. Disagreements between the two reviewers were resolved by discussion and consensus or by a third member of the team. We omitted studies deemed high risk of bias by two reviewers from our main data synthesis and main analyses; we included them only in sensitivity analyses. Appendix C details the criteria used for evaluating the risk of bias of all included studies and explains the rationale for high risk of bias ratings.

## Data Synthesis

We conducted quantitative synthesis using meta-analyses of outcomes reported by multiple studies that were sufficiently homogeneous to justify combining their results. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies under consideration following established guidance.53 We did this by qualitatively assessing the PICOTS of the included studies and looking for similarities and differences. When quantitative synthesis was not appropriate (e.g., because of clinical heterogeneity, insufficient numbers of similar studies, or insufficiency or variation in outcome reporting), we synthesized the data qualitatively.

We used random-effects models to estimate pooled effects.54 For continuous outcomes (e.g., scales for symptom reduction), we used weighted mean differences (WMDs). For binary outcomes we calculated risk differences (RDs) between groups. We did not include studies rated as high or unclear risk of bias in our main analyses, but did include them in sensitivity analyses. For alcohol consumption outcomes, if studies reported consumption in grams, we used a conversion factor of 13.7 grams as equivalent to a standard drink.55 All quantitative analyses were conducted using Stata^®^ version 11.1 (StataCorp LP, College Station, TX).

We calculated the chi-squared statistic and the I^2^ statistic to assess statistical heterogeneity in effects between studies.56,57 An I^2^ from 0 to 40 percent might not be important, 30 percent to 60 percent may represent moderate heterogeneity, 50 percent to 90 percent may represent substantial heterogeneity, and ≥75 percent represents considerable heterogeneity.58 The importance of the observed value of I^2^ depends on the magnitude and direction of effects and on the strength of evidence (SOE) for heterogeneity (e.g., p value from the chi-squared test, or a confidence interval for I^2^). Whenever we include a meta-analysis with considerable statistical heterogeneity in this report, we attempt to provide an explanation for the heterogeneity, considering the magnitude and direction of effects.58 We examined potential sources of heterogeneity by stratifying analyses by patient population or setting (i.e., U.S.-based trials compared with others; studies that enrolled a dual diagnosis population compared with those that did not), variation in interventions (i.e., dose and route of delivery), and duration of treatment.

For systematic reviews meeting our inclusion criteria, we describe their main findings qualitatively to allow a comparison of our findings with those of recent systematic reviews.

## Strength of the Body of Evidence

We graded SOE based on the guidance established for the Evidence-based Practice Center program.59 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: risk of bias (includes study design and aggregate quality), consistency, directness, and precision of the evidence. It also considers optional domains, such as a dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias. Table 4 defines the grades of evidence that we assigned.

Table 4 Definitions of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Source: Owens et al., 2010^59^

Two reviewers assessed each domain for each key outcome and determined an overall SOE grade based on domain ratings. We generally required consistent, direct, precise evidence from studies with aggregate low risk of bias to give high SOE grades. An unfavorable assessment for any one of the four key domains (i.e., inconsistency, indirectness, imprecision, or medium aggregate risk of bias) typically resulted in downgrading to moderate SOE. Two unfavorable assessments typically resulted in downgrading to low SOE. We allowed reviewers to include the optional domains listed above (e.g., dose-response association, publication bias) if relevant, and to upgrade or downgrade the SOE for those domains if appropriate. In the event of disagreements on the domain or overall grade, they resolved differences by consensus discussion or by consulting with a third, experienced EPC investigator.

We graded the SOE for the following outcomes: return to any drinking, return to heavy drinking, drinking days, heavy drinking days, drinks per drinking day, accidents, injuries, quality of life or function, mortality, and adverse events. Appendix D includes tables showing our assessments for each domain and the resulting SOE grades for each outcome, organized by KQ and intervention/comparison pair.

## Applicability

We assessed applicability of the evidence following guidance from the “Methods Guide for Comparative Effectiveness Reviews.”60 We used the PICOTS framework to explore factors that affect applicability. Some factors identified a priori that may limit the applicability of evidence include the age, sex, and race or ethnicity of enrolled populations; smoking status of enrolled populations; co-occurring disorders of enrolled populations; setting; type of provider prescribing the treatment; and source of subject recruitment. Regarding the source of subject recruitment, studies of subjects recruited via advertisements may enroll people that have less severe disorders, and may be less applicable to patients with more severe forms of alcohol-use disorders.

## Peer Review and Public Commentary

An external peer review was performed on this report. We compiled all comments and addressed each one individually, revising the text as appropriate. AHRQ also provided review from its own staff. In addition, AHRQ's Scientific Resource Center placed the draft report on the AHRQ Web site (www.effectivehealthcare.ahrq.gov/) for public review.