# Peer Reviewers

Peer Reviewers are invited to provide written comments on the draft report based on their clinical, content, or methodologic expertise. Peer review comments on the preliminary draft of the report are considered by the EPC in preparation of the final draft of the report. Peer Reviewers do not participate in writing or editing the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer review comments are documented and will, for Comparative Effectiveness Reviews and Technical Briefs, be published 3 months after the publication of the evidence report.

Potential reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited Peer Reviewers may not have any financial conflict of interest greater than $10,000. Peer Reviewers who disclose potential business or professional conflicts of interest may submit comments on draft reports through the public comment mechanism.

The list of Peer Reviewers follows:

- Raymond Anton, M.D.
  Medical University of South Carolina
  Charleston, SC
- Katharine Bradley, M.D., M.P.H.
  Group Health Research Institute
  U.S. Department of Veterans Affairs Puget Sound Health Care System
  University of Washington
  Seattle, WA
- Jonathan Chick, M.A., M.Phil., M.B.Ch.B., D.Sc., FRCPsych, FRCPE
  Queen Margaret University
  Edinburgh, Scotland
- Raye Litten, Ph.D.
  National Institute on Alcohol Abuse and Alcoholism
  Bethesda, MD
- David Oslin, M.D.
  University of Pennsylvania
  Philadelphia, PA
- Ismene Petrakis, M.D.
  Yale University; U.S. Department of Veterans Affairs Connecticut Healthcare System
  West Haven, CT
- Sandrine Pirard, M.D., Ph.D., M.P.H.
  National Institute on Drug Abuse,
  National Institutes of Health
  Baltimore, MD
- Elizabeth Ralevski, Ph.D.
  Yale University
  New Haven, CT
- Joseph Volpicelli, M.D., Ph.D.
  Institute of Addiction Medicine
  Plymouth Meeting, PA