# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officers, Carmen Kelly, Pharm.D., R.Ph., and Aysegul Gozu, M.D., M.P.H., and our Associate Editor, Melissa McPheeters, M.P.H., Ph.D., as well as the continued guidance of Christine Chang, M.D., M.P.H. We extend our appreciation to our Key Informants and members of our Technical Expert Panel (listed below), all of whom provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International and the University of North Carolina (UNC) at Chapel Hill. We express our gratitude to the following individuals for their contributions to this project: Carol Woodell, B.S.P.H., our Project Manager; Meera Viswanathan, Ph.D., Director of the RTI-UNC EPC; Timothy S. Carey, M.D., M.P.H., Director of the Cecil G. Sheps Center for Health Services Research at UNC; Christiane Voisin, M.S.L.S., our EPC Librarian; Claire Baker, our Research Assistant; Jennifer Drolet, M.A., Editor; and Loraine Monroe and Judy Cannada, our EPC Publications Specialists.