# Discussion

Below, we summarize the main findings and strength of evidence (SOE). We then discuss the findings in relation to what is already known, applicability of the findings, implications for decisionmaking, limitations, research gaps, and conclusions. When we have graded evidence as insufficient, it indicates that evidence is either unavailable, does not permit estimation of an effect, or does not permit us to draw a conclusion with at least a low level of confidence. It does not indicate that a treatment has been proven to lack efficacy.

## Key Findings and Strength of Evidence

### Efficacy and Comparative Effectiveness

We found moderate SOE that both acamprosate and oral naltrexone (50 mg per day) are effective for improving alcohol consumption outcomes (Table 37). Numbers needed to treat (NNT) to prevent 1 person from returning to any drinking were 12 and 20, respectively. For return to heavy drinking, evidence did not support the efficacy of acamprosate, whereas oral naltrexone (50 mg per day) was efficacious with an NNT of 12. Relatively limited evidence from well-controlled trials does not adequately support the efficacy of disulfiram compared with placebo for preventing return to any drinking or for other alcohol consumption outcomes. Some disulfiram trials reported fewer drinking days for subjects who returned to any drinking and who had a complete set of assessment interviews, and suggest that disulfiram may have a role in the treatment of AUDs for some individuals.

Table 37 Summary of findings and strength of evidence for efficacy of FDA-approved medications for alcohol dependence

Medication | Outcome | N Studies; N Subjects^a^ | Results Effect Size (95% CI)^b^ | NNT^c^ | Strength of Evidence
ACA | Return to any drinking | 16; 4,847 | RD: -0.09 (-0.14 to -0.04) | 12 | Moderate
ACA | Return to heavy drinking | 7; 2,496 | RD: -0.01 (-0.04 to 0.03) | NA | Moderate
ACA | % DDs | 13; 4,485 | WMD: -8.8 (-12.8 to -4.8) | NA | Moderate
ACA | % HDDs | 1; 100 | WMD: -2.6 (-11.4 to 6.2) | NA | Insufficient
ACA | Drinks per DD | 1; 116 | WMD: 0.4 (-1.8 to 2.6) | NA | Insufficient
ACA | Accidents or injuries | 0;^d^ 0 | NA | NA | Insufficient
ACA | QoL or function | 1; 612 | NSD | NA | Insufficient
ACA | Mortality | 8; 2,677 | 7 events (ACA) vs. 6 events (placebo) | NA | Insufficient
DIS | Return to any drinking | 2; 492 | RD: -0.04 (-0.11 to 0.03)^e^ | NA | Low
DIS | Return to heavy drinking | 0; 0 | NA | NA | Insufficient
DIS | % DDs | 2; 290 | NSD^f^ | NA | Insufficient
DIS | % HDDs | 0; 0 | NA | NA | Insufficient
DIS | Drinks per DD | 0; 0 | NA | NA | Insufficient
DIS | Accidents or injuries | 0; 0 | NA | NA | Insufficient
DIS | QoL or function | 0; 0 | NA | NA | Insufficient
DIS | Mortality | 0; 0 | NA | NA | Insufficient
NTX 50 mg oral | Return to any drinking | 16; 2,347 | RD: -0.05 (-0.10 to -0.00) | 20 | Moderate
NTX 50 mg oral | Return to heavy drinking | 19; 2,875 | RD: -0.09 (-0.13 to -0.04) | 12 | Moderate
NTX 50 mg oral | % DDs | 15; 1,992 | WMD: -5.4 (-7.5 to -3.2) | NA | Moderate
NTX 50 mg oral | % HDDs | 6; 521 | WMD: -4.1 (-7.6 to -0.61) | NA | Moderate
NTX 50 mg oral | Drinks per DD | 9; 1,018 | WMD: -0.49 (-0.92 to -0.06) | NA | Low
NTX 100 mg oral | Return to any drinking | 3; 946 | RD: -0.03 (-0.08 to 0.02) | NA | Low
NTX 100 mg oral | Return to heavy drinking | 2; 858 | RD: -0.05 (-0.11 to 0.01) | NA | Low
NTX 100 mg oral | % DDs | 2; 858 | WMD: -0.9 (-4.2 to 2.5) | NA | Low
NTX 100 mg oral | % HDDs | 2; 423 | WMD: -3.1 (-5.8 to -0.3) | NA | Low
NTX 100 mg oral | Drinks per DD | 1; 240 | WMD: 1.9 (-1.5 to 5.2) | NA | Insufficient
NTX injection | Return to any drinking | 2; 939 | RD: -0.04 (-0.10 to 0.03) | NA | Low
NTX injection | Return to heavy drinking | 2; 615 | RD: -0.01 (-0.14 to 0.13) | NA | Low
NTX injection | % DDs | 1; 315 | WMD: -8.6 (-16.0 to -1.2) | NA | Insufficient
NTX injection | % HDDs | 2^g^; 926 | WMD: -4.6 (-8.5 to -0.56) | NA | Low
NTX injection | Drinks per DD | 0; 0 | NA | NA | Insufficient
NTX (any dose) | Accidents or injuries | 0; 0 | NA | NA | Insufficient
NTX (any dose) | QoL or function | 4; 1,513 | Some conflicting results^h^ | NA | Insufficient
NTX (any dose) | Mortality | 6; 1,738 | 1 event (NTX) vs. 2 events (placebo) | NA | Insufficient

ACA = acamprosate; CI = confidence interval; DD, drinking day; DIS = disulfiram; FDA = U.S. Food and Drug Administration; HDD, heavy drinking day; N = number; NA = not applicable; NNT = number needed to treat; NSD = no statistically significant difference; NTX = naltrexone; QoL, quality of life; RD = risk difference; vs. = versus; WMD = weighted mean difference.

a Includes only studies rated as low or medium risk of bias included in the main analyses; these numbers do not include studies rated as high or unclear risk of bias that were included in sensitivity analyses.

b Negative effect sizes favor intervention over placebo/control.

c NA entry for numbers needed to treat (NNT) indicates that the risk difference (95% CI) was not statistically significant, so we did not calculate a NNT, or that the effect measure was not one that allows direct calculation of NNT (e.g., WMD).

d One study rated as unclear risk of bias reported that one patient in the placebo group died by “accident.” No other details on the cause or nature of the accident were provided.78 That study also reported 1 injury in the acamprosate group and 2 in the placebo group. Another study, rated high risk of bias, reported a traffic accident in the acamprosate group.184

e From meta-analysis of disulfiram 250 mg versus control (disulfiram 1 mg).92,93 Meta-analysis including studies rated as high risk of bias also found no significant difference (RD, -0.00; 95% CI, -0.10 to 0.09). Similarly, our meta-analysis found no statistically significant difference between disulfiram 250 mg per day and riboflavin (i.e., no disulfiram) (RD, -0.04; 95% CI, -0.11 to 0.03).

f One study (N=128) reported similar percentages and no significant difference;93 the other reported that disulfiram was favored among the subset of subjects (N=162 of 605 subjects) who drank and had a complete set of assessment interviews, but it did not report this outcome for the full randomized sample.92 Overall, evidence was insufficient due to imprecision, inconsistency, and indirectness.

g Contains data from personal communication (B. Silverman, November 14, 2013).

h Unable to pool data. Two studies found no significant difference between naltrexone- and placebo-treated subjects.102,193 One study reported that patients receiving injectable naltrexone 380 mg per month had greater improvement on the mental health summary score than those receiving placebo at 24 weeks (8.2 versus 6.2, p=0.044).131 One study measured alcohol-related consequences (with the DrInC) and reported that more subjects who received placebo (N=34) had at least 1 alcohol-related consequence than those who received naltrexone (N=34): 76 percent versus 45 percent, p=0.02.^42^

We found insufficient direct evidence to conclude that treatment with acamprosate or naltrexone leads to improvement in health outcomes—i.e., accidents, injuries, quality of life (QoL), function, or mortality. Very few trials reported any health outcomes, and the included trials were not designed or powered to assess impact on health outcomes—they typically focused on alcohol consumption outcomes. It is noteworthy that the largest pharmacotherapy trial in alcohol dependence, COMBINE, did report some evidence of improvement in QoL with naltrexone plus behavioral intervention (on the 12-item Short-Form Health Survey [SF-12v2] physical health scale), but the difference between groups did not reach a clinically meaningful threshold.193 Evidence from epidemiologic literature consistently relates high average alcohol consumption and heavy per-occasion use to an increased risk of health problems, such as cancers of the oral cavity, esophagus, larynx, colon, rectum, liver, and breast; liver cirrhosis; chronic pancreatitis; coronary heart disease; stroke; depression; preterm birth complications; fetal alcohol syndrome; and injuries and violence.13,24,220-222 Such epidemiologic evidence would suggest that improving alcohol consumption outcomes is likely to result in improved health outcomes. A recent model estimated that increasing treatment coverage to 40 percent of all people with alcohol dependence in the European Union would reduce alcohol-attributable mortality by 13 percent for men and 9 percent for women.223 Further, a cost study based on the COMBINE trial reported that several treatment combinations that include pharmacotherapy led to reduced median social costs associated with health care, arrests, and motor vehicle accidents compared with medical management plus placebo.224

Our meta-analyses of 4 head-to-head randomized controlled trials (RCTs) comparing acamprosate with naltrexone,61,65,74,79 all rated as low risk of bias, found no statistically significant difference between the two medications for improvement in alcohol consumption outcomes (Table 38). The COMBINE study was one of the 4 RCTs.65 It found that “patients receiving medical management with naltrexone, combined behavioral intervention (CBI), or both fared better on drinking outcomes than those who received placebo, but acamprosate showed no evidence of efficacy, with or without CBI.”

Table 38 Summary of findings and strength of evidence for comparative effectiveness of acamprosate and naltrexone

Intervention | Outcome | N studies; N subjects^a^ | Results Effect Size (95% CI)^b^ | Strength of Evidence
ACA vs. NTX | Return to any drinking | 3; 800 | RD: 0.02 (-0.03 to 0.08) | Moderate
ACA vs. NTX | Return to heavy drinking | 4; 1,141 | RD: 0.01 (-0.05 to 0.06) | Moderate
ACA vs. NTX | Percentage drinking days | 2; 720 | WMD: -2.98 (-13.4 to 7.5) | Low

ACA = acamprosate; CI = confidence interval; N = number; NTX = naltrexone; RD = risk difference; WMD = weighted mean difference.

Note: Table only includes comparisons of medications with evidence of efficacy (as determined in KQ 1) and with sufficient data for synthesis. We did not include rows in this table for outcomes that we graded as having insufficient SOE (percentage heavy drinking days, drinks per drinking day, accidents or injuries, quality of life or function, and mortality).

a Includes only studies rated as low or medium risk of bias included in the main analyses; these numbers do not include studies rated as high or unclear risk of bias that were included in sensitivity analyses.

b Negative effect sizes favor acamprosate over naltrexone.

For the vast majority of medications used off-label, and those under investigation, the evidence either was insufficient to determine whether they are efficacious for reducing alcohol consumption or the evidence suggested that they are not efficacious for people with AUDs. We found some exceptions. First, for topiramate, we found moderate SOE supporting efficacy for reducing drinking days, heavy drinking days, and drinks per drinking day—based on the results of 2 RCTs rated as low or medium risk of bias (total N=521).175,179 The included RCTs did not report data for return to any drinking or return to heavy drinking. Second, for nalmefene, we found moderate SOE supporting efficacy for reducing heavy drinking days per month (WMD -2.0; 95% CI, -3.0 to -1.0) and drinks per drinking day (WMD, -1.0; 95% CI, -1.8 to -0.3).159,160 We found insufficient evidence of efficacy for nalmefene for other consumption outcomes (return to any drinking and return to heavy drinking) and low SOE that nalmefene is not efficacious for reducing drinking days (WMD, -1.1; 95% CI, -7.6 to 5.4). Finally, limited evidence from 2 small RCTs (total N=88) supports efficacy of valproic acid for reducing return to heavy drinking, heavy drinking days, and drinks per drinking day (low SOE for all).

### Harms

Adverse events were often not collected using standardized measures, and methods for systematically capturing adverse events were often not reported. Studies were generally not designed primarily to assess adverse events; the vast majority focused on alcohol consumption outcomes. Evidence for many potential adverse events was insufficient to determine whether the risk was increased or not, often primarily because of lack of precision. For most of the specific adverse events, point estimates favored placebo (i.e., there were more adverse events with medications), but the differences were not statistically significant.

In head-to-head studies, the risk of withdrawal due to adverse events was not significantly different between acamprosate and naltrexone, whereas the risks of headache and vomiting were higher for those treated with naltrexone. Compared with placebo, patients treated with acamprosate had a higher risk of anxiety, diarrhea, and vomiting; those treated with naltrexone had a higher risk of dizziness, nausea, and vomiting; and those treated with nalmefene had a higher risk of dizziness, headache, insomnia, nausea, and vomiting. Trials of topiramate reported increased risk of many adverse events, including paresthesias, taste perversion, anorexia, difficulty with concentration/attention, nervousness, dizziness, pruritis, psychomotor slowing, and weight loss.175,179 A single trial that reported adverse effects for valproic acid compared with placebo found a higher rate of nausea for patients treated with valproic acid.

According to the package insert,225 acamprosate is contraindicated for people with severe renal impairment (creatinine clearance 30 mL per minute or less) and requires dose adjustments for moderate renal impairment (creatinine clearance between 30 and 50 mL per minute). Precautions are listed to monitor for depression and suicidal ideation. Common side effects include diarrhea and somnolence.

Oral naltrexone is contraindicated for patients with acute hepatitis or liver failure, and for those currently using opioids or with anticipated need for opioids.226,227 It can precipitate severe withdrawal for patients dependent on opioids.226,227 Precautions are listed in the package insert for other hepatic disease, renal impairment, and history of suicide attempts or depression. Patients should be advised to carry a wallet card to alert medical personnel because larger doses may be required and respiratory depression may be deeper and more prolonged if opioid analgesia is needed. Serious adverse events include precipitation of severe withdrawal if the patient is dependent on opioids, and hepatotoxicity (although it is not believed to be a hepatotoxin at the recommended doses). Common side effects include nausea, vomiting, decreased appetite, headache, dizziness, fatigue, somnolence, and anxiety. Injectable naltrexone can also cause injection site reactions. The prescribing information for injectable naltrexone is somewhat different.227 For example, contraindications for injectable naltrexone include patients receiving opioid analgesics, with current physiologic opioid dependence, with acute opioid withdrawal, or who have failed a naloxone challenge test. It is not contraindicated for patients with acute hepatitis or liver failure, or for those with anticipated need for opioids.

### Primary Care Settings

Evidence from primary care settings was scant. One trial (N=100) that recruited subjects primarily by advertisement in two family medicine settings in the United States found no significant treatment effect when comparing acamprosate with placebo.69 The only other trial meeting our inclusion criteria that was conducted partly in primary care settings compared nalmefene with placebo in 15 sites (about half were primary care settings) in Finland.158

Some included studies conducted in non-primary care settings used interventions that may be adaptable for delivery in primary care. For example, in the COMBINE study,65 providers delivered a medical management intervention of up to 9 manual-guided counseling visits. The first visit was approximately 45 minutes and followup visits were about 20 minutes each. Medical management included advice for reducing drinking, inquiries about medication side-effects, and emphasis on the importance of taking medications as prescribed. Another trial (included in Key Question [KQ] 1 but not in KQ 4) that compared naltrexone with placebo for 12 weeks in the United States described the use of a “primary care model.”101 Although the trial did not take place in a primary care setting (it was a treatment research center), and the investigators were from a department of psychiatry, the psychosocial co-intervention was delivered by a nurse practitioner with a primary care background, and the trial may have implications for how psychosocial co-interventions could be provided in primary care settings.

In terms of implementing treatment programs for AUDs in primary care, we identified four other publications that did not meet our inclusion criteria (due to the study design or comparators) that may have important implications for primary care settings.228-231 While these studies found conflicting results, they demonstrated the feasibility of managing AUDs in primary care. In general, these interventions involve formal clinic structure, staffing, and protocols. They used variations of chronic care management, multidisciplinary team-based care, and care-coordination between primary care providers and mental health providers (e.g., physicians coordinating with social workers to connect patients to community resources or provide counseling).

First, a nested sequence of three U.S.-based RCTs compared naltrexone plus “primary care management” (PCM) with naltrexone plus cognitive behavioral therapy.228 PCM was provided by nurse practitioners, physician assistants, and one internist in an initial 45-minute visit, followed by 15- to 20-minute sessions in weeks 1, 2, 3, 4, 6, 8, and 10. The study found no difference in response to treatment, as measured by avoiding persistent heavy drinking, between those who received PCM and those who received cognitive behavioral therapy (84.1 percent versus 86.5 percent). Among responders enrolled in a maintenance trial, it found higher response for those who received naltrexone and PCM than for those who received placebo and PCM (80.8 percent versus 51.9 percent, p=0.03). Second, a pragmatic trial with 149 general practitioners in France who were “used to managing alcohol-dependent patients in their daily practice” randomized patients (N=422) to acamprosate plus standard care or standard care alone.229 Standard care in France was described as typically consisting of outpatient detoxification followed by a rehabilitation program (involving some type of psychotherapy). The trial reported better outcomes for the acamprosate group for the Alcohol-Related Problems Questionnaire score, the number of subjects with no alcohol-related problems, and for all secondary outcome measures, including QoL. Third, another U.S-based RCT (N=163) compared a primary-care based alcohol care management (ACM) program with a specialty outpatient addiction treatment program.230 A greater proportion of the ACM group received naltrexone than the specialty treatment group (65.9 percent versus 11.5 percent), the ACM group had a higher proportion of participants engaged in treatment over the 26 weeks (OR, 5.36; 95 % CI, 2.99 to 9.59), and the percentage of heavy drinking days was lower in the ACM group (OR, 2.16; 95 % CI, 1.27 to 3.66). Overall abstinence did not differ between groups. Fourth, the U.S.-based AHEAD trial (N=563) compared chronic care management (CCM) that included longitudinal care coordinated by a primary care clinician with no CCM for people with alcohol or drug dependence who were not currently engaged in primary care.231 Of those enrolled, 12 percent had alcohol dependence without also meeting criteria for other drug dependence. CCM included motivational enhancement therapy; relapse prevention counseling; on-site medical, addiction, and psychiatric treatment; social work assistance; and referrals. The no-CCM group received a primary care appointment and a list of treatment resources including a telephone number to arrange counseling. The trial found no difference between groups for the primary outcome of abstinence over 12 months.

Barriers to prescribing medications for AUDs in primary care may include lack of familiarity with the medications, lack of confidence in their effectiveness, or inability to provide suitable psychosocial co-interventions (e.g., due to competing demands or insufficient practice resources, personnel, or training). Like behavioral counseling interventions for risky drinking delivered in primary care, implementing the use of medications and psychosocial co-interventions for AUDs in primary care might require development of support systems and additional provider and staff training.13,232 Further, primary care providers are typically trained to refer patients with AUDs for specialized treatment. O'Malley and O'Connor recently reviewed the issues surrounding the use of medications for alcohol dependence in primary care settings.34 They concluded that “the implementation and widespread use of medications to treat alcohol problems faces a unique set of barriers in primary care. Although primary care providers are proficient at prescribing a wide variety of medications, they generally are unfamiliar with medications for treating alcohol problems other than those used to treat alcohol withdrawal.” They referenced a growing body of research to support basic screening methods, brief interventions, and especially medication therapy that has yet to have a major impact on how primary care providers care for individuals at risk for or with alcohol problems.233

### Subgroups and Genetic Polymorphisms

We did not find any convincing evidence that either naltrexone or acamprosate are more or less effective (compared with each other) for men or women, older adults, young adults, racial or ethnic minorities, smokers, or those with co-occurring disorders. We found no studies that assessed the clinical utility of genotype-guided dosing strategies or genotype-guided medication selection, and none that randomized by genotype. All included studies were either subgroup analyses of trials or prospective cohort studies of people treated with a medication, and all assessed the association between genotype and response to medication (i.e., clinical validity). For most polymorphism-medication pairs, we found just 1 eligible study, and we graded the SOE as insufficient.

We found 7 eligible studies assessing variation in naltrexone response related to mu-opioid receptor gene (OPRM1) polymorphisms. Our meta-analyses for return to any drinking and return to heavy drinking found no significant difference between A-allele homozygotes and those with at least one G allele, both without and with inclusion of studies rated as high or unclear risk of bias. Of note, the total number of subjects contributing data to the analyses was relatively low, and firm conclusions are limited by the imprecision of the results. Point estimates for return to heavy drinking suggest it is possible that patients with at least one G allele of A118G polymorphism of OPRM1 might be more likely to respond to naltrexone, but confidence intervals were wide; additional studies are needed to improve confidence in the estimate of the effect.

### Findings in Relation to What Is Already Known

Existing guidelines and systematic reviews support our main findings.16,37,38,46-48 As described in the introduction, the U.S. Department of Veterans Affairs (VA), National Institute on Alcohol Abuse and Alcoholism (NIAAA), and Substance Abuse and Mental Health Services Administration (SAMHSA) all have guidelines addressing the use of pharmacotherapy for alcohol dependence.46-48 The various guidelines recommend that naltrexone and/or acamprosate routinely be considered for patients with alcohol dependence in combination with addiction-focused counseling.

Whereas we did not find statistically significant effects on alcohol consumption outcomes for injectable naltrexone,fewer studies and subjects were available for injectable naltrexone; thus, analyses have less precision.

### Applicability

Most studies reported that all subjects met criteria for alcohol dependence. We did not identify any studies that evaluated medications and reported them to be efficacious for people with alcohol use disorders who did not meet criteria for alcohol dependence (i.e., people with alcohol abuse or harmful alcohol use). The included literature used definitions from DSM-III or DSM–IV. DSM-5 (2013) describes a single alcohol use disorder category measured on a continuum from mild to severe, and no longer has separate categories for alcohol abuse and dependence.12 Using DSM-5 terminology, most participants in the included studies likely had moderate to severe AUDs. Thus, applicability of our findings to people with mild AUDs is uncertain. The mean age of subjects was generally in the 40s, with very few studies enrolling slightly younger or older populations. Thus, it is uncertain whether the medications have similar efficacy for older (e.g., those 65 and older) or younger (e.g., in the 20s) subgroups as they have for patients enrolled in the trials. We did not find evidence to confirm or refute whether treatments are more or less efficacious for many other subgroups, including gender groups, racial or ethnic minorities, smokers or nonsmokers, and those with certain coexisting conditions.

Although the majority of included trials assessing the efficacy of acamprosate were conducted in Europe (16 of 22) and a minority were conducted in the United States (4 of 22), the opposite was true for naltrexone (27 of 44 in the United States and 8 of 44 in Europe). Further, the few studies of acamprosate conducted in the United States did not find it to be efficacious. It is unclear whether the different results were due to population differences or other factors. The European trials of acamprosate typically identified patients from inpatient settings or treatment programs, whereas the U.S.-based trials of acamprosate relied on advertisements and referrals. It is possible that this resulted in populations with differing AUD severity and differing potential for benefit. For example, studies of subjects recruited via advertisements may enroll people who have less severe disorders, and may be less applicable to patients with more severe forms of alcohol-use disorders.

Most studies required patients to abstain for at least a few days prior to initiating medication, and the medications are generally recommended for maintenance of abstinence. Acamprosate and injectable naltrexone are only approved for use in patients who have established abstinence, though the duration of required abstinence is not set. However, some studies enrolling patients who were not yet abstinent have reported reduction in heavy drinking with naltrexone97,234 or acamprosate.73

## Implications for Clinical and Policy Decisionmaking

Evidence supports the efficacy of more than one pharmacological treatment for AUDs, and clinical uncertainty exists about what treatment to select for individual patients. Acamprosate and naltrexone have the best evidence supporting their efficacy, but head-to-head trials have not consistently established superiority of either medication. Thus, other factors may contribute to medication choices, such as frequency of administration, cost, potential type of benefits, potential adverse events, and availability of treatments (e.g., acamprosate and injectable naltrexone227 are currently nonformulary medications for the VA).

For example, acamprosate is typically dosed as two 333 mg tablets given three times daily, whereas oral naltrexone is one tablet once daily, and injectable naltrexone is given once monthly. Acamprosate is contraindicated for people with severe renal impairment and requires dose adjustments for moderate renal impairment. Oral naltrexone is contraindicated for patients with acute hepatitis or liver failure, and for those currently using opioids or with anticipated need for opioids, and it can precipitate severe withdrawal for patients dependent on opioids (see Harms section above for injectable naltrexone contraindications). Trials of topiramate have reported a significantly increased risk of many adverse events, including paresthesias, taste perversion, anorexia, difficulty with concentration/attention, nervousness, dizziness, pruritis, psychomotor slowing, and weight loss.175,179

Given that medications for AUDs have been underutilized,45,235 entities providing health care for people with AUDs may need to develop systems to optimize dissemination and implementation. For example, these could include campaigns to educate providers about the use of medications for AUDs; systems to screen for unhealthy alcohol use and to provide appropriate interventions for people with unhealthy alcohol use; systems to ensure that people with AUDs have access to knowledgeable providers who can prescribe medications for AUDs; or systems to remind or incentivize providers to use effective medications for AUDs when appropriate.

Although we did not evaluate the effectiveness or comparative effectiveness of psychosocial interventions for alcohol use disorders (e.g., cognitive behavioral therapy, 12-step programs, combined behavioral intervention), such interventions have been evaluated within some of the included pharmacotherapy studies and in studies that were not included in our review. It may be important for decisionmakers to have information about the efficacy of psychosocial interventions from other sources. Further, decisionmakers may want information about the efficacy of medications when used independently of psychosocial interventions (which is limited) and when used together with them.

## Limitations of the Comparative Effectiveness Review Process

The scope of this review was focused on medications. We did not evaluate the effectiveness or comparative effectiveness of other interventions for alcohol use disorders (e.g., cognitive behavioral therapy, motivational enhancement therapy, 12-step programs). We required that trials have at least 12 weeks of followup from the time of medication initiation, excluding trials of shorter duration. Some might consider this approach to omit potentially important information from shorter trials. However, longitudinal studies have found that shorter treatment periods may yield misleading conclusions about treatment efficacy, due to fluctuations in drinking behavior that are typical of the course of AUDs236,237—suggesting that longer durations of followup might more accurately reflect the outcomes of greatest interest and importance.

Our review focused on benefits and harms of medications and how they compare with other medications, and our findings generally reflect the added benefits of medications beyond those of psychosocial co-interventions. However, studies used a variety of different psychosocial co-interventions, and this heterogeneity limits our certainty about the effect of medications when used alone (with no psychosocial co-intervention) or when added to a particular psychosocial intervention. Reporting of previous and ongoing psychosocial interventions was variable across the included studies and we were unable to determine whether subjects actually received some co-interventions (e.g., Alcoholics Anonymous was recommended, but no information was reported about how many subjects adhered to the recommendation).

We combined studies that described including populations with a dual diagnosis (e.g., alcohol dependence and depression) and those that did not in our meta-analyses. To determine whether this potential population heterogeneity would have a significant impact on our conclusions, we conducted sensitivity analyses for acamprosate and naltrexone (the medications with enough studies to conduct a stratified analysis by presence of dual diagnosis). Ultimately, the analyses were not very revealing and do not significantly impact our findings because there are so few studies that specify enrolling a population with dual diagnoses (just 1 trial for acamprosate and 6 for naltrexone that contributed data to any of our meta-analyses; see Appendix F). Effect sizes did not change significantly and were sometimes identical. The one possible exception, that might be considered a significant change in the effect size, was for heavy drinking days and naltrexone. When including all studies, subjects treated with naltrexone had 3.8 percent fewer heavy drinking days than those treated with placebo (WMD, -3.8; 95% CI, -5.8 to -1.8; 11 trials); when excluding 3 studies that enrolled patients with dual diagnoses, the effect size was slightly larger (WMD -4.9; 95% CI, -7.1 to -2.7; 8 trials). It might be somewhat artificial to separate studies that describe a dual diagnosis population from those that do not because many people with AUDs have additional psychiatric diagnoses and many studies don't report information on co-occurring diagnoses.

For KQ 5 (on subgroups), we did not review subgroup analyses from placebo-controlled trials. The question we aimed to answer was a comparative question. We were looking for direct evidence for whether any of the medications are more or less effective than other medications for certain subgroups. To be eligible, studies had to compare at least 2 medications.

Finally, publication bias and selective reporting are potential limitations. Although we searched for unpublished studies and unpublished outcomes, and did not find direct evidence of either of these biases, many of the included trials were published prior to the availability of trial registries (e.g., clinicaltrials.gov) that would allow for greater certainty in determining the potential for either type of bias.

## Limitations of the Evidence Base

The evidence base was inadequate to draw conclusions for some of our questions or subquestions of interest. In particular, as described above, we found insufficient direct evidence on health outcomes, limited and varying reporting on harms, few trials conducted in primary care settings, and scant head-to-head evidence on differences for population subgroups.

We found insufficient direct evidence to determine whether medications are efficacious for improving health outcomes. Although evidence from epidemiologic literature consistently relates high average and heavy per-occasion alcohol use to an increased risk of health problems, it is challenging to estimate the magnitude of reduction in the risk of health problems that is derived from a reduction in consumption. For example, it is unclear how much benefit (for health outcomes) is derived from 10 percent fewer patients returning to any drinking, or from 8 percent fewer patients returning to heavy drinking.

Many of the included trials had methodological limitations introducing some risk of bias. Some trials had high proportions of subjects lost to follow up. High attrition rates are not uncommon in studies of psychiatric conditions. Methods of handling missing data varied, and some trials did nothing to address missing data (i.e., only analyzing completers). However, many trials conducted true intention-to-treat analyses and used appropriate methods of handling missing data, such as imputing return to heavy drinking for subjects lost to followup or multiple imputation.

Reporting of previous treatments and ongoing treatments (i.e., co-interventions) was variable across the included studies. We were often unable to determine whether subjects had received any previous treatments for AUDs.

## Research Gaps

We identified numerous gaps in the evidence that future research could address. Many of these gaps are highlighted in the previous sections of this Discussion. Of note, these gaps relate only to the KQs addressed by this report, and they should not eliminate a wide range of potentially important research that falls outside of our scope. Table 39 summarizes the key gaps and potential future research that could address the gaps.

Table 39 Evidence gaps for future research by key question

KQ | Evidence Gap | Potential Future Research
1 | Evidence was insufficient to determine efficacy of some medications either because of inconsistency and imprecision or because we found 0 or just 1 small trial with low to medium risk of bias (e.g., amitryptiline, aripiprazole, atomoxetine, baclofen, buspirone, citalopram, desipramine, fluoxetine, fluvoxamine, imipramine, olanzapine, paroxetine, quetiapine). | Future studies could evaluate medications that have some evidence (often from 1 or 2 small trials) suggesting possible efficacy (e.g., baclofen) or medications that have not yet been studied with some theoretical basis to support their potential efficacy.
1 | We found no head-to-head studies of oral naltrexone and injectable naltrexone. | Future studies could compare the benefits of harms of oral and injectable naltrexone.
1 | Whether patients need to stop drinking before starting medications in order to benefit is somewhat unclear. Most studies required patients to abstain for at least a few days prior to initiating medication, but some studies enrolling patients who were not yet abstinent have reported reduction in heavy drinking with naltrexone97,234 or acamprosate.73 | Future studies could assess the efficacy of medications for patients who are not ready to abstain.
2 | We found insufficient^a^ direct evidence to conclude that treatment with acamprosate or naltrexone leads to improvement in health outcomes. | Future studies could focus on health outcomes, such as accidents, injuries, QoL, function, or mortality. These could include large prospective studies to evaluate harm and health consequences with various levels of drinking.
3 | Relatively few studies reported information about suicide, suicidal ideation, or self-harmful behaviors. | Additional studies could be conducted to determine whether precautions about suicide, suicidal thoughts, or self-harmful behaviors are warranted.
3 | Little evidence was available to determine whether naltrexone can be used for people with various liver conditions.^b^ | Future studies could evaluate the use of naltrexone for people with various chronic liver conditions.
4 | No eligible trials assessed the use of FDA-approved medications in primary care settings. | Future studies could evaluate the use of acamprosate and naltrexone in primary care settings.
5 | Evidence on whether any medications are more or less effective than other medications for population subgroups was scant. | Future studies could compare the use of acamprosate and naltrexone for subgroups of patients (e.g., enrolling subjects who all have depression or other psychiatric conditions; comparing effectiveness for men or women or among older or younger patients)
6 | Relatively few subjects contributed data to our analyses of variation in naltrexone response and OPRM1 polymorphisms. Patients with at least one G allele may be more likely to respond to naltrexone, but confidence intervals were wide and the effect was not statistically significant. | Additional studies are likely to change our confidence in the estimate of the effect and to change the estimate.
6 | No studies assessed the clinical utility of genotype-guided dosing strategies or genotype-guided medication selection, and none randomized by genotype. | If variation in naltrexone response by OPRM1 polymorphisms becomes established, then future studies could assess the clinical utility of using genotype-guided dosing strategies. For example, studies might compare the use of genotype-guided dosing strategies (e.g., use naltrexone for patients with at least one G allele, but use acamprosate for A-allele homozygotes) with using naltrexone or acamprosate for all subjects.
6 | Only 1 study was available for most polymorphism-medication response associations. | Future studies could explore other genotypic associations (i.e., not limiting future studies to OPRM1 polymorphisms).

FDA = U.S. Food and Drug Administration; OPRM1 = mu-opioid receptor gene; QoL = quality of life.

a Evidence was insufficient for health outcomes because we found no trials meeting inclusion/exclusion criteria rated as low or medium risk of bias (i.e., accidents and injuries) or mainly because of inconsistency and imprecision (i.e., quality of life and mortality). Very few trials reported any health outcomes, and the included trials were not designed or powered to assess impact on health outcomes—they typically focused on alcohol consumption outcomes.

b The FDA removed the black box warning for hepatotoxicity for injectable naltrexone, but it is unclear whether naltrexone should be used in people with various chronic liver conditions.

## Conclusions

Acamprosate and oral naltrexone (50 mg per day) are effective for improving alcohol consumption outcomes for patients with AUDs (moderate SOE). Numbers needed to treat (NNT) to prevent one person from returning to any drinking were 12 and 20, respectively; NNT to prevent one person from returning to heavy drinking was 12 for oral naltrexone (50 mg per day). Our meta-analyses of head-to-head trials found no statistically significant difference between the two medications for improvement in alcohol consumption outcomes (moderate SOE). Among medications used off-label, moderate evidence supports the efficacy of nalmefene and topiramate for improving some consumption outcomes, and limited evidence supports the efficacy of valproic acid. We found insufficient direct evidence to conclude whether medications for AUDs are effective for improving health outcomes. Evidence from primary care was scant. Evidence was generally insufficient to determine comparative effectiveness of acamprosate and naltrexone for subgroups.