# Additional Studies of Genetic Polymorphisms Meeting Inclusion Criteria but With Only One Study for a Drug-Polymorphism Pair

## Characteristics of Trials

Table G-1 summarizes characteristics of the six included studies. Five were analyses of subjects from randomized controlled trials, and one was a prospective cohort study of patients taking disulfiram.1 One of the trials compared naltrexone 50 mg/day with topiramate 50 to 400 mg/day;2 one was a three-arm study that compared acamprosate 1,998 mg/day, naltrexone 50 mg/day and placebo;3 the others were placebo-controlled trials of nalmefene 20 mg/day,4 olanzapine 5 mg/day,5 and sertraline 200 mg/day.6 Duration of treatment ranged from 12 to 28 weeks; one trial also reported three- and six-month off-treatment follow-up data.6 Two were conducted in the U.S.,5,6 two in Germany,1,3 and one each in Finland4 and Spain.2

Table G-1 Characteristics of included studies that assessed the association between genetic polymorphisms and medication response

Author, Year | Arm Dose, mg/day (N) | Genotypes Assessed | Medication Duration (F-u) | Setting | Age Years | Percentage Non-White | Percentage Female | Cointervention(s) | Risk of Bias
Arias, 2008^4^ | Nalmefene 20 (166) Placebo (106) | OPRM OPRD OPRK | 28 | Finland; Outpatient 15 sites | 49 to 50 | 0 | 20 | BRENDA 100% | High
Florez, 2008^2^ | Topiramate 50-400 (45) Naltrexone 50 (45) | DRD2 DRD3 HTR2A SLC6A | 26 | Spain; Outpatient | 46 | 0 | 13 | NR | High
Hutchison, 2006^5^ | Olanzapine 5 (33) Placebo (31) | DRD4 | 12 | U.S.; Outpatient clinical research center | 43 to 45 | 4 to 33 | 26 to 42 | Brief structured psychosocial intervention 100% | High
Kiefer, 2011^3^ | Acamprosate 1998 (147) Naltrexone 50 (148) Placebo (74) | GATA4 | 12 | Germany; Unclear | 45 | NR | NR | Medical management (CBI) 100% | High
Kranzler, 2012^6^ | Sertraline 200 intended, mean dose 169 (63) Placebo (71) | 5-HTTLPR a | 12 (26) | U.S.; Outpatient; university health center | 48 | 8 | 19 | CS 100% | Med
Mutschler, 2012^1^ | Disulfiram NR (62) | DBH b | 12 | Germany; SA treatment, Outpatient | 48 | NR | 32 | CBI 100% | High

a 5-HTTLPR is a polymorphism in the serotonin transporter gene. Variation at this locus includes higher-activity long (L) and lower-activity short (S) alleles.

b SNP tested was rs1611115, located in the promoter region of the DBH gene.

Notes: Age (y) is the mean age in years, unless otherwise stated

Abbreviations: CBI, combined behavioral intervention; CS, coping skills; DBH, dopamine beta-hydroxylase; DR, dopamine receptor; follow-up in weeks; HTR2A, serotonin 2A receptor; mg, milligrams; N = Number; NR, not reported; OPRD, δ-opioid receptor; OPRK, κ-opioid receptor; OPRM, μ-opioid receptor; prosp., prospective; SLC6A, dopamine transporter; SSGA, secondary or subgroup analysis of a randomized controlled trial; U.S., United States

Mean age was very similar across studies, in the 40s. All patients met criteria for alcohol dependence. Enrollment of women and non-White subjects, when reported, was generally low. None of the studies reported information on smoking history at baseline. Two studies reported co-occurring psychiatric conditions: in one, 23 percent had a personality disorder,2 and in the other, 26 percent had a concurrent drug use disorder.6 Co-interventions in the studies included BRENDA, combined behavioral interventions, and coping skills therapy. One study was rated medium risk of bias;6 the other five were rated high risk of bias.

In the three-arm study that compared acamprosate, naltrexone and placebo,3 the rs13273672 polymorphism in the GATA4 gene was associated with relapse. At the end of 90 days of treatment, fewer patients with AA genotype relapsed than patients with AG or GG (45.7 percent versus 53.9 percent versus 69.0 percent, p=0.0066). The polymorphism was associated with relapse for patients treated with acamprosate, but not for those who received naltrexone or placebo.

In the trial that compared sertraline with placebo, analyses examined the main and interaction effects with time of 3 factors—medication group, age of onset of alcohol dependence, and 5-HTTLPR genotype.6 The study reported differential effects for S' carriers and for L' homozygotes, with no significant effects in S' carriers. Late-onset (>25 years of age) alcoholics with the L'L' genotype who received sertraline had fewer drinking days at 12 weeks than those who received placebo (p=0.007), but there was no treatment difference in heavy drinking days. Early-onset L'L' individuals who received sertraline had more drinking days and more heavy drinking days (p=0.002 and p=0.004, respectively) at 12 weeks than those who received placebo. At three months off-treatment, late onset L'L' patients who had received sertraline continued to have fewer drinking days compared with placebo-treated patients (p=0.027).

The prospective cohort study of disulfiram revealed no significant gene-treatment interaction for time to relapse or cumulative abstinence between genotype groups based on the SNP rs1611115 of the DBH gene.1

## References for Appendix G

1 Mutschler J, Abbruzzese E, Witt SH, et al. Functional polymorphism of the dopamine β-hydroxylase gene is associated with increased risk of disulfiram-induced adverse effects in alcohol-dependent patients. J Clin Psychopharmacol. 2012;32(4):578-80. [pmid: 22760354].
2 Florez G, Saiz P, Garcia-Portilla P, et al. Association between the Stin2 VNTR polymorphism of the serotonin transporter gene and treatment outcome in alcohol-dependent patients. Alcohol Alcohol. Sep-Oct. 2008;43(5):516-22. [pmid: 18552399].
3 Kiefer F, Witt SH, Frank J, et al. Involvement of the atrial natriuretic peptide transcription factor GATA4 in alcohol dependence, relapse risk and treatment response to acamprosate. Pharmacogenomics J. Oct. 2011;11(5):368-74. [pmid: 20585342].
4 Arias AJ, Armeli S, Gelernter J, et al. Effects of opioid receptor gene variation on targeted nalmefene treatment in heavy drinkers. Alcohol Clin Exp Res. Jul. 2008;32(7):1159-66. [pmid: 18537939].
5 Hutchison KE, Ray L, Sandman E, et al. The effect of olanzapine on craving and alcohol consumption. Neuropsychopharmacology. Jun. 2006;31(6):1310-7. [pmid: 16237394].
6 Kranzler HR, Armeli S, Tennen H. Post-treatment outcomes in a double-blind, randomized trial of sertraline for alcohol dependence. Alcohol Clin Exp Res. Apr. 2012;36(4):739-44. [pmid: 21981418].