# Meta-Analyses

## Key Question 1 Meta-Analysis Results

Figure F-1 Acamprosate versus placebo: Return to any drinking by risk of bias rating

Note: doses combined for Mason, 2006, Paille, 1995, and Pelc, 1997.

Figure F-1 is titled, “Acamprosate versus Placebo: Return to Any Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 19 studies reporting rates of return to any drinking in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 16 studies rated low or medium risk of bias (ROB) found an RD of -0.09 with a 95% confidence interval (CI) of -0.14 to -0.04. Meta-analysis of the 3 studies rated high ROB found the RD (95% CI) to be -0.13 (-0.20 to -0.06) with an I-squared value of the overall meta-analysis equal to 15.1%.

Figure F-2 Acamprosate versus placebo: Return to any drinking by country

Note: doses combined for Mason, 2006, Paille, 1995, and Pelc, 1997.

Figure F-2 is titled, “Acamprosate versus Placebo: Return to Any Drinking by Country.” This figure displays a forest plot showing a meta-analysis of 16 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with acamprosate or placebo with the results stratified by country--United States versus other. A positive risk difference (RD) favors placebo. Meta-analysis of the 3 United States studies found an RD of 0.03 with a 95% confidence interval (CI) of -0.03 to 0.09 and an I-squared value of 60.0%. Meta-analysis of the 13 non-U.S. studies resulted in an RD (95% CI) of -0.12 (-0.16 to -0.08) with an I-squared of 59.0%.

Figure F-3 Acamprosate versus placebo: Return to any drinking by duration of treatment

Note: doses combined for Mason, 2006, Paille, 1995, and Pelc, 1997.

Figure F-3 is titled, “Acamprosate versus Placebo: Return to Any Drinking by Duration of Treatment.” This figure displays a forest plot showing a meta-analysis of 16 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with acamprosate or placebo with the results stratified by duration of treatment. A positive risk difference (RD) favors placebo. Meta-analysis of the six 12- to 16-week studies found an RD of -0.09 with a 95% confidence interval (CI) of -0.20 to 0.03 and an I-squared value of 80.6%. Meta-analysis of the six 24- to 26-week studies studies resulted in an RD (95% CI) of -0.07 (-0.16 to 0.01) with an I-squared of 86.1%. Meta-analysis of the four 48- to 52-week studies found an RD (95% CI) of -0.11 (-0.14 to -0.04) and an I-squared of 25.7%.

Figure F-4 Acamprosate versus placebo: Return to heavy drinking by risk of bias rating

Note: doses combined for Mason, 2006

Figure F-4 is titled, “Acamprosate versus Placebo: Return to Heavy Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 7 studies reporting rates of return to heavy drinking in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis found an RD of -0.01 with a 95% confidence interval (CI) of -0.04 to 0.03 and an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-5 Acamprosate versus placebo: Percent drinking days by risk of bias rating

Figure F-5 is titled, “Acamprosate versus Placebo: Percent Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 14 studies reporting percent drinking days in patients treated with acamprosate or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 13 studies rated low or medium risk of bias (ROB) found a WMD of -8.77 with a 95% confidence interval (CI) of -12.76 to -4.78. When the 1 study rated high ROB was included, we found the WMD (95% CI) to be -8.28 (-12.19 to -4.38) with an I-squared value of the overall meta-analysis equal to 67.5%.

Figure F-6 Acamprosate versus placebo: Percent drinking days by country

Figure F-6 is titled, “Acamprosate versus Placebo: Percent Drinking Days by Country.” This figure displays a forest plot showing a meta-analysis of 13 studies reporting percent drinking days in patients treated with acamprosate or placebo and stratified by country. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 3 U.S. studies found a WMD of -2.14 with a 95% confidence interval (CI) of -6.39 to 2.11 and an I-squared value of 30.7%. Meta-analysis of the 10 non-U.S. studies found the WMD (95% CI) to be -11.17 (-15.79 to -6.56) with an I-squared value of 62.8%.

Figure F-7 Acamprosate versus placebo: Percent drinking days by duration of treatment

Figure F-7 is titled, “Acamprosate versus Placebo: Percent Drinking Days by Duration of Treatment.” This figure displays a forest plot showing a meta-analysis of 13 studies rated low or medium risk of bias reporting percent drinking days in patients treated with acamprosate or placebo with the results stratified by duration of treatment. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the three 12- to 16-week studies found a WMD of -6.14 with a 95% confidence interval (CI) of -18.69 to 6.40 and an I-squared value of 79.2%. Meta-analysis of the six 24- to 26-week studies studies resulted in a WMD (95% CI) of -7.47 (-12.65 to -2.29) with an I-squared of 61.8%. Meta-analysis of the four 48- to 52-week studies found a WMD (95% CI) of -12.19 (-16.38 to -8.00) and an I-squared of 0.0%.

Figure F-8 Acamprosate versus placebo: Percent drinking days by dual diagnosis (low/medium risk of bias only)

Figure F-8 is titled, “Acamprosate versus Placebo: Percent Drinking Days by Dual Diagnosis (low/medium risk of bias).” This figure displays a forest plot showing a meta-analysis of 13 studies rated low or medium risk of bias reporting percent drinking days in patients treated with acamprosate or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the thirteen studies that did not include dually-diagnosed patients found a WMD of -8.77 with a 95% confidence interval (CI) of -12.76 to -4.78 and an I-squared value of 68.9%. There were no studies including dually-diagnosed patients for this outcome.

Figure F-9 Acamprosate versus placebo: Percent drinking days by dual diagnosis (all risk of bias)

Figure F-9 is titled, “Acamprosate versus Placebo: Percent Drinking Days by Dual Diagnosis (all risk of bias).” This figure displays a forest plot showing a meta-analysis of 14 studies reporting percent drinking days in patients treated with acamprosate or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the thirteen studies that did not include dually-diagnosed patients found a WMD of -8.77 with a 95% confidence interval (CI) of -12.76 to -4.78 and an I-squared value of 68.9%. One study rated high risk of bias enrolled dually-diagnosed patients; the WMD from that study was 3.70 with a 95% confidence interval of -12.50 to 19.50.

Figure F-10 Acamprosate versus placebo: Percent heavy drinking days by risk of bias

Figure F-10 is titled, “Acamprosate versus Placebo: Percent Heavy Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting percent heavy drinking days in patients treated with acamprosate or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found a WMD of -2.60 with a 95% confidence interval (CI) of -11.38 to 6.18. When the 1 study rated high ROB was included, we found the WMD (95% CI) to be -0.34 (-6.54 to 5.86) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-11 Acamprosate versus placebo: Percent heavy drinking days by dual diagnosis

Note: Berger is low/medium risk of bias; Ralevski is high risk of bias

Figure F-11 is titled, “Acamprosate versus Placebo: Percent Heavy Drinking Days by Dual Diagnosis.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting percent heavy drinking days in patients treated with acamprosate or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 1 study that did not include dually-diagnosed patients found a WMD of -2.60 with a 95% confidence interval (CI) of -11.38 to 6.18. Meta-analysis of the 1 study that did include dually-diagnosed patients found a WMD of 1.90 with a 95% confidence interval (CI) of -6.86 to 10.66.

Figure F-12 Acamprosate versus placebo: Drinks per drinking day by risk of bias

Figure F-12 is titled, “Acamprosate versus Placebo: Drinks per Drinking Day by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting drinks per drinking day in patients treated with acamprosate or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found a WMD of 0.40 with a 95% confidence interval (CI) of -1.81 to 2.61. When the 1 study rated high ROB was included, we found the WMD (95% CI) to be 0.60 (-1.43 to 2.64) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-13 Acamprosate versus placebo: Drinks per drinking day by dual diagnosis

Note: Morley is low/medium risk of bias; Ralevski is high risk of bias

Figure F-13 is titled, “Acamprosate versus Placebo: Drinks per Drinking Day by Dual Diagnosis.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting drinks per drinking day in patients treated with acamprosate or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 1 study that did not include dually-diagnosed patients found a WMD of 0.40 with a 95% confidence interval (CI) of -1.81 to 2.61. Meta-analysis of the 1 study that did include dually-diagnosed patients found a WMD (95% CI) to be 1.80 (-3.53 to 7.13) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-14 Disulfiram versus control: Return to any drinking by risk of bias

Note: Control - Fuller, 1979 and Fuller, 1986 control = Disulfiram 1 mg; Petrakis, 2005 control = placebo

Figure F-14 is titled, “Disulfiram versus Control: Return to Any Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of return to any drinking in patients treated with disulfiram or control. A positive risk difference (RD) favors control. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.04 with a 95% confidence interval (CI) of -0.03 to 0.11. When the 1 study rated high ROB was included, we found the RD (95% CI) to be -0.00 (-0.10 to 0.09) with an I-squared value of the overall meta-analysis equal to 38.1%.

Figure F-15 Disulfiram versus no disulfiram: Return to any drinking by risk of bias

Figure F-15 is titled, “Disulfiram versus No Disulfiram Return to Any Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of return to any drinking in patients treated with disulfiram or no disulfiram. A positive risk difference (RD) favors no disulfiram. Meta-analysis of the 2 studies found an RD of -0.04 with a 95% confidence interval (CI) of -0.11 to 0.03 and an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-16 Naltrexone versus placebo: Return to any drinking by risk of bias

Note: does not include Brown, 2009; doses combined for Garbutt, 2005; used data from Volpicelli 1995 (N=99) rather than the smaller subset (N=70) in Volpicelli 1992 to avoid double counting.

Figure F-16 is titled, “Naltrexone versus Placebo: Return to Any Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 25 studies reporting rates of return to any drinking in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 21 studies rated low or medium risk of bias (ROB) found an RD of -0.04 with a 95% confidence interval (CI) of -0.07 to -0.01. When the 4 studies rated high ROB were included [RD (95% CI) -0.9 (-0.19, 0.1)], we found the RD (95% CI) to be exactly the same with an I-squared value of the overall meta-analysis equal to 31.9%.

Figure F-17 Naltrexone versus placebo: Return to any drinking by country

Figure F-17 is titled, “Naltrexone versus Placebo: Return to Any Drinking by Country.” This figure displays a forest plot showing a meta-analysis of 21 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with naltrexone or placebo with the results stratified by country--United States versus other. A positive risk difference (RD) favors placebo. Meta-analysis of the 14 United States studies found an RD of -0.04 with a 95% confidence interval (CI) of -0.08 to -0.01 and an I-squared value of 23.5%. Meta-analysis of the 7 non-U.S. studies resulted in an RD (95% CI) of -0.04 (-0.11 to 0.03) with an I-squared of 55.8%.

Figure F-18 Naltrexone versus placebo: Return to any drinking by duration of treatment

Figure F-18 is titled, “Naltrexone versus Placebo: Return to Any Drinking by Duration of Treatment.” This figure displays a forest plot showing a meta-analysis of 21 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with naltrexone or placebo with the results stratified by duration of treatment. A positive risk difference (RD) favors placebo. Meta-analysis of the eighteen 12- to 16-week studies found an RD of -0.06 with a 95% confidence interval (CI) of -0.09 to -0.02 and an I-squared value of 25.1%. Meta-analysis of the three 24- to 26-week studies studies resulted in an RD (95% CI) of -0.00 (-0.03 to 0.03) with an I-squared of 0.0%.

Figure F-19 Naltrexone versus placebo: Return to any drinking by naltrexone dose

Note: Dose for Oslin, 1997 represents an average of 50 mg.day; study participants received 100 mg two times per week and 150 mg one time per week.

Figure F-19 is titled, “Naltrexone versus Placebo: Return to Any Drinking by Naltrexone Dose.” This figure displays a forest plot showing a meta-analysis of 21 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with naltrexone or placebo with the results stratified by dose of naltrexone. A positive risk difference (RD) favors placebo. Meta-analysis of the three 100 mg per day studies found an RD of -0.03 with a 95% confidence interval (CI) of -0.08 to 0.02 and an I-squared value of 0.0%. Meta-analysis of the sixteen 50 mg per day studies resulted in an RD (95% CI) of -0.05 (-0.10 to -0.00) with an I-squared of 46.4%. Meta-analysis of the two injectable naltrexone studies resulted in an RD (95% CI) of -0.04 (-0.10 to 0.03) with an I-squared of 58.5%.

Figure F-20 Naltrexone versus placebo: Return to any drinking by dual diagnosis (low/medium risk of bias only)

Figure F-20 is titled, “Naltrexone versus Placebo: Return to Any Drinking by Dual Diagnosis (low/medium risk of bias).” This figure displays a forest plot showing a meta-analysis of 21 studies rated low or medium risk of bias reporting return to any drinking in patients treated with naltrexone or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 19 studies that did not include dually-diagnosed patients found a WMD of -0.04 with a 95% confidence interval (CI) of -0.08 to -0.01 and an I-squared value of 41.8%. Meta-analysis of the 2 studies that did include dually-diagnosed patients found a WMD of 0.02 with a 95% confidence interval (CI) of -0.10 to 0.14 and an I-squared value of 0.0%.

Figure F-21 Naltrexone versus placebo: Return to any drinking by dual diagnosis (all risk of bias)

Figure F-21 is titled, “Naltrexone versus Placebo: Return to Any Drinking by Dual Diagnosis (all risk of bias).” This figure displays a forest plot showing a meta-analysis of 25 studies reporting return to any drinking in patients treated with naltrexone or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 23 studies that did not include dually-diagnosed patients found a WMD of -0.05 with a 95% confidence interval (CI) of -0.08 to -0.02 and an I-squared value of 37.0%. Meta-analysis of the 3 studies that did include dually-diagnosed patients found a WMD of 0.02 with a 95% confidence interval (CI) of -0.10 to 0.14 and an I-squared value of 0.0%.

Figure F-22 Naltrexone versus placebo: Return to heavy drinking by risk of bias

Note: Used data from Volpicelli 1995 (N=99) rather than the smaller subset (N=70) in Volpicelli 1992 to avoid double counting

Figure F-22 is titled, “Naltrexone versus Placebo: Return to Heavy Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 27 studies reporting rates of return to heavy drinking in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 23 studies rated low or medium risk of bias (ROB) found an RD of -0.07 with a 95% confidence interval (CI) of -0.11 to -0.03. When the 4 studies rated high ROB were included [RD (95% CI) -0.20 (-0.37, -0.3)], we found the RD (95% CI) to be -0.09 (-0.13 to -0.05) with an I-squared value of the overall meta-analysis equal to 53.0%.

Figure F-23 Naltrexone versus placebo: Return to heavy drinking by country

Figure F-23 is titled, “Naltrexone versus Placebo: Return to Heavy Drinking by Country.” This figure displays a forest plot showing a meta-analysis of 23 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with naltrexone or placebo with the results stratified by country--United States versus other. A positive risk difference (RD) favors placebo. Meta-analysis of the 13 United States studies found an RD of -0.08 with a 95% confidence interval (CI) of -0.12 to -0.04 and an I-squared value of 12.4%. Meta-analysis of the 10 non-U.S. studies resulted in an RD (95% CI) of -0.05 (-0.12 to 0.01) with an I-squared of 58.7%.

Figure F-24 Naltrexone versus placebo: Return to heavy drinking by duration of treatment

Figure F-24 is titled, “Naltrexone versus Placebo: Return to Heavy Drinking by Duration of Treatment.” This figure displays a forest plot showing a meta-analysis of 23 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with naltrexone or placebo with the results stratified by duration of treatment. A positive risk difference (RD) favors placebo. Meta-analysis of the twenty-one 12- to 16-week studies found an RD of -0.08 with a 95% confidence interval (CI) of -0.12 to -0.04 and an I-squared value of 41.2%. Meta-analysis of the two 24- to 26-week studies studies resulted in an RD (95% CI) of -0.00 (-0.07 to 0.07) with an I-squared of 0.0%.

Figure F-25 Naltrexone versus placebo: Return to heavy drinking by naltrexone dose

Note: Dose for Oslin, 1997 represents an average of 50 mg.day; study participants received 100 mg two times per week and 150 mg one time per week.

Figure F-25 is titled, “Naltrexone versus Placebo: Return to Heavy Drinking by Naltrexone Dose.” This figure displays a forest plot showing a meta-analysis of 23 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with naltrexone or placebo with the results stratified by dose of naltrexone. A positive risk difference (RD) favors placebo. Meta-analysis of the two 100 mg per day studies found an RD of -0.05 with a 95% confidence interval (CI) of -0.11 to 0.01 and an I-squared value of 0.0%. Meta-analysis of the nineteen 50 mg per day studies resulted in an RD (95% CI) of -0.09 (-0.13 to -0.04) with an I-squared of 43.7%. Meta-analysis of the two injectable naltrexone studies resulted in an RD (95% CI) of -0.01 (-0.14 to 0.13) with an I-squared of 72.2%.

Figure F-26 Naltrexone versus placebo: Return to heavy drinking by dual diagnosis (low/medium risk of bias only)

Figure F-26 is titled, “Naltrexone versus Placebo: Return to Heavy Drinking by Dual Diagnosis (low/medium risk of bias).” This figure displays a forest plot showing a meta-analysis of 23 studies rated low or medium risk of bias reporting return to heavy drinking in patients treated with naltrexone or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 23 studies that did not include dually-diagnosed patients found a WMD of -0.07 with a 95% confidence interval (CI) of -0.11 to -0.03 and an I-squared value of 41.5%. No studies rated low or medium risk of bias enrolled dually-diagnosed patients.

Figure F-27 Naltrexone versus placebo: Return to heavy drinking by dual diagnosis (all risk of bias)

Figure F-27 is titled, “Naltrexone versus Placebo: Return to Heavy Drinking by Dual Diagnosis (all risk of bias).” This figure displays a forest plot showing a meta-analysis of 27 studies reporting return to heavy drinking in patients treated with naltrexone or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 26 studies that did not include dually-diagnosed patients found a WMD of -0.08 with a 95% confidence interval (CI) of -0.12 to -0.04 and an I-squared value of 52.8%. Meta-analysis of the 1 study that did include dually-diagnosed patients found a WMD of -0.28 with a 95% confidence interval (CI) of -0.55 to -0.01.

Figure F-28 Naltrexone versus placebo: Percent drinking days by risk of bias

Note: Brown, 2009 not included

Figure F-28 is titled, “Naltrexone versus Placebo: Percent Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 22 studies reporting percent drinking days in patients treated with naltrexone or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 19 studies rated low or medium risk of bias (ROB) found a WMD of -4.57 with a 95% confidence interval (CI) of -6.61 to -2.53. When the 3 studies rated high ROB were included, we found the WMD (95% CI) to be -4.41 (-6.36 to -2.47) with an I-squared value of the overall meta-analysis equal to 51.3%.

Figure F-29 Naltrexone versus placebo: Percent drinking days by country

Figure F-29 is titled, “Naltrexone versus Placebo: Percent Drinking Days by Country.” This figure displays a forest plot showing a meta-analysis of 19 studies reporting percent drinking days in patients treated with naltrexone or placebo and stratified by country. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 14 U.S. studies found a WMD of -4.51 with a 95% confidence interval (CI) of -6.79 to -2.22 and an I-squared value of 64.9%. Meta-analysis of the 5 non-U.S. studies found the WMD (95% CI) to be -4.67 (-9.63 to 0.29) with an I-squared value of 0.0%.

Figure F-30 Naltrexone versus placebo: Percent drinking days by duration of treatment

Figure F-30 is titled, “Naltrexone versus Placebo: Percent Drinking Days by Duration of Treatment.” This figure displays a forest plot showing a meta-analysis of 19 studies rated low or medium risk of bias reporting percent drinking days in patients treated with naltrexone or placebo with the results stratified by duration of treatment. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the seventeen 12- to 16-week studies found a WMD of -4.69 with a 95% confidence interval (CI) of -6.80 to -2.59 and an I-squared value of 54.5%. Meta-analysis of the two 24- to 26-week studies studies resulted in a WMD (95% CI) of -4.05 (-13.11 to 5.01) with an I-squared of 57.8%.

Figure F-31 Naltrexone versus placebo: Percent drinking days by naltrexone dose

Note: Dose for Oslin, 1997 represents an average of 50 mg.day; study participants received 100 mg two times per week and 150 mg one time per week.

Figure F-31 is titled, “Naltrexone versus Placebo: Percent Drinking Days by Naltrexone Dose.” This figure displays a forest plot showing a meta-analysis of 19 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with naltrexone or placebo with the results stratified by dose of naltrexone. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the two 100 mg per day studies found a WMD of -0.86 with a 95% confidence interval (CI) of -4.20 to 2.47 and an I-squared value of 0.0%. Meta-analysis of the one 150 mg per day study resulted in a WMD (95% CI) of -2.30 (-6.85 to 2.25). Meta-analysis of the fifteen 50 mg per day studies resulted in a WMD (95% CI) of -5.38 (-7.52 to -3.24) with an I-squared of 41.2%. Meta-analysis of the one injectable naltrexone study resulted in a WMD (95% CI) of -8.60 (-16.01 to -1.19).

Figure F-32 Naltrexone versus placebo: Percent drinking days by dual diagnosis (low/medium risk of bias)

Figure F-32 is titled, “Naltrexone versus Placebo: Percent Drinking Days by Dual Diagnosis (low/medium risk of bias).” This figure displays a forest plot showing a meta-analysis of 19 studies rated low or medium risk of bias reporting percent drinking days in patients treated with naltrexone or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 16 studies that did not include dually-diagnosed patients found a WMD of -4.89 with a 95% confidence interval (CI) of -7.13 to -2.64 and an I-squared value of 53.4%. Meta-analysis of the 3 studies that did include dually-diagnosed patients found a WMD of -2.67 with a 95% confidence interval (CI) of -5.75 to 0.41 and an I-squared value of 0.0%.

Figure F-33 Naltrexone versus placebo: Percent drinking days by dual diagnosis (all risk of bias)

Figure F-33 is titled, “Naltrexone versus Placebo: Percent Drinking Days by Dual Diagnosis (all risk of bias).” This figure displays a forest plot showing a meta-analysis of 22 studies reporting percent drinking days in patients treated with naltrexone or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 18 studies that did not include dually-diagnosed patients found a WMD of -4.97 with a 95% confidence interval (CI) of -7.11 to -2.82 and an I-squared value of 47.2%. Meta-analysis of the 4 studies that did include dually-diagnosed patients found a WMD of -2.26 with a 95% confidence interval (CI) of -5.04 to 0.53 and an I-squared value of 0.0%.

Figure F-34 Naltrexone versus placebo: Percent heavy drinking days by risk of bias

Figure F-34 is titled, “Naltrexone versus Placebo: Percent Heavy Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 13 studies reporting percent drinking days in patients treated with naltrexone or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 11 studies rated low or medium risk of bias (ROB) found a WMD of -3.81 with a 95% confidence interval (CI) of -5.85 to -1.78. When the 2 studies rated high ROB were included [WMD (95% CI) -8.63 (-22.88, 5.62)], we found the WMD (95% CI) to be -3.92 (-5.86 to -1.97) with an I-squared value of the overall meta-analysis equal to 54.0%.

Figure F-35 Naltrexone versus placebo: Percent heavy drinking days by country

Figure F-35 is titled, “Naltrexone versus Placebo: Percent Heavy Drinking Days by Country.” This figure displays a forest plot showing a meta-analysis of 11 studies reporting percent drinking days in patients treated with naltrexone or placebo and stratified by country. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 9 U.S. studies found a WMD of -3.66 with a 95% confidence interval (CI) of -5.78 to -1.55 and an I-squared value of 66.1%. Meta-analysis of the 2 non-U.S. studies found the WMD (95% CI) to be -5.87 (-16.73 to 5.17) with an I-squared value of 52.0%.

Figure F-36 Naltrexone versus placebo: Percent heavy drinking days by duration of treatment

Figure F-36 is titled, “Naltrexone versus Placebo: Percent Heavy Drinking Days by Duration of Treatment.” This figure displays a forest plot showing a meta-analysis of 11 studies rated low or medium risk of bias reporting percent drinking days in patients treated with naltrexone or placebo with the results stratified by duration of treatment. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the eight 12- to 16-week studies found a WMD of -3.53 with a 95% confidence interval (CI) of -5.98 to -1.08 and an I-squared value of 68.4%. Meta-analysis of the three 24- to 26-week studies studies resulted in a WMD (95% CI) of -4.46 (-8.43 to -0.50) with an I-squared of 32.8%.

Figure F-37 Naltrexone versus placebo: Percent heavy drinking days by naltrexone dose

Figure F-37 is titled, “Naltrexone versus Placebo: Percent Heavy Drinking Days by Naltrexone Dose.” This figure displays a forest plot showing a meta-analysis of 11 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with naltrexone or placebo with the results stratified by dose of naltrexone. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the two 100 mg per day studies found a WMD of -3.07 with a 95% confidence interval (CI) of -5.84 to -0.30 and an I-squared value of 0.0%. Meta-analysis of the one 150 mg per day study resulted in a WMD (95% CI) of -2.72 (-6.16 to 0.72). Meta-analysis of the six 50 mg per day studies resulted in a WMD (95% CI) of -4.13 (-7.64 to -0.61) with an I-squared of 74.1%. Meta-analysis of the two injectable naltrexone studies resulted in a WMD (95% CI) of -4.55 (-8.53 to -0.56) and an I-squared of 0.0%

Figure F-38 Naltrexone versus placebo: Percent heavy drinking days by dual diagnosis (low/medium risk of bias)

Figure F-38 is titled, “Naltrexone versus Placebo: Percent Heavy Drinking Days by Dual Diagnosis (low/medium risk of bias).” This figure displays a forest plot showing a meta-analysis of 11 studies rated low or medium risk of bias reporting percent heavy drinking days in patients treated with naltrexone or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 8 studies that did not include dually-diagnosed patients found a WMD of -4.91 with a 95% confidence interval (CI) of -7.13 to -2.69 and an I-squared value of 43.2%. Meta-analysis of the 3 studies that did include dually-diagnosed patients found a WMD of -2.02 with a 95% confidence interval (CI) of -4.01 to -0.03 and an I-squared value of 0.0%.

Figure F-39 Naltrexone versus placebo: Percent heavy drinking days by dual diagnosis (all risk of bias)

Figure F-39 is titled, “Naltrexone versus Placebo: Percent Heavy Drinking Days by Dual Diagnosis (all risk of bias).” This figure displays a forest plot showing a meta-analysis of 13 studies reporting percent heavy drinking days in patients treated with naltrexone or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 10 studies that did not include dually-diagnosed patients found a WMD of -5.15 with a 95% confidence interval (CI) of -7.13 to -3.17 and an I-squared value of 28.1%. Meta-analysis of the 3 studies that did include dually-diagnosed patients found a WMD of -2.02 with a 95% confidence interval (CI) of -4.01 to -0.03 and an I-squared value of 0.0%.

Figure F-40 Naltrexone versus placebo: Drinks per drinking day by risk of bias

Note: Monti, 2001 and Krystal, 2001 are rated High risk of bias for this outcome because of attrition

Figure F-40 is titled, “Naltrexone versus Placebo: Drinks per Drinking Day by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 16 studies reporting drinks per drinking day in patients treated with naltrexone or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 11 studies rated low or medium risk of bias (ROB) found a WMD of -0.54 with a 95% confidence interval (CI) of -1.01 to -0.07. When the 5 studies rated high ROB were included [WMD (95% CI) -1.39 (-2.97, 0.20)], we found the WMD (95% CI) to be -0.85 (-1.44 to -0.26) with an I-squared value of the overall meta-analysis equal to 66.3%.

Figure F-41 Naltrexone versus placebo: Drinks per drinking day by country

Figure F-41 is titled, “Naltrexone versus Placebo: Drinks per Drinking Day by Country.” This figure displays a forest plot showing a meta-analysis of 11 studies reporting percent drinking days in patients treated with naltrexone or placebo and stratified by country. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 8 U.S. studies found a WMD of -0.60 with a 95% confidence interval (CI) of -1.39 to 0.19 and an I-squared value of 49.4%. Meta-analysis of the 3 non-U.S. studies found the WMD (95% CI) to be -0.48 (-0.97 to 0.00) with an I-squared value of 0.0%.

Figure F-42 Naltrexone versus placebo: Drinks per drinking day by duration of treatment

Figure F-42 is titled, “Naltrexone versus Placebo: Drinks per Drinking Day by Duration of Treatment.” This figure displays a forest plot showing a meta-analysis of 11 studies rated low or medium risk of bias reporting percent drinking days in patients treated with naltrexone or placebo with the results stratified by duration of treatment. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the nine 12- to 16-week studies found a WMD of -0.64 with a 95% confidence interval (CI) of -1.12 to -0.16 and an I-squared value of 35.4%. Meta-analysis of the two 24- to 26-week studies resulted in a WMD (95% CI) of 0.53 (-0.96 to 2.02) with an I-squared of 0.0%.

Figure F-43 Naltrexone versus placebo: Drinks per drinking day by naltrexone dose

Figure F-43 is titled, “Naltrexone versus Placebo: Drinks per Drinking Day by Naltrexone Dose.” This figure displays a forest plot showing a meta-analysis of 11 studies rated low or medium risk of bias reporting rates of return to any drinking in patients treated with naltrexone or placebo with the results stratified by dose of naltrexone. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the one 100 mg per day study found a WMD of 1.86 with a 95% confidence interval (CI) of -1.47 to 5.19. Meta-analysis of the one 150 mg per day study resulted in a WMD (95% CI) of -1.70 (-3.29 to -0.11). Meta-analysis of the nine 50 mg per day studies resulted in a WMD (95% CI) of -0.49 (-0.92 to -0.06) with an I-squared of 24.9%.

Figure F-44 Naltrexone versus placebo: Drinks per drinking day by dual diagnosis (low/medium risk of bias)

Figure F-44 is titled, “Naltrexone versus Placebo: Drinks per Drinking Day by Dual Diagnosis (low/medium risk of bias).” This figure displays a forest plot showing a meta-analysis of 11 studies rated low or medium risk of bias reporting percent drinks per drinking day in patients treated with naltrexone or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 9 studies that did not include dually-diagnosed patients found a WMD of -0.47 with a 95% confidence interval (CI) of -0.93 to -0.01 and an I-squared value of 31.6%. Meta-analysis of the 2 studies that did include dually-diagnosed patients found a WMD of -0.90 with a 95% confidence interval (CI) of -4.35 to 2.55 and an I-squared value of 28.1%.

Figure F-45 Naltrexone versus placebo: Drinks per drinking day by dual diagnosis (all risk of bias)

Figure F-45 is titled, “Naltrexone versus Placebo: Drinks per Drinking Day by Dual Diagnosis (all risk of bias).” This figure displays a forest plot showing a meta-analysis of 16 studies reporting drinks per drinking day in patients treated with naltrexone or placebo with the results stratified by enrollment of dual-diagnosis patients. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 12 studies that did not include dually-diagnosed patients found a WMD of -0.84 with a 95% confidence interval (CI) of -1.48 to -0.20 and an I-squared value of 70.8%. Meta-analysis of the 4 studies that did include dually-diagnosed patients found a WMD of -0.72 with a 95% confidence interval (CI) of -2.54 to 1.09 and an I-squared value of 49.3%.

Figure F-46 Acamprosate versus naltrexone: Return to any drinking by risk of bias

Figure F-46 is titled, “Acamprosate versus Naltrexone: Return to Any Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of return to any drinking in patients treated with acamprosate or naltrexone. A positive risk difference (RD) favors naltrexone. Meta-analysis of the 3 studies rated low or medium risk of bias (ROB) found an RD of 0.02 with a 95% confidence interval (CI) of -0.03 to 0.08 and an I-squared value of 0.0%.

Figure F-47 Acamprosate versus naltrexone: Return to heavy drinking by risk of bias

Figure F-47 is titled, “Acamprosate versus Naltrexone: Return to Heavy Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 4 studies reporting rates of return to heavy drinking in patients treated with acamprosate or naltrexone. A positive risk difference (RD) favors naltrexone. Meta-analysis of the 4 studies rated low or medium risk of bias (ROB) found an RD of 0.01 with a 95% confidence interval (CI) of -0.05 to 0.06 and an I-squared value of 0.0%.

Figure F-48 Acamprosate versus naltrexone: Percent drinking days by risk of bias

Figure F-48 is titled, “Acamprosate versus Naltrexone: Percent Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting percent drinking days in patients treated with acamprosate or naltrexone. A positive weighted mean difference (WMD) favors naltrexone. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -2.98 with a 95% confidence interval (CI) of -13.42 to 7.45 and an I-squared value of 64.6%.

Figure F-49 Buspirone versus placebo: Return to any drinking by risk of bias

Figure F-49 is titled, “Buspirone versus Placebo: Return to Any Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of return to any drinking in patients treated with buspirone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of 0.07 with a 95% confidence interval (CI) of -0.19 to 0.34. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.04 (-0.13 to 0.22) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-50 Fluoxetine versus placebo: Return to any drinking by risk of bias

Figure F-50 is titled, “Fluoxetine versus Placebo: Return to Any Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of return to any drinking in patients treated with fluoxetine or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of -0.13 with a 95% confidence interval (CI) of -0.35 to 0.10. When the 1 study rated high ROB was included, we found the RD (95% CI) to be -0.02 (-0.29 to 0.26) with an I-squared value of the overall meta-analysis equal to 44.7%.

Figure F-51 Valproic acid versus placebo: Return to heavy drinking by risk of bias

Figure F-51 is titled, “Valproic Acid versus Placebo: Return to Any Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of return to any drinking in patients treated with valproic acid or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of -0.32 with a 95% confidence interval (CI) of -0.52 to -0.11 and an I-squared value of 0.0%.

Figure F-52 Nalmefene versus placebo: Return to heavy drinking by risk of bias

Figure F-52 is titled, “Nalmefene versus Placebo: Return to Heavy Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of return to heavy drinking in patients treated with nalmefene or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of -0.23 with a 95% confidence interval (CI) of -0.43 to -0.03. When the 1 study rated high ROB was included, we found the RD (95% CI) to be -0.20 (-0.38 to -0.02) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-53 Sertraline versus placebo: Return to heavy drinking by risk of bias

Figure F-53 is titled, “Sertraline versus Placebo: Return to Heavy Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of return to heavy drinking in patients treated with sertraline or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of -0.04 with a 95% confidence interval (CI) of -0.31 to 0.23 and an I-squared value of 67.4%.

Figure F-54 Buspirone versus placebo: Percent drinking days by risk of bias

Figure F-54 is titled, “Buspirone versus Placebo: Percent Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting percent drinking days in patients treated with buspirone or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -3.39 with a 95% confidence interval (CI) of -9.23 to 2.44 and an I-squared value of 47.0%.

Figure F-55 Fluoxetine versus placebo: Percent drinking days by risk of bias

Figure F-55 is titled, “Fluoxetine versus Placebo: Percent Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting percent drinking days in patients treated with fluoxetine or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -3.15 with a 95% confidence interval (CI) of -18.17 to 11.87 and an I-squared value of 82.7%.

Figure F-56 Nalmefene versus placebo: Percent drinking days by risk of bias

Figure F-56 is titled, “Nalmefene versus Placebo: Percent Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting percent drinking days in patients treated with nalmefene or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -1.12 with a 95% confidence interval (CI) of -7.63 to 5.39 and an I-squared value of 44.8%.

Figure F-57 Quetiapine versus placebo: Percent drinking days by risk of bias

Figure F-57 is titled, “Quetiapine versus Placebo: Percent Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting percent drinking days in patients treated with quetiapine or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 3 studies rated high risk of bias (ROB) found a WMD of -2.67 with a 95% confidence interval (CI) of -12.81 to 7.47 and an I-squared value of 74.4%.

Figure F-58 Sertraline versus placebo: Percent drinking days by risk of bias

Figure F-58 is titled, “Sertraline versus Placebo: Percent Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting percent drinking days in patients treated with sertraline or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 3 studies rated low or medium risk of bias (ROB) found a WMD of 1.80 with a 95% confidence interval (CI) of -6.25 to 9.86. Meta-analysis including the 1 study rated high risk of bias (ROB) found a WMD of 0.64 with a 95% confidence interval (CI) of -5.71 to 6.99 and an I-squared value of 0.0%.

Figure F-59 Topiramate versus placebo: Percent drinking days by risk of bias

Figure F-59 is titled, “Topiramate versus Placebo: Percent Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting percent drinking days in patients treated with topiramate or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found a WMD of -8.50 with a 95% confidence interval (CI) of -15.88 to -1.12. Meta-analysis including the 1 study rated high risk of bias (ROB) found a WMD of -9.72 with a 95% confidence interval (CI) of -16.36 to -3.09 and an I-squared value of 0.0%.

Figure F-60 Valproic acid versus placebo: Percent drinking days by risk of bias

Figure F-60 is titled, “Valproic Acid versus Placebo: Percent Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting percent drinking days in patients treated with valproic acid or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -8.51 with a 95% confidence interval (CI) of -15.92 to -1.09 and an I-squared value of 0.0%.

Figure F-61 Nalmefene versus placebo: Change in heavy drinking days over the past month by risk of bias; observed cases (OC) analysis

Figure F-61 is titled, “Nalmefene versus Placebo: Change in Heavy Drinking Days Over the Past Month by Risk of Bias; Observed Cases (OC) Analysis.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting change in heavy drinking days over the past month in patients treated with nalmefene or placebo, using an observed cases analysis. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -1.98 with a 95% confidence interval (CI) of -3.01 to -0.96. Meta-analysis including the 1 study rated high risk of bias (ROB) found a WMD of -1.83 with a 95% confidence interval (CI) of -2.65 to -1.01 and an I-squared value of 0.0%.

Figure F-62 Nalmefene versus placebo: Change in heavy drinking days over the past month by risk of bias; placebo mean imputation (PMI) analysis

Figure F-62 is titled, “Nalmefene versus Placebo: Change in Heavy Drinking Days Over the Past Month by Risk of Bias; Placebo Mean Imputation (PMI) Analysis.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting change in heavy drinking days over the past month in patients treated with nalmefene or placebo, using a placebo mean imputation analysis. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -1.25 with a 95% confidence interval (CI) of -2.23 to -0.27 and an I-squared value of 0.0%.

Figure F-63 Quetiapine versus placebo: Percent heavy drinking days by risk of bias

Figure F-63 is titled, “Quetiapine versus Placebo: Percent Heavy Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting percent heavy drinking days in patients treated with quetiapine or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 3 studies rated high risk of bias (ROB) found a WMD of -3.07 with a 95% confidence interval (CI) of -10.10 to 3.97 and an I-squared value of 68.7%.

Figure F-64 Sertraline versus placebo: Percent heavy drinking days by risk of bias

Figure F-64 is titled, “Sertraline versus Placebo: Percent Heavy Drinking Days by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting percent heavy drinking days in patients treated with sertraline or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of 1.85 with a 95% confidence interval (CI) of 0.70 to 3.00 and an I-squared value of 0.0%.

Figure F-65 Topiramate versus placebo: Percent heavy drinking days; low and medium risk of bias

Figure F-65 is titled, “Topiramate versus Placebo: Percent Heavy Drinking Days, Low and Medium Risk of Bias.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting percent heavy drinking days in patients treated with topiramate or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -11.53 with a 95% confidence interval (CI) of -18.29 to -4.77.

Figure F-66 Topiramate versus placebo: Percent heavy drinking days; sensitivity analysis

Figure F-66 is titled, “Topiramate versus Placebo: Percent Heavy Drinking Days, Sensitivity Analysis.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting percent heavy drinking days in patients treated with topiramate or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 3 studies found a WMD of -12.54 with a 95% confidence interval (CI) of -17.93 to -7.16.

Figure F-67 Valproic acid versus placebo: Drinks per drinking day by risk of bias

Figure F-67 is titled, “Valproic Acid versus Placebo: Drinks per Drinking Day by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting drinks per drinking day in patients treated with valproic acid or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -2.56 with a 95% confidence interval (CI) of -4.97 to -0.15 and an I-squared value of 0.0%.

Figure F-68 Fluoxetine versus placebo: Drinks per drinking day by risk of bias

Figure F-68 is titled, “Fluoxetine versus Placebo: Drinks per Drinking Day by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting drinks per drinking day in patients treated with fluoxetine or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -1.20 with a 95% confidence interval (CI) of -4.63 to 2.23 and an I-squared value of 78.3%.

Figure F-69 Nalmefene versus placebo: Drinks per drinking day by risk of bias

Figure F-69 is titled, “Nalmefene versus Placebo: Drinks per Drinking Day by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting drinks per drinking day in patients treated with nalmefene or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 3 studies rated low or medium risk of bias (ROB) found a WMD of -1.02 with a 95% confidence interval (CI) of -1.77 to -0.28 and an I-squared value of 0.0%.

Figure F-70 Sertraline versus placebo: Drinks per drinking day by risk of bias

Figure F-70 is titled, “Sertraline versus Placebo: Drinks per Drinking Day by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting drinks per drinking day in patients treated with sertraline or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -0.86 with a 95% confidence interval (CI) of -2.19 to 0.48 and an I-squared value of 6.6%.

Figure F-71 Topiramate versus placebo: Drinks per drinking day, low/medium risk of bias studies

Figure F-71 is titled, “Topiramate versus Placebo: Drinks per Drinking Day, Low/Medium Risk of Bias Studies.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting drinks per drinking day in patients treated with topiramate or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found a WMD of -1.10 with a 95% confidence interval (CI) of -1.75 to -0.45.

WMD: -1.098, 95% CI (-1.747 to -0.449)

Heterogeneity
Q-value | df (Q) | P-value | I-squared
0.156202 | 1 | 0.692677 | 0

Figure F-72 Topiramate versus placebo: Drinks per drinking day, sensitivity analysis with high risk of bias study

Figure F-72 is titled, “Topiramate versus Placebo: Drinks per Drinking Day, Sensitivity Analysis with High Risk of Bias Study.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting drinks per drinking day in patients treated with topiramate or placebo. A positive weighted mean difference (WMD) favors placebo. Meta-analysis of the 3 studies found a WMD of -1.18 with a 95% confidence interval (CI) of -1.81 to -0.55.

WMD: -1.179, 95% CI (-1.806 to -0.552)

Heterogeneity
Q-value | df (Q) | P-value | I-squared
1.043611 | 2 | 0.593448 | 0

## Key Question 3 Meta-Analysis Results

We found insufficient data for all included medications to perform meta-analyses for the following harms: Glaucoma, Metabolic Acidosis, Palpitations

Figure F-73 Anxiety – Acamprosate versus placebo by risk of bias rating

Figure F-73 is titled, “Anxiety--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of anxiety in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. The 1 study rated low or medium risk of bias (ROB) found an RD of 0.16 with a 95% confidence interval (CI) of 0.10 to 0.23. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.16 (0.09 to 0.22) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-74 Anxiety – Naltrexone versus placebo by risk of bias rating

Figure F-74 is titled, “Anxiety--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 9 studies reporting rates of anxiety in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 7 studies rated low or medium risk of bias (ROB) found an RD of 0.01 with a 95% confidence interval (CI) of -0.02 to 0.04. When the 2 studies rated high ROB were included, we found the RD (95% CI) to be exactly the same with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-75 Cognitive dysfunction – Nalmefene versus placebo by risk of bias rating

Figure F-75 is titled, “Cognitive dysfunction--Nalmefene compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of cognitive dysfunction in patients treated with nalmefene or placebo. A positive risk difference (RD) favors placebo. The 1 study rated low or medium risk of bias (ROB) found an RD of 0.05 with a 95% confidence interval (CI) of 0.01 to 0.09. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.03 (-0.03 to 0.08) with an I-squared value of the overall meta-analysis equal to 81.9%.

Figure F-76 Cognitive dysfunction – Topiramate versus placebo by risk of bias

* Note: Values from Johnson, 2007 are from data reported as “difficulty with memory;” the study also reported data for “difficulty with concentration,” which also favored placebo.

Figure F-76 is titled, “Cognitive dysfunction--Topiramate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of cognitive dysfunction in patients treated with topiramate or placebo. A positive risk difference (RD) favors placebo. Both studies were rated low or medium risk of bias (ROB); we found the RD (95% CI) to be 0.08 (0.01 to 0.16) with an I-squared value of the overall meta-analysis equal to 38.5%.

Figure F-77 Diarrhea – Acamprosate versus placebo by risk of bias rating

Figure F-77 is titled, “Diarrhea--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 14 studies reporting rates of diarrhea in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 12 studies rated low or medium risk of bias (ROB) found an RD of 0.10 with a 95% confidence interval (CI) of 0.03 to 0.17. When the 2 studies rated high ROB were included, we found the RD (95% CI) to be 0.09 (0.04 to 0.15) with an I-squared value of the overall meta-analysis equal to 85.8%.

Figure F-78 Diarrhea – Naltrexone versus placebo by risk of bias rating

Figure F-78 is titled, “Diarrhea--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 12 studies reporting rates of diarrhea in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 11 studies rated low or medium risk of bias (ROB) found an RD of 0.01 with a 95% confidence interval (CI) of -0.01 to 0.04. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.01 (-0.02 to 0.03) with an I-squared value of the overall meta-analysis equal to 30.2%.

Figure F-79 Diarrhea – Acamprosate versus naltrexone by risk of bias rating

Figure F-79 is titled, “Diarrhea--Acamprosate compared with Naltrexone by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 5 studies reporting rates of diarrhea in patients treated with acamprosate or naltrexone A positive risk difference (RD) favors naltrexone Meta-analysis of the 4 studies rated low or medium risk of bias (ROB) found an RD of 0.18 with a 95% confidence interval (CI) of -0.02 to 0.37. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.14 (-0.07 to 0.35) with an I-squared value of the overall meta-analysis equal to 96.0%.

Figure F-80 Diarrhea – Nalmefene versus placebo by risk of bias rating

Figure F-80 is titled, “Diarrhea--Nalmefene compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of diarrhea in patients treated with nalmefene or placebo. A positive risk difference (RD) favors placebo. Both studies were rated low or medium risk of bias (ROB); we found the RD (95% CI) to be -0.03 (-0.06 to -0.01) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-81 Diarrhea – Topiramate compared with placebo by risk of bias rating

Figure F-81 is titled, “Diarrhea--Topiramate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of diarrhea in patients treated with topiramate or placebo. A positive risk difference (RD) favors placebo. The 1 study rated low or medium risk of bias (ROB) found an RD of 0.04 with a 95% confidence interval (CI) of -0.03 to 0.10. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.00 (-0.07 to 0.08) with an I-squared value of the overall meta-analysis equal to 61.1%.

Figure F-82 Dizziness – Acamprosate versus placebo by risk of bias rating

Figure F-82 is titled, “Dizziness--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of dizziness in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Both studies were rated low or medium risk of bias (ROB); we found the RD (95% CI) to be 0.08 (-0.22 to 0.38) with an I-squared value of the overall meta-analysis equal to 80.3%.

Figure F-83 Dizziness – Naltrexone versus placebo by risk of bias rating

Figure F-83 is titled, “Dizziness--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 17 studies reporting rates of dizziness in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 13 studies rated low or medium risk of bias (ROB) found an RD of 0.06 with a 95% confidence interval (CI) of 0.04 to 0.09. When the 4 studies rated high ROB were included, we found the RD (95% CI) to be 0.06 (0.04 to 0.08) with an I-squared value of the overall meta-analysis equal to 27.1%.

Figure F-84 Dizziness – Acamprosate versus naltrexone by risk of bias rating

Figure F-84 is titled, “Dizziness--Acamprosate compared with Naltrexone by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of dizziness in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.08 with a 95% confidence interval (CI) of -0.23 to 0.39 and an I-squared value of 81.7%. When the 1 study rated high ROB was included, we found the RD (95% CI) to be -0.03 (-0.19 to 0.13) with an I-squared value of the overall meta-analysis equal to 82.4%.

Figure F-85 Dizziness – Nalmefene versus placebo by risk of bias rating

Figure F-85 is titled, “Dizziness--Nalmefene compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 6 studies reporting rates of dizziness in patients treated with nalmefene or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 4 studies rated low or medium risk of bias (ROB) found an RD of 0.16 with a 95% confidence interval (CI) of 0.11 to 0.21. When the 2 studies rated high ROB were included, we found the RD (95% CI) to be 0.14 (0.10 to 0.18) with an I-squared value of the overall meta-analysis equal to 53.5%.

Figure F-86 Dizziness – Topiramate versus placebo by risk of bias rating

Figure F-86 is titled, “Dizziness--Topiramate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of dizziness in patients treated with topiramate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.10 with a 95% confidence interval (CI) of -0.01 to 0.22. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.08 (0.01 to 0.14) with an I-squared value of the overall meta-analysis equal to 51.5%.

Figure F-87 Headache – Acamprosate versus placebo by risk of bias rating

Figure F-87 is titled, “Headache--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 7 studies reporting rates of headache in patients treated with acamprosate or placebo A positive risk difference (RD) favors placebo. Meta-analysis of the 6 studies rated low or medium risk of bias (ROB) found an RD of 0.00 with a 95% confidence interval (CI) of -0.05 to 0.05 When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.00 (-0.04 to 0.04) with an I-squared value of the overall meta-analysis equal to 60.2%.

Figure F-88 Headache – Naltrexone versus placebo by risk of bias rating

Figure F-88 is titled, “Headache--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 22 studies reporting rates of headache in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 17 studies rated low or medium risk of bias (ROB) found an RD of 0.01 with a 95% confidence interval (CI) of -0.02 to 0.03. When the 5 studies rated high ROB were included, we found the RD (95% CI) to be 0.00 (-0.02 to 0.03) with an I-squared value of the overall meta-analysis equal to 20.9%.

Figure F-89 Headache – Acamprosate versus naltrexone by risk of bias rating

Figure F-89 is titled, “Headache--Acamprosate compared with Naltrexone by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 4 studies reporting rates of headache in patients treated with acamprosate or naltrexone. A positive risk difference (RD) favors naltrexone. Meta-analysis of the 3 studies rated low or medium risk of bias (ROB) found an RD of -0.06 with a 95% confidence interval (CI) of -0.12 to 0.01 When the 1 study rated high ROB as included, we found the RD (95% CI) to be -0.09 (-0.16 to -0.01) with an I-squared value of the overall meta-analysis equal to 36.3%.

Figure F-90 Headache – Nalmefene versus placebo by risk of bias rating

Figure F-90 is titled, “Headache--Nalmefene compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 4 studies reporting rates of headache in patients treated with nalmefene or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 3 studies rated low or medium risk of bias (ROB) found an RD of 0.04 with a 95% confidence interval (CI) of 0.01 to 0.07. When the 1 study rated high ROB was included, we found the RD (95% CI) to be exactly the same with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-91 Insomnia – Acamprosate versus placebo by risk of bias rating

Figure F-91 is titled, “Insomnia--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 4 studies reporting rates of insomnia in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 3 studies rated low or medium risk of bias (ROB) found an RD of 0.02 with a 95% confidence interval (CI) of -0.10 to 0.14. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.02 (-0.06 to 0.09) with an I-squared value of the overall meta-analysis equal to 63.8%.

Figure F-92 Insomnia – Naltrexone versus placebo by risk of bias rating

Figure F-92 is titled, “Insomnia--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 12 studies reporting rates of insomnia in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 8 studies rated low or medium risk of bias (ROB) found an RD of 0.03 with a 95% confidence interval (CI) of -0.00 to 0.06. When the 4 studies rated high ROB were included, we found the RD (95% CI) to be 0.03 (0.00 to 0.05) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-93 Insomnia – Acamprosate versus naltrexone by risk of bias rating

Figure F-93 is titled, “Insomnia--Acamprosate compared with Naltrexone by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of insomnia in patients treated with acamprosate or naltrexone. A positive risk difference (RD) favors naltrexone. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.07 with a 95% confidence interval (CI) of -0.20 to 0.34. and an I-squared value equal to 65.5%.

Figure F-94 Insomnia – Nalmefene versus placebo by risk of bias rating

Figure F-94 is titled, “Insomnia--Nalmefene compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 6 studies reporting rates of insomnia in patients treated with nalmefene or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 5 studies rated low or medium risk of bias (ROB) found an RD of 0.10 with a 95% confidence interval (CI) of 0.06 to 0.14 . When the 1 study rated high ROB as included, we found the RD (95% CI) to be 0.09 (0.06 to 0.12) with an I-squared value of the overall meta-analysis equal to 34.9%.

Figure F-95 Insomnia – Topiramate versus placebo by risk of bias rating

Figure F-95 is titled, “Insomnia--Topiramate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of insomnia in patients treated with topiramate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of 0.03 with a 95% confidence interval (CI) of -0.05 to 0.11 . When the 1 study rated high ROB as included, we found the RD (95% CI) to be 0.03 (-0.03 to 0.10) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-96 Nausea – Acamprosate versus placebo by risk of bias rating

Figure F-96 is titled, “Nausea--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 8 studies reporting rates of nausea in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 7 studies rated low or medium risk of bias (ROB) found an RD of 0.01 with a 95% confidence interval (CI) of -0.01 to 0.02. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.01 (-0.01 to 0.03) with an I-squared value of the overall meta-analysis equal to 12.5%.

Figure F-97 Nausea – Naltrexone versus placebo by risk of bias rating

*Footnote: Kranzler, 2009 combines events reported by targeted and daily naltrexone and by targeted and daily placebo

Figure F-97 is titled, “Nausea--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 31 studies reporting rates of nausea in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 24 studies rated low or medium risk of bias (ROB) found an RD of 0.11 with a 95% confidence interval (CI) of 0.07 to 0.15. When the 7 studies rated high ROB were included, we found the RD (95% CI) to be 0.10 (0.07 to 0.13) with an I-squared value of the overall meta-analysis equal to 65.9%.

Figure F-98 Nausea – Acamprosate versus naltrexone by risk of bias rating

Figure F-98 is titled, “Nausea--Acamprosate compared with Naltrexone by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 6 studies reporting rates of nausea in patients treated with acamprosate or naltrexone. A positive risk difference (RD) favors naltrexone. Meta-analysis of the 4 studies rated low or medium risk of bias (ROB) found an RD of -0.08 with a 95% confidence interval (CI) of -0.18 to 0.02. When the 2 studies rated high ROB were included, we found the RD (95% CI) to be -0.10 (-0.18 to -0.02) with an I-squared value of the overall meta-analysis equal to 71.6%.

Figure F-99 Nausea – Nalmefene versus placebo by risk of bias rating

Figure F-99 is titled, “Nausea--Nalmefene compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 6 studies reporting rates of nausea in patients treated with nalmefene or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 5 studies rated low or medium risk of bias (ROB) found an RD of 0.16 with a 95% confidence interval (CI) of 0.10 to 0.22. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.16 (0.11 to 0.21) with an I-squared value of the overall meta-analysis equal to 69.8%.

Figure F-100 Nausea – Topiramate versus placebo by risk of bias rating

Figure F-100 is titled, “Nausea--Topiramate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of nausea in patients treated with topiramate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of -0.06 with a 95% confidence interval (CI) of -0.13 to 0.01 . When the 1 study rated high ROB was included, we found the RD (95% CI) to be -0.02 (-0.11 to 0.06) with an I-squared value of the overall meta-analysis equal to 62.0%.

Figure F-101 Numbness – Acamprosate versus placebo by risk of bias rating

Figure F-101 is titled, “Numbness--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of numbness in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of 0.01 with a 95% confidence interval (CI) of -0.01 to 0.03. When the 1 study rated high ROB was included, we found the RD (95% CI) to be exactly the same with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-102 Numbness – Naltrexone versus placebo by risk of bias rating

Figure F-102 is titled, “Numbness--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of numbness in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of -0.01 with a 95% confidence interval (CI) of -0.19 to 0.17. When the 1 study rated high ROB was included, we found the RD (95% CI) to be -0.02 (-0.08 to 0.04) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-103 Numbness – Topiramate versus placebo by risk of bias rating

Figure F-103 is titled, “Numbness--Topiramate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of numbness in patients treated with topiramate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.40 with a 95% confidence interval (CI) of 0.32 to 0.47. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.29 (0.05 to 0.52) with an I-squared value of the overall meta-analysis equal to 93.1%.

Figure F-104 Rash – Acamprosate versus placebo by risk of bias rating

Figure F-104 is titled, “Rash--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of rash in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of 0.11 with a 95% confidence interval (CI) of -0.06 to 0.28. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.07 (-0.01 to 0.16) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-105 Rash – Naltrexone versus placebo by risk of bias rating

Figure F-105 is titled, “Rash--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 5 studies reporting rates of rash in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 4 studies rated low or medium risk of bias (ROB) found an RD of -0.01 with a 95% confidence interval (CI) of -0.06 to 0.04. When the 1 study rated high ROB was included, we found the RD (95% CI) to be -0.02 (-0.06 to 0.02) with an I-squared value of the overall meta-analysis equal to 21.5%.

Figure F-106 Suicide attempts/suicidal ideation – Acamprosate versus placebo by risk of bias rating

Figure F-106 is titled, “Suicidal Ideation--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of suicidal ideation in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of 0.01 with a 95% confidence interval (CI) of -0.00 to 0.02. When the 2 studies rated high ROB were included, we found the RD (95% CI) to be 0.00 (-0.01 to 0.01) with an I-squared value of the overall meta-analysis equal to 14.6%.

Figure F-107 Suicide attempts/suicidal ideation – Nalmefene versus placebo by risk of bias rating

Figure F-107 is titled, “Suicidal Ideation--Nalmefene compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of suicidal ideation in patients treated with nalmefene or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of -0.01 with a 95% confidence interval (CI) of -0.02 to 0.00. When the 1 study rated high ROB was included, we found the RD (95% CI) to be -0.00 (-0.01 to 0.01) with an I-squared value of the overall meta-analysis equal to 39.2%.

Figure F-108 Vision changes (blurred vision) – Naltrexone versus placebo by risk of bias rating

Figure F-108 is titled, “Vision Changes--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of blurred vision in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.08 with a 95% confidence interval (CI) of -0.17 to 0.33 and an I-squared value equal to 46.3%.

Figure F-109 Vomiting – Acamprosate versus placebo by risk of bias rating

Figure F-109 is titled, “Vomiting--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 5 studies reporting rates of vomiting in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 4 studies rated low or medium risk of bias (ROB) found an RD of 0.02 with a 95% confidence interval (CI) of 0.01 to 0.04 . When the 1 study rated high ROB was included, we found the RD (95% CI) to be exactly the same with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-110 Vomiting – Naltrexone versus placebo by risk of bias rating

Figure F-110 is titled, “Vomiting--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 11 studies reporting rates of vomiting in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 9 studies rated low or medium risk of bias (ROB) found an RD of 0.04 with a 95% confidence interval (CI) of 0.02 to 0.06 . When the 2 studies rated high ROB were included, we found the RD (95% CI) to be exactly the same with an I-squared value of the overall meta-analysis equal to 1.1%.

Figure F-111 Vomiting – Acamprosate versus naltrexone by risk of bias rating

Figure F-111 is titled, “Vomiting--Acamprosate compared with Naltrexone by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 2 studies reporting rates of vomiting in patients treated with acamprosate or naltrexone. A positive risk difference (RD) favors naltrexone. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of -0.06 with a 95% confidence interval (CI) of -0.11 to -0.01 and an I-squared value equal to 0.0%.

Figure F-112 Vomiting – Nalmefene versus placebo by risk of bias rating

Figure F-112 is titled, “Vomiting--Nalmefene compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 4 studies reporting rates of vomiting in patients treated with nalmefene or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 3 studies rated low or medium risk of bias (ROB) found an RD of 0.06 with a 95% confidence interval (CI) of 0.02 to 0.10 . When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.07 (0.03 to 0.11) with an I-squared value of the overall meta-analysis equal to 76.2%.

Figure F-113 Withdrawals due to adverse events – Acamprosate versus placebo by risk of bias rating

Figure F-113 is titled, “Withdrawals due to Adverse Events (AEs)--Acamprosate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 16 studies reporting rates of withdrawal due to AEs in patients treated with acamprosate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 13 studies rated low or medium risk of bias (ROB) found an RD of 0.01 with a 95% confidence interval (CI) of -0.00 to 0.02. When the 3 studies rated high ROB were included, we found the RD (95% CI) to be 0.01 (0.00 to 0.01) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-114 Withdrawals due to adverse events – Naltrexone versus placebo by risk of bias rating

Figure F-114 is titled, “Withdrawals due to Adverse Events (AEs)--Naltrexone compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 20 studies reporting rates of withdrawal due to AEs in patients treated with naltrexone or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 17 studies rated low or medium risk of bias (ROB) found an RD of 0.02 with a 95% confidence interval (CI) of 0.01 to 0.03. When the 3 studies rated high ROB were included, we found the RD (95% CI) to be exactly the same with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-115 Withdrawals due to adverse events – Acamprosate versus naltrexone by risk of bias rating

Figure F-115 is titled, “Withdrawals due to Adverse Events (AEs)--Acamprosate compared with Naltrexone by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of withdrawal due to AEs in patients treated with acamprosate or naltrexone. A positive risk difference (RD) favors naltrexone. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.01 with a 95% confidence interval (CI) of -0.04 to 0.07. When the 1 study rated high ROB as included, we found the RD (95% CI) to be 0.00 (-0.04 to 0.04) with an I-squared value of the overall meta-analysis equal to 64.5%.

Figure F-116 Withdrawals due to adverse events – Nalmefene versus placebo by risk of bias rating

Figure F-116 is titled, “Withdrawals due to Adverse Events (AEs)--Nalmefene compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 7 studies reporting rates of withdrawal due to AEs in patients treated with nalmefene or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 5 studies rated low or medium risk of bias (ROB) found an RD of 0.08 with a 95% confidence interval (CI) of 0.02 to 0.15. When the 2 studies rated high ROB were included, we found the RD (95% CI) to be 0.08 (0.04 to 0.12) with an I-squared value of the overall meta-analysis equal to 79.5%.

Figure F-117 Withdrawals due to adverse events – Topiramate versus placebo by risk of bias rating

Figure F-117 is titled, “Withdrawals due to Adverse Events (AEs)--Topiramate compared with Placebo by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of withdrawal due to AEs in patients treated with topiramate or placebo. A positive risk difference (RD) favors placebo. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.06 with a 95% confidence interval (CI) of -0.12 to 0.25. When the 1 study rated high ROB was included, we found the RD (95% CI) to be 0.06 (-0.06 to 0.18) with an I-squared value of the overall meta-analysis equal to 86.9%.

## Key Question 6 Meta-Analysis Results

Figure F-118 Return to any drinking: Naltrexone response by genotype, AA versus AG, GG by risk of bias rating

Figure F-118 is titled, “Naltrexone (NTX) response by genotype: Return to Any Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of return to any drinking in patients treated with naltrexone by genotype--AA versus AG or GG. A positive risk difference (RD) favors AG/GG. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of -0.03 with a 95% confidence interval (CI) of -0.59 to 0.54. When the 2 studies rated high ROB were included, we found the RD (95% CI) to be 0.01 (-0.19 to 0.21) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-119 Return to any drinking: Naltrexone response by genotype, AA versus AG, GG; Sensitivity Analysis I

Note: This SA is with imputing bad outcome (return to any drinking) for those dropped from Kim results that they reported.

Main analysis used Kim data reported by the article for the 32/63 who were adherent to NTX for 12 weeks; SA run with importing bad outcome for those lost (9 more for AA group and 22 more for the G carrier group)

Figure F-119 is titled, “Naltrexone (NTX) response by genotype: Sensitivity Analysis I.” This figure displays a forest plot showing a meta-analysis of 3 studies reporting rates of return to any drinking in patients treated with naltrexone by genotype--AA versus AG or GG--with imputation of bad outcome for the dropped observations in one of the high ROB studies. A positive risk difference (RD) favors AG/GG. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of -0.03 with a 95% confidence interval (CI) of -0.59 to 0.54. When the 2 studies rated high ROB were included, we found the RD (95% CI) to be -0.06 (-0.22 to 0.11) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-120 Return to any drinking: Naltrexone response by genotype, AA versus AG, GG; Sensitivity Analysis II

Note: Added Oslin 2003 (which did not meet inclusion criteria): Oslin 2003: Despite the main effect of genotype in the naltrexone-treated group, there was no medication by genotype interaction on relapse rates (OR 2.27 (95% CI: 0.44, 11.60, P 0.326). There was also no medication by genotype interaction for abstinence OR 0.89 (95% CI: 0.18, 4.38), P 0.889). Of note, there was a significant effect of naltrexone in reducing rates of relapse in the overall pooled sample even when genotype was included in the regression analysis (OR 2.42 (95% CI: 1.09, 5.39), p 0.030)

Figure F-120 is titled, “Naltrexone (NTX) response by genotype: Sensitivity Analysis II.” This figure displays a forest plot showing a meta-analysis of 4 studies reporting rates of return to any drinking in patients treated with naltrexone by genotype--AA versus AG or GG. It includes results from one study which did not meet our inclusion criteria. A positive risk difference (RD) favors AG/GG. Meta-analysis of the 1 study rated low or medium risk of bias (ROB) found an RD of -0.03 with a 95% confidence interval (CI) of -0.59 to 0.54. When the 3 studies rated high ROB were included, we found the RD (95% CI) to be 0.03 (-0.13 to 0.18) with an I-squared value of the overall meta-analysis equal to 0.0%.

Figure F-121 Return to heavy drinking: Naltrexone response by genotype, AA versus AG, GG by risk of bias rating (RoB)

Figure F-121 is titled, “Naltrexone (NTX) response by genotype: Return to Heavy Drinking by Risk of Bias Rating.” This figure displays a forest plot showing a meta-analysis of 5 studies reporting rates of return to heavy drinking in patients treated with naltrexone by genotype--AA versus AG or GG. A positive risk difference (RD) favors AG/GG. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.26 with a 95% confidence interval (CI) of -0.01 to 0.53. When the 3 studies rated high ROB were included, we found the RD (95% CI) to be 0.14 (-0.03 to 0.30) with an I-squared value of the overall meta-analysis equal to 54.9%.

Figure F-122 Return to heavy drinking: Naltrexone response by genotype, AA versus AG, GG; Sensitivity Analysis I

Note: This sensitivity analysis done with imputing bad outcome for Kim, 2009 missing data

Figure F-122 is titled, “Naltrexone (NTX) response by genotype: Return to Heavy Drinking: Sensitivity Analysis I.” This figure displays a forest plot showing a meta-analysis of 5 studies reporting rates of return to heavy drinking in patients treated with naltrexone by genotype--AA versus AG or GG--with imputation of bad outcome for the dropped observations in one of the high ROB studies. A positive risk difference (RD) favors AG/GG. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.26 with a 95% confidence interval (CI) of -0.01 to 0.53. When the 3 studies rated high ROB were included, we found the RD (95% CI) to be 0.08 (-0.10 to 0.27) with an I-squared value of the overall meta-analysis equal to 66.2%.

Figure F-123 Return to heavy drinking: Naltrexone response by genotype, AA versus AG, GG; Sensitivity Analysis II

Note: Added Oslin, 2003 (which did not meet inclusion criteria)

Figure F-123 is titled, “Naltrexone (NTX) response by genotype: Return to Heavy Drinking: Sensitivity Analysis II.” This figure displays a forest plot showing a meta-analysis of 6 studies reporting rates of return to heavy drinking in patients treated with naltrexone by genotype--AA versus AG or GG. It includes results from one study which did not meet our inclusion criteria. A positive risk difference (RD) favors AG/GG. Meta-analysis of the 2 studies rated low or medium risk of bias (ROB) found an RD of 0.26 with a 95% confidence interval (CI) of -0.01 to 0.53. When the 4 studies rated high ROB were included, we found the RD (95% CI) to be 0.16 (0.02 to 0.29) with an I-squared value of the overall meta-analysis equal to 43.9%.