# Placebo-Controlled Trials of Medications Used Off-Label or Those Under Investigation for Which We Found Only One Trial Meeting Inclusion Criteria

## Aripiprazole

### Characteristics of Trials

Table E-1 summarizes characteristics of the one trial meeting our inclusion criteria.1 It was conducted across 16 academic centers in the U.S. and compared aripiprazole, titrated from 2 mg/day to 30 mg/day over the initial four weeks, with placebo. All participants (N=295) received an enhanced form of cognitive behavioral therapy. The recruitment method was not reported. All patients were alcohol-dependent, and the proportions of smokers and of patients with co-occurring conditions were not reported.

Table E-1 Characteristics of included double-blind randomized placebo-controlled trials of aripiprazole

Author, Year | Arm Dose, mg/day (N) | Medication Duration (Followup) | Country | Setting | Age Years | Percentage Non-White | Percentage Female | Co-intervention(s) | Risk of Bias
Anton, 2008^1^ | Aripiprazole titrated from 2 to 30 over 4 wks (149) Placebo (146) | 12 | U.S. | 16 academic centers | 47 | 15 to 16 | 25 to 38 | Enhanced CBT 100% | Med

Notes: Age (y) is the mean age in years, unless otherwise stated

Abbreviations: CBT = cognitive behavioral therapy; mg = milligrams; U.S. = United States; wks = weeks

#### Return to Any Drinking

More patients treated with aripiprazole returned to any drinking than with placebo (89 percent versus 78 percent, p=0.02).

#### Return to Heavy Drinking

The proportion returning to heavy drinking did not differ between groups (73 percent versus 73 percent).

#### Drinking Days

Patients treated with aripiprazole drank on a mean of 41 percent of days; patients treated with placebo drank on 37 percent of days. The difference was not statistically significant.

#### Drinks per Drinking Day

Patients treated with aripiprazole reported fewer drinks per drinking day than patients treated with placebo (4.4 versus 5.5, p<0.001).

## Atomoxetine

### Characteristics of Trials

Table E-2 summarizes characteristics of the one trial meeting our inclusion criteria.2 It was a multi-institutional study conducted in the U.S. and Canada. Investigators compared atomoxetine, titrated from 25 mg/day to 100 mg/day, with placebo. The mean final dose for atomoxetine was 89.9mg. Twelve-step program attendance was allowed, but all other types of co-intervention were prohibited. The recruitment method was not reported. Slightly more than half of the patients met criteria for alcohol dependence, and all patients were diagnosed with attention deficit hyperactivity disorder (ADHD). The proportion of smokers was not reported. The study was rated as high risk of bias, primarily for high risk of attrition bias and inadequate handling of missing data (see Appendix C for details).

Table E-2 Characteristics of included double-blind randomized placebo-controlled trials of atomoxetine

Author, Year | Arm Dose, mg/day (N) | Medication Duration (Follow-up) | Country | Setting | Age Years | Percentage Non-White | Percentage F | Percentage With Co-Occurring Condition(s) | Risk of Bias
Wilens, 2008^2^ | Atomoxetine titrated from 25 to 100 (72) Placebo (75) | 12 | U.S. and Canada | Multi-institution | 35 | 12 | 15 | 100 (ADHD) | High

Notes: Age (y) is the mean age in years, unless otherwise stated

Abbreviations: ADHD, attention deficit hyperactivity disorder; mg, milligrams; Rx = prescription; U.S., United States

#### Return to Heavy Drinking

The trial found no significant difference between groups. (94 percent for patients treated with atomoxetine versus 96 percent for patients taking placebo).

#### Drinking Days

Patients treated with atomoxetine drank on roughly 50 percent of days; patients treated with placebo drank on roughly 60 percent of days. The difference between groups was not statistically significant.

#### Heavy Drinking Days

Atomoxetine-treated patients had a 26 percent lower rate of heavy drinking days compared with placebo (event ratio=0.74, p=0.02).

#### Drinks per Drinking Day

The reduction in drinks per drinking day from baseline was not significantly different between groups (1.1 for the atomoxetine group versus 0.6 for the placebo group, p NS).

## Desipramine

### Characteristics of Trials

Table E-3 summarizes characteristics of the one trial meeting our inclusion criteria.3 It was conducted in the outpatient psychiatry departments at two urban medical centers in the U.S. Investigators compared desipramine (median dose=200 mg/day) with placebo. No co-interventions were required, though Alcoholics Anonymous attendance was encouraged. Patients were recruited through inpatient and outpatient psychiatric referrals and via public service announcements. All patients met criteria for alcohol dependence, and 39 percent were also diagnosed with depression. The proportion of smokers was not reported. The study was rated as high risk of bias, primarily for high risk of attrition bias and inadequate handling of missing data (see Appendix C for details).

Table E-3 Characteristics of included double-blind randomized placebo-controlled trials of desipramine

Author, Year | Arm Dose, mg/day (N) | Medication Duration (follow-up) | Country | Setting | Age Years | Percentage Non-White | Percentage Female | Percentage With Co-Occurring Condition(s) | Risk of Bias
Mason, 1996^3^ | Desipramine median 200 (37) Placebo (34) | 26 | U.S. | Psychiatry outpatient departments at 2 urban medical centers | Median=40 | 38 | 17 | Depression 39% | High

Notes: Age (y) is the mean age in years, unless otherwise stated

Abbreviations: U.S. = United States; wks = weeks

#### Return to Heavy Drinking

In this study, a return to heavy drinking was defined as two heavy drinking days per week for two consecutive weeks. Twelve percent of patients in the desipramine arm returned to heavy drinking, compared with 32 percent of patients taking placebo. The difference between groups was not statistically significant.

#### Drinking Days

Non-depressed patients treated with desipramine (N=14) drank on a median of 68 percent of days; non-depressed patients treated with placebo (N=15) drank on 72 percent of days (p NS). Depressed patients treated with desipramine (N=12) drank on a median of 40 percent of days; depressed patients treated with placebo (N=10) drank on 64 percent of days (p NS).

## Fluvoxamine

### Characteristics of Trials

Table E-4 summarizes characteristics of the one trial meeting our inclusion criteria.4 It was conducted in ten outpatient sites in four European countries. Investigators compared fluvoxamine 100-300 mg/day with placebo. In addition, patients received each site's usual psychosocial treatment. Recruitment method was not reported. All patients met criteria for alcohol dependence; the study did not report the proportion of patients with co-occurring conditions. The proportions of smokers and non-white participants were not reported.

Table E-4 Characteristics of Included double-blind randomized placebo-controlled trials of fluvoxamine

Author, Year | Arm Dose, mg/day (N) | Medication Duration (Follow-up) | Country | Setting | Age Years | Percentage Female | Risk of Bias
Chick, 2004^4^ | Fluvoxamine 100-300 (261) Placebo (260) | 52 | U.K., Eire, Austria, Switzerland | 10 outpatient sites | 42 (19-72) | 35 | Med

Notes: Age (y) is the mean age in years, unless otherwise stated

Abbreviations: mg = milligram; N = number; U.K. = United Kingdom

#### Return to Any Drinking

At 12 weeks, the trial found no significant different between groups (58 percent of fluvoxamine-treated patients versus 54 percent of placebo-treated patients returned to drinking since the assessment at week 8, P NS). Similarly, at 52 weeks, there was no difference between groups in percentage of patients who returned to drinking since the previous assessment at week 40 (71 percent versus 71 percent).

#### Return to Heavy Drinking

At 12 weeks, the study did not find a difference between those treated with fluvoxamine and those who received placebo (46 percent versus 40 percent, P NS). Similarly, at 52 weeks, the study reported no difference between groups (64 percent versus 64 percent).

#### Drinking Days

At 12 weeks, fluvoxamine-treated patients had more drinking days since the previous (at week 8) assessment than placebo-treated patients (31 percent versus 23 percent, p=0.009). At 52 weeks, the study did not find a significant difference between groups for dinking days since the previous assessment (44 percent versus 38 percent, p NS).

#### Mortality

During the 52-week study, there was no difference between those treated with fluvoxamine and those who received placebo: one patient in each arm died.

## Imipramine

### Characteristics of Trials

Table E-5 summarizes characteristics of the one trial meeting our inclusion criteria.5 It was conducted in a university-based depression research clinic in the U.S. Investigators compared imipramine 50-300 mg/day (mean dose=262 mg/day) with placebo. In addition, all patients received individual relapse prevention counseling. Patients were recruited using advertisements and via referrals. Almost all patients met criteria for alcohol dependence (96 percent), and all had some form of depression. The proportion of smokers was not reported. Roughly 20 percent of enrollees were non-white, and about half were female.

Table E-5 Characteristics of included double-blind randomized placebo-controlled trials of imipramine

Author, Year | Arm Dose, mg/day (N) | Medication Duration (Follow-up) | Country | Setting | Age Years | Percentage Non-White | Percentage Female | Percentage With Co-Occurring Condition(s) | Risk of Bias
McGrath, 1996^5^ | Imipramine 50-300; mean 262 (36) Placebo (33) | 12 | U.S. | University-based depression research clinic | 37 imipramine, 11 placebo^a^ | 17 to 22 | 49 to 53 | MDD 71 to 72 Bipolar 11 to 12 Atypical depression 70 to 72 Other substance abuse 16 | Med

a The study reported 11 years, but it was clearly a reporting error; likely 31 or 41 years.

Notes: Age (y) is the mean age in years, unless otherwise stated

Abbreviations: MDD = major depressive disorder; mg = milligrams; U.S. = United States

#### Return to Any Drinking

The study found no significant difference between groups (69 percent of those receiving imipramine versus 79 percent of those receiving placebo, p NS).

#### Drinking Days

The study found no significant difference between groups (Imipramine-treated patients drank on 28 percent of days versus 31 percent for those who received placebo, p NS).

#### Heavy Drinking Days

The study found no significant difference between groups (Imipramine-treated patients drank heavily on 13.5 percent of days versus 9 percent for those who received placebo, p NS).

#### Drinks per Drinking Day

The mean number of drinks per drinking day was 3.7 for imipramine-treated patients and 4.1 for placebo-treated patients. The difference between groups was not statistically significant.

## Olanzapine

### Characteristics of Trials

Table E-6 summarizes characteristics of the one trial meeting our inclusion criteria.6 Patients were treatment-seekers in a psychiatry department-based addictive behavior unit in a hospital in Spain. Investigators compared olanzapine 5 to 15 mg/day with placebo. In addition, all patients received cognitive behavioral therapy. All patients met criteria for alcohol dependence. The proportions of smokers and non-white patients were not reported.

Table E-6 Characteristics of included double-blind randomized placebo-controlled trials of olanzapine

Author, Year | Arm Dose, mg/day (N) | Medication Duration (Follow-up) | Country | Setting | Age Years | Percentage Female | Risk of Bias
Guardia, 2004^6^ | Olanzapine 5-15 (29) Placebo (31) | 12 (16) | Spain | Addictive behavior unit of a hospital psychiatry department | 43 | 23 to 27 | Med

Notes: Age (y) is the mean age in years, unless otherwise stated

Abbreviations: mg = milligrams; N = number; Rx = prescription

#### Return to Heavy Drinking

Thirty-eight percent of olanzapine patients returned to heavy drinking by the end of the study compared with 29 percent of placebo-treated patients. The difference between groups was not statistically significant.

#### Drinking Days

Olanzapine-treated patients drank on 13 percent of days; those who received placebo drank on 23 percent of days. The difference between groups was not statistically significant.

#### Drinks per Drinking Day

The mean number of drinks per drinking day was 1.8 for olanzapine-treated patients and 2.0 for placebo-treated patients. This difference was not statistically significant.

## Ondansetron

### Characteristics of Trials

Table E-7 summarizes characteristics of the one trial meeting our inclusion criteria.7 It was conducted at a single university in Brazil and compared ondansetron 16 mg/day with placebo. All participants (N=102) received a standardized brief cognitive behavioral intervention. Patients were enrolled as outpatients in a substance abuse treatment program at the university. All patients were alcohol-dependent, and 64% were smokers.

Table E-7 Characteristics of included double-blind randomized placebo-controlled trials of ondansetron

Author, Year | Arm Dose, mg/day (N) | Medication Duration (Followup) | Country | Setting | Age Years | Percentage Non-White | Percentage Female | Co-intervention(s) | Risk of Bias
Corrêa Filho, 2013^7^ | Ondansetron 16 (50) Placebo (52) | 12 | Brazil | University-based outpatient substance abuse treatment center | 42 to 44 | 60 to 73 | 0 | Standardized brief cognitive behavioral intervention | High

Notes: Age (y) is the mean age in years, unless otherwise stated

Abbreviations: mg = milligrams

#### Drinking Days

Patients treated with ondansetron drank on a mean of 22 percent of days; patients treated with placebo drank on 33 percent of days. The difference was not statistically significant.

#### Heavy Drinking Days

Patients treated with ondansetron drank heavily (>5 drinks) on a mean of 8 percent of days; patients treated with placebo drank heavily on 12 percent of days. The difference was statistically significant (p=0.02).

## Paroxetine

### Characteristics of Trials

Table E-8 summarizes characteristics of the one trial meeting our inclusion criteria.8,9 It was conducted in the U.S., but the specific setting was not reported. Investigators compared paroxetine, titrated from 10 to 60 mg/day over four weeks (mean dose=45 mg/day) with placebo; no psychosocial or psychological therapy was provided. Patients were recruited using media advertisements. Most of the patients met criteria for alcohol dependence (79 percent), and all had social anxiety disorder. Roughly ten percent were also diagnosed with major depression. The proportion of smokers was not reported.

Table E-8 Characteristics of included double-blind randomized placebo-controlled trials of paroxetine

Author, Year | Arm Dose, mg/day (N) | Medication Duration (Follow-up) | Country | Age Years | Per-cen-tage Non-White | Percentage Female | Percentage With Co-Occurring Condition(s) | Risk of Bias
Book, 2008^8^; Thomas, 2008^9^ | Paroxetine titration over 4 weeks 10-60; avg. 45 (20) Placebo (22) | 16 | U.S. | 28 to 30 | 0 to 18 | 45 to 50 | Social anxiety disorder 100%; MDD ∼10 | Med

Notes: Age (y) is the mean age in years, unless otherwise stated

Abbreviations: MDD = major depressive disorder; mg = milligrams; U.S. = United States

#### Drinking Days

The study found no significant difference between groups (paroxetine-treated patients versus placebo-treated: 34 percent versus 35 percent, p NS).

#### Heavy Drinking Days

The study found no significant difference between groups (paroxetine-treated patients versus placebo-treated: 54 percent versus 55 percent, p NS).

#### Drinks per Drinking Day

At week 16, the mean number of drinks per drinking day was 5.9 for paroxetine-treated patients and 7.0 for placebo-treated patients. The difference between groups was not statistically significant.

## Varenicline

### Characteristics of Trials

Table E-9 summarizes characteristics of the one trial meeting our inclusion criteria.10 It was conducted at 5 outpatient academic sites in the U.S. Investigators compared varenicline, titrated from 0.5mg/day to 2 mg/day during the first week and at 2 mg/day through week 13, with placebo. Patients were also required to participate in a computerized self-help program. Patients were recruited via advertisements at each study site. All patients were alcohol dependent, 39 percent were smokers, and 13% used marijuana.

Table E-9 Characteristics of included double-blind randomized placebo-controlled trials of varenicline

Author, Year | Arm Dose, mg/day (N) | Medication Duration (Follow-up) | Country | Age Years | Per-cen-tage Non-White | Percentage Female | Percentage With Co-Occurring Condition(s) | Risk of Bias
Litten, 2013^10^ | Varenicline 2 (99) Placebo (101) | 13 | U.S. | 45 to 46 | 30 to 38 | 27 to 32 | 12 to 14% marijuana users | Low

Notes: Age (y) is the mean age in years, unless otherwise stated

Abbreviations: MDD = major depressive disorder; mg = milligrams; U.S. = United States

#### Return to Any Drinking

The study found no difference between varenicline-treated patients and placebo-treated (97.9 percent versus 98 percent, respectively; p=0.81)

#### Return to Heavy Drinking

The study found no difference between varenicline-treated patients and placebo-treated (92.7 percent versus 95 percent, respectively; p=0.50)

#### Drinking Days

The study found no difference between varenicline-treated patients and placebo-treated (60.0 percent versus 64.4 percent, respectively; p=0.29).

#### Heavy Drinking Days

The study found that varenicline-treated patients reported fewer heavy drinking days compared with placebo-treated (37.9 percent versus 48.4 percent, respectively; p=0.03).

#### Drinks per Drinking Day

The study found that varenicline-treated patients reported fewer drinks per drinking day compared with placebo-treated (5.8 versus 6.8; p=0.03).

#### Quality of Life

The study found no difference in SF-12 mental (mean difference 0.7; p=0.55) or physical (mean difference 0.4; p=0.38) scores between varenicline-treated and placebo-treated patients.

#### Mortality

During the 13-week treatment period, there was a shooting death in the varenicline arm and no deaths in the placebo arm.

## References for Appendix E

1 Anton RF, Kranzler H, Breder C, et al. A randomized, multicenter, double-blind, placebo-controlled study of the efficacy and safety of aripiprazole for the treatment of alcohol dependence. J Clin Psychopharmacol. Feb. 2008;28(1):5-12. [pmid: 18204334].
2 Wilens TE, Adler LA, Weiss MD, et al. Atomoxetine treatment of adults with ADHD and comorbid alcohol use disorders. Drug Alcohol Depend. Jul. 1. 2008;96(1-2):145-54. [pmid: 18403134].
3 Mason BJ, Kocsis JH, Ritvo EC, et al. A double-blind, placebo-controlled trial of desipramine for primary alcohol dependence stratified on the presence or absence of major depression. JAMA. Mar. 13. 1996;275(10):761-7. [pmid: 8598592].
4 Chick J, Aschauer H, Hornik K. Efficacy of fluvoxamine in preventing relapse in alcohol dependence: a one-year, double-blind, placebo-controlled multicentre study with analysis by typology. Drug Alcohol Depend. Apr. 9. 2004;74(1):61-70. [pmid: 15072808].
5 McGrath PJ, Nunes EV, Stewart JW, et al. Imipramine treatment of alcoholics with primary depression: A placebo-controlled clinical trial. Arch Gen Psychiatry. Mar. 1996;53(3):232-40. [pmid: 8611060].
6 Guardia J, Segura L, Gonzalvo B, et al. A double-blind, placebo-controlled study of olanzapine in the treatment of alcohol-dependence disorder. Alcohol Clin Exp Res. May. 2004;28(5):736-45. [pmid: 15166648].
7 Corrêa Filho JM, Baltieri DA. A pilot study of full-dose ondansetron to treat heavy-drinking men withdrawing from alcohol in Brazil. Addict Behav. 2013;38(4):2044-51. 2013-05932-027. First Author & Affiliation: Corrêa Filho, João Maria. [pmid: 23396176].
8 Book SW, Thomas SE, Randall PK, et al. Paroxetine reduces social anxiety in individuals with a co-occurring alcohol use disorder. J Anxiety Disord. 2008;22(2):310-8. [pmid: 17448631].
9 Thomas SE, Randall PK, Book SW, et al. A complex relationship between co-occurring social anxiety and alcohol use disorders: what effect does treating social anxiety have on drinking?. Alcohol Clin Exp Res. Jan. 2008;32(1):77-84. [pmid: 18028529].
10 Litten RZ, Ryan ML, Fertig JB, et al. A double-blind, placebo-controlled trial assessing the efficacy of varenicline tartrate for alcohol dependence. J Addict Med. Jul-Aug. 2013;7(4):277-86. [pmid: 23728065].