# Strength of Evidence Assessments

## KQ 1 and KQ 2

Table D-1 Acamprosate compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 16^a^; 4,847 | Medium; RCTs | Consistent^b^ | Direct | Precise | RD: -0.09 (-0.14 to -0.04) | Moderate
Return to heavy drinking | 7; 2,496 | Low; RCTs | Consistent | Direct | Precise | RD: -0.01 (-0.04 to 0.03) | Moderate^c^
Drinking days | 13^d^; 4,485 | Medium; RCTs | Consistent | Direct | Precise | WMD: -8.8 (-12.8 to -4.8) | Moderate
Heavy drinking days | 1; 100 | Medium; RCT | Unknown | Direct | Imprecise | WMD: -2.6 (-11.4 to 6.2) | Insufficient
Drinks per drinking day | 1^d^; 116 | Low; RCT | Unknown | Direct | Imprecise | WMD: 0.40 (-1.81 to 2.61) | Insufficient
Accidents | 0^e^; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 1; 612 | Low; RCT | Unknown | Direct | Unknown | NSD^f^ | Insufficient
Mortality | 8^g^; 2,677 | Medium; RCTs | Unknown | Direct | Imprecise | 7 (ACA) vs. 6 (PBO) | Insufficient

a 2 additional studies were rated high risk of bias; 1 additional study was rated as unclear risk of bias

b Although there was considerable statistical heterogeneity, fourteen of fifteen studies reported point estimates that favored acamprosate; differences were in magnitude of benefit

c The relatively small number of studies reporting this outcome raises concern for potential reporting bias, hence the rating of moderate rather than high rating

d 1 additional study was rated high risk of bias

e The single study that reported this outcome was rated as unclear risk of bias. It reported that one patient in the placebo group died by “accident.” No other details on the cause or nature of the accident were provided.1

f Results were not reported for each treatment group separately, but there were no clinically significant differences across treatment groups

g One additional study reported a death but did not specify in which treatment group it occurred.2

Abbreviations: ACA = acamprosate; CI = confidence interval; NA = not applicable; NSD = no statistically significant difference; PBO = placebo; RCT = randomized controlled trial; RD = risk difference; WMD = weighted mean difference

Table D-2 Disulfiram compared with control

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 2^a^; 492 | Medium; RCTs | Consistent^b^ | Direct | Imprecise | RD: 0.04 (-0.11 to 0.03) | Low
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 2; 290 | Medium; RCTs | Inconsistent | Indirect^c^ | Imprecise | 1 study reported similar percentages and no significant difference; the other reported that DIS was favored among the subset of subjects who drank and had a complete set of assessment interviews (N=162/605 subjects), p=0.05 | Insufficient
Heavy drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a 1 additional study was rated high risk of bias.3

b Inclusion of the study rated high risk of bias would have made this inconsistent, though it would not have changed the conclusion (the meta-analysis still found no statistically significant difference between groups).

c We considered this indirect because the larger study did not report the outcome for the randomized sample; it only reported this outcome for the subset (162/605) who drank and who had a complete set of assessment interviews.

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial; RD = risk difference

Table D-3 Naltrexone (any dose and delivery) compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 21^a^; 4,233 | Medium; RCTs | Consistent | Direct | Precise | RD: -0.04 (-0.07 to -0.01) | Moderate
Return to heavy drinking | 23^a^; 4,347 | Medium; RCTs | Consistent | Direct | Precise | RD: -0.07 (-0.11 to -0.03) | Moderate
Drinking days | 19^b^; 3,329 | Medium; RCTs | Consistent | Direct | Precise | WMD: -4.57 (-6.61 to -2.53) | Moderate
Heavy drinking days | 11^c^; 2034 | Medium; RCTs | Consistent | Direct | Precise | WMD: -3.81 (-5.85 to -1.78) | Moderate
Drinks per drinking day | 11^d^; 1,422 | Medium; RCTs | Consistent | Direct | Imprecise | WMD: -0.54 (-1.01 to -0.07) | Low
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life | 4; 1,513 | Medium; RCTs | Inconsistent | Direct | Imprecise | Unable to pool data, some conflicting results^e^ | Insufficient
Mortality | 6^f^; 1,738 | Medium; RCTs | Unknown | Direct | Imprecise | 1 (NTX) vs. 2 (PBO) | Insufficient

a 2 additional studies were rated high risk of bias; 2 additional studies were rated as unclear risk of bias

b 3 additional studies were rated high risk of bias

c 2 additional studies were rated high risk of bias

d 5 additional studies were rated high risk of bias

e Two studies found no significant difference between naltrexone- and placebo-treated subjects.4,5 One study reported that patients receiving injectable naltrexone 380mg/month had greater improvement on the mental health summary score than those receiving placebo at 24 weeks (8.2 vs. 6.2, p=0.044).6 One study measured alcohol-related consequences (with the DrInC) and reported that more subjects who received placebo (N=34) had ≥1 alcohol-related consequence than those who received naltrexone (N=34): 76% vs. 45%, P=0.02.^7^

f One additional study reported a death but did not specify in which treatment group it occurred.2

Abbreviations: CI, confidence interval; NA, not applicable; NSD, no significant difference; NTX, naltrexone; PBO, placebo; RCT, randomized controlled trial; RD, risk difference; WMD, weighted mean difference

Table D-4 Oral naltrexone (50mg) compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 16; 2,347 | Medium; RCTs | Consistent | Direct | Precise | RD: -0.05 (-0.10 to -0.00) | Moderate
Return to heavy drinking | 19; 2,875 | Medium; RCTs | Consistent | Direct | Precise | RD: -0.09 (-0.13 to -0.04) | Moderate
Drinking days | 15; 1,992 | Medium; RCTs | Consistent | Direct | Precise | WMD: -5.4 (-7.5 to -3.2) | Moderate
Heavy drinking days | 6; 521 | Medium; RCTs | Consistent | Direct | Precise | WMD: -4.1 (-7.6 to -0.61) | Moderate
Drinks per drinking day | 9; 1,018 | Medium; RCTs | Consistent | Direct | Imprecise | WMD: -0.49 (-0.92 to -0.06) | Low

Abbreviations: CI, confidence interval; NA, not applicable; NSD, no significant difference; NTX, naltrexone; PBO, placebo; RCT, randomized controlled trial; RD, risk difference; WMD, weighted mean difference

Table D-5 Oral naltrexone (100mg) compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 3; 946 | Medium; RCTs | Consistent | Direct | Imprecise | RD: -0.03 (-0.08 to 0.02) | Low
Return to heavy drinking | 2; 858 | Medium; RCTs | Consistent | Direct | Imprecise | RD: -0.05 (-0.11 to 0.01) | Low
Drinking days | 2; 858 | Medium; RCTs | Consistent | Direct | Imprecise | WMD: -0.9 (-4.2 to 2.5) | Low
Heavy drinking days | 2; 423 | Medium; RCTs | Consistent | Direct | Imprecise | WMD: -3.1 (-5.8 to -0.3) | Low
Drinks per drinking day | 1; 240 | Medium; RCTs | Unknown | Direct | Imprecise | WMD: 1.9 (-1.5 to 5.2) | Insufficient

Abbreviations: CI, confidence interval; NA, not applicable; NSD, no significant difference; NTX, naltrexone; PBO, placebo; RCT, randomized controlled trial; RD, risk difference; WMD, weighted mean difference

Table D-6 Injectable naltrexone compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 2; 939 | Medium; RCTs | Consistent | Direct | Imprecise | RD: -0.04 (-0.10 to 0.03) | Low
Return to heavy drinking | 2; 615 | Medium; RCTs | Inconsistent | Direct | Imprecise | RD: -0.01 (-0.14 to 0.13) | Low
Drinking days | 1; 315 | Medium; RCTs | Unknown | Direct | Imprecise | WMD: -8.6 (-16.0 to -1.2) | Insufficient
Heavy drinking days | 2^a^; 926 | Medium; RCTs | Consistent | Direct | Imprecise | WMD: -4.6 (-8.5 to -0.56) | Low
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a Contains data from personal communication (B. Silverman, November 14, 2013).

Abbreviations: CI, confidence interval; NA, not applicable; NSD, no significant difference; NTX, naltrexone; PBO, placebo; RCT, randomized controlled trial; RD, risk difference; WMD, weighted mean difference

Table D-7 Acamprosate compared with disulfir77am

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient

a The one study reporting this outcome was rated high risk of bias.8 It reported one traffic accident in the disulfiram group and none in the acamprosate group over 52 weeks. No details of the event were described, it was noted that the study coordinator determined that the event was not related to the study treatment. One person committed suicide and two persons drowned in the acamprosate group but there were no events in the disulfiram group. Quality of life improved for both groups over the 52 week follow-up compared with baseline with no difference between the acamprosate and disulfiram groups.

Abbreviations: CI, confidence interval; NA, not applicable

Table D-8 Acamprosate compared with naltrexone

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 3; 800 | Low; RCTs | Consistent | Direct | Imprecise | RD: 0.02 (-0.03 to 0.08)^a^ | Moderate
Return to heavy drinking | 4; 1,141 | Low; RCTs | Consistent | Direct | Imprecise | RD: 0.01 (-0.05 to 0.06)^a^ | Moderate
Drinking days | 2; 720 | Low; RCTs | Inconsistent | Direct | Imprecise | WMD: -2.98 (-13.42 to 7.45)^a^ | Low
Heavy drinking days | 1; 612 | Low; RCT | Unknown | Direct | Unknown | Significant NTX by CBI interaction, P=0.006 | Insufficient
Drinks per drinking day | 2; 720 | Low; RCTs | Inconsistent | Direct | Unknown | Unable to pool data^b^ | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 1^c^; 612 | Low; RCT | Unknown | Direct | Imprecise | NSD for all measures except SF-12v2 physical health, which favored NTX+CBI | Insufficient
Mortality | 0^d^; 0 | NA | NA | NA | NA | NA | Insufficient

a Positive value indicates that naltrexone is favored

b Two trials reported some information about drinks per drinking day, but not enough data for us to conduct quantitative synthesis. One trial conducted in Australia reported no statistically significant difference between acamprosate and naltrexone (mean, SD: 7.5, 6.1 vs. 5.9, 6.1; P not reported).9,10 The COMBINE study reported that analyses of alternative summary measures of drinking, including drinks per drinking day (P=0.03), were consistent with those for the co-primary end points (percent days abstinent from alcohol and time to first heavy drinking day), all showing a significant naltrexone by CBI interaction.2

c One additional study was rated high risk of bias.8 It found that quality of life improved for both groups over the 52 week follow-up compared with baseline, but found no difference between the acamprosate and naltrexone groups.

d One study that reported this outcome was rated high risk of bias; another reported one death but did not specify in which treatment group it occurred

Abbreviations: ACA = acamprosate; CBI = combined behavioral intervention; CI = confidence interval; NA = not applicable; NTX = naltrexone; RCT = randomized controlled trial; RD = risk difference; WMD = weighted mean difference

Table D-9 Disulfiram compared with naltrexone

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0^b^; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0^b^; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0^c^; 0 | NA | NA | NA | NA | NA | Insufficient

a The single study that reported this outcome was rated high risk of bias.3 The trial reported no statistically significant difference between disulfiram and naltrexone for number of subjects achieving total abstinence (51 vs. 38, P=0.11), the percentage of days abstinent (96.6 vs. 95.4, P=0.55), or the percentage of heavy drinking days (3.2 vs. 4, P=0.65).

b The only study that reported this outcome was rated high risk of bias.8 It reported one traffic accident in the disulfiram group and no accident or injuries in the naltrexone group. No details of the event were described, it was noted that the study coordinator determined that the event was not related to the study treatment. Quality of life improved for both groups over the 52 week follow-up compared with baseline with no difference between the disulfiram and naltrexone groups.

c The only study that reported this outcome was rated high risk of bias.3 One person died in the naltrexone group and no deaths were reported in the disulfiram group.

Abbreviations: CI = confidence interval; NA = not applicable; RCT = randomized controlled trial

Table D-10 Amitriptyline compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI, confidence interval; NA, not applicable

Table D-11 Aripiprazole compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size | Strength of Evidence Grade
Return to any drinking | 1; 288 | Medium; RCT | Unknown | Direct | Imprecise | 89% (ARI) vs. 78% (PBO); p=0.02 | Insufficient
Return to heavy drinking | 1; 288 | Medium; RCT | Unknown | Direct | Imprecise | 73% (ARI) vs. 73% (PBO); p=0.98 | Insufficient
Drinking days | 1; 288 | Medium; RCT | Unknown | Direct | Imprecise | 41% (ARI) vs. 37% (PBO); p=0.23 | Insufficient
Heavy drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 1; 288 | Medium; RCT | Unknown | Direct | Imprecise | 4.4 (ARI) vs. 5.5 (PBO); p<0.001 | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: ARI, aripiprazole; NA, not applicable; PBO, placebo; RCT, randomized controlled trial

Table D-12 Atomoxetine compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a The single study reporting this outcome was rated high risk of bias.11 The trial found no significant difference between groups for return to heavy drinking (94% for atomoxetine vs. 96% for placebo), drinking days, or reduction in drinks per drinking day. It did report a 26% lower rate of cumulative heavy drinking days for atomoxetine compared with placebo (P=0.02).

Abbreviations: ATO = atomoxetine; CI = confidence interval; HDD = heavy drinking days; NA = not applicable; PBO = placebo; RCT = randomized controlled trial

Table D-13 Baclofen compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size | Strength of Evidence Grade
Return to any drinking | 2; 164 | Medium; RCTs | Inconsistent | Direct | Imprecise | Study 1: OR 6.3, 95% CI, 2.4 to 16.1 Study 2: No difference^a^ | Insufficient
Return to heavy drinking | 2; 164 | Medium; RCTs | Inconsistent | Direct | Imprecise | Study 1: BAC significantly lower than PBO (data in Figure, p=0.0062) Study 2: HR 0.924, p=0.76 | Insufficient
Drinking days | 1; 80 | Medium; RCT | Unknown | Direct | Imprecise | 50.1% (BAC) vs. 49.4% (PBO); p=0.50 | Insufficient
Heavy drinking days | 1; 80 | Medium; RCT | Unknown | Direct | Imprecise | 25.9% (BAC) vs. 25.5% (PBO); p=0.73 | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a One trial conducted in Italy (N=84) reported that a lower percentage of patients treated with baclofen returned to any drinking than with placebo (29 percent [12/42] versus 71 percent [30/42]; OR, 6.3; 95% CI, 2.4 to 16.1).12 One trial conducted in the U.S. (N=80) did not report numbers for rates of return to any drinking, but reported no difference between groups for time to first usage (p=0.13), and included a figure for percentage abstinent that shows over 90 percent of subjects returned to any drinking over the course of the trial.13

Abbreviations: BAC = baclofen; CI = confidence interval; NA = not applicable; PBO = placebo; RCT = randomized controlled trial

Table D-14 Buspirone compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 1^a^; 54 | Medium; RCT | Unknown | Direct | Imprecise | RD: 0.07 (-0.19 to 0.34) | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 2; 161 | Medium; RCTs | Consistent | Direct | Imprecise | WMD: -3.39 (-9.23 to 2.44) | Low
Heavy drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 1; 61 | Medium; RCT | Unknown | Direct | Imprecise | 0.7 vs. 2.1; p NS | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a 1 additional study was rated high risk of bias.14 Neither trial found a statistically significant difference between groups, and point estimates favored placebo in both trials.14,15

Abbreviations: CI, confidence interval; NA, not applicable; RCT, randomized controlled trial; RD, risk difference; weighted mean difference

Table D-15 Citalopram compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0^b^; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0^b^; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a One trial conducted in Finland, rated as high risk of bias, reported 25 of 31 citalopram-treated patients and 28 of 31 placebo-treated patients returned to any drinking (p=0.10).16

b One trial rated as high risk of bias conducted in Canada found similar proportions of drinking days for those who received citalopram and those who received placebo (72.7 percent versus 76.5 percent, p NS) and similar reductions in drinks per drinking day for those who received citalopram and those who received placebo (26.1 percent versus 26.4 percent, p NS) over the 12 weeks of treatment.17

Abbreviations: CI, confidence interval; NA, not applicable; RCT, randomized controlled trial

Table D-16 Desipramine compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a One study rated as high risk of bias, reported that 12 percent of patients in the desipramine arm returned to heavy drinking, compared with 32 percent of patients taking placebo (p=NS).18 It also reported that non-depressed patients treated with desipramine (N=14) drank on a median of 68 percent of days; non-depressed patients treated with placebo (N=15) drank on 72 percent of days (p NS).

Abbreviations: CI = confidence interval; NA = not applicable

Table D-17 Fluoxetine compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 1^a^; 51 | Medium; RCT | Unknown | Direct | Imprecise | RD: -0.13 (-0.35 to 0.10) | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 2; 146 | Medium; RCTs | Inconsistent | Direct | Imprecise | WMD: -3.15 (-18.2 to 11.9) | Low
Heavy drinking days | 1; 51 | Medium; RCT | Unknown | Direct | Imprecise | 4.8 (FLUOX) vs. 16 (PBO); P=0.04 | Insufficient
Drinks per drinking day | 2; 146 | Medium; RCTs | Inconsistent | Direct | Imprecise | WMD: -1.20 (-4.63 to 2.23) | Low
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a 1 additional study (N=28) reporting this outcome was rated high risk of bias.19 Both trials found no statistically significant difference between fluoxetine and placebo.19,20

Abbreviations: CI = confidence interval; FLUOX = fluoxetine; NA = not applicable; PBO = placebo; RCT = randomized controlled trial; RD = risk difference; WMD = weighted mean difference

Table D-18 Fluvoxamine compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking^a^ | 1; 492 | Medium; RCT | Unknown | Direct | Imprecise | 12 weeks: 58% (FLUV) vs. 54% (PBO); P=0.40 52 weeks: 71% (FLUV) vs. 71% (PBO); P=0.94 | Insufficient
Return to heavy drinking | 1; 492 | Medium; RCT | Unknown | Direct | Imprecise | 12 weeks: 46% (FLUV) vs. 40% (PBO); P=0.18 52 weeks: 64% (FLUV) vs. 64% (PBO); P=0.47 | Insufficient
Drinking days^a^ | 1; 492 | Medium; RCT | Unknown | Direct | Imprecise | 12 weeks: 31% (FLUV) vs. 23% (PBO); P=0.009 52 weeks: 44% (FLUV) vs. 38% (PBO); P=0.13 | Insufficient
Heavy drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 1; 492 | Medium; RCT | Unknown | Direct | Imprecise | 52 weeks: 1 (FLUV) vs. 1 (PBO) | Insufficient

a The study reported return to drinking and percent drinking days since the previous assessment. At 12 weeks, the previous assessment was at week 8; at 52 weeks, the previous assessment was at week 40.^21^

Abbreviations: CI = confidence interval; FLUV = fluvoxamine; NA = not applicable; PBO = placebo; RCT = randomized controlled trial

Table D-19 Imipramine compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking^a^ | 1; 56 | Medium; RCT | Unknown | Direct | Imprecise | 69% (IMI) vs. 79% (PBO); P NS | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 1; 56 | Medium; RCT | Unknown | Direct | Imprecise | 28.3% (IMI) vs. 30.8% (PBO); P NS | Insufficient
Heavy drinking days | 1; 56 | Medium; RCT | Unknown | Direct | Imprecise | 13.5% (IMI) vs.9.0% (PBO); P NS | Insufficient
Drinks per drinking day | 1; 56 | Medium; RCT | Unknown | Direct | Imprecise | 3.7 (IMI) vs. 4.1 (PBO); P NS | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a The study reported return to drinking within the previous 4 weeks.22

Abbreviations: CI = confidence interval; IMI = imipramine; NA = not applicable; NS = not significant; PBO = placebo; RCT = randomized controlled trial

Table D-20 Nalmefene compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 1^a^; 105 | Medium; RCT | Unknown | Direct | Imprecise | RD: -0.23 (-0.43 to -0.03)^a^ | Insufficient
Drinking days | 2; 508 | Medium; RCTs | Inconsistent | Direct | Imprecise | WMD: -1.1 (-7.6 to 5.4) | Low
Heavy drinking days | 1; 403 | Medium; RCT | Unknown | Direct | Imprecise | 18.1% (NALM) vs. 29.7% (PBO); P=0.024 | Insufficient
Change in HDDs per month: OC analysis PMI analysis | 2^b^; 806 2; 1,234 | Medium; RCTs | Consistent | Direct | Precise | WMD: -2.0 (-3.0 to -1.0) WMD: -1.3 (-2.2 to -0.3) | Moderate
Drinks per drinking day | 3; 608 | Medium; RCTs | Consistent | Direct | Precise | WMD: -1.02 (-1.77 to -0.28) | Moderate
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 2; 1,253 | Medium; RCTs | Inconsistent | Direct | Imprecise | Study 1: 0 (NALM) vs. 2 (PBO)23 Study 2: 1 (NALM) vs. 1 (PBO)24 | Insufficient

a 1 additional study reported return to heavy drinking—a pilot study rated as high risk of bias (N=21).25 It found no difference between groups (RD, -0.05; 95% CI, -0.51 to 0.41). Pooling both studies found a 19% reduction in return to heavy drinking with nalmefene (RD, -0.19; 95% CI, -0.37 to, -0.01).

b 1 additional trial (the SENSE trial) rated as high risk of bias reported change in HDDs per month using an OC analysis.26 The trial (N analyzed=430) did not find a difference in monthly heavy drinking days between the 2 treatments at month 6, but did report a difference at month 13 (mean difference, -1.6; 95% CI, -2.9 to -0.2).

Abbreviations: CI = confidence interval; NA = not applicable; NALM = nalmefene; OC = observed cases; PBO = placebo; PMI = placebo mean imputation; RCT = randomized controlled trial; RD = risk difference; WMD = weighted mean difference

Table D-21 Olanzapine compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 1; 60 | Medium; RCT | Unknown | Direct | Imprecise | 37.9% (OLA) vs. 29.0% (PBO); p=0.50^24^ | Insufficient
Drinking days | 1; 60 | Medium; RCT | Unknown | Direct | Imprecise | 13.1% (OLA) vs. 22.7% (PBO); p=0.18^24^ | Insufficient
Heavy drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 1; 60 | Medium; RCT | Unknown | Direct | Imprecise | 1.79 (OLA) vs. 2.02 (PBO); p=0.71^24^ | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; OLA = olanzapine; PBO = placebo; RCT = randomized controlled trial

Table D-22 Ondansetron compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a The only study that met our inclusion criteria was rated as high risk of bias.27 It reported drinking days and heavy drinking days. Patients treated with ondansetron drank on a mean of 22 percent of days; patients treated with placebo drank on 33 percent of days. The difference was not statistically significant. Patients treated with ondansetron drank heavily (>5 drinks) on a mean of 8 percent of days; patients treated with placebo drank heavily on 12 percent of days. The difference was statistically significant (p=0.02).

Abbreviations: CI = confidence interval; NA = not applicable; PBO = placebo; RCT = randomized controlled trial; RD = risk difference; VAL = valproic acid; WMD = weighted mean difference

Table D-23 Paroxetine compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 1; 42 | Medium; RCT | Unknown | Direct | Imprecise | 34% (PAR) vs. 35% (PBO); p=NS25,26 | Insufficient
Heavy drinking days^a^ | 1; 42 | Medium; RCT | Unknown | Direct | Imprecise | 54% (PAR) vs. 55% (PBO); p=NS25,26 | Insufficient
Drinks per drinking day | 1; 42 | Medium; RCT | Unknown | Direct | Imprecise | 5.9 (PAR) vs. 7.0 (PBO); p=NS25,26 | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a These results indicate the percent of heavy drinking days within the number of any drinking days.

Abbreviations: CI = confidence interval; NA = not applicable; PAR = paroxetine; PBO = placebo; RCT = randomized controlled trial

Table D-24 Quetiapine compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0^b^; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0^b^; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0^c^; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0^c^; 0 | NA | NA | NA | NA | NA | Insufficient

a The one study that reported this outcome was rated as high risk of bias.28 It did not enroll subjects with co-occurring bipolar disorder and it reported that more subjects treated with quetiapine achieved complete abstinence (9/29 versus 2/32, p=0.012)—i.e., fewer subjects treated with quetiapine returned to any drinking (20/29 versus 30/32).

b Three studies reported this outcome; all three were rated as high risk of bias.28-30 Our meta-analysis of the three trials found no difference in drinking days between patients treated with quetiapine and those who received placebo (WMD, -2.7; 95% CI, -12.8 to 7.5). Our meta-analysis of the three trials found no difference in heavy drinking days between patients treated with quetiapine and those who received placebo (WMD, -3.1; 95% CI, -10.1 to 4.0).

c One placebo-controlled trial of quetiapine rated as high risk of bias reported two deaths (one in each treatment group); one after a skull fracture caused by blunt trauma in the quetiapine group and one attributed to myocardial ischemia more than 30 days after treatment in the placebo group.30 Both deaths were judged to be unrelated to the study medications by the study investigators. The trial also reported no difference between groups for quality of life and function.

Abbreviations: CI = confidence interval; NA = not applicable

Table D-25 Sertraline compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 1; 79 | Medium; RCT | Unknown | Direct | Imprecise | 29/40 (SER) vs. 30/39 (PBO), p NS. | Insufficient
Return to heavy drinking | 2; 142 | Medium; RCTs | Inconsistent | Direct | Imprecise | RD: -0.04 (-0.31 to 0.23) | Low
Drinking days | 3^a^; 299 | Medium; RCTs | Consistent | Direct | Imprecise | WMD: 1.8 (-6.25 to 9.86)^a^ | Low
Heavy drinking days | 2; 228 | Medium; RCT | Consistent | Direct | Imprecise | WMD: 1.85 (0.70 to 3.0) | Low (favors placebo)
Drinks per drinking day | 2; 176 | Medium; RCTs | Consistent | Direct | Imprecise | WMD: -0.9 (-2.2 to 0.5) | Low
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 1; 83 | Medium; RCT | Unknown | Direct | Imprecise | Graph only, data NR (p=0.031)^b^ | Insufficient
Mortality | 1; 79 | Medium; RCT | Unknown | Direct | Imprecise | 0 (SER) vs. 0 (PBO)31 | Insufficient

a One additional study reporting this outcome was rated as unclear risk of bias.31 Our meta-analysis found no significant difference between patients treated with sertraline and those who received placebo, both without and with including the trial rated as unclear risk of bias (when including that trial: WMD, -0.64; 95% CI, -5.71 to 6.99).

b The single study that reported this outcome enrolled patients with co-existing depression and measured QoL using the SF-36 at 24 weeks. Scores were presented in a figure only (bar graph, data not reported). QoL improved during treatment for both the placebo and sertraline groups; the authors noted that the sertraline group improved more than placebo in only the mental health summary score of the SF-36 (p=0.031).32

Abbreviations: CI = confidence interval; NA = not applicable; PBO = placebo; RCT = randomized controlled trial; RD = risk difference; SER = sertraline; WMD = weighted mean difference

Table D-26 Topiramate compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 2^b^; 521 | Low; RCTs | Consistent | Direct | Imprecise | Trial 1^34^: WMD: -8.5 (-15.9 to -1.1)^b^ Trial 2^35^: mean difference -11.6 (-3.98 to -19.3) | Moderate^b^
Heavy drinking days | 2^b^; 521 | Low; RCTs | Consistent | Direct | Imprecise | WMD: -11.53 (-18.29 to -4.77) | Moderate^b^
Drinks per drinking day | 2^b^; 521 | Low; RCT | Consistent | Direct | Imprecise | WMD: -1.10 (-1.75 to -0.45) | Moderate^b^
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 1; 371 | Low; RCT | Unknown | Direct | Imprecise | 4.4% (TOP) vs. 11.7% (PBO); p=0.01^34^ | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 1; 371 | Low; RCT | Unknown | Direct | Imprecise | 0 (TOP) vs. 1 (PBO)34 | Insufficient

a One study conducted in Brazil, rated as high risk of bias, reported this outcome.33 It reported that more patients treated with topiramate returned to any drinking than with placebo (24/52 versus 15/54).

b One additional study reporting this outcome was rated as high risk of bias.34 Our meta-analysis found a lower percentage of drinking days for patients treated with topiramate than for those who received placebo both without and with including the trial rated as high risk of bias (WMD, -9.7; 95% CI, -16.4 to -3.1). Our meta-analysis found a lower percentage of heavy drinking days for patients treated with topiramate than for those who received placebo both without and with including the trial rated as high risk of bias (WMD, -11.4; 95% CI, -20.4 to -2.4). Our meta-analysis found no statistically significant difference between topiramate and placebo when only including the trial rated as low risk of bias, but found a statistically significant reduction of 1.2 drinks per drinking day when including the trial rated as high risk of bias (WMD, -1.2; 95% CI, -2.2 to -0.2). We were unable to include “trial 2” (N=150),35 rated as medium risk of bias, in our meta-analyses due to differences in the type of data reported, but its findings are shown in the SOE table, and were generally consistent with those of the low risk of bias trial (“trial 1”, N=371).35

Abbreviations: CI = confidence interval; NA = not applicable; PBO = placebo; RCT = randomized controlled trial; TOP = topiramate; WMD = weighted mean difference

Table D-27 Valproic acid compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 1; 29 | Medium; RCT | Unknown | Direct | Imprecise | 81% (VAL) vs. 83% (PBO); P NS | Insufficient
Return to heavy drinking | 2; 81 | Medium; RCTs | Consistent | Direct | Imprecise | RD: -0.32 (-0.52 to -0.11) | Low
Drinking days | 1; 29 | Medium; RCT | Unknown | Direct | Imprecise | 15.9 (VAL) vs. 19.6 (PBO); P NS | Insufficient
Heavy drinking days | 2; 81 | Medium; RCTs | Consistent | Direct | Imprecise | WMD: -8.5 (-15.9 to -1.1) | Low
Drinks per drinking day | 2; 81 | Medium; RCTs | Consistent | Direct | Imprecise | WMD: -2.6 (-5.0 to -0.2) | Low
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; PBO = placebo; RCT = randomized controlled trial; RD = risk difference; VAL = valproic acid; WMD = weighted mean difference

Table D-28 Varenicline compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 1; 200 | Low; RCT | Unknown | Direct | Imprecise | 97.9% (VAR) vs. 98% (PBO); p 0.81 | Insufficient
Return to heavy drinking | 1; 200 | Low; RCT | Unknown | Direct | Imprecise | 92.7% (VAR) vs. 95% (PBO); p 0.50 | Insufficient
Drinking days | 1; 200 | Low; RCT | Unknown | Direct | Imprecise | 60.0% (VAR) vs. 64.4% (PBO); p 0.29 | Insufficient
Heavy drinking days | 1; 200 | Low; RCT | Unknown | Direct | Imprecise | 37.9% (VAR) vs. 48.4% (PBO); p 0.03 | Insufficient
Drinks per drinking day | 1; 200 | Low; RCT | Unknown | Direct | Imprecise | 5.8 (VAR) vs. 6.8 (PBO); p 0.03 | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 1; 200 | Low; RCT | Unknown | Direct | Imprecise | The study found no difference in SF-12 mental (mean difference 0.7; p 0.55) or physical (mean difference 0.4; p 0.38) scores between varenicline-treated and placebo-treated patients. | Insufficient
Mortality | 1; 200 | Low; RCT | Unknown | Direct | Imprecise | During the 13-week treatment period, there was 1 shooting death in the varenicline arm and no deaths in the placebo arm. | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; PBO = placebo; RCT = randomized controlled trial; RD = risk difference; VAL = valproic acid; WMD = weighted mean difference

Table D-29 Aripiprazole compared with naltrexone

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 1; 57 | Medium; RCT | Unknown | Direct | Imprecise | NSD^38^ | Insufficient
Return to heavy drinking | 1; 57 | Medium; RCT | Unknown | Direct | Imprecise | NSD^38^ | Insufficient
Drinking days | 1; 57 | Medium; RCT | Unknown | Direct | Imprecise | NSD^38^ | Insufficient
Heavy drinking days | 1; 57 | Medium; RCT | Unknown | Direct | Imprecise | NSD^38^ | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; NSD = no significant difference; RCT = randomized controlled trial

Table D-30 Desipramine compared with paroxetine

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a One included trial, rated as high risk of bias, randomized patients with PTSD and alcohol dependence to desipramine, paroxetine, desipramine plus naltrexone, or paroxetine plus naltrexone.36 The trial found that patients treated with desipramine had fewer heavy drinking days (p=0.009) and drinks per drinking day (p=0.027) than those who received paroxetine.

Abbreviations: CI = confidence interval; NA = not applicable

Table D-31 Sertraline compared with naltrexone

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 1; 89 | Medium; RCT | Unknown | Direct | Imprecise | 72.5% (SER) vs. 78.7 (NTX); p NS31 | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 1; 89 | Medium; RCT | Unknown | Direct | Imprecise | 0 (SER) vs. 0 (NTX)31 | Insufficient

Abbreviations: CI = confidence interval; NA = not applicable; NTX = naltrexone; RCT = randomized controlled trial; SER = sertraline

Table D-32 Topiramate compared with naltrexone

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Return to any drinking | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Return to heavy drinking | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Drinking days | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Heavy drinking days | 0^a^; 0 | NA | NA | NA | NA | NA | Insufficient
Drinks per drinking day | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Accidents | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Injuries | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Quality of life or function | 0^b^; 0 | NA | NA | NA | NA | NA | Insufficient
Mortality | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a The only included trial that was eligible for KQ 1 and that reported these outcomes, rated as high risk of bias, reported no significant differences between topiramate and naltrexone for proportion of abstinent subjects, cumulative abstinence duration, time to first relapse, or heavy drinking weeks.33 Significantly more subjects in the topiramate group participated in AA than in the naltrexone group (19.2 percent versus 4.1 percent, p=0.04).

b The two studies that reported this outcome were rated as high risk of bias.

Abbreviations: CI = confidence interval; NA = not applicable

## KQ 3

Table D-33 Acamprosate compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Withdrawals due to AEs | 13^a^; 4,653 | Medium; RCTs | Consistent | Direct | Imprecise | RD 0.006 (-0.003 to 0.015) | Low
Anorexia | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Anxiety | 1^b^; 601 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.164 (0.095 to 0.234) | Insufficient
Cognitive dysfunction | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Diarrhea | 12^c^; 3,299 | Medium; RCTs | Consistent | Direct | Precise | RD 0.099 (0.030 to 0.168) | Moderate
Dizziness | 2; 151 | Low to medium; RCTs | Inconsistent | Direct | Imprecise | RD 0.08 (-0.22 to 0.38) | Low
Headache | 6^b^; 1,074 | Medium; RCTs | Inconsistent | Direct | Imprecise | RD 0.001 (-0.052 to 0.05) | Low
Insomnia | 3^b^; 251 | Medium; RCT | Inconsistent | Direct | Imprecise | RD 0.019 (-0.10 to 0.138) | Low
Nausea | 7^b^; 1,758 | Low to medium; RCTs | Consistent | Direct | Imprecise | RD 0.006 (-0.012 to 0.023) | Moderate
Numbness / tingling / paresthesias | 1^b^; 262 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.008 (-0.013 to 0.029) | Insufficient
Rash | 1^b^; 35 | Low; RCT | Unknown | Direct | Imprecise | RD 0.111 (-0.069 to 0.291) | Insufficient
Suicide attempts or suicidal ideation | 1^c^; 581 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.007 (-0.005, 0.019) | Insufficient
Taste abnormalities | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Vision changes | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Vomiting | 4^b^; 1,817 | Medium; RCTs | Consistent | Direct | Precise | RD 0.024 (0.007 to 0.042) | Moderate

a Three additional studies were rated high or unclear risk of bias

b One additional study was rated high or unclear risk of bias

c Two additional studies were rated high or unclear risk of bias

Abbreviations: AE = adverse effect; CI = confidence interval; RCT = randomized controlled trial; RD risk difference

Table D-34 Naltrexone compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Withdrawals due to AEs | 17^a^; 2,743 | Medium; RCTs | Consistent | Direct | Precise | RD 0.021 (0.009 to 0.034) | Moderate
Anorexia | 1; 175 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.077 (0.014 to 0.140) | Insufficient
Anxiety | 7^b^; 1,461 | Medium; RCTs | Consistent | Direct | Imprecise | RD 0.007 (-0.022 to 0.036) | Low
Cognitive dysfunction | 1; 123 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.190 (0.038 to 0.341) | Insufficient
Diarrhea | 11^c^; 2,358 | Medium; RCTs | Consistent | Direct | Imprecise | RD 0.013 (-0.011 to 0.038) | Moderate
Dizziness | 13^d^; 2,675 | Medium; RCTs | Consistent | Direct | Precise | RD 0.063 (0.036 to 0.089) | Moderate
Headache | 17^e^; 3,347 | Medium; RCTs | Inconsistent | Direct | Imprecise | RD 0.008 (-0.019 to 0.034) | Low
Insomnia | 8^d^; 1,637 | Medium; RCTs | Consistent | Direct | Imprecise | RD 0.027 (-0.002 to 0.057) | Low
Nausea | 24^f^; 4,655 | Medium; RCTs | Consistent | Direct | Precise | RD 0.112 (0.075 to 0.149) | Moderate
Numbness / tingling / paresthesias | 1^b^; 123 | Medium; RCT | Unknown | Direct | Imprecise | RD -0.008 (-0.185 to 0.168) | Insufficient
Rash | 4^c^; 469 | Medium; RCTs | Consistent | Direct | Imprecise | RD -0.010 (-0.060 to 0.040) | Low
Suicide | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Taste abnormalities | 1; 123 | Medium; RCT | Unknown | Direct | Imprecise | RD -0.006 (-0.182 to 0.171) | Insufficient
Vision changes (blurred vision) | 2; 133 | Medium; RCTs | Inconsistent | Direct | Imprecise | RD 0.079 (-0.172 to 0.331) | Low
Vomiting | 9^b^; 2,438 | Medium; RCTs | Consistent | Direct | Precise | RD 0.043 (0.023 to 0.062) | Moderate

a Three additional studies were rated high or unclear risk of bias

b Two additional studies were rated high or unclear risk of bias

c One additional study was rated high or unclear risk of bias

d Four additional studies were rated high or unclear risk of bias

e Five additional studies were rated high or unclear risk of bias

f Seven additional studies were rated as high or unclear risk of bias

Abbreviations: AE = adverse effect; CI = confidence interval; RD = risk difference

Table D-35 Acamprosate compared with Naltrexone

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI)^a^ | Strength of Evidence Grade
Withdrawals due to AEs | 2^b^; 953 | Medium; RCT | Consistent | Direct | Imprecise | RD 0.015 (-0.04 to 0.07) | Low
Anorexia | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Anxiety | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Cognitive dysfunction | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Diarrhea | 4^b^; 836 | Low to medium; RCTs | Consistent | Direct | Imprecise | RD 0.18 (-0.02 to 0.37) | Moderate
Dizziness | 2^b^; 144 | Low to medium; RCT | Inconsistent | Direct | Imprecise | RD 0.08 (-0.23 to 0.39) | Low
Headache | 3^b^; 301 | Medium; RCT | Inconsistent | Direct | Imprecise | RD -0.056 (-0.120 to 0.008) | Low^d^
Insomnia | 2; 144 | Low to medium; RCTs | Inconsistent | Direct | Imprecise | RD 0.07 (-0.20 to 0.34) | Low
Nausea | 4^c^; 836 | Low to medium; RCTs | Consistent | Direct | Imprecise | RD -0.08 (-0.18 to 0.02) | Low^e^
Numbness / tingling / paresthesias | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Rash | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Suicide | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Taste abnormalities | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Vision changes | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Vomiting | 2; 648 | Low; RCTs | Consistent | Direct | Precise | RD -0.06 (-0.11 to -0.01) | Moderate

a In this column, a positive value favors naltrexone

b One additional study was rated high or unclear risk of bias

c Two additional studies were rated high risk of bias

d The additional study rated as high risk of bias found similar results as the medium risk of bias studies. Meta-analysis including all three found a higher risk of headache with naltrexone than with acamprosate: RD -0.087 (-0.159 to -0.015)

e Meta-analysis including the two additional studies rated as high or unclear risk of bias found a higher risk of nausea with naltrexone than with acamprosate: RD -0.096 (-0.178 to -0.015)

Abbreviations: ACA = acamprosate; AE = adverse effect; CI = confidence interval; NTX = naltrexone; RCT = randomized controlled trial; RD = risk difference

Table D-36 Nalmefene compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Withdrawals due to AEs | 5^a^; 2,054 | Medium; RCTs | Consistent | Direct | Precise | RD 0.083 (0.020 to 0.145) | Moderate
Anorexia | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Anxiety | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Cognitive dysfunction | 1^b^; 265 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.051 (0.013 to 0.088) | Insufficient
Diarrhea | 2; 1,081 | Medium; RCTs | Consistent | Direct | Precise | RD -0.031 (-0.056 to -0.006) | Moderate
Dizziness | 4^a^; 1,944 | Medium; RCTs | Consistent | Direct | Precise | RD 0.158 (0.108 to 0.207) | Moderate
Headache | 3^b^; 1,401 | Medium; RCTs | Consistent | Direct | Precise | RD 0.039 (0.007 to 0.071) | Moderate
Insomnia | 5^b^; 2,049 | Medium; RCTs | Consistent | Direct | Precise | RD 0.101 (0.061 to 0.141) | Moderate
Nausea | 5^b^; 2,049 | Medium; RCTs | Consistent | Direct | Precise | RD 0.158 (0.095 to 0.220) | Moderate
Numbness / tingling / paresthesias | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Rash | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Suicide attempts or suicidal ideation | 2^b^; 1,253 | Medium; RCTs | Consistent | Direct | Imprecise | RD -0.01 (-0.021 to 0.001) | Low
Taste abnormalities | 1; 403 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.041 (0.008 to 0.074) | Insufficient
Vision changes | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Vomiting | 3^b^; 1,679 | Medium; RCTs | Consistent | Direct | Precise | RD 0.059 (0.021 to 0.096) | Moderate

a Two additional studies were rated high or unclear risk of bias

b One additional study was rated high or unclear risk of bias

Abbreviations: AE = adverse effect; CI = confidence interval; RCT = randomized controlled trial; RD risk difference

Table D-37 Topiramate compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Withdrawals due to AEs | 2^a^; 521 | Medium; RCTs | Inconsistent | Direct | Imprecise | RD 0.065 (-0.119 to 0.248) | Low
Anorexia | 1; 371 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.128 (0.060 to 0.196) | Insufficient
Anxiety | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Cognitive dysfunction | 2; 521 | Medium; RCTs | Consistent | Direct | Precise | RD 0.084 (0.012 to 0.156) | Moderate
Diarrhea | 1^a^; 371 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.035 (-0.027 to 0.097) | Insufficient
Dizziness | 2^a^; 521 | Medium; RCTs | Consistent | Direct | Imprecise | RD 0.105 (-0.007 to 0.216) | Low
Headache | 1; 371 | Medium; RCT | Unknown | Direct | Imprecise | RD -0.079 (-0.170 to 0.012) | Insufficient
Insomnia | 1^a^; 371 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.032 (-0.046 to 0.109) | Insufficient
Nausea | 1^a^; 371 | Medium; RCT | Unknown | Direct | Imprecise | RD -0.061 (-0.130 to 0.008) | Insufficient
Numbness / tingling / paresthesias | 2^a^; 521 | Medium; RCTs | Consistent | Direct | Precise | RD 0.398 (0.325 to 0.471) | Moderate
Rash | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Suicide attempts or suicidal ideation | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Taste abnormalities | 1; 371 | Medium; RCT | Unknown | Direct | Imprecise | RD 0.182 (0.113 to 0.250) | Insufficient
Vision changes | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Vomiting | 0; 0 | NA | NA | NA | NA | NA | Insufficient

a One additional study was rated high or unclear risk of bias

Abbreviations: AE = adverse effect; CI = confidence interval; RCT = randomized controlled trial; RD risk difference

Table D-38 Valproic acid compared with placebo

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design | Consistency | Directness | Precision | Summary Effect Size (95% CI) | Strength of Evidence Grade
Withdrawals due to AEs | 1; 52 | Low; RCT | Unknown | Direct | Imprecise | RD 0.037 (-0.065 to 0.140) | Insufficient
Anorexia | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Anxiety | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Cognitive dysfunction | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Diarrhea | 1; 52 | Low; RCT | Unknown | Direct | Imprecise | RD 0.099 (-0.120 to 0.318) | Insufficient
Dizziness | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Headache | 1; 52 | Low; RCT | Unknown | Direct | Imprecise | RD 0.053 (-0.197 to 0.304) | Insufficient
Insomnia | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Nausea | 1; 52 | Low; RCT | Unknown | Direct | Imprecise | RD 0.253 (0.046 to 0.461) | Insufficient
Numbness / tingling / paresthesias | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Rash | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Suicide attempts or suicidal ideation | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Taste abnormalities | 0; 0 | NA | NA | NA | NA | NA | Insufficient
Vision changes | 1; 52 | Low; RCT | Unknown | Direct | Imprecise | RD -0.021 (-0.262 to 0.221) | Insufficient
Vomiting | 0; 0 | NA | NA | NA | NA | NA | Insufficient

Abbreviations: AE = adverse effect; CI = confidence interval; RCT = randomized controlled trial; RD risk difference

## References for Appendix D

1 Lhuintre JP, Moore N, Tran G, et al. Acamprosate appears to decrease alcohol intake in weaned alcoholics. Alcohol Alcohol. 1990;25(6):613-22. [pmid: 2085344].
2 Anton RF, O'Malley SS, Ciraulo DA, et al. Combined pharmacotherapies and behavioral interventions for alcohol dependence: the COMBINE study: a randomized controlled trial. JAMA. May. 3. 2006;295(17):2003-17. [pmid: 16670409].
3 Petrakis IL, Poling J, Levinson C, et al. Naltrexone and disulfiram in patients with alcohol dependence and comorbid psychiatric disorders. Biol Psychiatry. May. 15. 2005;57(10):1128-37. [pmid: 15866552].
4 LoCastro JS, Youngblood M, Cisler RA, et al. Alcohol treatment effects on secondary nondrinking outcomes and quality of life: the COMBINE study. J Stud Alcohol Drugs. Mar. 2009;70(2):186-96. [pmid: 19261230].
5 Morgenstern J, Kuerbis AN, Chen AC, et al. A randomized clinical trial of naltrexone and behavioral therapy for problem drinking men who have sex with men. J Consult Clin Psychol. 2012;80(5):863-75. [pmid: 22612306].
6 Pettinati HM, Gastfriend DR, Dong Q, et al. Effect of extended-release naltrexone (XR-NTX) on quality of life in alcohol-dependent patients. Alcohol Clin Exp Res. Feb. 2009;33(2):350-6. [pmid: 19053979].
7 O'Malley SS, Robin RW, Levenson AL, et al. Naltrexone alone and with sertraline for the treatment of alcohol dependence in Alaska natives and non-natives residing in rural settings: a randomized controlled trial. Alcohol Clin Exp Res. Jul. 2008;32(7):1271-83. [pmid: 18482155].
8 Laaksonen E, Koski-Jannes A, Salaspuro M, et al. A randomized, multicentre, open-label, comparative trial of disulfiram, naltrexone and acamprosate in the treatment of alcohol dependence. Alcohol Alcohol. Jan-Feb. 2008;43(1):53-61. [pmid: 17965444].
9 Morley KC, Teesson M, Reid SC, et al. Naltrexone versus acamprosate in the treatment of alcohol dependence: A multi-centre, randomized, double-blind, placebo-controlled trial. Addiction. Oct. 2006;101(10):1451-62. [pmid: 16968347].
10 Morley KC, Teesson M, Sannibale C, et al. Clinical predictors of outcome from an Australian pharmacological relapse prevention trial. Alcohol Alcohol. Nov-Dec. 2010;45(6):520-6. [pmid: 20952764].
11 Wilens TE, Adler LA, Weiss MD, et al. Atomoxetine treatment of adults with ADHD and comorbid alcohol use disorders. Drug Alcohol Depend. Jul. 1. 2008;96(1-2):145-54. [pmid: 18403134].
12 Addolorato G, Leggio L, Ferrulli A, et al. Effectiveness and safety of baclofen for maintenance of alcohol abstinence in alcohol-dependent patients with liver cirrhosis: randomised, double-blind controlled study. Lancet. Dec. 8. 2007;370(9603):1915-22. [pmid: 18068515].
13 Garbutt JC, Kampov-Polevoy AB, Gallop R, et al. Efficacy and safety of baclofen for alcohol dependence: a randomized, double-blind, placebo-controlled trial. Alcohol Clin Exp Res. Nov. 2010;34(11):1849-57. [pmid: 20662805].
14 Malec E, Malec T, Gagne MA, et al. Buspirone in the treatment of alcohol dependence: a placebo-controlled trial. Alcohol Clin Exp Res. Apr. 1996;20(2):307-12. [pmid: 8730222].
15 Malcolm R, Anton RF, Randall CL, et al. A placebo-controlled trial of buspirone in anxious inpatient alcoholics. Alcohol Clin Exp Res. Dec. 1992;16(6):1007-13. [pmid: 1335217].
16 Tiihonen J, Ryynanen OP, Kauhanen J, et al. Citalopram in the treatment of alcoholism: a double-blind placebo-controlled study. Pharmacopsychiatry. Jan. 1996;29(1):27-9. [pmid: 8852531].
17 Naranjo CA, Bremner KE, Lanctot KL. Effects of citalopram and a brief psycho-social intervention on alcohol intake, dependence and problems. Addiction. Jan. 1995;90(1):87-99. [pmid: 7888983].
18 Mason BJ, Kocsis JH, Ritvo EC, et al. A double-blind, placebo-controlled trial of desipramine for primary alcohol dependence stratified on the presence or absence of major depression. JAMA. Mar. 13. 1996;275(10):761-7. [pmid: 8598592].
19 Kabel DI, Petty F. A placebo-controlled, double-blind study of fluoxetine in severe alcohol dependence: adjunctive pharmacotherapy during and after inpatient treatment. Alcohol Clin Exp Res. Jun. 1996;20(4):780-4. [pmid: 8800399].
20 Cornelius JR, Salloum IM, Ehler JG, et al. Fluoxetine in depressed alcoholics. A double-blind, placebo-controlled trial. Arch Gen Psychiatry. Aug. 1997;54(8):700-5. [pmid: 9283504].
21 Chick J, Aschauer H, Hornik K. Efficacy of fluvoxamine in preventing relapse in alcohol dependence: a one-year, double-blind, placebo-controlled multicentre study with analysis by typology. Drug Alcohol Depend. Apr. 9. 2004;74(1):61-70. [pmid: 15072808].
22 McGrath PJ, Nunes EV, Stewart JW, et al. Imipramine treatment of alcoholics with primary depression: A placebo-controlled clinical trial. Arch Gen Psychiatry. Mar. 1996;53(3):232-40. [pmid: 8611060].
23 Mann K, Bladström A, Torup L, et al. Extending the treatment options in alcohol dependence: A randomized controlled study of as-needed nalmefene. Biol Psychiatry. 2013;73(8):706-13. 2013-12092-010. First Author & Affiliation: Mann, Karl. [pmid: 23237314].
24 Gual A, He Y, Torup L, et al. A randomised, double-blind, placebo-controlled, efficacy study of nalmefene, as-needed use, in patients with alcohol dependence. Eur Neuropsychopharmacol. 2013. Apr. 3. [pmid: 23562264].
25 Mason BJ, Ritvo EC, Morgan RO, et al. A double-blind, placebo-controlled pilot study to evaluate the efficacy and safety of oral nalmefene HCl for alcohol dependence. Alcohol. 1994;18(5):1162-7.
26 Safety and Efficacy of Nalmefene in Patients with Alcohol Dependence (SENSE). 2013.
27 Corrêa Filho JM, Baltieri DA. A pilot study of full-dose ondansetron to treat heavy-drinking men withdrawing from alcohol in Brazil. Addict Behav. 2013;38(4):2044-51. 2013-05932-027. First Author & Affiliation: Corrêa Filho, João Maria. [pmid: 23396176].
28 Kampman KM, Pettinati HM, Lynch KG, et al. A double-blind, placebo-controlled pilot trial of quetiapine for the treatment of Type A and Type B alcoholism. J Clin Psychopharmacol. Aug. 2007;27(4):344-51. [pmid: 17632217].
29 Brown ES, Garza M, Carmody TJ. A randomized, double-blind, placebo-controlled add-on trial of quetiapine in outpatients with bipolar disorder and alcohol use disorders. J Clin Psychiatry. May. 2008;69(5):701-5. [pmid: 18312058].
30 Stedman M, Pettinati HM, Brown ES, et al. A double-blind, placebo-controlled study with quetiapine as adjunct therapy with lithium or divalproex in bipolar I patients with coexisting alcohol dependence. Alcohol Clin Exp Res. Oct. 2010;34(10):1822-31. [pmid: 20626727].
31 Pettinati HM, Volpicelli JR, Luck G, et al. Double-blind clinical trial of sertraline treatment for alcohol dependence. J Clin Psychopharmacol. Apr. 2001;21(2):143-53. [pmid: 11270910].
32 Gual A, Balcells M, Torres M, et al. Sertraline for the prevention of relapse in detoxicated alcohol dependent patients with a comorbid depressive disorder: a randomized controlled trial. Alcohol Alcohol. Nov-Dec. 2003;38(6):619-25. [pmid: 14633652].
33 Baltieri DA, Daro FR, Ribeiro PL, et al. Comparing topiramate with naltrexone in the treatment of alcohol dependence. Addiction. Dec. 2008;103(12):2035-44. [pmid: 18855810].
34 Rubio G, Martinez-Gras I, Manzanares J. Modulation of impulsivity by topiramate: implications for the treatment of alcohol dependence. J Clin Psychopharmacol. Dec. 2009;29(6):584-9. [pmid: 19910725].
35 Johnson BA, Rosenthal N, Capece JA, et al. Topiramate for treating alcohol dependence: a randomized controlled trial. JAMA. Oct. 10. 2007;298(14):1641-51. [pmid: 17925516].
36 Petrakis IL, Ralevski E, Desai N, et al. Noradrenergic vs serotonergic antidepressant with or without naltrexone for veterans with PTSD and comorbid alcohol dependence. Neuropsychopharmacology. Mar. 2012;37(4):996-1004. [pmid: 22089316].