# Risk of Bias Assessments for Included Studies

Table C-1 Risk of bias assessment for RCTs and related secondary/subgroup analyses

Table C-2 Continued risk of bias assessment for RCTs and related secondary/subgroup analyses

Table C-3 Additional risk of bias questions for RCTs and related secondary/subgroup analyses that report harms

Table C-4 Risk of bias assessment for observational studies

Table C-5 Continued risk of bias assessment for observational studies

Table C-6 Additional risk of bias questions for observational studies that report harms

Table C-7 Risk of bias assessment for systematic reviews and meta-analyses

Table C-8 Continued risk of bias assessment for systematic reviews and meta-analyses

Table C-9 Risk of bias assessments for studies assessing naltrexone response and polymorphisms of the opioid receptor gene

## References for Appendix C

1 Petrakis IL, Ralevski E, Desai N, et al. Noradrenergic vs serotonergic antidepressant with or without naltrexone for veterans with PTSD and comorbid alcohol dependence. Neuropsychopharmacology. Mar. 2012;37(4):996-1004. [pmid: 22089316].
2 Kranzler HR, Armeli S, Tennen H, et al. A double-blind, randomized trial of sertraline for alcohol dependence: moderation by age of onset [corrected] and 5-hydroxytryptamine transporter-linked promoter region genotype. J Clin Psychopharmacol. Feb. 2011;31(1):22-30. [pmid: 21192139].
3 Fogaca MN, Santos-Galduroz RF, Eserian JK, et al. The effects of polyunsaturated fatty acids in alcohol dependence treatment--a double-blind, placebo-controlled pilot study. BMC Clin Pharmacol. 2011;11:10. [pmid: 21787433].
4 Ralevski E, O'Brien E, Jane JS, et al. Effects of acamprosate on cognition in a treatment study of patients with schizophrenia spectrum disorders and comorbid alcohol dependence. J Nerv Ment Dis. Jul. 2011;199(7):499-505. [pmid: 21716064].
5 Ralevski E, O'Brien E, Jane JS, et al. Treatment with acamprosate in patients with schizophrenia spectrum disorders and comorbid alcohol dependence. J Dual Diagn. 2011;7(1-2):64-73.
6 Wolwer W, Frommann N, Janner M, et al. The effects of combined acamprosate and integrative behaviour therapy in the outpatient treatment of alcohol dependence: a randomized controlled trial. Drug Alcohol Depend. Nov. 1. 2011;118(2-3):417-22. [pmid: 21621929].
7 Anton RF, Myrick H, Wright TM, et al. Gabapentin combined with naltrexone for the treatment of alcohol dependence. Am J Psychiatry. Jul. 2011;168(7):709-17. [pmid: 21454917].
8 Florez G, Saiz PA, Garcia-Portilla P, et al. Topiramate for the treatment of alcohol dependence: comparison with naltrexone. Eur Addict Res. 2011;17(1):29-36. [pmid: 20975274].
9 Garbutt JC, Kampov-Polevoy AB, Gallop R, et al. Efficacy and safety of baclofen for alcohol dependence: a randomized, double-blind, placebo-controlled trial. Alcohol Clin Exp Res. Nov. 2010;34(11):1849-57. [pmid: 20662805].
10 Stedman M, Pettinati HM, Brown ES, et al. A double-blind, placebo-controlled study with quetiapine as adjunct therapy with lithium or divalproex in bipolar I patients with coexisting alcohol dependence. Alcohol Clin Exp Res. Oct. 2010;34(10):1822-31. [pmid: 20626727].
11 Kiefer F, Witt SH, Frank J, et al. Involvement of the atrial natriuretic peptide transcription factor GATA4 in alcohol dependence, relapse risk and treatment response to acamprosate. Pharmacogenomics J. Oct. 2011;11(5):368-74. [pmid: 20585342].
12 Pettinati HM, Oslin DW, Kampman KM, et al. A double-blind, placebo-controlled trial combining sertraline and naltrexone for treating co-occurring depression and alcohol dependence. Am J Psychiatry. Jun. 2010;167(6):668-75. [pmid: 20231324].
13 Rubio G, Martinez-Gras I, Manzanares J. Modulation of impulsivity by topiramate: implications for the treatment of alcohol dependence. J Clin Psychopharmacol. Dec. 2009;29(6):584-9. [pmid: 19910725].
14 Schmitz JM, Lindsay JA, Green CE, et al. High-dose naltrexone therapy for cocaine-alcohol dependence. Am J Addict. Sep-Oct. 2009;18(5):356-62. [pmid: 19874153].
15 Brown ES, Carmody TJ, Schmitz JM, et al. A randomized, double-blind, placebo-controlled pilot study of naltrexone in outpatients with bipolar disorder and alcohol dependence. Alcohol Clin Exp Res. Nov. 2009;33(11):1863-9. [pmid: 19673746].
16 Longabaugh R, Wirtz PW, Gulliver SB, et al. Extended naltrexone and broad spectrum treatment or motivational enhancement therapy. Psychopharmacology (Berl). Oct. 2009;206(3):367-76. [pmid: 19639303].
17 Kranzler HR, Tennen H, Armeli S, et al. Targeted naltrexone for problem drinkers. J Clin Psychopharmacol. Aug. 2009;29(4):350-7. [pmid: 19593174].
18 Baltieri DA, Daro FR, Ribeiro PL, et al. Comparing topiramate with naltrexone in the treatment of alcohol dependence. Addiction. Dec. 2008;103(12):2035-44. [pmid: 18855810].
19 Baltieri DA, Daro FR, Ribeiro PL, et al. Effects of topiramate or naltrexone on tobacco use among male alcohol-dependent outpatients. Drug Alcohol Depend. Nov. 1. 2009;105(1-2):33-41. [pmid: 19595518].
20 Florez G, Saiz P, Garcia-Portilla P, et al. Association between the Stin2 VNTR polymorphism of the serotonin transporter gene and treatment outcome in alcohol-dependent patients. Alcohol Alcohol. Sep-Oct. 2008;43(5):516-22. [pmid: 18552399].
21 Oslin DW, Lynch KG, Pettinati HM, et al. A placebo-controlled randomized clinical trial of naltrexone in the context of different levels of psychosocial intervention. Alcohol Clin Exp Res. Jul. 2008;32(7):1299-308. [pmid: 18540910].
22 Arias AJ, Armeli S, Gelernter J, et al. Effects of opioid receptor gene variation on targeted nalmefene treatment in heavy drinkers. Alcohol Clin Exp Res. Jul. 2008;32(7):1159-66. [pmid: 18537939].
23 Martinotti G, Di Nicola M, Di Giannantonio M, et al. Aripiprazole in the treatment of patients with alcohol dependence: a double-blind, comparison trial vs. naltrexone. J Psychopharmacol. Mar. 2009;23(2):123-9. [pmid: 18515460].
24 Florez G, Garcia-Portilla P, Alvarez S, et al. Using topiramate or naltrexone for the treatment of alcohol-dependent patients. Alcohol Clin Exp Res. Jul. 2008;32(7):1251-9. [pmid: 18482157].
25 O'Malley SS, Robin RW, Levenson AL, et al. Naltrexone alone and with sertraline for the treatment of alcohol dependence in Alaska natives and non-natives residing in rural settings: a randomized controlled trial. Alcohol Clin Exp Res. Jul. 2008;32(7):1271-83. [pmid: 18482155].
26 Wilens TE, Adler LA, Weiss MD, et al. Atomoxetine treatment of adults with ADHD and comorbid alcohol use disorders. Drug Alcohol Depend. Jul. 1. 2008;96(1-2):145-54. [pmid: 18403134].
27 Brown ES, Garza M, Carmody TJ. A randomized, double-blind, placebo-controlled add-on trial of quetiapine in outpatients with bipolar disorder and alcohol use disorders. J Clin Psychiatry. May. 2008;69(5):701-5. [pmid: 18312058].
28 Anton RF, Oroszi G, O'Malley S, et al. An evaluation of mu-opioid receptor (OPRM1) as a predictor of naltrexone response in the treatment of alcohol dependence: results from the Combined Pharmacotherapies and Behavioral Interventions for Alcohol Dependence (COMBINE) study. Arch Gen Psychiatry. Feb. 2008;65(2):135-44. [pmid: 18250251].
29 Anton RF, Kranzler H, Breder C, et al. A randomized, multicenter, double-blind, placebo-controlled study of the efficacy and safety of aripiprazole for the treatment of alcohol dependence. J Clin Psychopharmacol. Feb. 2008;28(1):5-12. [pmid: 18204334].
30 Addolorato G, Leggio L, Ferrulli A, et al. Effectiveness and safety of baclofen for maintenance of alcohol abstinence in alcohol-dependent patients with liver cirrhosis: randomised, double-blind controlled study. Lancet. Dec. 8. 2007;370(9603):1915-22. [pmid: 18068515].
31 Laaksonen E, Koski-Jannes A, Salaspuro M, et al. A randomized, multicentre, open-label, comparative trial of disulfiram, naltrexone and acamprosate in the treatment of alcohol dependence. Alcohol Alcohol. Jan-Feb. 2008;43(1):53-61. [pmid: 17965444].
32 Johnson BA, Rosenthal N, Capece JA, et al. Topiramate for treating alcohol dependence: a randomized controlled trial. JAMA. Oct. 10. 2007;298(14):1641-51. [pmid: 17925516].
33 Johnson BA, Rosenthal N, Capece JA, et al. Improvement of physical health and quality of life of alcohol-dependent individuals with topiramate treatment: US multisite randomized controlled trial. Arch Intern Med. Jun. 9. 2008;168(11):1188-99. [pmid: 18541827].
34 Pettinati HM, Kampman KM, Lynch KG, et al. Gender differences with high-dose naltrexone in patients with co-occurring cocaine and alcohol dependence. J Subst Abuse Treat. Jun. 2008;34(4):378-90. [pmid: 17664051].
35 Kampman KM, Pettinati HM, Lynch KG, et al. A double-blind, placebo-controlled pilot trial of quetiapine for the treatment of Type A and Type B alcoholism. J Clin Psychopharmacol. Aug. 2007;27(4):344-51. [pmid: 17632217].
36 De Sousa AA, De Sousa J, Kapoor H. An open randomized trial comparing disulfiram and topiramate in the treatment of alcohol dependence. J Subst Abuse Treat. Jun. 2008;34(4):460-3. [pmid: 17629442].
37 Karhuvaara S, Simojoki K, Virta A, et al. Targeted nalmefene with simple medical management in the treatment of heavy drinkers: a randomized double-blind placebo-controlled multicenter study. Alcohol Clin Exp Res. Jul. 2007;31(7):1179-87. [pmid: 17451401].
38 Book SW, Thomas SE, Randall PK, et al. Paroxetine reduces social anxiety in individuals with a co-occurring alcohol use disorder. J Anxiety Disord. 2008;22(2):310-8. [pmid: 17448631].
39 Thomas SE, Randall PK, Book SW, et al. A complex relationship between co-occurring social anxiety and alcohol use disorders: what effect does treating social anxiety have on drinking?. Alcohol Clin Exp Res. Jan. 2008;32(1):77-84. [pmid: 18028529].
40 O'Malley SS, Sinha R, Grilo CM, et al. Naltrexone and cognitive behavioral coping skills therapy for the treatment of alcohol drinking and eating disorder features in alcohol-dependent women: a randomized controlled trial. Alcohol Clin Exp Res. Apr. 2007;31(4):625-34. [pmid: 17374042].
41 Gelernter J, Gueorguieva R, Kranzler HR, et al. Opioid receptor gene (OPRM1, OPRK1, and OPRD1) variants and response to naltrexone treatment for alcohol dependence: results from the VA Cooperative Study. Alcohol Clin Exp Res. Apr. 2007;31(4):555-63. [pmid: 17374034].
42 Nava F, Premi S, Manzato E, et al. Comparing treatments of alcoholism on craving and biochemical measures of alcohol consumptionst. J Psychoactive Drugs. Sep. 2006;38(3):211-7. [pmid: 17165363].
43 Morley KC, Teesson M, Reid SC, et al. Naltrexone versus acamprosate in the treatment of alcohol dependence: A multi-centre, randomized, double-blind, placebo-controlled trial. Addiction. Oct. 2006;101(10):1451-62. [pmid: 16968347].
44 Morley KC, Teesson M, Sannibale C, et al. Clinical predictors of outcome from an Australian pharmacological relapse prevention trial. Alcohol Alcohol. Nov-Dec. 2010;45(6):520-6. [pmid: 20952764].
45 Anton RF, O'Malley SS, Ciraulo DA, et al. Combined pharmacotherapies and behavioral interventions for alcohol dependence: the COMBINE study: a randomized controlled trial. JAMA. May. 3. 2006;295(17):2003-17. [pmid: 16670409].
46 Donovan DM, Anton RF, Miller WR, et al. Combined pharmacotherapies and behavioral interventions for alcohol dependence (The COMBINE Study): examination of posttreatment drinking outcomes. J Stud Alcohol Drugs. Jan. 2008;69(1):5-13. [pmid: 18080059].
47 LoCastro JS, Youngblood M, Cisler RA, et al. Alcohol treatment effects on secondary nondrinking outcomes and quality of life: the COMBINE study. J Stud Alcohol Drugs. Mar. 2009;70(2):186-96. [pmid: 19261230].
48 Greenfield SF, Pettinati HM, O'Malley S, et al. Gender differences in alcohol treatment: an analysis of outcome from the COMBINE study. Alcohol Clin Exp Res. Oct. 2010;34(10):1803-12. [pmid: 20645934].
49 Fucito LM, Park A, Gulliver SB, et al. Cigarette smoking predicts differential benefit from naltrexone for alcohol dependence. Biol Psychiatry. 2012;72(10):832-8. [pmid: 22541040].
50 Mason BJ, Goodman AM, Chabac S, et al. Effect of oral acamprosate on abstinence in patients with alcohol dependence in a double-blind, placebo-controlled trial: the role of patient motivation. J Psychiatr Res. Aug. 2006;40(5):383-93. [pmid: 16546214].
51 Hutchison KE, Ray L, Sandman E, et al. The effect of olanzapine on craving and alcohol consumption. Neuropsychopharmacology. Jun. 2006;31(6):1310-7. [pmid: 16237394].
52 Huang MC, Chen CH, Yu JM, et al. A double-blind, placebo-controlled study of naltrexone in the treatment of alcohol dependence in Taiwan. Addict Biol. Sep. 2005;10(3):289-92. [pmid: 16109592].
53 de Sousa A, de Sousa A. An open randomized study comparing disulfiram and acamprosate in the treatment of alcohol dependence. Alcohol Alcohol. Nov-Dec. 2005;40(6):545-8. [pmid: 16043433].
54 Anton RF, Moak DH, Latham P, et al. Naltrexone combined with either cognitive behavioral or motivational enhancement therapy for alcohol dependence. J Clin Psychopharmacol. Aug. 2005;25(4):349-57. [pmid: 16012278].
55 Petrakis IL, Poling J, Levinson C, et al. Naltrexone and disulfiram in patients with alcohol dependence and comorbid psychiatric disorders. Biol Psychiatry. May. 15. 2005;57(10):1128-37. [pmid: 15866552].
56 Ralevski E, Ball S, Nich C, et al. The impact of personality disorders on alcohol-use outcomes in a pharmacotherapy trial for alcohol dependence and comorbid Axis I disorders. Am J Addict. Nov-Dec. 2007;16(6):443-9. [pmid: 18058408].
57 Petrakis I, Ralevski E, Nich C, et al. Naltrexone and disulfiram in patients with alcohol dependence and current depression. J Clin Psychopharmacol. Apr. 2007;27(2):160-5. [pmid: 17414239].
58 Petrakis IL, Poling J, Levinson C, et al. Naltrexone and disulfiram in patients with alcohol dependence and comorbid post-traumatic stress disorder. Biol Psychiatry. Oct. 1. 2006;60(7):777-83. [pmid: 17008146].
59 Garbutt JC, Kranzler HR, O'Malley SS, et al. Efficacy and tolerability of long-acting injectable naltrexone for alcohol dependence: a randomized controlled trial. JAMA. Apr. 6. 2005;293(13):1617-25. [pmid: 15811981].
60 Brady KT, Sonne S, Anton RF, et al. Sertraline in the treatment of co-occurring alcohol dependence and posttraumatic stress disorder. Alcohol Clin Exp Res. Mar. 2005;29(3):395-401. [pmid: 15770115].
61 Salloum IM, Cornelius JR, Daley DC, et al. Efficacy of valproate maintenance in patients with bipolar disorder and alcoholism: a double-blind placebo-controlled study. Arch Gen Psychiatry. Jan. 2005;62(1):37-45. [pmid: 15630071].
62 Killeen TK, Brady KT, Gold PB, et al. Effectiveness of naltrexone in a community treatment program. Alcohol Clin Exp Res. Nov. 2004;28(11):1710-7. [pmid: 15547458].
63 De Sousa A, De Sousa A. A one-year pragmatic trial of naltrexone vs disulfiram in the treatment of alcohol dependence. Alcohol Alcohol. Nov-Dec. 2004;39(6):528-31. [pmid: 15525790].
64 Schmitz JM, Stotts AL, Sayre SL, et al. Treatment of cocaine-alcohol dependence with naltrexone and relapse prevention therapy. Am J Addict. Jul-Sep. 2004;13(4):333-41. [pmid: 15370932].
65 Johnson BA, Ait-Daoud N, Aubin HJ, et al. A pilot evaluation of the safety and tolerability of repeat dose administration of long-acting injectable naltrexone (Vivitrex) in patients with alcohol dependence. Alcohol Clin Exp Res. Sep. 2004;28(9):1356-61. [pmid: 15365306].
66 Johnson BA, Ait-Daoud N, Akhtar FZ, et al. Oral topiramate reduces the consequences of drinking and improves the quality of life of alcohol-dependent individuals: a randomized controlled trial. Arch Gen Psychiatry. Sep. 2004;61(9):905-12. [pmid: 15351769].
67 Kranzler HR, Wesson DR, Billot L. Naltrexone depot for treatment of alcohol dependence: a multicenter, randomized, placebo-controlled clinical trial. Alcohol Clin Exp Res. Jul. 2004;28(7):1051-9. [pmid: 15252291].
68 Anton RF, Pettinati H, Zweben A, et al. A multi-site dose ranging study of nalmefene in the treatment of alcohol dependence. J Clin Psychopharmacol. Aug. 2004;24(4):421-8. [pmid: 15232334].
69 Guardia J, Segura L, Gonzalvo B, et al. A double-blind, placebo-controlled study of olanzapine in the treatment of alcohol-dependence disorder. Alcohol Clin Exp Res. May. 2004;28(5):736-45. [pmid: 15166648].
70 Chick J, Aschauer H, Hornik K. Efficacy of fluvoxamine in preventing relapse in alcohol dependence: a one-year, double-blind, placebo-controlled multicentre study with analysis by typology. Drug Alcohol Depend. Apr. 9. 2004;74(1):61-70. [pmid: 15072808].
71 Baltieri DA, De Andrade AG. Acamprosate in alcohol dependence: a randomized controlled efficacy study in a standard clinical setting. J Stud Alcohol. Jan. 2004;65(1):136-9. [pmid: 15000513].
72 Petrakis IL, O'Malley S, Rounsaville B, et al. Naltrexone augmentation of neuroleptic treatment in alcohol abusing patients with schizophrenia. Psychopharmacology (Berl). Mar. 2004;172(3):291-7. [pmid: 14634716].
73 Ralevski E, Balachandra K, Gueorguieva R, et al. Effects of naltrexone on cognition in a treatment study of patients with schizophrenia and comorbid alcohol dependence. J Dual Diagn. 2006;2(4):53-69.
74 Gual A, Balcells M, Torres M, et al. Sertraline for the prevention of relapse in detoxicated alcohol dependent patients with a comorbid depressive disorder: a randomized controlled trial. Alcohol Alcohol. Nov-Dec. 2003;38(6):619-25. [pmid: 14633652].
75 Moak DH, Anton RF, Latham PK, et al. Sertraline and cognitive behavioral therapy for depressed alcoholics: results of a placebo-controlled trial. J Clin Psychopharmacol. Dec. 2003;23(6):553-62. [pmid: 14624185].
76 Balldin J, Berglund M, Borg S, et al. A 6-month controlled naltrexone study: combined effect with cognitive behavioral therapy in outpatient treatment of alcohol dependence. Alcohol Clin Exp Res. Jul. 2003;27(7):1142-9. [pmid: 12878920].
77 Johnson BA, Ait-Daoud N, Bowden CL, et al. Oral topiramate for treatment of alcohol dependence: a randomised controlled trial. Lancet. May. 17. 2003;361(9370):1677-85. [pmid: 12767733].
78 Ma JZ, Ait-Daoud N, Johnson BA. Topiramate reduces the harm of excessive drinking: implications for public health and primary care. Addiction. Nov. 2006;101(11):1561-8. [pmid: 17034435].
79 Kiefer F, Jahn H, Tarnaske T, et al. Comparing and combining naltrexone and acamprosate in relapse prevention of alcoholism: a double-blind, placebo-controlled study. Arch Gen Psychiatry. Jan. 2003;60(1):92-9. [pmid: 12511176].
80 Kiefer F, Helwig H, Tarnaske T, et al. Pharmacological relapse prevention of alcoholism: clinical predictors of outcome. Eur Addict Res. 2005;11(2):83-91. [pmid: 15785069].
81 Gastpar M, Bonnet U, Boning J, et al. Lack of efficacy of naltrexone in the prevention of alcohol relapse: results from a German multicenter study. J Clin Psychopharmacol. Dec. 2002;22(6):592-8. [pmid: 12454559].
82 Guardia J, Caso C, Arias F, et al. A double-blind, placebo-controlled study of naltrexone in the treatment of alcohol-dependence disorder: results from a multicenter clinical trial. Alcohol Clin Exp Res. Sep. 2002;26(9):1381-7. [pmid: 12351933].
83 Brady KT, Myrick H, Henderson S, et al. The use of divalproex in alcohol relapse prevention: a pilot study. Drug Alcohol Depend. Aug. 1. 2002;67(3):323-30. [pmid: 12127203].
84 Latt NC, Jurd S, Houseman J, et al. Naltrexone in alcohol dependence: a randomised controlled trial of effectiveness in a standard clinical setting. Med J Aust. Jun. 3. 2002;176(11):530-4. [pmid: 12064984].
85 Morris PL, Hopwood M, Whelan G, et al. Naltrexone for alcohol dependence: a randomized controlled trial. Addiction. Nov. 2001;96(11):1565-73. [pmid: 11784454].
86 Krystal JH, Cramer JA, Krol WF, et al. Naltrexone in the treatment of alcohol dependence. N Engl J Med. Dec. 13. 2001;345(24):1734-9. [pmid: 11742047].
87 Monti PM, Rohsenow DJ, Swift RM, et al. Naltrexone and cue exposure with coping and communication skills training for alcoholics: treatment process and 1-year outcomes. Alcohol Clin Exp Res. Nov. 2001;25(11):1634-47. [pmid: 11707638].
88 Rohsenow DJ, Miranda R Jr., McGeary JE, et al. Family history and antisocial traits moderate naltrexone's effects on heavy drinking in alcoholics. Exp Clin Psychopharmacol. Jun. 2007;15(3):272-81. [pmid: 17563214].
89 Rohsenow DJ, Colby SM, Monti PM, et al. Predictors of compliance with naltrexone among alcoholics. Alcohol Clin Exp Res. Oct. 2000;24(10):1542-9. [pmid: 11045863].
90 Monterosso JR, Flannery BA, Pettinati HM, et al. Predicting treatment response to naltrexone: the influence of craving and family history. Am J Addict. Summer. 2001;10(3):258-68. [pmid: 11579624].
91 Rubio G, Jimenez-Arriero MA, Ponce G, et al. Naltrexone versus acamprosate: one year follow-up of alcohol dependence treatment. Alcohol Alcohol. Sep-Oct. 2001;36(5):419-25. [pmid: 11524308].
92 Heinala P, Alho H, Kiianmaa K, et al. Targeted use of naltrexone without prior detoxification in the treatment of alcohol dependence: a factorial double-blind, placebo-controlled trial. J Clin Psychopharmacol. Jun. 2001;21(3):287-92. [pmid: 11386491].
93 Pettinati HM, Volpicelli JR, Luck G, et al. Double-blind clinical trial of sertraline treatment for alcohol dependence. J Clin Psychopharmacol. Apr. 2001;21(2):143-53. [pmid: 11270910].
94 Chick J, Anton R, Checinski K, et al. A multicentre, randomized, double-blind, placebo-controlled trial of naltrexone in the treatment of alcohol dependence or abuse. Alcohol Alcohol. Nov-Dec. 2000;35(6):587-93. [pmid: 11093966].
95 Fawcett J, Kravitz HM, McGuire M, et al. Pharmacological treatments for alcoholism: revisiting lithium and considering buspirone. Alcohol Clin Exp Res. May. 2000;24(5):666-74. [pmid: 10832908].
96 Tempesta E, Janiri L, Bignamini A, et al. Acamprosate and relapse prevention in the treatment of alcohol dependence: a placebo-controlled study. Alcohol Alcohol. Mar-Apr. 2000;35(2):202-9. [pmid: 10787398].
97 Chick J, Howlett H, Morgan MY, et al. United Kingdom Multicentre Acamprosate Study (UKMAS): a 6-month prospective study of acamprosate versus placebo in preventing relapse after withdrawal from alcohol. Alcohol Alcohol. Mar-Apr. 2000;35(2):176-87. [pmid: 10787394].
98 Anton RF, Moak DH, Waid LR, et al. Naltrexone and cognitive behavioral therapy for the treatment of outpatient alcoholics: results of a placebo-controlled trial. Am J Psychiatry. Nov. 1999;156(11):1758-64. [pmid: 10553740].
99 Anton RF, Moak DH, Latham PK, et al. Posttreatment results of combining naltrexone with cognitive-behavior therapy for the treatment of alcoholism. J Clin Psychopharmacol. Feb. 2001;21(1):72-7. [pmid: 11199951].
100 George DT, Rawlings R, Eckardt MJ, et al. Buspirone treatment of alcoholism: age of onset, and cerebrospinal fluid 5-hydroxyindolacetic acid and homovanillic acid concentrations, but not medication treatment, predict return to drinking. Alcohol Clin Exp Res. Feb. 1999;23(2):272-8. [pmid: 10069556].
101 Besson J, Aeby F, Kasas A, et al. Combined efficacy of acamprosate and disulfiram in the treatment of alcoholism: a controlled study. Alcohol Clin Exp Res. May. 1998;22(3):573-9. [pmid: 9622434].
102 Poldrugo F. Acamprosate treatment in a long-term community-based alcohol rehabilitation programme. Addiction. Nov. 1997;92(11):1537-46. [pmid: 9519495].
103 Oslin D, Liberto JG, O'Brien J, et al. Naltrexone as an adjunctive treatment for older patients with alcohol dependence. Am J Geriatr Psychiatry. Fall. 1997;5(4):324-32. [pmid: 9363289].
104 Volpicelli JR, Rhines KC, Rhines JS, et al. Naltrexone and alcohol dependence. Role of subject compliance. Arch Gen Psychiatry. Aug. 1997;54(8):737-42. [pmid: 9283509].
105 Cornelius JR, Salloum IM, Ehler JG, et al. Fluoxetine in depressed alcoholics. A double-blind, placebo-controlled trial. Arch Gen Psychiatry. Aug. 1997;54(8):700-5. [pmid: 9283504].
106 Cornelius JR, Salloum IM, Cornelius MD, et al. Preliminary report: double-blind, placebo-controlled study of fluoxetine in depressed alcoholics. Psychopharmacol Bull. 1995;31(2):297-303. [pmid: 7491382].
107 Pelc I, Verbanck P, Le Bon O, et al. Efficacy and safety of acamprosate in the treatment of detoxified alcohol-dependent patients. A 90-day placebo-controlled dose-finding study. Br J Psychiatry. Jul. 1997;171:73-7. [pmid: 9328500].
108 Sass H, Soyka M, Mann K, et al. Relapse prevention by acamprosate. Results from a placebo-controlled study on alcohol dependence. Arch Gen Psychiatry. Aug. 1996;53(8):673-80. [pmid: 8694680].
109 Kabel DI, Petty F. A placebo-controlled, double-blind study of fluoxetine in severe alcohol dependence: adjunctive pharmacotherapy during and after inpatient treatment. Alcohol Clin Exp Res. Jun. 1996;20(4):780-4. [pmid: 8800399].
110 Whitworth AB, Fischer F, Lesch OM, et al. Comparison of acamprosate and placebo in long-term treatment of alcohol dependence. Lancet. May. 25. 1996;347(9013):1438-42. [pmid: 8676626].
111 Malec E, Malec T, Gagne MA, et al. Buspirone in the treatment of alcohol dependence: a placebo-controlled trial. Alcohol Clin Exp Res. Apr. 1996;20(2):307-12. [pmid: 8730222].
112 Mason BJ, Kocsis JH, Ritvo EC, et al. A double-blind, placebo-controlled trial of desipramine for primary alcohol dependence stratified on the presence or absence of major depression. JAMA. Mar. 13. 1996;275(10):761-7. [pmid: 8598592].
113 McGrath PJ, Nunes EV, Stewart JW, et al. Imipramine treatment of alcoholics with primary depression: A placebo-controlled clinical trial. Arch Gen Psychiatry. Mar. 1996;53(3):232-40. [pmid: 8611060].
114 Tiihonen J, Ryynanen OP, Kauhanen J, et al. Citalopram in the treatment of alcoholism: a double-blind placebo-controlled study. Pharmacopsychiatry. Jan. 1996;29(1):27-9. [pmid: 8852531].
115 Kranzler HR, Burleson JA, Korner P, et al. Placebo-controlled trial of fluoxetine as an adjunct to relapse prevention in alcoholics. Am J Psychiatry. Mar. 1995;152(3):391-7. [pmid: 7864265].
116 Paille FM, Guelfi JD, Perkins AC, et al. Double-blind randomized multicentre trial of acamprosate in maintaining abstinence from alcohol. Alcohol Alcohol. Mar. 1995;30(2):239-47. [pmid: 7662044].
117 Naranjo CA, Bremner KE, Lanctot KL. Effects of citalopram and a brief psycho-social intervention on alcohol intake, dependence and problems. Addiction. Jan. 1995;90(1):87-99. [pmid: 7888983].
118 Volpicelli JR, Clay KL, Watson NT, et al. Naltrexone in the treatment of alcoholism: predicting response to naltrexone. J Clin Psychiatry. Suppl 7. 1995;56:39-44. [pmid: 7673104].
119 Kranzler HR, Burleson JA, Del Boca FK, et al. Buspirone treatment of anxious alcoholics. A placebo-controlled trial. Arch Gen Psychiatry. Sep. 1994;51(9):720-31. [pmid: 8080349].
120 Malcolm R, Anton RF, Randall CL, et al. A placebo-controlled trial of buspirone in anxious inpatient alcoholics. Alcohol Clin Exp Res. Dec. 1992;16(6):1007-13. [pmid: 1335217].
121 O'Malley SS, Jaffe AJ, Chang G, et al. Naltrexone and coping skills therapy for alcohol dependence. A controlled study. Arch Gen Psychiatry. Nov. 1992;49(11):881-7. [pmid: 1444726].
122 O'Malley SS, Jaffe AJ, Chang G, et al. Six-month follow-up of naltrexone and psychotherapy for alcohol dependence. Arch Gen Psychiatry. Mar. 1996;53(3):217-24. [pmid: 8611058].
123 Lhuintre JP, Moore N, Tran G, et al. Acamprosate appears to decrease alcohol intake in weaned alcoholics. Alcohol Alcohol. 1990;25(6):613-22. [pmid: 2085344].
124 Fuller RK, Branchey L, Brightwell DR, et al. Disulfiram treatment of alcoholism. A Veterans Administration cooperative study. JAMA. Sep. 19. 1986;256(11):1449-55. [pmid: 3528541].
125 Lhuintre JP, Daoust M, Moore ND, et al. Ability of calcium bis acetyl homotaurine, a GABA agonist, to prevent relapse in weaned alcoholics. Lancet. May. 4. 1985;1(8436):1014-6. [pmid: 2859465].
126 Ling W, Weiss DG, Charuvastra VC, et al. Use of disulfiram for alcoholics in methadone maintenance programs. A Veterans Administration Cooperative Study. Arch Gen Psychiatry. Aug. 1983;40(8):851-4. [pmid: 6347118].
127 Fuller RK, Roth HP. Disulfiram for the treatment of alcoholism. An evaluation in 128 men. Ann Intern Med. Jun. 1979;90(6):901-4. [pmid: 389121].
128 Gual A, Lehert P. Acamprosate during and after acute alcohol withdrawal: a double-blind placebo-controlled study in Spain. Alcohol Alcohol. 2001;36(5):413-8. CN-00367117. [pmid: 11524307].
129 Coskunol H, Gökden O, Ercan ES, et al. Long-term efficacy of sertraline in the prevention of alcoholic relapses in alcohol-dependent patients: a single-center, double-blind, randomized, placebo-controlled, parallel-group study. Current Therapeutic Research. 2002;63(11):759-71.
130 Kranzler HR, Armeli S, Covault J, et al. Variation in OPRM1 moderates the effect of desire to drink on subsequent drinking and its attenuation by naltrexone treatment. Addiction Biology. 2013;18(1):193-201. [pmid: 22784013].
131 Ahmadi J, Ahmadi N. A double blind, placebo-controlled study of naltrexone in the treatment of alcohol dependence. German Journal of Psychiatry. 2002;5(4):85-9.
132 Ahmadi J, Babaeebeigi M, Maany I, et al. Naltrexone for alcohol-dependent patients. Ir J Med Sci. Jan-Mar. 2004;173(1):34-7. [pmid: 15732235].
133 Mason BJ, Salvato FR, Williams LD, et al. A double-blind, placebo-controlled study of oral nalmefene for alcohol dependence. Arch Gen Psychiatry. 1999;56(8):719-24. [pmid: 10435606].
134 Geerlings PJ, Ansoms C, Van Den Brink W. Acamprosate and prevention of relapse in alcoholics. Results of a randomized, placebo-controlled, double-blind study in out-patient alcoholics in the Netherlands, Belgium and Luxembourg. Eur Addict Res. 1997;3(3):129-37.
135 Mason BJ, Ritvo EC, Morgan RO, et al. A double-blind, placebo-controlled pilot study to evaluate the efficacy and safety of oral nalmefene HCl for alcohol dependence. Alcohol. 1994;18(5):1162-7.
136 Tollefson GD, Lancaster SP, Montague-Clouse J. The association of buspirone and its metabolite 1-pyrimidinylpiperazine in the remission of comorbid anxiety with depressive features and alcohol dependency. Psychopharmacol Bull. 1991;27(2):163-70. [pmid: 1924664].
137 Tollefson GD, Montague-Clouse J, Tollefson SL. Treatment of comorbid generalized anxiety in a recently detoxified alcoholic population with a selective serotonergic drug (buspirone). J Clin Psychopharmacol. Feb. 1992;12(1):19-26. [pmid: 1552035].
138 Lee A, Tan S, Lim D, et al. Naltrexone in the treatment of male alcoholics—An effectiveness study In Singapore. Drug and Alcohol Review. 2001;20(2):193-9.
139 Carroll K, Ziedonis D, O'Malley SS, et al. Pharmacologic interventions for alcohol- and cocaine-abusing individuals: A pilot study of disulfiram vs. naltrexone. Am J Addict. 1993;2(1):77-9.
140 Morgenstern J, Kuerbis AN, Chen AC, et al. A randomized clinical trial of naltrexone and behavioral therapy for problem drinking men who have sex with men. J Consult Clin Psychol. 2012;80(5):863-75. [pmid: 22612306].
141 Pelc I, Le Bon O, Lehert P, et al. Acamprosate in the Treatment of Alcohol Dependence: A 6-Month Postdetoxification Study. Soyka M, editor. Acamprosate in Relapse Prevention of Alcoholism. Springer Berlin Heidelberg. 1996:133-42.
142 Pelc I, Le Bon O, Verbanck P, et al. Calciumacetylhomotaurinate for maintaining abstinence in weaned alcoholic patients: a placebo-controlled double-blind multi-centre study. Naranjo CA, Sellers EM, editors. Novel Pharmacological Interventions for Alcoholism. New York. Springer-Verlag. 1992.
143 Berger L, Fisher M, Brondino M, et al. Efficacy of acamprosate for alcohol dependence in a family medicine setting in the United States: A randomized, double-blind, placebo-controlled study. Alcohol. 2013;37(4):668-74. 2013-11440-015. First Author & Affiliation: Berger, Lisa. [pmid: 23134193].
144 Corrêa Filho JM, Baltieri DA. A pilot study of full-dose ondansetron to treat heavy-drinking men withdrawing from alcohol in Brazil. Addict Behav. 2013;38(4):2044-51. 2013-05932-027. First Author & Affiliation: Corrêa Filho, João Maria. [pmid: 23396176].
145 Mann K, Bladström A, Torup L, et al. Extending the treatment options in alcohol dependence: A randomized controlled study of as-needed nalmefene. Biol Psychiatry. 2013;73(8):706-13. 2013-12092-010. First Author & Affiliation: Mann, Karl. [pmid: 23237314].
146 Gual A, He Y, Torup L, et al. A randomised, double-blind, placebo-controlled, efficacy study of nalmefene, as-needed use, in patients with alcohol dependence. Eur Neuropsychopharmacol. 2013. Apr. 3. [pmid: 23562264].
147 ALK21-014: Efficacy and Safety of Medisorb® Naltrexone (VIVITROL®) After Enforced Abstinence. 2011.
148 Safety and Efficacy of Nalmefene in Patients with Alcohol Dependence (SENSE). 2013.
149 Litten RZ, Ryan ML, Fertig JB, et al. A double-blind, placebo-controlled trial assessing the efficacy of varenicline tartrate for alcohol dependence. J Addict Med. Jul-Aug. 2013;7(4):277-86. [pmid: 23728065].
150 Mann K, Lemenager T, Hoffmann S, et al. Results of a double-blind, placebo-controlled pharmacotherapy trial in alcoholism conducted in Germany and comparison with the US COMBINE study. Addict Biol. 2012. Dec. 12. [pmid: 23231446].
151 Anton RF. Testing combined pharmacotherapies and behavioral interventions for alcohol dependence (the COMBINE study): A pilot feasibility study. Alcohol. 2003;27(7):1123-31.
152 Kranzler HR, Armeli S, Tennen H. Post-treatment outcomes in a double-blind, randomized trial of sertraline for alcohol dependence. Alcohol Clin Exp Res. Apr. 2012;36(4):739-44. [pmid: 21981418].
153 Rohsenow DJ, Colby SM, Monti PM, et al. Pedictors of compliance with naltrexone among alcoholics. Alcohol. 2000;24(10):1542-9.
154 Cornelius JR, Salloum IM, Ehler JG, et al. Double-blind fluoxetine in depressed alcoholic smokers. Psychopharmacol Bull. 1997;33(1):165-70. [pmid: 9133770].
155 Coller JK, Cahill S, Edmonds C, et al. OPRM1 A118G genotype fails to predict the effectiveness of naltrexone treatment for alcohol dependence. Pharmacogenet Genomics. Dec. 2011;21(12):902-5. [pmid: 21946895].
156 Kim SG, Kim CM, Choi SW, et al. A mu opioid receptor gene polymorphism (A118G) and naltrexone treatment response in adherent Korean alcohol-dependent patients. Psychopharmacology (Berl). 2009;201(4):611-8. [pmid: 18795264].
157 Narayama PL, Gupta AK, Sharma PK. Use of anti-craving agents in soldiers with alcohol dependence syndrome. Medical Journal Armed Forces India. 2008;64(4):320-4.
158 Mutschler J, Abbruzzese E, Witt SH, et al. Functional polymorphism of the dopamine β-hydroxylase gene is associated with increased risk of disulfiram-induced adverse effects in alcohol-dependent patients. J Clin Psychopharmacol. 2012;32(4):578-80. [pmid: 22760354].
159 Rubio G, Ponce G, Jiménez-Arriero MA, et al. Polymorphism for m-opioid receptor (+118) as a prognostic variable of naltrexone in alcohol dependence treatment: Preliminary results. Eur Neuropsychopharmacol. 2002;12:397. [pmid: 12208557].
160 Mason BJ, Lehert P. Acamprosate for alcohol dependence: a sex-specific meta-analysis based on individual patient data. Alcohol Clin Exp Res. Mar. 2012;36(3):497-508. [pmid: 21895717].
161 Jorgensen CH, Pedersen B, Tonnesen H. The efficacy of disulfiram for the treatment of alcohol use disorder. Alcohol Clin Exp Res. Oct. 2011;35(10):1749-58. [pmid: 21615426].
162 Rosner S, Hackl-Herrwerth A, Leucht S, et al. Acamprosate for alcohol dependence. Cochrane Database Syst Rev. 2010;(9):CD004332. [pmid: 20824837].
163 Rösner S, Hackl-Herrwerth A, Leucht S, et al. Opioid antagonists for alcohol dependence. Cochrane Database Syst Rev. 2010;(12):CD001867. [pmid: 21154349].
164 Lobmaier P, Kornor H, Kunoe N, et al. Sustained-Release Naltrexone For Opioid Dependence. Cochrane Database Syst Rev. 2008;(2):CD006140. [pmid: 18425938].
165 National Collaborating Centre for Mental Health. Alcohol-Use Disorders. Diagnosis, Assessment and Management of Harmful Drinking and Alcohol Dependence. National Clinical Practice Guideline 115 National Institute for Health & Clinical Excellence. London. Psychiatrists TBPSaTRCo. 2011. http://guidance.nice.org.uk/CG115/Guidance/pdf/English.