# Excluded Studies

Exclusion Codes
- X1: Not published in English
- X2: Not original research
- X3: Ineligible population
- X4: Ineligible intervention
- X5: Ineligible comparator
- X6: Ineligible outcome
- X7: Ineligible setting
- X8: Ineligible study design
- X9: Treatment duration less than 12 weeks
- X10: Systematic review with search that ended prior to 2007

1 Preventing Alcohol Withdrawal With Oral Baclofen. Exclusion Code: X7.
2 Testing combined pharmacotherapies and behavioral interventions in alcohol dependence: Rationale and methods. Alcohol. 2003;27(7):1107-22. Exclusion Code: X6.
3 The Effects of Quetiapine (Seroquel XR) on Sleep During Alcohol Abstinence. 2013. Exclusion Code: X9.
4 Oral vs. Injectable Naltrexone for Hospitalized Veterans With Alcohol Dependence. 2014. Exclusion Code: X7.
5 Extended-Release vs. Oral Naltrexone Alcohol Treatment in Primary Care. 2018. Exclusion Code: X5.
6 Harm Reduction With Pharmacotherapy (HaRP). 2018. Exclusion Code: X8.
7 Abtahi MA, Abtahi SH, Fazel F, et al. Topiramate and the vision: A systematic review. Clin Opthalmol. 2012;6(1):117-31. Exclusion Code: X3.
8 Addolorato G, Caputo F, Capristo E, et al. Baclofen efficacy in reducing alcohol craving and intake: a preliminary double-blind randomized controlled study. Alcohol Alcohol. Sep-Oct. 2002;37(5):504-8. Exclusion Code: X9. [pmid: 12217947].
9 Addolorato G, Leggio L, Ferrulli A, et al. Dose-response effect of baclofen in reducing daily alcohol intake in alcohol dependence: secondary analysis of a randomized, double-blind, placebo-controlled trial. Alcohol Alcohol. May-Jun. 2011;46(3):312-7. Exclusion Code: X8. [pmid: 21414953].
10 Adler L, Wilens T, Zhang S, et al. Retrospective safety analysis of atomoxetine in adult ADHD patients with or without comorbid alcohol abuse and dependence. Am J Addict. Sep-Oct. 2009;18(5):393-401. Exclusion Code: X8. [pmid: 19874159].
11 Agosti V, Nunes EV, O'shea D. Do manualized psychosocial interventions help reduce relapse among alcohol-dependent adults treated with naltrexone or placebo? A meta-analysis. Am J Addict. 2012;21(6):501-7. Exclusion Code: X5. [pmid: 23082827].
12 Aguiar P, Neto D, Lambaz R, et al. Prognostic factors during outpatient treatment for alcohol dependence: Cohort study with 6 months of treatment follow-up. Alcohol Alcohol. 2012;47(6):702-10. Exclusion Code: X5. [pmid: 22986010].
13 Ait-Daoud N, Johnson BA, Javors M, et al. Combining ondansetron and naltrexone treats biological alcoholics: corroboration of self-reported drinking by serum carbohydrate deficient transferrin, a biomarker. Alcohol Clin Exp Res. Jun. 2001;25(6):847-9. Exclusion Code: X4. [pmid: 11410720].
14 Ait-Daoud N, Johnson BA, Prihoda TJ, et al. Combining ondansetron and naltrexone reduces craving among biologically predisposed alcoholics: preliminary clinical evidence. Psychopharmacology (Berl). Feb. 2001;154(1):23-7. Exclusion Code: X4. [pmid: 11292002].
15 Aliyev NN. Trial of interferon in chronic alcoholism. Psychiatry Res. 1994;54(3):307-8. Exclusion Code: X5. [pmid: 7792335].
16 Allen JP, Sillamaukee P, Anton R. Contribution of carbohydrate deficient transferrin to gamma glutamyl transpeptidase in evaluating progress of patients in treatment for alcoholism. Alcohol Clin Exp Res. Jan. 1999;23(1):115-20. Exclusion Code: X4. [pmid: 10029211].
17 Altamura AC, Mauri MC, Girardi T, et al. Alcoholism and depression: a placebo controlled study with viloxazine. Int J Clin Pharmacol Res. 1990;10(5):293-8. Exclusion Code: X6. [pmid: 2079386].
18 Altintoprak AE, Zorlu N, Coskunol H, et al. Effectiveness and tolerability of mirtazapine and amitriptyline in alcoholic patients with co-morbid depressive disorder: a randomized, double-blind study. Hum Psychopharmacol. Jun. 2008;23(4):313-9. Exclusion Code: X5. [pmid: 18327889].
19 Anderson N, Oliver MN. Oral topiramate effective for alcoholism. J Fam Pract. 2003;52(9):682-7. Exclusion Code: X2. [pmid: 12967537].
20 Angelone SM, Bellini L, Di Bella D, et al. Effects of fluvoxamine and citalopram in maintaining abstinence in a sample of Italian detoxified alcoholics. Alcohol Alcohol. Mar-Apr. 1998;33(2):151-6. Exclusion Code: X8. [pmid: 9566477].
21 Anton RF. Naltrexone for the management of alcohol dependence. N Engl J Med. Aug. 14. 2008;359(7):715-21. Exclusion Code: X2. [pmid: 18703474].
22 Anton RF, Moak DH, Latham PK. The obsessive compulsive drinking scale: A new method of assessing outcome in alcoholism treatment studies. Arch Gen Psychiatry. Mar. 1996;53(3):225-31. Exclusion Code: X6. [pmid: 8611059].
23 Anton RF, Myrick H, Baros AM, et al. Efficacy of a combination of flumazenil and gabapentin in the treatment of alcohol dependence: relationship to alcohol withdrawal symptoms. J Clin Psychopharmacol. Aug. 2009;29(4):334-42. Exclusion Code: X4. [pmid: 19593171].
24 Armeli S, Feinn R, Tennen H, et al. The effects of naltrexone on alcohol consumption and affect reactivity to daily interpersonal events among heavy drinkers. Exp Clin Psychopharmacol. May. 2006;14(2):199-208. Exclusion Code: X6. [pmid: 16756424].
25 Auriacombe M, Robinson M, Grabot D, et al. Naltrexone is ineffective to prevent relapse to alcohol in a realistic outpatient setting. A double blind one-year controlled study. [abstract]. College of Problems of Drug Dependence. 2000. San Juan, Puerto Rico. Exclusion Code: X8.
26 Back SE, Brady KT, Sonne SC, et al. Symptom improvement in co-occurring PTSD and alcohol dependence. J Nerv Ment Dis. Sep. 2006;194(9):690-6. Exclusion Code: X6. [pmid: 16971821].
27 Balldin J, Berggren U, Engel J, et al. Effect of citalopram on alcohol intake in heavy drinkers. Alcohol Clin Exp Res. Oct. 1994;18(5):1133-6. Exclusion Code: X3. [pmid: 7847595].
28 Baltieri DA, Correa Filho JM. Role of two clusters of male alcoholics in treatment retention. Eur Addict Res. 2012;18(4):201-11. Exclusion Code: X6. [pmid: 22507891].
29 Baltieri DA, de Andrade AG. Efficacy of acamprosate in the treatment of alcohol-dependent outpatients. Rev Bras Psiquiatr. Sep. 2003;25(3):156-9. Exclusion Code: X6. [pmid: 12975689].
30 Barber TJ, Marett B, Waldron S, et al. Are disulfiram-like reactions associated with abacavir-containing antiretroviral regimens in clinical practice?. AIDS. Aug. 20. 2007;21(13):1823-4. Exclusion Code: X8. [pmid: 17690585].
31 Baros AM, Latham PK, Anton RF. Naltrexone and cognitive behavioral therapy for the treatment of alcohol dependence: do sex differences exist?. Alcohol Clin Exp Res. May. 2008;32(5):771-6. Exclusion Code: X8. [pmid: 18336635].
32 Baros AM, Latham PK, Moak DH, et al. What role does measuring medication compliance play in evaluating the efficacy of naltrexone?. Alcohol Clin Exp Res. Apr. 2007;31(4):596-603. Exclusion Code: X6. [pmid: 17374038].
33 Barrias JA, Chabac S, Ferreira L, et al. Acamprosate: multicenter Portuguese efficacy and tolerance evaluation study. Psiquiatria Clinica. 1997;18:149-60. Exclusion Code: X1.
34 Basu D, Jhirwal OP, Mattoo SK. Clinical characterization of use of acamprosate and naltrexone: data from an addiction center in India. Am J Addict. Jul-Sep. 2005;14(4):381-95. Exclusion Code: X8. [pmid: 16188718].
35 Beresford TP, Arciniegas D, Clapp L, et al. Reduction of affective lability and alcohol use following traumatic brain injury: a clinical pilot study of anti-convulsant medications. Brain Inj. Apr. 2005;19(4):309-13. Exclusion Code: X6. [pmid: 15832875].
36 Berglund KJ, Balldin J, Berggren U, et al. Childhood maltreatment affects the serotonergic system in male alcohol-dependent individuals. Alcohol. 2013;37(5):757-62. 2013-15234-008. First Author & Affiliation: Berglund, Kristina J. Exclusion Code: X8. [pmid: 23384117].
37 Bergstrom B, Ohlin H, Lindblom PE, et al. Is disulfiram implantation effective?. Lancet. Jan. 2. 1982;1(8262):49-50. Exclusion Code: X5. [pmid: 6119442].
38 Blomqvist O, Hernandez-Avila CA, Burleson JA, et al. Self-Efficacy as a Predictor of Relapse during Treatment for Alcohol Dependence. Addict Disord Their Treat. 2003;2(4):135-45. Exclusion Code: X8.
39 Bonnet U, Specka M, Leweke FM, et al. Gabapentin's acute effect on mood profile -- a controlled study on patients with alcohol withdrawal. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 30. 2007;31(2):434-8. Exclusion Code: X3. [pmid: 17178181].
40 Brady KT, Sonne SC, Roberts JM. Sertraline treatment of comorbid posttraumatic stress disorder and alcohol dependence. J Clin Psychiatry. Nov. 1995;56(11):502-5. Exclusion Code: X5. [pmid: 7592501].
41 Brahen LS, Capone T, Heller RC, et al. Controlled clinical study of naltrexone side effects comparing first-day doses and maintenance regimens. Am J Drug Alcohol Abuse. 1978;5(2):235-45. CN-00019998. Exclusion Code: X3. [pmid: 747177].
42 Brahen LS, Henderson RK, Capone T, et al. Naltrexone treatment in a jail work-release program. J Clin Psychiatry. 1984;45(9, Sect 2):49-52. Exclusion Code: X3. [pmid: 6469937].
43 Brower KJ, Myra Kim H, Strobbe S, et al. A randomized double-blind pilot trial of gabapentin versus placebo to treat alcohol dependence and comorbid insomnia. Alcohol Clin Exp Res. Aug. 2008;32(8):1429-38. Exclusion Code: X9. [pmid: 18540923].
44 Brunette MF, O'Keefe C, Zimmet S, et al. Clozapine, olanzapine, or typical antipsychotics for alcohol use disorder in patients with schizophrenia. J Dual Diagn. 2008;4(4):344-54. Exclusion Code: X8.
45 Bruno F. Buspirone in the treatment of alcoholic patients. Psychopathology. Suppl 1. 1989;22:49-59. Exclusion Code: X9. [pmid: 2657838].
46 Bujarski S, O'Malley SS, Lunny K, et al. The effects of drinking goal on treatment outcome for alcoholism. J Consult Clin Psychol. 2013;81(1):13-22. Exclusion Code: X6. [pmid: 23231573].
47 Buri C, Moggi F, Giovanoli A, et al. Prescription procedures in medication for relapse prevention after inpatient treatment for alcohol use disorders in Switzerland. Alcohol Alcohol. Jul-Aug. 2007;42(4):333-9. Exclusion Code: X8. [pmid: 17517820].
48 Burman WJ, Terra M, Breese P, et al. Lack of toxicity from concomitant directly observed disulfiram and isoniazid-containing therapy for active tuberculosis. Int J Tuberc Lung Dis. 2002;6(9):839-42. Exclusion Code: X8. [pmid: 12234141].
49 Capone C, Kahler CW, Swift RM, et al. Does family history of alcoholism moderate naltrexone's effects on alcohol use?. J Stud Alcohol Drugs. Jan. 2011;72(1):135-40. Exclusion Code: X5. [pmid: 21138720].
50 Caputo F, Addolorato G, Lorenzini F, et al. Gamma-hydroxybutyric acid versus naltrexone in maintaining alcohol abstinence: an open randomized comparative study. Drug Alcohol Depend. May. 1. 2003;70(1):85-91. Exclusion Code: X8. [pmid: 12681528].
51 Caputo F, Addolorato G, Stoppo M, et al. Comparing and combining gamma-hydroxybutyric acid (GHB) and naltrexone in maintaining abstinence from alcohol: an open randomised comparative study. Eur Neuropsychopharmacol. Dec. 2007;17(12):781-9. Exclusion Code: X5. [pmid: 17611081].
52 Carroll KM, Nich C, Ball SA, et al. Treatment of cocaine and alcohol dependence with psychotherapy and disulfiram. Addiction. May. 1998;93(5):713-27. Exclusion Code: X5. [pmid: 9692270].
53 Carter AC, Miranda R, Gwaltney C, et al. Naltrexone's impact on alcohol expectancies in heavy drinkers. Alcoholism. 2010;34(6):177A. Exclusion Code: X3.
54 Castro LA, Laranjeira R. A double blind, randomized and placebo-controlled clinical trial with naltrexone and brief intervention in outpatient treatment of alcohol dependence. J Bras Psiquiatr. 2009;58(2):79-85. CN-00754994. Exclusion Code: X1.
55 Chen J, Johnson BA, Wang XQ, et al. Trajectory analyses in alcohol treatment research. Alcohol Clin Exp Res. Aug. 2012;36(8):1442-8. Exclusion Code: X6. [pmid: 22525000].
56 Chick J, Gough K, Falkowski W, et al. Disulfiram treatment of alcoholism. Br J Psychiatry. Jul. 1992;161:84-9. Exclusion Code: X8. [pmid: 1638335].
57 Christensen JK. Side-effects after Antabuse--myths or reality?. Br J Clin Pract Suppl. 1984;36:21-8. Exclusion Code: X7. [pmid: 6437426].
58 Christensen JK, Ronsted P, Vaag UH. Side effects after disulfiram. Comparison of disulfiram and placebo in a double-blind multicentre study. Acta Psychiatr Scand. Apr. 1984;69(4):265-73. Exclusion Code: X9. [pmid: 6372372].
59 Ciraulo DA, Dong Q, Silverman BL, et al. Early treatment response in alcohol dependence with extended-release naltrexone. J Clin Psychiatry. Feb. 2008;69(2):190-5. Exclusion Code: X9. [pmid: 18348601].
60 Collins GB, Janesz JW, Byerly-Thrope J. The Cleveland Clinic Alcohol Rehabilitation Program: A treatment outcome study. A preliminary report. Cleve Clin Q. 1985;52(2):245-51. Exclusion Code: X4. [pmid: 4028426].
61 Connery H, Greenfield S, Livchits V, et al. Training and fidelity monitoring of alcohol treatment interventions integrated into routine tuberculosis care in Tomsk, Russia: The IMPACT effectiveness trial. Subst Use Misuse. 2013;48(9):806-14. 2013-21629-011. First Author & Affiliation: Connery, Hilary. Exclusion Code: X5.
62 Corbin WR, Scott C, Leeman RF, et al. Early Subjective Response and Acquired Tolerance as Predictors of Alcohol Use and Related Problems in a Clinical Sample. Alcohol. 2013. Exclusion Code: X6.
63 Cornelius JR, Perkins KA, Salloum IM, et al. Fluoxetine versus placebo to decrease the smoking of depressed alcoholic patients. J Clin Psychopharmacol. 1999;19(2):183-4. Exclusion Code: X8. [pmid: 10211921].
64 Cornelius JR, Salloum IM, Cornelius MD, et al. Preliminary report: double-blind, placebo-controlled study of fluoxetine in depressed alcoholics. Psychopharmacol Bull. 1995;31(2):297-303. Exclusion Code: X6. [pmid: 7491382].
65 Cornelius JR, Salloum IM, Ehler JG, et al. Double-blind fluoxetine in depressed alcoholic smokers. Psychopharmacol Bull. 1997;33(1):165-70. Exclusion Code: X8. [pmid: 9133770].
66 Cornelius JR, Salloum IM, Haskett RF, et al. Fluoxetine versus placebo in depressed alcoholics: a 1-year follow-up study. Addict Behav. Mar-Apr. 2000;25(2):307-10. Exclusion Code: X8. [pmid: 10795957].
67 Cornelius JR, Salloum IM, Thase ME, et al. Fluoxetine versus placebo in depressed alcoholic cocaine abusers. Psychopharmacol Bull. 1998;34(1):117-21. Exclusion Code: X8. [pmid: 9564208].
68 Cramer J, Rosenheck R, Kirk G, et al. Medication compliance feedback and monitoring in a clinical trial: predictors and outcomes. Value Health. Sep-Oct. 2003;6(5):566-73. Exclusion Code: X6. [pmid: 14627063].
69 Critchfield GC, Eddy DM. A confidence profile analysis of the effectiveness of disulfiram in the treatment of chronic alcoholism. Med Care. Dec. 1987;25(12 Suppl):S66-75. Exclusion Code: X8. [pmid: 3323686].
70 Croissant B, Diehl A, Klein O, et al. A pilot study of oxcarbazepine versus acamprosate in alcohol-dependent patients. Alcohol Clin Exp Res. Apr. 2006;30(4):630-5. Exclusion Code: X5. [pmid: 16573580].
71 Croissant B, Klein O, Gehrlein L, et al. Quetiapine in relapse prevention in alcoholics suffering from craving and affective symptoms: a case series. Eur Psychiatry. Dec. 2006;21(8):570-3. Exclusion Code: X5. [pmid: 17161284].
72 Croop RS, Faulkner EB, Labriola DF. The safety profile of naltrexone in the treatment of alcoholism. Results from a multicenter usage study. The Naltrexone Usage Study Group. Arch Gen Psychiatry. Dec. 1997;54(12):1130-5. Exclusion Code: X5. [pmid: 9400350].
73 Cutler RB. Abatement of craving in recovering alcoholics: A descriptive analysis. Addict Res Theory. 2005;13(2):111-27. Exclusion Code: X6.
74 Davidson D, Saha C, Scifres S, et al. Naltrexone and brief counseling to reduce heavy drinking in hazardous drinkers. Addict Behav. Aug. 2004;29(6):1253-8. Exclusion Code: X3. [pmid: 15236831].
75 Davidson D, Wirtz PW, Gulliver SB, et al. Naltrexone's suppressant effects on drinking are limited to the first 3 months of treatment. Psychopharmacology (Berl). Sep. 2007;194(1):1-10. Exclusion Code: X8. [pmid: 17514344].
76 DiClemente CC, Doyle SR, Donovan D. Predicting treatment seekers' readiness to change their drinking behavior in the COMBINE study. Alcohol. 2009;33(5):879-92. Exclusion Code: X4.
77 Diehl A, Ulmer L, Mutschler J, et al. Why is disulfiram superior to acamprosate in the routine clinical setting? A retrospective long-term study in 353 alcohol-dependent patients. Alcohol Alcohol. May-Jun. 2010;45(3):271-7. Exclusion Code: X8. [pmid: 20348436].
78 Dinh-Zarr Tho B, Goss Cynthia W, Heitman E, et al. Interventions for preventing injuries in problem drinkers. Cochrane Database Syst Rev. 2004;(3):CD001857. Exclusion Code: X4. [pmid: 15266456].
79 Dongier M. What treatment options exist for alcohol abuse?. J Psychiatry Neurosci. Jan. 2003;28(1):80. Exclusion Code: X2. [pmid: 12587852].
80 Donovan D, Mattson ME, Cisler RA, et al. Quality of life as an outcome measure in alcoholism treatment research. J Stud Alcohol. 2005;66(SUPPL. 15):119-39. Exclusion Code: X5.
81 Doty P, De Wit H. Effects of naltrexone pretreatment on the subjective and performance effects of ethanol in social drinkers. Behav Pharmacol. 1995;6(4):386-94. Exclusion Code: X3. [pmid: 11224347].
82 Drake RE, Mercer-McFadden C, Mueser KT, et al. Review of integrated mental health and substance abuse treatment for patients with dual disorders (Structured abstract). Schizophr Bull. 1998:589-608. Exclusion Code: X2. [pmid: 9853791].
83 Drobes DJ, Anton RF. Drinking in alcoholics following an alcohol challenge research protocol. J Stud Alcohol. Mar. 2000;61(2):220-4. Exclusion Code: X7. [pmid: 10757131].
84 Drobes DJ, Anton RF, Thomas SE, et al. A clinical laboratory paradigm for evaluating medication effects on alcohol consumption: naltrexone and nalmefene. Neuropsychopharmacology. Apr. 2003;28(4):755-64. Exclusion Code: X7. [pmid: 12655322].
85 Drtil J. Placebo therapy of alcohol dependent persons. Homeost Health Dis. 1997;38(4). Exclusion Code: X2.
86 Duckert F, Johnsen J. Behavioral use of disulfiram in the treatment of problem drinking. Int J Addict. May. 1987;22(5):445-54. Exclusion Code: X8. [pmid: 3596857].
87 Dundon W, Lynch KG, Pettinati HM, et al. Treatment outcomes in type A and B alcohol dependence 6 months after serotonergic pharmacotherapy. Alcohol Clin Exp Res. Jul. 2004;28(7):1065-73. Exclusion Code: X8. [pmid: 15252293].
88 Epstein EE, Rhines KC, Cook S, et al. Changes in alcohol craving and consumption by phase of menstrual cycle in alcohol dependent women. J Subst Use. 2006;11(5):323-32. Exclusion Code: X4.
89 Eriksson M, Berggren U, Blennow K, et al. Further investigation of citalopram on alcohol consumption in heavy drinkers: responsiveness possibly linked to the DRD2 A2/A2 genotype. Alcohol. May. 2001;24(1):15-23. Exclusion Code: X9. [pmid: 11524178].
90 Falk D, Wang XQ, Liu L, et al. Percentage of subjects with no heavy drinking days: Evaluation as an efficacy endpoint for alcoholclinical trials. Alcohol. 2010;34(12):2022-34. Exclusion Code: X6.
91 Fantozzi R, Caramelli L, Ledda F, et al. Biological markers and therapeutic outcome in alcoholic disease: a twelve-year survey. Klin Wochenschr. Jan. 5. 1987;65(1):27-33. Exclusion Code: X4. [pmid: 3560786].
92 Farren CK, O'Malley SS. Occurrence and management of depression in the context of naltrexone treatment of alcoholism. Am J Psychiatry. Aug. 1999;156(8):1258-62. Exclusion Code: X8. [pmid: 10450269].
93 Farwell WR, Stump TE, Wang J, et al. Weight gain and new onset diabetes associated with olanzapine and risperidone. J Gen Intern Med. 2004;19(12):1200-5. Exclusion Code: X3. [pmid: 15610330].
94 Feeney GF, Connor JP, Mc DYR, et al. Is acamprosate use in alcohol dependence treatment reflected in improved subjective health status outcomes beyond cognitive behavioural therapy alone?. J Addict Dis. 2006;25(4):49-58. Exclusion Code: X5. [pmid: 17088225].
95 Feeney GF, Connor JP, Young RM, et al. Combined acamprosate and naltrexone, with cognitive behavioural therapy is superior to either medication alone for alcohol abstinence: a single centres' experience with pharmacotherapy. Alcohol Alcohol. May-Jun. 2006;41(3):321-7. Exclusion Code: X8. [pmid: 16467406].
96 Feinn R, Tennen H, Cramer J, et al. Measurement and prediction of medication compliance in problem drinkers. Alcohol Clin Exp Res. Aug. 2003;27(8):1286-92. Exclusion Code: X6. [pmid: 12966323].
97 Fernandez Miranda JJ, Marina Gonzalez PA, Montes Perez M, et al. Topiramate as add-on therapy in non-respondent alcohol dependant patients: a 12 month follow-up study. Actas Esp Psiquiatr. Jul-Aug. 2007;35(4):236-42. Exclusion Code: X5. [pmid: 17592785].
98 Finigan MW, Perkins T, Zold-Kilbourn P, et al. Preliminary evaluation of extended-release naltrexone in Michigan and Missouri drug courts. J Subst Abuse Treat. Oct. 2011;41(3):288-93. Exclusion Code: X8. [pmid: 21696912].
99 Flannery BA, Poole SA, Gallop RJ, et al. Alcohol craving predicts drinking during treatment: an analysis of three assessment instruments. J Stud Alcohol. Jan. 2003;64(1):120-6. Exclusion Code: X5. [pmid: 12608492].
100 Flannery BA, Volpicelli JR, Pettinati HM. Psychometric properties of the Penn Alcohol Craving Scale. Alcohol Clin Exp Res. Aug. 1999;23(8):1289-95. Exclusion Code: X6. [pmid: 10470970].
101 Foa EB, Yusko DA, McLean CP, et al. Concurrent naltrexone and prolonged exposure therapy for patients with comorbid alcohol dependence and PTSD: a randomized clinical trial. JAMA. Aug. 7. 2013;310(5):488-95. Exclusion Code: X8. [pmid: 23925619].
102 Fox HC, Anderson GM, Tuit K, et al. Prazosin effects on stress- and cue-induced craving and stress response in alcohol-dependent individuals: preliminary findings. Alcohol Clin Exp Res. Feb. 2012;36(2):351-60. Exclusion Code: X6. [pmid: 21919922].
103 Freeman SA. Focus on time-sensitive factors that may respond to treatment. Curr Psychiatry. 2012;11(1):53-7. Exclusion Code: X8.
104 Frick KM, Loessl B, Brueck RK, et al. What works for patients in outpatient treatment for alcohol addiction? an explorative study into clients' evaluation of subjective factors and therapy satisfaction. Subst Abuse. 2011;5(1):27-34. Exclusion Code: X6. [pmid: 22879748].
105 Friedmann PD, Mello D, Lonergan S, et al. Aversion to injection limits acceptability of extended-release naltrexone among homeless, alcohol-dependent patients. Substance Abuse. 2013;34(2):94-6. First Author & Affiliation: Friedmann, Peter D. Exclusion Code: X5. [pmid: 23577900].
106 Friedmann PD, Mello D, Lonergan S, et al. Aversion to injection limits acceptability of extended-release naltrexone among homeless, alcohol-dependent patients. Substance Abuse. 2013;34(2):94-6. 2013-13571-004. First Author & Affiliation: Friedmann, Peter D. Exclusion Code: X8. [pmid: 23577900].
107 Fucito LM, Toll BA, Wu R, et al. A preliminary investigation of varenicline for heavy drinking smokers. Psychopharmacology (Berl). Jun. 2011;215(4):655-63. Exclusion Code: X5. [pmid: 21221531].
108 Fuller R, Roth H, Long S. Compliance with disulfiram treatment of alcoholism. J Chronic Dis. 1983;36(2):161-70. Exclusion Code: X6. [pmid: 6337171].
109 Fuller RK, Williford WO, Lee KK, et al. Veterans Administration cooperative study of disulfiram in the treatment of alcoholism: study design and methodological considerations. Control Clin Trials. Sep. 1984;5(3):263-73. Exclusion Code: X2. [pmid: 6386330].
110 Furieri FA, Nakamura-Palacios EM. Gabapentin reduces alcohol consumption and craving: a randomized, double-blind, placebo-controlled trial. J Clin Psychiatry. Nov. 2007;68(11):1691-700. Exclusion Code: X9. [pmid: 18052562].
111 Gache P, Hadengue A. Baclofen improves abstinence in alcoholic cirrhosis: Still better to come?. J Hepatol. 2008;49(6):1083-5. Exclusion Code: X2. [pmid: 18930331].
112 Galarza NJ, Diaz Ramirez D, Guzman F, et al. The use of naltrexone to treat ambulatory patients with alcohol dependence. Bol Asoc Med P R. Oct-Dec. 1997;89(10-12):157-60. Exclusion Code: X9. [pmid: 9577049].
113 Gallant D. Reduction of ethanol intake by pharmacologic agents--investigational problems. Alcohol Clin Exp Res. Aug. 1992;16(4):836-7. Exclusion Code: X2. [pmid: 1530148].
114 Gamburg AL, Aranovich AG, Rasnyuk VA, et al. Some aspects of contemporary treatment of chronic alcoholics. Soviet Neurology & Psychiatry. 1984;17(2):50-7. Exclusion Code: X8.
115 Garbutt JC, West SL, Carey TS, et al. Pharmacological treatment of alcohol dependence: a review of the evidence. JAMA. Apr. 14. 1999;281(14):1318-25. Exclusion Code: X10. [pmid: 10208148].
116 Geerlings P, Ansoms C, Van DBW. Acamprosate and relapse prevention in outpatient alcoholics; results from a randomized, placebo-controlled double-blind study in the Benelux. Tijdschrift Voor Alcohol, Drugs En Andere Psychotrope Stoffen. 1995;21(3):129-41. CN-00170357. Exclusion Code: X1.
117 George DT, Phillips MJ, Lifshitz M, et al. Fluoxetine treatment of alcoholic perpetrators of domestic violence: A 12-week, double-blind, randomized, placebo-controlled intervention study. J Clin Psychiatry. 2011;72(1):60-5. Exclusion Code: X6. [pmid: 20673556].
118 Gerra G, Caccavari R, Delsignore R, et al. Effects of fluoxetine and Ca-acetyl-homotaurinate on alcohol intake in familial and nonfamilial alcoholic patients. Curr Ther Res Clin Exp. 1992;52(2):291-5. Exclusion Code: X8.
119 Goldstein MZ, Pataki A, Webb MT. Alcoholism among elderly persons. Psychiatr Serv. Sep. 1996;47(9):941-3. Exclusion Code: X2. [pmid: 8875656].
120 Goodwin FK. From the Alcohol, Drug Abuse, and Mental Health Administration. JAMA. Mar. 23-30. 1990;263(12):1610. Exclusion Code: X3. [pmid: 2155326].
121 Gopalakrishnan R, Ross J, O'Brien C, et al. Course of late-life depression with alcoholism following combination therapy. J Stud Alcohol Drugs. Mar. 2009;70(2):237-41. Exclusion Code: X5. [pmid: 19261235].
122 Goyer PF, Major LF. Hepatotoxicity in disulfiram-treated patients. J Stud Alcohol. 1979;40(1):133-7. Exclusion Code: X7. [pmid: 449328].
123 Graf M. Pharmacological treatments at the East Kent Alcohol Service. Neuropsychopharmacol Hung. 2012;14:38. Exclusion Code: X8.
124 Grassi MC, Cioce AM, Giudici FD, et al. Short-term efficacy of Disulfiram or Naltrexone in reducing positive urinalysis for both cocaine and cocaethylene in cocaine abusers: A pilot study. Pharmacol Res. 2007;55(2):117-21. Exclusion Code: X9. [pmid: 17174102].
125 Gross CM, Spiegelhalder K, Mercak J, et al. Predictability of alcohol relapse by hippocampal volumetry and psychometric variables. Psychiatry Res. Apr. 30. 2013;212(1):14-8. Exclusion Code: X8. [pmid: 23473987].
126 Guardia J, Roncero C, Galan J, et al. A double-blind, placebo-controlled, randomized pilot study comparing quetiapine with placebo, associated to naltrexone, in the treatment of alcohol-dependent patients. Addict Behav. Mar. 2011;36(3):265-9. Exclusion Code: X5. [pmid: 21146937].
127 Gueorguieva R, Wu R, Donovan D, et al. Naltrexone and combined behavioral intervention effects on trajectories of drinking in the COMBINE study. Drug Alcohol Depend. Mar. 1. 2010;107(2-3):221-9. Exclusion Code: X6. [pmid: 19969427].
128 Gueorguieva R, Wu R, Pittman B, et al. New insights into the efficacy of naltrexone based on trajectory-based reanalyses of two negative clinical trials. Biol Psychiatry. Jun. 1. 2007;61(11):1290-5. Exclusion Code: X8. [pmid: 17224132].
129 Guerrini I, Gentili C, Nelli G, et al. A follow up study on the efficacy of metadoxine in the treatment of alcohol dependence. Subst Abuse Treat Prev Policy. 2006;1:35. Exclusion Code: X4. [pmid: 17176456].
130 Guglielmo R, Martinotti G, Clerici M, et al. Pregabalin for alcohol dependence: a critical review of the literature. Adv Ther. Nov. 2012;29(11):947-57. Exclusion Code: X4. [pmid: 23132700].
131 Hameedi FA, Rosen MI, McCance-Katz EF, et al. Behavioral, physiological, and pharmacological interaction of cocaine and disulfiram in humans. Biol Psychiatry. Apr. 15. 1995;37(8):560-3. Exclusion Code: X7. [pmid: 7619981].
132 Hammarberg A, Jayaram-Lindstrom N, Beck O, et al. The effects of acamprosate on alcohol-cue reactivity and alcohol priming in dependent patients: a randomized controlled trial. Psychopharmacology (Berl). Jul. 2009;205(1):53-62. Exclusion Code: X9. [pmid: 19319508].
133 Hammarberg A, Nylander I, Zhou Q, et al. The effect of acamprosate on alcohol craving and correlation with hypothalamic pituitary adrenal (HPA) axis hormones and beta-endorphin. Brain Res. Dec. 11. 2009;1305(Suppl):S2-6. Exclusion Code: X9. [pmid: 19799882].
134 Hasin DS, Endicott J, Keller MB. Alcohol problems in psychiatric patients: 5-year course. Compr Psychiatry. Jul-Aug. 1991;32(4):303-16. Exclusion Code: X4. [pmid: 1935019].
135 Hernandez-Avila CA, Burleson JA, Kranzler HR. Stage of change as a predictor of abstinence among alcohol-dependent subjects in pharmacotherapy trials. Substance Abuse. 1998;19(2):81-91. Exclusion Code: X6. [pmid: 12511809].
136 Hernandez-Avila CA, Song C, Kuo L, et al. Targeted versus daily naltrexone: secondary analysis of effects on average daily drinking. Alcohol Clin Exp Res. May. 2006;30(5):860-5. Exclusion Code: X9. [pmid: 16634855].
137 Hersh D, Van Kirk JR, Kranzler HR. Naltrexone treatment of comorbid alcohol and cocaine use disorders. Psychopharmacology (Berl). Sep. 1998;139(1-2):44-52. Exclusion Code: X9. [pmid: 9768541].
138 Higgins ST, Budney AJ, Bickel WK, et al. Disulfiram therapy in patients abusing cocaine and alcohol. Am J Psychiatry. 1993;150(4):675-6. Exclusion Code: X8. [pmid: 8465895].
139 Hobbs JD, Kushner MG, Lee SS, et al. Meta-analysis of supplemental treatment for depressive and anxiety disorders in patients being treated for alcohol dependence (Structured abstract). Am J Addict. 2011:319-29. Exclusion Code: X8. [pmid: 21679263].
140 Howland RH, Rush AJ, Wisniewski SR, et al. Concurrent anxiety and substance use disorders among outpatients with major depression: Clinical features and effect on treatment outcome. Drug Alcohol Depend. 2009;99(1-3):248-60. Exclusion Code: X3. [pmid: 18986774].
141 Hunter-Reel D, Witkiewitz K, Zweben A. Does session attendance by a supportive significant other predict outcomes in individual treatment for alcohol use disorders?. Alcohol Clin Exp Res. Jul. 2012;36(7):1237-43. Exclusion Code: X6. [pmid: 22324565].
142 Hussar DA. New drugs: acamprosate calcium and solifenacin succinate. J Am Pharm Assoc (2003). Jan-Feb. 2005;45(1):109-11. Exclusion Code: X2. [pmid: 15730126].
143 Hutchison KE, Wooden A, Swift RM, et al. Olanzapine reduces craving for alcohol: a DRD4 VNTR polymorphism by pharmacotherapy interaction. Neuropsychopharmacology. Oct. 2003;28(10):1882-8. Exclusion Code: X7. [pmid: 12888781].
144 Ionescu R. Lithium salts in alcohol addiction therapy. Revue Roumaine de Neurologie et Psychiatrie. 1985;23(1):3-10. Exclusion Code: X8.
145 Ivanets NN, Anokhina IP, Kogan BM, et al. The efficacy and mechanisms of action of lerivon in alcoholism. Zhurnal nevrologii i psikhiatrii imeni S.S. Korsakova / Ministerstvo zdravookhraneniia i meditsinsko? promyshlennosti Rossi?sko? Federatsii, Vserossi?skoe obshchestvo nevrologov [i] Vserossi?skoe obshchestvo psikhiatrov. 1996;96(5):52-8. CN-00134237. Exclusion Code: X1.
146 Jaffe AJ, Rounsaville B, Chang G, et al. Naltrexone, relapse prevention, and supportive therapy with alcoholics: an analysis of patient treatment matching. J Consult Clin Psychol. Oct. 1996;64(5):1044-53. Exclusion Code: X6. [pmid: 8916634].
147 Janiri L, Gobbi G, Mannelli P, et al. Effects of fluoxetine and antidepressant doses on short-term outcome of detoxified alcoholics. Int Clin Psychopharmacol. 1996;11(2):109-17. Exclusion Code: X9. [pmid: 8803648].
148 Janiri L, Gobbi G, Mannelli P, et al. Effects of fluoxetine at antidepressant doses on short-term outcome of detoxified alcoholics. Int Clin Psychopharmacol. Jun. 1996;11(2):109-17. Exclusion Code: X9. [pmid: 8803648].
149 Janiri L, Martinotti G, Di Nicola M. Aripiprazole for relapse prevention and craving in alcohol-dependent subjects: Results from a pilot study. J Clin Psychopharmacol. 2007;27(5):519-20. Exclusion Code: X5. [pmid: 17873691].
150 Jensen SB, Christoffersen CB, Noerregaard A. Apomorphine in outpatient treatment of alcohol intoxication and abstinence: a double-blind study. Br J Addict Alcohol Other Drugs. Dec. 1977;72(4):325-30. Exclusion Code: X4. [pmid: 341937].
151 Johnsen J, Morland J. Disulfiram implant: a double-blind placebo controlled follow-up on treatment outcome. Alcohol Clin Exp Res. Jun. 1991;15(3):532-6. Exclusion Code: X4. [pmid: 1877740].
152 Johnson BA, Ait-Daoud N, Bowden CL, et al. Oral topiramate was effective as an adjunt to standardised medication compliance management in alcohol dependence. Evid-Based Med. 2004;9(1):24. Exclusion Code: X2.
153 Johnson BA, Ait-Daoud N, Ma JZ, et al. Ondansetron reduces mood disturbance among biologically predisposed, alcohol-dependent individuals. Alcohol Clin Exp Res. Nov. 2003;27(11):1773-9. Exclusion Code: X6. [pmid: 14634493].
154 Johnson BA, Ait-Daoud N, Prihoda TJ. Combining ondansetron and naltrexone effectively treats biologically predisposed alcoholics: from hypotheses to preliminary clinical evidence. Alcohol Clin Exp Res. May. 2000;24(5):737-42. Exclusion Code: X4. [pmid: 10832917].
155 Johnson BA, Ait-Daoud N, Seneviratne C, et al. Pharmacogenetic approach at the serotonin transporter gene as a method of reducing the severity of alcohol drinking. Am J Psychiatry. Mar. 2011;168(3):265-75. Exclusion Code: X9. [pmid: 21247998].
156 Johnson BA, O'Malley SS, Ciraulo DA, et al. Dose-ranging kinetics and behavioral pharmacology of naltrexone and acamprosate, both alone and combined, in alcohol-dependent subjects. J Clin Psychopharmacol. Jun. 2003;23(3):281-93. Exclusion Code: X8. [pmid: 12826990].
157 Johnson BA, Roache JD, Ait-Daoud N, et al. Ondansetron reduces the craving of biologically predisposed alcoholics. Psychopharmacology (Berl). Apr. 2002;160(4):408-13. Exclusion Code: X6. [pmid: 11919668].
158 Johnson BA, Roache JD, Javors MA, et al. Ondansetron for reduction of drinking among biologically predisposed alcoholic patients: A randomized controlled trial. JAMA. Aug. 23-30. 2000;284(8):963-71. Exclusion Code: X9. [pmid: 10944641].
159 Johnson BA, Seneviratne C, Wang XQ, et al. Determination of genotype combinations that can predict the outcome of the treatment of alcohol dependence using the 5-HT(3) antagonist ondansetron. Am J Psychiatry. Sep. 1. 2013;170(9):1020-31. Exclusion Code: X9. [pmid: 23897038].
160 Johnson JL, Wiechelt SA, Ahmed AU, et al. Outcomes for substance user treatment in women: Results from the Baltimore Drug and Alcohol Treatment Outcomes Study. Subst Use Misuse. 2003;38(11-13):1807-29. +920-922. Exclusion Code: X3. [pmid: 14582579].
161 Kampman KM, Pettinati HM, Lynch KG, et al. Initiating acamprosate within-detoxification versus post-detoxification in the treatment of alcohol dependence. Addict Behav. Jun-Jul. 2009;34(6-7):581-6. Exclusion Code: X5. [pmid: 19345510].
162 Karam-Hage M, Brower KJ. Open pilot study of gabapentin versus trazodone to treat insomnia in alcoholic outpatients. Psychiatry Clin Neurosci. 2003;57(5):542-4. Exclusion Code: X8. [pmid: 12950711].
163 Kenna GA, Zywiak WH, McGeary JE, et al. A within-group design of nontreatment seeking 5-HTTLPR genotyped alcohol-dependent subjects receiving ondansetron and sertraline. Alcohol Clin Exp Res. Feb. 2009;33(2):315-23. Exclusion Code: X9. [pmid: 19032576].
164 Kiec-Swierczynska M, Krecisz B, Fabicka B. Systemic contact dermatitis from implanted disulfiram. Contact Dermatitis. Oct. 2000;43(4):246-7. Exclusion Code: X8. [pmid: 11011945].
165 Kiefer F, Jahn H, Holzbach R, et al. The NALCAM-study: Efficacy, tolerability, outcome. Sucht. 2003;49(6):342-51. CN-00475102. Exclusion Code: X1.
166 Kiefer F, Jahn H, Otte C, et al. Hypothalamic-pituitary-adrenocortical axis activity: a target of pharmacological anticraving treatment?. Biol Psychiatry. Jul. 1. 2006;60(1):74-6. Exclusion Code: X6. [pmid: 16483549].
167 Kiefer F, Jimenez-Arriero MA, Klein O, et al. Cloninger's typology and treatment outcome in alcohol-dependent subjects during pharmacotherapy with naltrexone. Addict Biol. Mar. 2008;13(1):124-9. Exclusion Code: X8. [pmid: 17573782].
168 King A, Cao D, Vanier C, et al. Naltrexone decreases heavy drinking rates in smoking cessation treatment: an exploratory study. Alcohol Clin Exp Res. Jun. 2009;33(6):1044-50. Exclusion Code: X3. [pmid: 19302083].
169 King AC, Volpicelli JR, Frazer A, et al. Effect of naltrexone on subjective alcohol response in subjects at high and low risk for future alcohol dependence. Psychopharmacology (Berl). Jan. 1997;129(1):15-22. Exclusion Code: X7. [pmid: 9122358].
170 Kingsbury SJ, Salzman C. Disulfiram in the treatment of alcoholic patients with schizophrenia. Hosp Community Psychiatry. 1990;41(2):133-4. Exclusion Code: X2. [pmid: 2303214].
171 Kiritze-Topor P, Huas D, Rosenzweig C, et al. A pragmatic trial of acamprosate in the treatment of alcohol dependence in primary care. Alcohol Alcohol. Nov-Dec. 2004;39(6):520-7. Exclusion Code: X5. [pmid: 15304381].
172 Knox PC, Donovan DM. Using naltrexone in inpatient alcoholism treatment. J Psychoactive Drugs. Oct-Dec. 1999;31(4):373-88. Exclusion Code: X7. [pmid: 10681104].
173 Knox WJ. Four-year follow-up of veterans treated on a small alcoholism treatment ward. Q J Stud Alcohol. Mar. 1972;33(1):105-10. Exclusion Code: X5. [pmid: 4551019].
174 Koeter MW, van den Brink W, Lehert P. Effect of early and late compliance on the effectiveness of acamprosate in the treatment of alcohol dependence. J Subst Abuse Treat. Oct. 2010;39(3):218-26. Exclusion Code: X8. [pmid: 20627222].
175 Koski A, Ojanpera I, Vuori E. Interaction of alcohol and drugs in fatal poisonings. Hum Exp Toxicol. May. 2003;22(5):281-7. Exclusion Code: X8. [pmid: 12774892].
176 Krampe H, Stawicki S, Wagner T, et al. Follow-up of 180 alcoholic patients for up to 7 years after outpatient treatment: impact of alcohol deterrents on outcome. Alcohol Clin Exp Res. Jan. 2006;30(1):86-95. Exclusion Code: X8. [pmid: 16433735].
177 Kranzler HR, Armeli S, Feinn R, et al. Targeted naltrexone treatment moderates the relations between mood and drinking behavior among problem drinkers. J Consult Clin Psychol. Apr. 2004;72(2):317-27. Exclusion Code: X9. [pmid: 15065964].
178 Kranzler HR, Armeli S, Tennen H, et al. Targeted naltrexone for early problem drinkers. J Clin Psychopharmacol. Jun. 2003;23(3):294-304. Exclusion Code: X9. [pmid: 12826991].
179 Kranzler HR, Burleson JA, Brown J, et al. Fluoxetine treatment seems to reduce the beneficial effects of cognitive-behavioral therapy in type B alcoholics. Alcohol Clin Exp Res. Dec. 1996;20(9):1534-41. Exclusion Code: X6. [pmid: 8986200].
180 Kranzler HR, Del Boca F, Korner P, et al. Adverse effects limit the usefulness of fluvoxamine for the treatment of alcoholism. J Subst Abuse Treat. May-Jun. 1993;10(3):283-7. Exclusion Code: X8. [pmid: 8315702].
181 Kranzler HR, Gage A. Acamprosate efficacy in alcohol-dependent patients: summary of results from three pivotal trials. Am J Addict. Jan-Feb. 2008;17(1):70-6. Exclusion Code: X8. [pmid: 18214726].
182 Kranzler HR, Modesto-Lowe V, Nuwayser ES. Sustained-release naltrexone for alcoholism treatment: a preliminary study. Alcohol Clin Exp Res. Aug. 1998;22(5):1074-9. Exclusion Code: X9. [pmid: 9726277].
183 Kranzler HR, Modesto-Lowe V, Van Kirk J. Naltrexone vs. nefazodone for treatment of alcohol dependence. A placebo-controlled trial. Neuropsychopharmacology. May. 2000;22(5):493-503. Exclusion Code: X9. [pmid: 10731624].
184 Kranzler HR, Mueller T, Cornelius J, et al. Sertraline treatment of co-occurring alcohol dependence and major depression. J Clin Psychopharmacol. Feb. 2006;26(1):13-20. Exclusion Code: X9. [pmid: 16415699].
185 Kranzler HR, Pierucci-Lagha A, Feinn R, et al. Effects of ondansetron in early- versus late-onset alcoholics: a prospective, open-label study. Alcohol Clin Exp Res. Jul. 2003;27(7):1150-5. Exclusion Code: X5. [pmid: 12878921].
186 Kranzler HR, Tennen H, Penta C, et al. Targeted naltrexone treatment of early problem drinkers. Addict Behav. May-Jun. 1997;22(3):431-6. Exclusion Code: X5. [pmid: 9183513].
187 Kranzler HR, Van Kirk J. Efficacy of naltrexone and acamprosate for alcoholism treatment: A meta-analysis. Alcohol. 2001;25(9):1335-41. Exclusion Code: X8.
188 Kravitz HM, Fawcett J, McGuire M, et al. Treatment attrition among alcohol-dependent men: is it related to novelty seeking personality traits?. J Clin Psychopharmacol. Feb. 1999;19(1):51-6. Exclusion Code: X6. [pmid: 9934943].
189 Krupitski EM, Burakov AM, Ivanov VB, et al. The use of baclofen for treating affective disorders in alcoholism. Zhurnal nevrologii i psikhiatrii imeni S.S. Korsakova / Ministerstvo zdravookhraneniia i meditsinsko? promyshlennosti Rossi?sko? Federatsii, Vserossi?skoe obshchestvo nevrologov [i] Vserossi?skoe obshchestvo psikhiatrov. 1994;94(1):57-61. CN-00102296. Exclusion Code: X1.
190 Krupitsky EM, Burakov AM, Ivanov VB, et al. Baclofen administration for the treatment of affective disorders in alcoholic patients. Drug Alcohol Depend. Sep. 1993;33(2):157-63. Exclusion Code: X6. [pmid: 8261880].
191 Krylov EN. Psychotropic activity of the antialcohol preparation Proproten-100. Bull Exp Biol Med. Jan. Suppl 7. 2003;135:176-80. Exclusion Code: X3. [pmid: 12949691].
192 Krystal JH, Gueorguieva R, Cramer J, et al. Naltrexone is associated with reduced drinking by alcohol dependent patients receiving antidepressants for mood and anxiety symptoms: Results from VA cooperative study no. 425, “naltrexone in the treatment of alcoholism”. Alcohol. 2008;32(1):85-91. Exclusion Code: X8.
193 Labbate LA, Sonne SC, Randal CL, et al. Does comorbid anxiety or depression affect clinical outcomes in patients with post-traumatic stress disorder and alcohol use disorders?. Compr Psychiatry. Jul-Aug. 2004;45(4):304-10. Exclusion Code: X6. [pmid: 15224273].
194 Ladewig D, Knecht T, Leher P, et al. Acamprosate--a stabilizing factor in long-term withdrawal of alcoholic patients. Therapeutische Umschau. Revue thérapeutique. 1993;50(3):182-8. Exclusion Code: X1. [pmid: 8475472].
195 Lake CR, Major LF, Ziegler MG, et al. Increased sympathetic nervous system activity in alcoholic patients treated with disulfiram. Am J Psychiatry. Dec. 1977;134(12):1411-4. Exclusion Code: X7. [pmid: 920841].
196 Landabaso MA, Iraurgi I, Sanz J, et al. Naltrexone in the treatment of alcoholism. Two-year follow up results. Eur J Psychiat. 1999;13(2):97-105. Exclusion Code: X4.
197 Lapham S, Forman R, Alexander M, et al. The effects of extended-release naltrexone on holiday drinking in alcohol-dependent patients. J Subst Abuse Treat. Jan. 2009;36(1):1-6. Exclusion Code: X6. [pmid: 18775624].
198 Leggio L, Ferrulli A, Zambon A, et al. Baclofen promotes alcohol abstinence in alcohol dependent cirrhotic patients with hepatitis C virus (HCV) infection. Addict Behav. Apr. 2012;37(4):561-4. Exclusion Code: X8. [pmid: 22244707].
199 Lesch OM, Riegler A, Gutierrez K, et al. The European acamprosate trials: Conclusions for research and therapy. J Biomed Sci. 2001;8(1):89-95. Exclusion Code: X2. [pmid: 11173981].
200 Lesch OM, Walter H. Subtypes of alcoholism and their role in therapy. Alcohol Alcohol. 1996;31(Suppl 1):63-7. Exclusion Code: X2. [pmid: 8737003].
201 Leslie WS, Hankey CR, Lean ME. Weight gain as an adverse effect of some commonly prescribed drugs: a systematic review (Structured abstract). QJM. 2007;100(7):395-404. DARE-12007002731. Exclusion Code: X2. [pmid: 17566010].
202 Lewis DC. The clinical usefulness of narcotic antagonists: preliminary findings on the use of naltrexone. Am J Drug Alcohol Abuse. 1975;2(3-4):403-15. Exclusion Code: X5. [pmid: 1227300].
203 Liebson I, Bigelow G. A behavioural-pharmacological treatment of dually addicted patients. Behav Res Ther. Nov. 1972;10(4):403-5. Exclusion Code: X5. [pmid: 4637497].
204 Likhitsathian S, Saengcharnchai P, Uttawichai K, et al. Cognitive changes in topiramate-treated patients with alcoholism: a 12-week prospective study in patients recently detoxified. Psychiatry Clin Neurosci. Apr. 2012;66(3):235-41. Exclusion Code: X5. [pmid: 22443246].
205 Litten RZ, Fertig JB, Falk DE, et al. A double-blind, placebo-controlled trial to assess the efficacy of quetiapine fumarate XR in very heavy-drinking alcohol-dependent patients. Alcohol Clin Exp Res. Mar. 2012;36(3):406-16. Exclusion Code: X9. [pmid: 21950727].
206 Loo H, Malka R, Defrance R, et al. Tianeptine and amitriptyline. Controlled double-blind trial in depressed alcoholic patients. Neuropsychobiology. 1988;19(2):79-85. Exclusion Code: X9. [pmid: 3067116].
207 Luggen AS. Alcohol and the older adult. Adv Nurse Pract. Jan. 2006;14(1):47-52. Exclusion Code: X2. [pmid: 16425516].
208 Maisel NC, Blodgett JC, Wilbourne PL, et al. Meta-analysis of naltrexone and acamprosate for treating alcohol use disorders: when are these medications most helpful?. Addiction. Feb. 2013;108(2):275-93. Exclusion Code: X8. [pmid: 23075288].
209 Malcolm R, Myrick LH, Veatch LM, et al. Self-reported sleep, sleepiness, and repeated alcohol withdrawals: a randomized, double blind, controlled comparison of lorazepam vs gabapentin. J Clin Sleep Med. Feb. 15. 2007;3(1):24-32. Exclusion Code: X3. [pmid: 17557449].
210 Malec TS, Malec EA, Dongier M. Efficacy of buspirone in alcohol dependence: A review. Alcoholism. 1996;20(5):853-8. Exclusion Code: X2. [pmid: 8865960].
211 Malla A. An outcome study comparing refusers and acceptors of treatment for alcoholism. Can J Psychiatry. Apr. 1988;33(3):183-7. Exclusion Code: X3. [pmid: 3383091].
212 Mann K, Kiefer F, Smolka M, et al. Searching for responders to acamprosate and naltrexone in alcoholism treatment: rationale and design of the PREDICT study. Alcohol Clin Exp Res. Apr. 2009;33(4):674-83. Exclusion Code: X8. [pmid: 19170666].
213 Mao YM, Zeng MD, Li YM, et al. Capsule metadoxine in the treatment of alcoholic liver disease: a randomized, double-blind, placebo-controlled, multicenter study. Zhonghua gan zang bing za zhi = Zhonghua ganzangbing zazhi. Chinese journal of hepatology. 2009;17(3):213-6. Exclusion Code: X1. [pmid: 19335986].
214 Maremmani AGI, Pani PP, Rovai L, et al. Long-term (gamma)-hydroxybutyric acid (GHB) and disulfiram combination therapy in GHB treatment-resistant chronic alcoholics. Int J Environmen Res Public Health. 2011;8(7):2816-27. Exclusion Code: X4.
215 Marrazzi MA, Wroblewski JM, Kinzie J, et al. High-dose naltrexone and liver function safety. Am J Addict. 1997;6(1):21-9. Exclusion Code: X3. [pmid: 9097868].
216 Martin PR, Adinoff B, Lane E, et al. Fluvoxamine treatment of alcoholic amnestic disorder. Eur Neuropsychopharmacol. Mar. 1995;5(1):27-33. Exclusion Code: X3. [pmid: 7542052].
217 Martin PR, Loewy J, Liou S, et al. Correlation of Serum Gamma-Glutamyl Transferase With Alcohol Consumption. 158th Annual Meeting of the American Psychiatric Association. 2005 May 21-26. Atlanta, GA. 2005:Nr215. Exclusion Code: X6.
218 Martinotti G, Di Nicola M, Romanelli R, et al. High and low dosage oxcarbazepine versus naltrexone for the prevention of relapse in alcohol-dependent patients. Hum Psychopharmacol. Apr. 2007;22(3):149-56. Exclusion Code: X5. [pmid: 17397097].
219 Martinotti G, Di Nicola M, Tedeschi D, et al. Pregabalin versus naltrexone in alcohol dependence: a randomised, double-blind, comparison trial. J Psychopharmacol. Sep. 2010;24(9):1367-74. Exclusion Code: X5. [pmid: 19346279].
220 Mason BJ, Kocsis JH. Desipramine treatment of alcoholism. Psychopharmacol Bull. 1991;27(2):155-61. Exclusion Code: X6. [pmid: 1924663].
221 Mason BJ, Lehert P. Effects of nicotine and illicit substance use on alcoholism treatment outcomes and acamprosate efficacy. J Addict Med. 2009;3(3):164-71. Exclusion Code: X8. [pmid: 21769013].
222 Mason BJ, Light JM, Williams LD, et al. Proof-of-concept human laboratory study for protracted abstinence in alcohol dependence: effects of gabapentin. Addict Biol. Jan. 2009;14(1):73-83. Exclusion Code: X6. [pmid: 18855801].
223 McGeary JE, Monti PM, Rohsenow DJ, et al. Genetic moderators of naltrexone's effects on alcohol cue reactivity. Alcohol Clin Exp Res. Aug. 2006;30(8):1288-96. Exclusion Code: X3. [pmid: 16899031].
224 McKee SA, Harrison EL, O'Malley SS, et al. Varenicline reduces alcohol self-administration in heavy-drinking smokers. Biol Psychiatry. Jul. 15. 2009;66(2):185-90. Exclusion Code: X7. [pmid: 19249750].
225 McKee SA, Young-Wolff KC, Harrison ELR, et al. Longitudinal associations between smoking cessation medications and alcohol consumption among smokers in the International Tobacco Control Four Country Survey. Alcohol. 2013;37(5):804-10. 2013-15234-013. First Author & Affiliation: McKee, Sherry A. Exclusion Code: X8. [pmid: 23240586].
226 McRae-Clark AL, Verduin ML, Tolliver BK, et al. An open-label trial of aripiprazole treatment in dual diagnosis individuals: Safety and efficacy. J Dual Diagn. 2009;5(1):83-96. Exclusion Code: X5.
227 Meszaros K, Willinger U, Fischer G, et al. The tridimensional personality model: influencing variables in a sample of detoxified alcohol dependents. European Fluvoxamine in Alcoholism Study Group. Compr Psychiatry. Mar-Apr. 1996;37(2):109-14. Exclusion Code: X6. [pmid: 8654059].
228 Minuk GY, Rockman GE, German GB, et al. The use of sodium valproate in the treatment of alcoholism. J Addict Dis. 1995;14(2):67-74. Exclusion Code: X8. [pmid: 8541361].
229 Miranda R, MacKillop J, Meehan J, et al. Biobehavioral effects of topiramate among heavy drinkers. Alcoholism. 2011;35:21A. Exclusion Code: X3.
230 Miranda R Jr., MacKillop J, Monti PM, et al. Effects of topiramate on urge to drink and the subjective effects of alcohol: a preliminary laboratory study. Alcohol Clin Exp Res. Mar. 2008;32(3):489-97. Exclusion Code: X3. [pmid: 18215213].
231 Miranda R, Ray L, Reynolds E, et al. Effects of naltrexone on adolescent drinking. Alcoholism. 2012;36:89A. Exclusion Code: X3.
232 Mitchell JM, Fields HL, White RL, et al. The Asp40 μ-Opioid Receptor Allele Does Not Predict Naltrexone Treatment Efficacy in Heavy Drinkers. J Clin Psychopharmacol. 2007;27(1):112-5. Exclusion Code: X3. [pmid: 17224736].
233 Mitchell JM, Teague CH, Kayser AS, et al. Varenicline decreases alcohol consumption in heavy-drinking smokers. Psychopharmacology (Berl). Oct. 2012;223(3):299-306. Exclusion Code: X3. [pmid: 22547331].
234 Moak DH, Anton RF, Malcolm R, et al. Alcoholic subjects with anxiety disorder: Characteristics of completers and noncompleters in a pharmacologic study. Am J Addict. 1993;2(1):39-47. Exclusion Code: X4.
235 Monahan SC, Finney JW. Explaining abstinence rates following treatment for alcohol abuse: a quantitative synthesis of patient, research design and treatment effects (Structured abstract). Addiction. 1996:787-805. Exclusion Code: X10. [pmid: 8696243].
236 Monnelly EP, Ciraulo DA, Knapp C, et al. Quetiapine for treatment of alcohol dependence. J Clin Psychopharmacol. Oct. 2004;24(5):532-5. Exclusion Code: X5. [pmid: 15349010].
237 Monnelly EP, LoCastro JS, Gagnon D, et al. Quetiapine versus trazodone in reducing rehospitalization for alcohol dependence: A large data-base study. J Addict Med. 2008;2(3):128-34. Exclusion Code: X8. [pmid: 21768982].
238 Monti PM, Rohsenow DJ. Coping-skills training and cue-exposure therapy in the treatment of alcoholism. Alcohol Research & Health. 1999;23(2):107-15. Exclusion Code: X2. [pmid: 10890804].
239 Morgan MY, Landron F, Lehert P. Improvement in quality of life after treatment for alcohol dependence with acamprosate and psychosocial support. Alcohol Clin Exp Res. Jan. 2004;28(1):64-77. Exclusion Code: X5. [pmid: 14745303].
240 Mueser KT, Noordsy DL, Fox L, et al. Disulfiram treatment for alcoholism in severe mental illness. Am J Addict. May-Jun. 2003;12(3):242-52. Exclusion Code: X8. [pmid: 12851020].
241 Muhonen LH, Lahti J, Alho H, et al. Serotonin transporter polymorphism as a predictor for escitalopram treatment of major depressive disorder comorbid with alcohol dependence. Psychiatry Res. Mar. 30. 2011;186(1):53-7. Exclusion Code: X6. [pmid: 20800901].
242 Muhonen LH, Lahti J, Sinclair D, et al. Treatment of alcohol dependence in patients with co-morbid major depressive disorder--predictors for the outcomes with memantine and escitalopram medication. Subst Abuse Treat Prev Policy. 2008;3:20. Exclusion Code: X5. [pmid: 18834506].
243 Muhonen LH, Lonnqvist J, Juva K, et al. Double-blind, randomized comparison of memantine and escitalopram for the treatment of major depressive disorder comorbid with alcohol dependence. J Clin Psychiatry. Mar. 2008;69(3):392-9. Exclusion Code: X5. [pmid: 18348597].
244 Murthy KK, Praveenlal K. An experience with disulfiram in the management of Alcohol Dependence Syndrome: I. Side effects of disulfiram and symptoms of alcohol-disulfiram reaction. Ind J Psychol Med. 1988;11(2):145-8. Exclusion Code: X5.
245 Myrick H, Anton R, Voronin K, et al. A double-blind evaluation of gabapentin on alcohol effects and drinking in a clinical laboratory paradigm. Alcohol Clin Exp Res. Feb. 2007;31(2):221-7. Exclusion Code: X7. [pmid: 17250613].
246 Myrick H, Li X, Randall PK, et al. The effect of aripiprazole on cue-induced brain activation and drinking parameters in alcoholics. J Clin Psychopharmacol. Aug. 2010;30(4):365-72. Exclusion Code: X9. [pmid: 20571434].
247 Myrick H, Malcolm R, Randall PK, et al. A double-blind trial of gabapentin versus lorazepam in the treatment of alcohol withdrawal. Alcohol Clin Exp Res. Sep. 2009;33(9):1582-8. Exclusion Code: X3. [pmid: 19485969].
248 Namkoong K, Lee BO, Lee PG, et al. Acamprosate in Korean alcohol-dependent patients: a multi-centre, randomized, double-blind, placebo-controlled study. Alcohol Alcohol. Mar-Apr. 2003;38(2):135-41. Exclusion Code: X9. [pmid: 12634260].
249 Naranjo CA, Kadlec KE, Sanhueza P, et al. Fluoxetine differentially alters alcohol intake and other consummatory behaviors in problem drinkers. Clin Pharmacol Ther. Apr. 1990;47(4):490-8. Exclusion Code: X9. [pmid: 2328557].
250 Naranjo CA, Knoke DM, Bremner KE. Variations in response to citalopram in men and women with alcohol dependence. J Psychiatry Neurosci. May. 2000;25(3):269-75. Exclusion Code: X8. [pmid: 10863887].
251 Naranjo CA, Poulos CX, Bremner KE, et al. Citalopram decreases desirability, liking, and consumption of alcohol in alcohol-dependent drinkers. Clin Pharmacol Ther. Jun. 1992;51(6):729-39. Exclusion Code: X7. [pmid: 1535302].
252 Naranjo CA, Poulos CX, Bremner KE, et al. Fluoxetine attenuates alcohol intake and desire to drink. Int Clin Psychopharmacol. Sep. 1994;9(3):163-72. Exclusion Code: X3. [pmid: 7814825].
253 Naranjo CA, Sellers EM, Sullivan JT, et al. The serotonin uptake inhibitor citalopram attenuates ethanol intake. Clin Pharmacol Ther. Mar. 1987;41(3):266-74. Exclusion Code: X3. [pmid: 3469057].
254 Neto D, Lambaz R, Tavares JE. Compliance with aftercare treatment, including disulfiram, and effect on outcome in alcohol-dependent patients. Alcohol Alcohol. Nov-Dec. 2007;42(6):604-9. Exclusion Code: X8. [pmid: 17878216].
255 Niederhofer H, Staffen W. Acamprosate and its efficacy in treating alcohol dependent adolescents. Eur Child Adolesc Psychiatry. Jun. 2003;12(3):144-8. Exclusion Code: X8. [pmid: 12768462].
256 Niederhofer H, Staffen W, Mair A. Comparison of naltrexone and placebo in treatment of alcohol dependence of adolescents. Alcohol Treat Q. 2003;21(2):87-95. Exclusion Code: X3.
257 Nunes EV, Levin FR. Treatment of Depression in Patients with Alcohol or Other Drug Dependence: A Meta-analysis. JAMA. 2004;291(15):1887-96. Exclusion Code: X3. [pmid: 15100209].
258 Nunes EV, McGrath PJ, Quitkin FM, et al. Imipramine treatment of alcoholism with comorbid depression. Am J Psychiatry. Jun. 1993;150(6):963-5. Exclusion Code: X9. [pmid: 8494079].
259 O'Brien CP, Volpicelli LA, Volpicelli JR. Naltrexone in the treatment of alcoholism: a clinical review. Alcohol. Jan-Feb. 1996;13(1):35-9. Exclusion Code: X6. [pmid: 8837932].
260 O'Carroll RE, Moffoot AP, Ebmeier KP, et al. Effects of fluvoxamine treatment on cognitive functioning in the alcoholic Korsakoff syndrome. Psychopharmacology (Berl). Sep. 1994;116(1):85-8. Exclusion Code: X3. [pmid: 7862935].
261 Ojehagen A, Skjaerris A, Berglund M. Long-term use of aversive drugs in outpatient alcoholism treatment. Acta Psychiatr Scand. Aug. 1991;84(2):185-90. Exclusion Code: X5. [pmid: 1950615].
262 O'Malley S. Naltrexone for heavy drinking in young adults. Alcohol. 2012;36:334A. Exclusion Code: X3.
263 O'Malley SS. Current strategies for the treatment of alcohol dependence in the United States. Drug Alcohol Depend. 1995;39(Suppl 1):S3-S7. Exclusion Code: X2. [pmid: 8565795].
264 O'Malley SS. Opioid antagonists in the treatment of alcohol dependence: Clinical efficacy and prevention of relapse. Alcohol Alcohol. 1996;31(Suppl 1):77-81. Exclusion Code: X2. [pmid: 8737005].
265 O'Malley SS, Croop RS, Wroblewski JM, et al. Naltrexone in the treatment of alcohol dependence: A combined analysis of two trials. Psychiatr Ann. 1995;25(11):681-8. Exclusion Code: X8.
266 O'Malley SS, Garbutt JC, Gastfriend DR, et al. Efficacy of extended-release naltrexone in alcohol-dependent patients who are abstinent before treatment. J Clin Psychopharmacol. Oct. 2007;27(5):507-12. Exclusion Code: X5. [pmid: 17873686].
267 O'Malley SS, Jaffe AJ, Rode S, et al. Experience of a ‘slip’ among alcoholics treated with naltrexone or placebo. Am J Psychiatry. 1996;153(2):281-3. Exclusion Code: X6. [pmid: 8561215].
268 O'Malley SS, Krishnan-Sarin S, McKee SA, et al. Dose-dependent reduction of hazardous alcohol use in a placebo-controlled trial of naltrexone for smoking cessation. Int J Neuropsychopharmacol. Jun. 2009;12(5):589-97. Exclusion Code: X3. [pmid: 18796184].
269 O'Malley SS, Rounsaville BJ, Farren C, et al. Initial and maintenance naltrexone treatment for alcohol dependence using primary care vs specialty care: a nested sequence of 3 randomized trials. Arch Intern Med. Jul. 28. 2003;163(14):1695-704. Exclusion Code: X8. [pmid: 12885685].
270 Oncken C, Van Kirk J, Kranzler HR. Adverse effects of oral naltrexone: analysis of data from two clinical trials. Psychopharmacology (Berl). Apr. 2001;154(4):397-402. Exclusion Code: X8. [pmid: 11349393].
271 Ooteman W, Naassila M, Koeter MW, et al. Predicting the effect of naltrexone and acamprosate in alcohol-dependent patients using genetic indicators. Addict Biol. Jul. 2009;14(3):328-37. Exclusion Code: X6. [pmid: 19523047].
272 Oroszi G, Anton RF, O'Malley S, et al. OPRM1 Asn40Asp predicts response to naltrexone treatment: a haplotype-based approach. Alcohol Clin Exp Res. Mar. 2009;33(3):383-93. Exclusion Code: X5. [pmid: 19053977].
273 Oslin D. OPRM1 sequence variation and clinical studies of alcohol dependent adults. Alcohol. 2011;35:314A. Exclusion Code: X8.
274 Oslin D, Liberto JG, O'Brien J, et al. Tolerability of naltrexone in treating older, alcohol-dependent patients. Am J Addict. Summer. 1997;6(3):266-70. Exclusion Code: X6. [pmid: 9256993].
275 Oslin DW. Treatment of late-life depression complicated by alcohol dependence. Am J Geriatr Psychiatry. Jun. 2005;13(6):491-500. Exclusion Code: X4. [pmid: 15956269].
276 Oslin DW, Berrettini W, Kranzler HR, et al. A functional polymorphism of the mu-opioid receptor gene is associated with naltrexone response in alcohol-dependent patients. Neuropsychopharmacology. Aug. 2003;28(8):1546-52. Exclusion Code: X8. [pmid: 12813472].
277 Oslin DW, Pettinati H, Volpicelli JR. Alcoholism treatment adherence: older age predicts better adherence and drinking outcomes. Am J Geriatr Psychiatry. Nov-Dec. 2002;10(6):740-7. Exclusion Code: X8. [pmid: 12427583].
278 Palatty PL, Saldanha E. Status of disulfiram in present day alcoholic deaddiction therapy. Indian J Psychiatry. 2011;53(1):25-9. Exclusion Code: X5. [pmid: 21431004].
279 Palliyath S, Schwartz BD. Disulfiram neuropathy: electrophysiological study. Electromyogr Clin Neurophysiol. Jun-Jul. 1988;28(5):245-7. Exclusion Code: X6. [pmid: 2847909].
280 Paparrigopoulos T, Tzavellas E, Karaiskos D, et al. Treatment of alcohol dependence with low-dose topiramate: an open-label controlled study. BMC Psychiatry. 2011;11:41. Exclusion Code: X8. [pmid: 21401921].
281 Peachey JE, Zilm DH, Robinson GM, et al. A placebo-controlled double-blind comparative clinical study of the disulfiram- and calcium carbimide-acetaldehyde mediated ethanol reactions in social drinkers. Alcohol Clin Exp Res. Spring. 1983;7(2):180-7. Exclusion Code: X7. [pmid: 6346921].
282 Perugi G, Toni C, Frare F, et al. Effectiveness of adjunctive gabapentin in resistant bipolar disorder: is it due to anxious-alcohol abuse comorbidity?. J Clin Psychopharmacol. Dec. 2002;22(6):584-91. Exclusion Code: X3. [pmid: 12454558].
283 Peterson AM. Improving adherence in patients with alcohol dependence: A new role for pharmacists. Am J Health Syst Pharm. 2007;64(5 SUPPL.):S23-S9. Exclusion Code: X2. [pmid: 17322179].
284 Petrakis IL, Carroll KM, Nich C, et al. Disulfiram treatment for cocaine dependence in methadone-maintained opioid addicts. Addiction. 2000;95(2):219-28. Exclusion Code: X3. [pmid: 10723850].
285 Pettinati HM, Dundon W, Lipkin C. Gender differences in response to sertraline pharmacotherapy in Type A alcohol dependence. Am J Addict. May-Jun. 2004;13(3):236-47. Exclusion Code: X8. [pmid: 15370943].
286 Pettinati HM, Kampman KM, Lynch KG, et al. A double blind, placebo-controlled trial that combines disulfiram and naltrexone for treating co-occurring cocaine and alcohol dependence. Addict Behav. May. 2008;33(5):651-67. Exclusion Code: X9. [pmid: 18079068].
287 Pettinati HM, O'Brien CP, Rabinowitz AR, et al. The status of naltrexone in the treatment of alcohol dependence: specific effects on heavy drinking. J Clin Psychopharmacol. Dec. 2006;26(6):610-25. Exclusion Code: X10. [pmid: 17110818].
288 Pettinati HM, Silverman BL, Battisti JJ, et al. Efficacy of extended-release naltrexone in patients with relatively higher severity of alcohol dependence. Alcohol Clin Exp Res. Oct. 2011;35(10):1804-11. Exclusion Code: X8. [pmid: 21575016].
289 Pettinati HM, Volpicelli JR, Kranzler HR, et al. Sertraline treatment for alcohol dependence: interactive effects of medication and alcoholic subtype. Alcohol Clin Exp Res. Jul. 2000;24(7):1041-9. Exclusion Code: X8. [pmid: 10924008].
290 Pettinati HM, Volpicelli JR, Pierce JD Jr., et al. Improving naltrexone response: an intervention for medical practitioners to enhance medication compliance in alcohol dependent patients. J Addict Dis. 2000;19(1):71-83. Exclusion Code: X8. [pmid: 10772604].
291 Ponce G, Sánchez-García J, Rubio G, et al. Efficacy of naltrexone in the treatment of alcohol dependence disorder in women. Actas españolas de psiquiatría. 2005;33(1):13-8. Exclusion Code: X1. [pmid: 15704026].
292 Pondé de-Sena E, Santos-Jesus R, Almeida Sarmento C, et al. Use of carbamazepine-buspirone combination in alcohol dependence. J Bras Psiquiatr. 1997;46(12):645-9. Exclusion Code: X1.
293 Powell BJ, Penick EC, Read MR, et al. Comparison of three outpatient treatment interventions: a twelve-month follow-up of men alcoholics. J Stud Alcohol. Jul. 1985;46(4):309-12. Exclusion Code: X5. [pmid: 2993750].
294 Prisciandaro JJ, Brown DG, Brady KT, et al. Comorbid anxiety disorders and baseline medication regimens predict clinical outcomes in individuals with co-occurring bipolar disorder and alcohol dependence: Results of a randomized controlled trial. Psychiatry Res. Aug. 15. 2011;188(3):361-5. Exclusion Code: X9. [pmid: 21641663].
295 Prisciandaro JJ, Desantis SM, Bandyopadhyay D. Simultaneous Modeling of the Impact of Treatments on Alcohol Consumption and Quality of Life in the COMBINE Study: A Coupled Hidden Markov Analysis. Alcohol. 2012;36(12):2141-9. Exclusion Code: X8.
296 Prochaska JJ, Delucchi K, Hall SM. A meta-analysis of smoking cessation interventions with individuals in substance abuse treatment or recovery (Structured abstract). J Consult Clin Psychol. 2004:1144-56. Exclusion Code: X3. [pmid: 15612860].
297 Randall CL, Johnson MR, Thevos AK, et al. Paroxetine for social anxiety and alcohol use in dual-diagnosed patients. Depress Anxiety. 2001;14(4):255-62. Exclusion Code: X9. [pmid: 11754136].
298 Ray LA, Hutchison KE, Bryan A. Psychosocial predictors of treatment outcome, dropout, and change processes in a pharmacological clinical trial for alcohol dependence. Addict Disord Their Treat. 2006;5(4):179-90. Exclusion Code: X6.
299 Ray LA, Miranda R Jr., MacKillop J, et al. A preliminary pharmacogenetic investigation of adverse events from topiramate in heavy drinkers. Exp Clin Psychopharmacol. Apr. 2009;17(2):122-9. Exclusion Code: X9. [pmid: 19331489].
300 Ray LA, Oslin DW. Naltrexone for the treatment of alcohol dependence among African Americans: results from the COMBINE Study. Drug Alcohol Depend. Dec. 1. 2009;105(3):256-8. Exclusion Code: X5. [pmid: 19717248].
301 Reid SC, Teesson M, Sannibale C, et al. The efficacy of compliance therapy in pharmacotherapy for alcohol dependence: a randomized controlled trial. J Stud Alcohol. Nov. 2005;66(6):833-41. Exclusion Code: X5. [pmid: 16459945].
302 Richardson K, Baillie A, Reid S, et al. Do acamprosate or naltrexone have an effect on daily drinking by reducing craving for alcohol?. Addiction. Jun. 2008;103(6):953-9. Exclusion Code: X6. [pmid: 18482418].
303 Roache JD. L/S serotonin transporter polymorphism predicts serotonergic treatment outcome in alcohol dependence. Alcohol. 2011;35:339A. Exclusion Code: X9.
304 Rohsenow DJ, Colby SM, Monti PM, et al. Predictors of compliance with naltrexone among alcoholics. Alcohol Clin Exp Res. Oct. 2000;24(10):1542-9. Exclusion Code: X6. [pmid: 11045863].
305 Roosa BA. Alcoholism treatment and medical utilization. US. ProQuest Information & Learning. 1986. Exclusion Code: X8.
306 Rosenberg CM. Drug maintenance in the outpatient treatment of chronic alcoholism. Arch Gen Psychiatry. Mar. 1974;30(3):373-7. Exclusion Code: X8. [pmid: 4813140].
307 Rosenthal RN, Gage A, Perhach JL, et al. Acamprosate: Safety and tolerability in the treatment of alcohol dependence. J Addict Med. 2008;2(1):40-50. Exclusion Code: X8. [pmid: 21768971].
308 Rosenthal RN, Perkel C, Singh P, et al. A pilot open randomized trial of valproate and phenobarbital in the treatment of acute alcohol withdrawal. Am J Addict. Summer. 1998;7(3):189-97. Exclusion Code: X6. [pmid: 9702286].
309 Rosner S, Leucht S, Lehert P, et al. Acamprosate supports abstinence, naltrexone prevents excessive drinking: evidence from a meta-analysis with unreported outcomes. J Psychopharmacol. Jan. 2008;22(1):11-23. Exclusion Code: X10. [pmid: 18187529].
310 Roussaux JP, Hers D, Ferauge M. Does acamprosate influence alcohol consumption of weaned alcoholics?. J Pharm Belg. 1996;51(2):65-8. CN-00173028. Exclusion Code: X1. [pmid: 8786520].
311 Roy A. Treating depression among alcoholics. Can J Psychiatry. 1996;41(3):194-5. Exclusion Code: X5. [pmid: 8722652].
312 Roy A. Placebo-controlled study of sertraline in depressed recently abstinent alcoholics. Biol Psychiatry. Oct. 1. 1998;44(7):633-7. Exclusion Code: X6. [pmid: 9787889].
313 Rubio G, Manzanares J, Lopez-Munoz F, et al. Naltrexone improves outcome of a controlled drinking program. J Subst Abuse Treat. Dec. 2002;23(4):361-6. Exclusion Code: X8. [pmid: 12495798].
314 Rubio G, Ponce G, Jimenez-Arriero MA, et al. Effects of topiramate in the treatment of alcohol dependence. Pharmacopsychiatry. Jan. 2004;37(1):37-40. Exclusion Code: X5. [pmid: 14750047].
315 Rubio G, Ponce G, Rodriguez-Jimenez R, et al. Clinical predictors of response to naltrexone in alcoholic patients: who benefits most from treatment with naltrexone?. Alcohol Alcohol. May-Jun. 2005;40(3):227-33. Exclusion Code: X5. [pmid: 15797885].
316 Schaumberg K, Kuerbis A, Morgenstern J, et al. Attributions of Change and Self-Efficacy in a Randomized Controlled Trial of Medication and Psychotherapy for Problem Drinking. Behav Ther. 2013;44(1):88-99. Exclusion Code: X6. [pmid: 23312429].
317 Schmidt LG, Smolka MN. Results from two pharmacotherapy trials show alcoholic smokers were more severely alcohol dependent but less prone to relapse than alcoholic non-smokers. Alcohol Alcohol. May-Jun. 2007;42(3):241-6. Exclusion Code: X8. [pmid: 17526634].
318 Scott C, Corbin WR, Leeman RF, et al. The influence of initial subjective response and acquired tolerance to alcohol on drinking behavior and problems in a clinical sample. Alcohol. 2011;35:165A. Exclusion Code: X6.
319 Sellers EM, Higgins GA, Tompkins DM, et al. Serotonin and alcohol drinking. NIDA Res Monogr. 1992;119:141-5. Exclusion Code: X9. [pmid: 1435969].
320 Sellers EM, Naranjo CA, Kadlec K. Do serotonin uptake inhibitors decrease smoking? Observations in a group of heavy drinkers. J Clin Psychopharmacol. Dec. 1987;7(6):417-20. Exclusion Code: X8. [pmid: 2963034].
321 Sellers EM, Toneatto T, Romach MK, et al. Clinical efficacy of the 5-HT3 antagonist ondansetron in alcohol abuse and dependence. Alcohol Clin Exp Res. Aug. 1994;18(4):879-85. Exclusion Code: X9. [pmid: 7978099].
322 Seneviratne C, Johnson BA. Serotonin transporter genomic biomarker for quantitative assessment of ondansetron treatment response in alcoholics. Front Psychiatry. 2012;3. Exclusion Code: X6. [pmid: 22470354].
323 Shin S, Livchits V, Connery HS, et al. Effectiveness of alcohol treatment interventions integrated into routine tuberculosis care in Tomsk, Russia. Addiction. 2013;108(8):1387-96. 2013-25290-007. First Author & Affiliation: Shin, Sonya. Exclusion Code: X5. [pmid: 23490304].
324 Simon GE, Heiligenstein J, Revicki D. More people with depression continued treatment with fluoxetine than with desipramine or imipramine. Evid Based Med. 2000;5(2):51. Exclusion Code: X3.
325 Simpson TL, Saxon AJ, Meredith CW, et al. A pilot trial of the alpha-1 adrenergic antagonist, prazosin, for alcohol dependence. Alcohol Clin Exp Res. Feb. 2009;33(2):255-63. Exclusion Code: X9. [pmid: 18945226].
326 Sloan TB, Roache JD, Johnson BA. The role of anxiety in predicting drinking behaviour. Alcohol Alcohol. Jul-Aug. 2003;38(4):360-3. Exclusion Code: X9. [pmid: 12814905].
327 Smith Erica J, Lui S, Terplan M. Pharmacologic Interventions for Pregnant Women Enrolled in Alcohol Treatment. Cochrane Database Syst Rev. John Wiley & Sons, Ltd. 2009. Exclusion Code: X6.
328 Snyder JL, Bowers TG. The efficacy of acamprosate and naltrexone in the treatment of alcohol dependence: a relative benefits analysis of randomized controlled trials. Am J Drug Alcohol Abuse. 2008;34(4):449-61. Exclusion Code: X10. [pmid: 18584575].
329 Snyder S, Karacan I, Salis PJ. Disulfiram and nocturnal penile tumescence in the chronic alcoholic. Biol Psychiatry. Apr. 1981;16(4):399-406. Exclusion Code: X6. [pmid: 7225493].
330 Snyder S, Karacan I, Salis PJ. Effects of disulfiram on the sleep of chronic alcoholics. Curr Alcohol. 1981;8:159-66. Exclusion Code: X7. [pmid: 6282542].
331 Snyder S, Keeler M. Acute effects of disulfiram on anxiety levels of chronic alcoholics. Int Pharmacopsychiatry. 1981;16(1):49-56. Exclusion Code: X7. [pmid: 7028657].
332 Soyka M, Sass H. Acamprosate: a new pharmacotherapeutic approach to relapse prevention in alcoholism--preliminary data. Alcohol Alcohol Suppl. 1994;2:531-6. Exclusion Code: X6. [pmid: 8974379].
333 Specka M, Lieb B, Kuhlmann T, et al. Marked reduction of heavy drinking did not reduce nicotine use over 1 year in a clinical sample of alcohol-dependent patients. Pharmacopsychiatry. 2011;44(3):120-1. Exclusion Code: X6. [pmid: 21298613].
334 Spies CD, Dubisz N, Neumann T, et al. Therapy of alcohol withdrawal syndrome in intensive care unit patients following trauma: results of a prospective, randomized trial. Crit Care Med. Mar. 1996;24(3):414-22. Exclusion Code: X3. [pmid: 8625628].
335 Srisurapanont M, Jarusuraisin N. Naltrexone for the treatment of alcoholism: a meta-analysis of randomized controlled trials. Int J Neuropsychopharmacol. Jun. 2005;8(2):267-80. Exclusion Code: X10. [pmid: 15850502].
336 Staner L, Boeijinga P, Danel T, et al. Effects of acamprosate on sleep during alcohol withdrawal: A double-blind placebo-controlled polysomnographic study in alcohol-dependent subjects. Alcohol Clin Exp Res. Sep. 2006;30(9):1492-9. Exclusion Code: X6. [pmid: 16930211].
337 Stapleton JM, Eckardt MJ, Martin P, et al. Treatment of alcoholic organic brain syndrome with the serotonin reuptake inhibitor fluvoxamine: a preliminary study. Adv Alcohol Subst Abuse. 1988;7(3-4):47-51. Exclusion Code: X6. [pmid: 2464912].
338 Streeton C, Whelan G. Naltrexone, a relapse prevention maintenance treatment of alcohol dependence: a meta-analysis of randomized controlled trials. Alcohol Alcohol. Nov-Dec. 2001;36(6):544-52. Exclusion Code: X10. [pmid: 11704620].
339 Su N, Zhang L, Fei F, et al. The brain-derived neurotrophic factor is associated with alcohol dependence-related depression and antidepressant response. Brain Res. Sep. 30. 2011;1415:119-26. Exclusion Code: X9. [pmid: 21880305].
340 Suh JJ, Pettinati HM, Kampman KM, et al. Gender differences in predictors of treatment attrition with high dose naltrexone in cocaine and alcohol dependence. Am J Addict. Nov-Dec. 2008;17(6):463-8. Exclusion Code: X6. [pmid: 19034737].
341 Swearingen CE, Moyer A, Finney JW. Alcoholism treatment outcome studies, 1970-1998: An expanded look at the nature of the research. Addict Behav. 2003;28(3):415-36. Exclusion Code: X6. [pmid: 12628616].
342 Swift R. Emerging approaches to managing alcohol dependence. Am J Health Syst Pharm. 2007;64(5 Suppl):S12-S22. Exclusion Code: X2. [pmid: 17322178].
343 Swift RM. The pharmacotherapy of alcohol dependence: Clinical and economic aspects. Econ Neurosci. 2001;3(12):62-6. Exclusion Code: X2.
344 Tauscher-Wisniewski S, Disch D, Plewes J, et al. Evaluating suicide-related adverse events in clinical trials of fluoxetine treatment in adults for indications other than major depressive disorder. Psychol Med. 2007;37(11):1585-93. Exclusion Code: X3. [pmid: 17640442].
345 Thevos AK, Brown JM, Malcolm R, et al. Alcohol treatment: measurement of effectiveness by global outcome. Soc Work Health Care. 1996;23(3):57-71. Exclusion Code: X6. [pmid: 8865515].
346 Tidey JW, Monti PM, Rohsenow DJ, et al. Moderators of naltrexone's effects on drinking, urge, and alcohol effects in non-treatment-seeking heavy drinkers in the natural environment. Alcohol Clin Exp Res. Jan. 2008;32(1):58-66. Exclusion Code: X9. [pmid: 18028530].
347 Tollefson GD. Serotonin and alcohol: Interrelationships. Psychopathology. 1989;22(SUPPL. 1):37-48. Exclusion Code: X8. [pmid: 2567040].
348 Tolliver BK, Brady KT. Glutamate neurotransmission as a potential therapeutic target in bipolar disorder: An overview of evidence and implications for treatment of co-occurring disorders. Bipolar Disord. 2011;13:100. Exclusion Code: X9.
349 Tolliver BK, Desantis SM, Brown DG, et al. A randomized, double-blind, placebo-controlled clinical trial of acamprosate in alcohol-dependent individuals with bipolar disorder: a preliminary report. Bipolar Disord. Feb. 2012;14(1):54-63. Exclusion Code: X9. [pmid: 22329472].
350 Tolliver BK, McRae AL, Sonne SC, et al. Safety and tolerability of acamprosate in alcohol-dependent individuals with bipolar disorder: An open-label pilot study. Addict Disord Their Treat. 2009;8(1):33-8. Exclusion Code: X8.
351 Toneatto T, Brands B, Selby P. A randomized, double-blind, placebo-controlled trial of naltrexone in the treatment of concurrent alcohol use disorder and pathological gambling. Am J Addict. May-Jun. 2009;18(3):219-25. Exclusion Code: X9. [pmid: 19340640].
352 Trevisan LA, Ralevski E, Keegan K, et al. Alcohol detoxification and relapse prevention using valproic acid versus gabapentin in alcohol-dependent patients. Addict Disord Their Treat. 2008;7(3):119-28. Exclusion Code: X9.
353 Ulmer A, Müller M, Frietsch B. Dihydrocodeine/agonists for alcohol dependents. Front Psychiatry. 2012;3. Exclusion Code: X8. [pmid: 22470353].
354 Ulrichsen J, Nielsen MK, Ulrichsen M. Disulfiram in severe alcoholisman open controlled study. Nord J Psychiatry. 2010;64(6):356-62. Exclusion Code: X5. [pmid: 20297945].
355 van den Brink W, Aubin HJ, Bladstrom A, et al. Efficacy of as-needed nalmefene in alcohol-dependent patients with at least a high drinking risk level: results from a subgroup analysis of two randomized controlled 6-month studies. Alcohol Alcohol. Sep-Oct. 2013;48(5):570-8. Exclusion Code: X8. [pmid: 23873853].
356 Vaughan MD, Hook JN, Wagley JN, et al. Changes in affect and drinking outcomes in a pharmacobehavioral trial for alcohol dependence. Addict Disord Their Treat. 2012;11(1):14-25. Exclusion Code: X6. [pmid: 22368517].
357 Vaz de Lima Fabiana B, Andriolo Régis B, da Silveira Dartiu X. Dopaminergic antagonists for alcohol dependence. Cochrane Database Syst Rev. 2010;(4):CD008460. Exclusion Code: X8.
358 Verheul R, Lehert P, Geerlings PJ, et al. Predictors of acamprosate efficacy: results from a pooled analysis of seven European trials including 1485 alcohol-dependent patients. Psychopharmacology (Berl). Mar. 2005;178(2-3):167-73. Exclusion Code: X8. [pmid: 15322728].
359 Volpicelli JR, Watson NT, King AC, et al. Effect of naltrexone on alcohol ‘high’ in alcoholics. Am J Psychiatry. 1995;152(4):613-5. Exclusion Code: X8. [pmid: 7694913].
360 Voronin K, Randall P, Myrick H, et al. Aripiprazole effects on alcohol consumption and subjective reports in a clinical laboratory paradigm--possible influence of self-control. Alcohol Clin Exp Res. Nov. 2008;32(11):1954-61. Exclusion Code: X7. [pmid: 18782344].
361 Weinrieb RM, O'Brien CP. Naltrexone in the treatment of alcoholism. Annu Rev Med. 1997;48:477-87. Exclusion Code: X8. [pmid: 9046978].
362 Weinrieb RM, Van Horn DH, McLellan AT, et al. Alcoholism treatment after liver transplantation: lessons learned from a clinical trial that failed. Psychosomatics. Mar-Apr. 2001;42(2):110-6. Exclusion Code: X6. [pmid: 11239123].
363 Wilens TE, Adler LA, Tanaka Y, et al. Correlates of alcohol use in adults with ADHD and comorbid alcohol use disorders: exploratory analysis of a placebo-controlled trial of atomoxetine. Curr Med Res Opin. Dec. 2011;27(12):2309-20. Exclusion Code: X5. [pmid: 22029549].
364 Wilens TE, Adler LA, Weiss MD, et al. Atomoxetine treatment of adults with ADHD and comorbid alcohol abuse. Proceedings of the 69th Annual Scientific Meeting of the College on Problems of Drug Dependence. 2007 June 16-21. Quebec City, Canada. 2007. Exclusion Code: X8.
365 Witkiewitz K. Predictors of heavy drinking during and following treatment. Psychol Addict Behav. 2011;25(3):426-38. Exclusion Code: X6. [pmid: 21480681].
366 Witte J, Bentley K, Evins AE, et al. A randomized, controlled, pilot study of acamprosate added to escitalopram in adults with major depressive disorder and alcohol use disorder. J Clin Psychopharmacol. 2012;32(6):787-96. Exclusion Code: X4. [pmid: 23131884].
367 Workeneh B, Balakumaran A, Bichet DG, et al. The dilemma of diagnosing the cause of hypernatraemia: Drinking habits vs diabetes insidipus. Nephrol Dial Transplant. 2004;19(12):3165-7. Exclusion Code: X8. [pmid: 15575005].
368 Yen MH, Ko HC, Tang FI, et al. Study of hepatotoxicity of naltrexone in the treatment of alcoholism. Alcohol. Feb. 2006;38(2):117-20. Exclusion Code: X8. [pmid: 16839858].
369 Zarkin GA, Bray JW, Aldridge A, et al. The effect of alcohol treatment on social costs of alcohol dependence: results from the COMBINE study. Med Care. May. 2010;48(5):396-401. Exclusion Code: X6. [pmid: 20393362].