# Search Strategy

PubMed, Original Search, 2-6-13

Search | Query | Items found
#1 | Search “Alcohol-Related Disorders” [MeSH] | 92008
#2 | Search “Alcoholism” [MeSH] | 64059
#3 | Search “Alcohol Drinking” [MeSH] | 46842
#4 | Search alcohol depend* | 8221
#5 | Search “alcohol misuse” | 1331
#6 | Search alcohol addiction* | 724
#7 | Search “alcohol abuse” | 12291
#8 | Search problem drink* | 2220
#9 | Search alcohol problem* | 2955
#10 | Search “alcohol consumption” | 25255
#11 | Search harmful alcohol* | 223
#12 | Search harmful drink* | 244
#13 | Search ((drinking[tiab] OR drinker[tiab] OR drinkers[tiab]) AND alcohol[tiab]) | 24901
#14 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13) | 146095
#15 | Search “Alcohol Deterrents”[MeSH] | 1053
#16 | Search (“Naltrexone”[Mesh] OR naltrexone) | 7566
#17 | Search ReVia | 7567
#18 | Search Vivitrol | 12
#19 | Search (“acamprosate” [Supplementary Concept] OR acamprosate) | 603
#20 | Search Campral | 605
#21 | Search (“Disulfiram”[Mesh] OR Disulfiram) | 3661
#22 | Search Antabuse | 3730
#23 | Search (“Amitriptyline”[Mesh] OR Amitriptyline) | 7828
#24 | Search (“aripiprazole” [Supplementary Concept] OR aripiprazole) | 2079
#25 | Search (“atomoxetine” [Supplementary Concept] OR atomoxetine) | 964
#26 | Search (“Baclofen”[Mesh] OR Baclofen) | 6326
#27 | Search (“Buspirone”[Mesh] OR Buspirone) | 2546
#28 | Search (“Citalopram”[Mesh] OR citalopram) | 4661
#29 | Search (“Desipramine”[Mesh] OR Desipramine) | 7383
#30 | Search escitalopram | 4916
#31 | Search (“Fluoxetine”[Mesh] OR Fluoxetine) | 10276
#32 | Search (“Fluvoxamine”[Mesh] OR Fluvoxamine) | 2470
#33 | Search (“gabapentin” [Supplementary Concept] OR gabapentin) | 4127
#34 | Search (“Imipramine”[Mesh] OR Imipramine) | 12137
#35 | Search (“nalmefene” [Supplementary Concept] OR nalmefene) | 245
#36 | Search (“olanzapine” [Supplementary Concept] OR olanzapine) | 6265
#37 | Search (“Ondansetron”[Mesh] OR Ondansetron) | 3576
#38 | Search (“Paroxetine”[Mesh] OR paroxetine) | 4965
#39 | Search (“Prazosin”[Mesh] OR Prazosin) | 12613
#40 | Search (“quetiapine” [Supplementary Concept] OR quetiapine) | 3081
#41 | Search (“Sertraline”[Mesh] OR Sertraline) | 3462
#42 | Search (“topiramate”[Supplementary Concept] OR topiramate) | 3130
#43 | Search (“Valproic Acid”[Mesh] OR Valproate) | 13895
#44 | Search (“varenicline”[Supplementary Concept] OR varenicline) | 820
#45 | Search (“Viloxazine”[Mesh] OR Viloxazine) | 318
#46 | Search (#15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45) | 105016
#47 | Search (#14 and #46) | 3828
#48 | Search (#14 and #46) Filters: Humans | 2856
#49 | Search (#14 and #46) Filters: Humans; English | 2406
#50 | Search (#14 and #46) Filters: Humans; English; Adult: 19+ years | 1296
#51 | Search (#14 and #46) Filters: Publication date from 1970/01/01; Humans; English; Adult: 19+ years | 1270
#52 | Search (comment[pt] OR editorial[pt] OR letter[pt] OR news[pt]) | 1353911
#53 | Search (#51 not #52) | 1165

PubMed, Update Search, 10-11-13

Search | Query | Items found
#1 | Search “Alcohol-Related Disorders” [MeSH] | 93541
#2 | Search “Alcoholism” [MeSH] | 64878
#3 | Search “Alcohol Drinking” [MeSH] | 48394
#4 | Search alcohol depend* | 8688
#5 | Search “alcohol misuse” | 1428
#6 | Search alcohol addiction* | 797
#7 | Search “alcohol abuse” | 12796
#8 | Search problem drink* | 2299
#9 | Search alcohol problem* | 3053
#10 | Search “alcohol consumption” | 26558
#11 | Search harmful alcohol* | 259
#12 | Search harmful drink* | 282
#13 | Search ((drinking[tiab] OR drinker[tiab] OR drinkers[tiab]) AND alcohol[tiab]) | 26208
#14 | Search (#1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13) | 150350
#15 | Search “Alcohol Deterrents”[MeSH] | 1080
#16 | Search (“Naltrexone”[Mesh] OR naltrexone) | 7792
#17 | Search ReVia | 7793
#18 | Search Vivitrol | 17
#19 | Search (“acamprosate” [Supplementary Concept] OR acamprosate) | 634
#20 | Search Campral | 636
#21 | Search (“Disulfiram”[Mesh] OR Disulfiram) | 3719
#22 | Search Antabuse | 3791
#23 | Search (“Amitriptyline”[Mesh] OR Amitriptyline) | 7964
#24 | Search (“aripiprazole” [Supplementary Concept] OR aripiprazole) | 2278
#25 | Search (“atomoxetine” [Supplementary Concept] OR atomoxetine) | 1054
#26 | Search (“Baclofen”[Mesh] OR Baclofen) | 6471
#27 | Search (“Buspirone”[Mesh] OR Buspirone) | 2583
#28 | Search (“Citalopram”[Mesh] OR citalopram) | 4889
#29 | Search (“Desipramine”[Mesh] OR Desipramine) | 7431
#30 | Search escitalopram | 5185
#31 | Search (“Fluoxetine”[Mesh] OR Fluoxetine) | 10600
#32 | Search (“Fluvoxamine”[Mesh] OR Fluvoxamine) | 2516
#33 | Search (“gabapentin” [Supplementary Concept] OR gabapentin) | 4349
#34 | Search (“Imipramine”[Mesh] OR Imipramine) | 12228
#35 | Search (“nalmefene” [Supplementary Concept] OR nalmefene) | 251
#36 | Search (“olanzapine” [Supplementary Concept] OR olanzapine) | 6590
#37 | Search (“Ondansetron”[Mesh] OR Ondansetron) | 3695
#38 | Search (“Paroxetine”[Mesh] OR paroxetine) | 5103
#39 | Search (“Prazosin”[Mesh] OR Prazosin) | 12737
#40 | Search (“quetiapine” [Supplementary Concept] OR quetiapine) | 3297
#41 | Search (“Sertraline”[Mesh] OR Sertraline) | 3608
#42 | Search (“topiramate”[Supplementary Concept] OR topiramate) | 3339
#43 | Search (“Valproic Acid”[Mesh] OR Valproate) | 14447
#44 | Search (“varenicline”[Supplementary Concept] OR varenicline) | 923
#45 | Search (“Viloxazine”[Mesh] OR Viloxazine) | 319
#46 | Search (#15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45) | 108190
#47 | Search (#14 and #46) | 3952
#48 | Search (#14 and #46) Filters: Humans | 2926
#49 | Search (#14 and #46) Filters: Humans; English | 2462
#50 | Search (#14 and #46) Filters: Humans; English; Adult: 19+ years | 1328
#51 | Search (#14 and #46) Filters: Publication date from 1970/01/01; Humans; English; Adult: 19+ years | 1302
#52 | Search (comment[pt] OR editorial[pt] OR letter[pt] OR news[pt])) | 1409249
#53 | Search (#51 NOT #52) | 1197
#54 | Search (#51 NOT #52) Filters: Publication date from 2012/02/11 to 2013/12/31 | 60
#55 | Search (#47 AND (“retraction”[All Fields] OR “Retracted Publication”[pt])) | 4

PSYCINFO, Original Search, 2-11-13

Search ID# | Search Terms | Search Options | Actions
S49 | S48 | Limiters - Publication Year from: 1970-2013; English; Language: English; Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | View Results (957) View Details Edit
S48 | S14 AND S46 | Narrow by SubjectAge: - adulthood (18 yrs & older) Search modes - Boolean/Phrase | View Results (997) View Details Edit
S47 | S14 AND S46 | Search modes - Boolean/Phrase | View Results (1,938) View Details Edit
S46 | S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 OR S42 OR S43 OR S44 OR S45 | Search modes - Boolean/Phrase | View Results (33,948) View Details Edit
S45 | Viloxazine | Search modes - Boolean/Phrase | View Results (108) View Details Edit
S44 | varenicline | Search modes - Boolean/Phrase | View Results (314) View Details Edit
S43 | “Valproic Acid” OR Valproate | Search modes - Boolean/Phrase | View Results (3,170) View Details Edit
S42 | topiramate | Search modes - Boolean/Phrase | View Results (1,147) View Details Edit
S41 | Sertraline | Search modes - Boolean/Phrase | View Results (2,064) View Details Edit
S40 | quetiapine | Search modes - Boolean/Phrase | View Results (2,387) View Details Edit
S39 | Prazosin | Search modes - Boolean/Phrase | View Results (486) View Details Edit
S38 | Paroxetine | Search modes - Boolean/Phrase | View Results (2,731) View Details Edit
S37 | Ondansetron | Search modes - Boolean/Phrase | View Results (367) View Details Edit
S36 | olanzapine | Search modes - Boolean/Phrase | View Results (4,620) View Details Edit
S35 | nalmefene | Search modes - Boolean/Phrase | View Results (68) View Details Edit
S34 | Imipramine | Search modes - Boolean/Phrase | View Results (3,866) View Details Edit
S33 | gabapentin | Search modes - Boolean/Phrase | View Results (954) View Details Edit
S32 | Fluvoxamine | Search modes - Boolean/Phrase | View Results (1,413) View Details Edit
S31 | Fluoxetine | Search modes - Boolean/Phrase | View Results (5,313) View Details Edit
S30 | escitalopram | Search modes - Boolean/Phrase | View Results (759) View Details Edit
S29 | Desipramine | Search modes - Boolean/Phrase | View Results (1,996) View Details Edit
S28 | Citalopram | Search modes - Boolean/Phrase | View Results (1,977) View Details Edit
S27 | Buspirone | Search modes - Boolean/Phrase | View Results (1,303) View Details Edit
S26 | Baclofen | Search modes - Boolean/Phrase | View Results (936) View Details Edit
S25 | atomoxetine | Search modes - Boolean/Phrase | View Results (495) View Details Edit
S24 | aripiprazole | Search modes - Boolean/Phrase | View Results (1,410) View Details Edit
S23 | Amitriptyline | Search modes - Boolean/Phrase | View Results (2,183) View Details Edit
S22 | Antabuse | Search modes - Boolean/Phrase | View Results (154) View Details Edit
S21 | Disulfiram | Search modes - Boolean/Phrase | View Results (573) View Details Edit
S20 | Campral | Search modes - Boolean/Phrase | View Results (13) View Details Edit
S19 | acamprosate | Search modes - Boolean/Phrase | View Results (329) View Details Edit
S18 | Vivitrol | Search modes - Boolean/Phrase | View Results (12) View Details Edit
S17 | ReVia | Search modes - Boolean/Phrase | View Results (18) View Details Edit
S16 | naltrexone | Search modes - Boolean/Phrase | View Results (2,556) View Details Edit
S15 | “Alcohol Deterrents” | Search modes - Boolean/Phrase | View Results (1) View Details Edit
S14 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 | Search modes - Boolean/Phrase | View Results (69,149) View Details Edit
S13 | TI ( (drinking OR drinker OR drinkers) AND alcohol ) OR AB ( (drinking OR drinker OR drinkers) AND alcohol ) | Search modes - Boolean/Phrase | View Results (19,034) View Details Edit
S12 | harmful drink* | Search modes - Boolean/Phrase | View Results (355) View Details Edit
S11 | harmful alcohol* | Search modes - Boolean/Phrase | View Results (479) View Details Edit
S10 | “alcohol consumption” | Search modes - Boolean/Phrase | View Results (11,811) View Details Edit
S9 | alcohol problem* | Search modes - Boolean/Phrase | View Results (10,184) View Details Edit
S8 | problem drink* | Search modes - Boolean/Phrase | View Results (4,978) View Details Edit
S7 | “alcohol abuse” | Search modes - Boolean/Phrase | View Results (20,553) View Details Edit
S6 | alcohol addiction* | Search modes - Boolean/Phrase | View Results (2,985) View Details Edit
S5 | “alcohol misuse” | Search modes - Boolean/Phrase | View Results (1,159) View Details Edit
S4 | alcohol depend* | Search modes - Boolean/Phrase | View Results (14,899) View Details Edit
S3 | (DE “Alcohol Drinking Attitudes” OR DE “Alcohol Drinking Patterns”) OR (DE “Alcohol Intoxication”) | Search modes - Boolean/Phrase | View Results (19,320) View Details Edit
S2 | DE “Alcoholism” | Search modes - Boolean/Phrase | View Results (23,596) View Details Edit
S1 | “Alcohol-Related Disorders” | Search modes - Boolean/Phrase | View Results (203) View Details Edit

PSYCINFO, Update Search, 10-11-13

# | Query | Limiters/Expanders | Last Run Via | Results
S50 | S49 | Limiters - Published Date: 20120801-20131231 Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 53
S49 | S48 | Limiters - Publication Year: 1970-2013; English; Language: English; Age Groups: Adulthood (18 yrs & older); Population Group: Human Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | [underlined: 1],002
S48 | S14 AND S46 | Limiters - Age Groups: Adulthood (18 yrs & older) Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,042
S47 | S14 AND S46 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,035
S46 | S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 OR S42 OR S43 OR S44 OR S45 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 35,405
S45 | Viloxazine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 109
S44 | varenicline | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 372
S43 | “Valproic Acid” OR Valproate | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 3,339
S42 | topiramate | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,227
S41 | Sertraline | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,159
S40 | quetiapine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,551
S39 | Prazosin | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 512
S38 | Paroxetine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,810
S37 | Ondansetron | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 383
S36 | olanzapine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4,873
S35 | nalmefene | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 72
S34 | Imipramine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 3,909
S33 | gabapentin | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,010
S32 | Fluvoxamine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,444
S31 | Fluoxetine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 5,497
S30 | escitalopram | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 849
S29 | Desipramine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,015
S28 | [underlined: Citalopram] | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,076
S27 | Buspirone | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,326
S26 | Baclofen | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 998
S25 | atomoxetine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 555
S24 | aripiprazole | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,550
S23 | Amitriptyline | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,216
S22 | Antabuse | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 157
S21 | Disulfiram | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 592
S20 | Campral | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 13
S19 | acamprosate | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 352
S18 | Vivitrol | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 14
S17 | ReVia | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 19
S16 | naltrexone | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,649
S15 | “Alcohol Deterrents” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1
S14 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 71,938
S13 | TI ( (drinking OR drinker OR drinkers) AND alcohol ) OR AB ( (drinking OR drinker OR drinkers) AND alcohol ) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 20,047
S12 | harmful drink* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 385
S11 | harmful alcohol* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search [underlined: Database]- PsycINFO | 524
S10 | “alcohol consumption” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 12,456
S9 | alcohol problem* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 10,591
S8 | problem drink* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 5,157
S7 | “alcohol abuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 21,291
S6 | alcohol addiction* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 3,141
S5 | “alcohol misuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,245
S4 | alcohol depend* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 15,716
S3 | (DE “Alcohol Drinking Attitudes” OR DE “Alcohol Drinking Patterns”) OR (DE “Alcohol Intoxication”) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 19,962
S2 | DE “Alcoholism” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 24,275
S1 | “Alcohol-Related Disorders” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 213

CINAHL, Original Search, 2-11-13

# | Query | Limiters/Expanders | Last Run Via | Results
S50 | S48 NOT S49 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 6
S49 | PT comment OR editorial OR letter OR news | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 65,069
S48 | S47 | Limiters - Published Date from: 19700101-20131231; English Language; Exclude MEDLINE records; Human; Language: English; Age Groups: All Adult Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 6
S47 | S14 AND S46 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 676
S46 | S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 OR S42 OR S43 OR S44 OR S45 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 9,728
S45 | Viloxazine | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 4
S44 | varenicline | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 233
S43 | “Valproic Acid” OR Valproate | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 1,159
S42 | topiramate | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 676
S41 | Sertraline | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 602
S40 | quetiapine | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 555
S39 | Prazosin | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 0
S38 | Paroxetine | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 695
S37 | Ondansetron | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 491
S36 | olanzapine | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 1,060
S35 | nalmefene | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 20
S34 | Imipramine | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 211
S33 | gabapentin | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 909
S32 | Fluvoxamine | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 139
S31 | Fluoxetine | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 1,095
S30 | escitalopram | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 173
S29 | Desipramine | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 111
S28 | Citalopram | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 566
S27 | Buspirone | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 147
S26 | Baclofen | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 608
S25 | atomoxetine | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 245
S24 | aripiprazole | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 391
S23 | Amitriptyline | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 512
S22 | Antabuse | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 16
S21 | Disulfiram | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 153
S20 | Campral | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 5
S19 | acamprosate | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 115
S18 | Vivitrol | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 35
S17 | ReVia | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 11
S16 | Naltrexone | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 800
S15 | (MH “Alcohol Deterrents”) | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 150
S14 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 25,084
S13 | TI ( (drinking OR drinker OR drinkers) AND alcohol ) OR AB ( (drinking OR drinker OR drinkers) AND alcohol ) | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 5,120
S12 | harmful drink* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 145
S11 | harmful alcohol* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 199
S10 | “alcohol consumption” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 4,342
S9 | alcohol problem* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 2,512
S8 | problem drink* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 744
S7 | “alcohol abuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 6,285
S6 | alcohol addiction* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 291
S5 | “alcohol misuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 490
S4 | alcohol depend* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 2,448
S3 | (MH “Alcohol Drinking”) | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 10,939
S2 | (MH “Alcoholism”) | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 7,614
S1 | (MH “Alcohol-Related Disorders”) | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text | 297

CINAHL, Update Search, 10-11-13

# | Query | Limiters/Expanders | Last Run Via | Results
S51 | S50 | Limiters - Published Date: 20120801-20131231 Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 0
S50 | S48 NOT S49 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 6
S49 | PT comment OR editorial OR letter OR news | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 67,134
S48 | S47 | Limiters - Published Date: 19700101-20131231; English Language; Exclude MEDLINE records; Human; Language: English; Age Groups: All Adult Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 6
S47 | S14 AND S46 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 707
S46 | S15 OR S16 OR S17 OR S18 OR S19 OR S20 OR S21 OR S22 OR S23 OR S24 OR S25 OR S26 OR S27 OR S28 OR S29 OR S30 OR S31 OR S32 OR S33 OR S34 OR S35 OR S36 OR S37 OR S38 OR S39 OR S40 OR S41 OR S42 OR S43 OR S44 OR S45 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 10,125
S45 | Viloxazine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 4
S44 | varenicline | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 254
S43 | “Valproic Acid” OR Valproate | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 1,218
S42 | topiramate | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 701
S41 | Sertraline | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 624
S40 | quetiapine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 575
S39 | Prazosin | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 168
S38 | Paroxetine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 714
S37 | Ondansetron | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 515
S36 | olanzapine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 1,088
S35 | nalmefene | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 22
S34 | Imipramine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 214
S33 | gabapentin | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 947
S32 | Fluvoxamine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 142
S31 | Fluoxetine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 1,121
S30 | escitalopram | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 188
S29 | Desipramine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 111
S28 | Citalopram | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 610
S27 | Buspirone | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 151
S26 | Baclofen | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 625
S25 | atomoxetine | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 257
S24 | aripiprazole | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 416
S23 | Amitriptyline | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 535
S22 | Antabuse | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 16
S21 | Disulfiram | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 156
S20 | Campral | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 4
S19 | acamprosate | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 119
S18 | Vivitrol | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 27
S17 | ReVia | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 11
S16 | Naltrexone | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 855
S15 | MH “Alcohol Deterrents” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 156
S14 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 26,288
S13 | TI ( (drinking OR drinker OR drinkers) AND alcohol ) OR AB ( (drinking OR drinker OR drinkers) AND alcohol ) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 5,369
S12 | harmful drink* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 152
S11 | harmful alcohol* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 211
S10 | “alcohol consumption” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 4,535
S9 | alcohol problem* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 2,609
S8 | problem drink* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 772
S7 | “alcohol abuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 6,574
S6 | alcohol addiction* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 304
S5 | “alcohol misuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 529
S4 | alcohol depend* | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 2,554
S3 | MH “Alcohol Drinking” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 11,535
S2 | MH “Alcoholism” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 7,875
S1 | MH “Alcohol-Related Disorders” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 355

EMBASE Minus PubMed, Original Search, 2-6-13

ID | Search | Hits
#50 | #48 NOT #49 AND [1970-2013]/py | 1,730
#49 | editorial:it OR letter:it OR note:it AND [1970-2013]/py | 1,757,884
#48 | #47 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND [embase]/lim AND [1970-2013]/py | 1,929
#47 | #14 AND #46 | 10,860
#46 | #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 | 249,162
#45 | ‘viloxazine’/exp OR viloxazine | 1,500
#44 | ‘varenicline’/exp OR varenicline | 2,131
#43 | ‘valproic acid’/exp OR ‘valproic acid’ OR ‘valproate’/exp OR valproate | 47,334
#42 | ‘topiramate’/exp OR topiramate | 13,558
#41 | ‘sertraline’/exp OR sertraline | 18,228
#40 | ‘quetiapine’/exp OR quetiapine | 14,084
#39 | ‘prazosin’/exp OR prazosin | 23,503
#38 | ‘paroxetine’/exp OR paroxetine | 21,767
#37 | ‘ondansetron’/exp OR ondansetron | 12,066
#36 | ‘olanzapine’/exp OR olanzapine | 22,547
#35 | ‘nalmefene’/exp OR nalmefene | 851
#34 | ‘imipramine’/exp OR imipramine | 33,844
#33 | ‘gabapentin’/exp OR gabapentin | 18,926
#32 | ‘fluvoxamine’/exp OR fluvoxamine | 11,524
#31 | ‘fluoxetine’/exp OR fluoxetine | 35,680
#30 | ‘escitalopram’/exp OR escitalopram | 5,709
#29 | ‘desipramine’/exp OR desipramine | 20,984
#28 | ‘citalopram’/exp OR citalopram | 16,194
#27 | ‘buspirone’/exp OR buspirone | 7,963
#26 | ‘baclofen’/exp OR baclofen | 14,053
#25 | ‘atomoxetine’/exp OR atomoxetine | 2,961
#24 | ‘aripiprazole’/exp OR aripiprazole | 7,609
#23 | ‘amitriptyline’/exp OR amitriptyline | 32,939
#22 | ‘antabuse’/exp OR antabuse | 7,397
#21 | ‘disulfiram’/exp OR disulfiram | 7,707
#20 | ‘campral’/exp OR campral | 1,631
#19 | ‘acamprosate’/exp OR acamprosate | 1,672
#18 | ‘vivitrol’/exp OR vivitrol | 10,702
#17 | ‘revia’/exp OR revia | 10,713
#16 | ‘naltrexone’/exp OR naltrexone | 11,537
#15 | ‘alcohol deterrents’ | 14
#14 | #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 | 218,034
#13 | drinking:ti OR drinker:ti OR drinkers:ti AND alcohol:ti OR (drinking:ab OR drinker:ab OR drinkers:ab AND alcohol:ab) | 31,024
#12 | harmful AND drink* | 1,545
#11 | harmful AND alcohol* | 2,907
#10 | ‘alcohol consumption’/exp | 64,311
#9 | ‘alcohol’/exp AND problem* | 50,149
#8 | problem AND drink* | 41,548
#7 | ‘alcohol abuse’/exp | 20,002
#6 | ‘alcohol’/exp AND addiction* | 36,999
#5 | ‘alcohol misuse’ | 1,697
#4 | ‘alcohol’/exp AND depend* | 30,931
#3 | ‘drinking behavior’/exp | 32,528
#2 | ‘alcoholism’/exp | 95,795
#1 | ‘alcohol-related disorders’/exp | 95.795

Cochrane Library, Original Search, 2-8-13

Cochrane Reviews – 209

Other reviews – 12

Trials – 587

Technology Assessments (1) ● Economic Evaluations (9) ● Cochrane Groups (3)

ID | Search | Hits
#1 | [mh “Alcohol-Related Disorders”] | 3159
#2 | [mh Alcoholism] | 2169
#3 | [mh “Alcohol Drinking”] | 2082
#4 | alcohol depend* | 3909
#5 | “alcohol misuse” | 170
#6 | alcohol addiction* | 1223
#7 | “alcohol abuse” | 1013
#8 | problem drink* | 1172
#9 | alcohol problem* | 2315
#10 | “alcohol consumption” | 2443
#11 | harmful alcohol* | 426
#12 | harmful drink* | 195
#13 | (drinking:ti or drinking:ab or drinker:ti or drinker:ab or drinkers:ti or drinkers:ab) and (alcohol:ti or alcohol:ab) | 2424
#14 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 | 9573
#15 | [mh “Alcohol Deterrents”] | 146
#16 | [mh Naltrexone] or naltrexone | 1073
#17 | ReVia | 8
#18 | Vivitrol | 3
#19 | acamprosate | 182
#20 | Campral | 8
#21 | [mh Disulfiram] or Disulfiram | 224
#22 | Antabuse | 24
#23 | [mh Amitriptyline] or Amitriptyline | 2241
#24 | aripiprazole | 431
#25 | atomoxetine | 217
#26 | [mh Baclofen] or Baclofen | 346
#27 | [mh Buspirone] or Buspirone | 488
#28 | [mh Citalopram] or Citalopram | 1232
#29 | [mh Desipramine] or Desipramine | 797
#30 | escitalopram | 507
#31 | [mh Fluoxetine] or Fluoxetine | 2595
#32 | [mh Fluvoxamine] or Fluvoxamine | 846
#33 | gabapentin | 770
#34 | [mh Imipramine] or Imipramine | 2152
#35 | nalmefene | 79
#36 | olanzapine | 1881
#37 | [mh Ondansetron] or Ondansetron | 1664
#38 | [mh Paroxetine] or Paroxetine | 1915
#39 | [mh Prazosin] or Prazosin | 1010
#40 | quetiapine | 773
#41 | [mh Sertraline] or Sertraline | 1450
#42 | topiramate | 604
#43 | [mh “Valproic Acid”] or Valproate | 1172
#44 | varenicline | 215
#45 | [mh Viloxazine] or Viloxazine | 142
#46 | #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 | 19565
#47 | #14 and #46 | 1238
#48 | comment:pt or editorial:pt or letter:pt or news:pt | 6337
#49 | #47 not #48 from 1970 to 2013 | 1223
#50 | adult or adults or [mh adult] | 292412
#51 | #49 and #50 | 821

Cochrane Library, Update Search, 10-11-13

Cochrane reviews = 116

Other reviews = 2

Trials = 31

ID | Search | Hits
#1 | [mh “Alcohol-Related Disorders”] | 3280
#2 | [mh Alcoholism] | 2249
#3 | [mh “Alcohol Drinking”] | 2172
#4 | alcohol depend* | 4188
#5 | “alcohol misuse” | 189
#6 | alcohol addiction* | 1266
#7 | “alcohol abuse” | 1065
#8 | problem drink* | 1248
#9 | alcohol problem* | 2476
#10 | “alcohol consumption” | 1849
#11 | harmful alcohol* | 486
#12 | harmful drink* | 227
#13 | (drinking:ti or drinking:ab or drinker:ti or drinker:ab or drinkers:ti or drinkers:ab) and (alcohol:ti or alcohol:ab) | 2514
#14 | #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 | 9883
#15 | [mh “Alcohol Deterrents”] | 155
#16 | [mh Naltrexone] or naltrexone | 1146
#17 | ReVia | 10
#18 | Vivitrol | 4
#19 | acamprosate | 202
#20 | Campral | 8
#21 | [mh Disulfiram] or Disulfiram | 234
#22 | Antabuse | 25
#23 | [mh Amitriptyline] or Amitriptyline | 2278
#24 | aripiprazole | 506
#25 | atomoxetine | 235
#26 | [mh Baclofen] or Baclofen | 363
#27 | [mh Buspirone] or Buspirone | 497
#28 | [mh Citalopram] or Citalopram | 1307
#29 | [mh Desipramine] or Desipramine | 809
#30 | escitalopram | 596
#31 | [mh Fluoxetine] or Fluoxetine | 2668
#32 | [mh Fluvoxamine] or Fluvoxamine | 863
#33 | gabapentin | 860
#34 | [mh Imipramine] or Imipramine | 2170
#35 | nalmefene | 86
#36 | olanzapine | 1967
#37 | [mh Ondansetron] or Ondansetron | 1694
#38 | [mh Paroxetine] or Paroxetine | 1994
#39 | [mh Prazosin] or Prazosin | 1037
#40 | quetiapine | 849
#41 | [mh Sertraline] or Sertraline | 1532
#42 | topiramate | 680
#43 | [mh “Valproic Acid”] or Valproate | 1233
#44 | varenicline | 240
#45 | [mh Viloxazine] or Viloxazine | 145
#46 | #15 or #16 or #17 or #18 or #19 or #20 or #21 or #22 or #23 or #24 or #25 or #26 or #27 or #28 or #29 or #30 or #31 or #32 or #33 or #34 or #35 or #36 or #37 or #38 or #39 or #40 or #41 or #42 or #43 or #44 or #45 | 20437
#47 | #14 and #46 | 1333
#48 | comment:pt or editorial:pt or letter:pt or news:pt | 6440
#49 | #47 not #48 | 1326
#50 | #49 from 1970 to 2013 | 1318
#51 | adult or adults or [mh adult] | 300762
#52 | #50 and #51 | 883
#53 | #52 from 2012 to 2013 | 150

ClinicalTrials.gov, Original Search, 2-8-13
- ( ( “Alcohol-Related Disorders” OR “Alcoholism” OR “Alcohol Drinking” OR alcohol depend* OR “alcohol misuse” OR alcohol addiction* OR “alcohol abuse” OR problem drink* OR alcohol problem* OR “alcohol consumption” OR harmful alcohol* OR harmful drink* OR ( drinking OR drinkerOR drinkers ) AND alcohol ) AND ( “Alcohol Deterrents” OR naltrexone OR Revia OR Vivitrol OR acamprosate OR Campral OR disulfiram OR Antabuse OR amitriptyline OR aripiprazole OR atomoxetine OR baclofen OR buspirone OR citalopram OR desipramine OR escitalopram OR fluoxetine OR fluvoxamine OR gabapentin OR imipramine OR nalmefene OR olanzapine OR ondansetron OR paroxetine OR prazosin OR quetiapine OR sertraline OR topiramate OR valproate OR “Valproic Acid” OR varenicline OR vilozaxine ) ) [ALL-FIELDS] AND ( “Adult” OR “Senior” ) [AGE-GROUP] AND ( “01/01/1970” : “02/08/2013” ) [FIRST-RECEIVED-DATE]
  Limited to:
  Age Groups: Adult, Senior
  First Received: 1/1/1970 - 2/8/2013

ClinicalTrials.gov Update, Update Search, 11-13-13
- ( ( “Alcohol-Related Disorders” OR “Alcoholism” OR “Alcohol Drinking” OR alcohol depend* OR “alcohol misuse” OR alcohol addiction* OR “alcohol abuse” OR problem drink* OR alcohol problem* OR “alcohol consumption” OR harmful alcohol* OR harmful drink* OR ( drinking OR drinkerOR drinkers ) AND alcohol ) AND ( “Alcohol Deterrents” OR naltrexone OR Revia OR Vivitrol OR acamprosate OR Campral OR disulfiram OR Antabuse OR amitriptyline OR aripiprazole OR atomoxetine OR baclofen OR buspirone OR citalopram OR desipramine OR escitalopram OR fluoxetine OR fluvoxamine OR gabapentin OR imipramine OR nalmefene OR olanzapine OR ondansetron OR paroxetine OR prazosin OR quetiapine OR sertraline OR topiramate OR valproate OR “Valproic Acid” OR varenicline OR vilozaxine ) ) [ALL-FIELDS] AND ( “Adult” OR “Senior” ) [AGE-GROUP] AND ( “02/08/2013” : “11/13/2013” ) [LAST-RELEASE-DATE]

WHO ICTRP (World Health Organization International Clinical Trials Registry Platform), Original Search, 2-8-2013
- Condition:
  Alcohol-Related Disorders OR Alcoholism OR Alcohol
  Intervention:
  alcohol deterrents OR naltrexone OR Revia OR Vivitrol OR acamprosate OR Campral OR disulfiram OR Antabuse OR amitriptyline OR aripiprazole OR atomoxetine OR baclofen OR buspirone OR citalopram OR desipramine OR escitalopram OR fluoxetine OR fluvoxamine OR gabapentin OR imipramine OR nalmefene OR olanzapine OR ondansetron OR paroxetine OR prazosin OR quetiapine OR sertraline OR topiramate OR valproate OR Valproic Acid OR varenicline OR vilozaxine
  Limited to:
  Did not check box to look for trials in children.
  First Received: 1/1/1970 – 2/8/2013

WHO ICTRP (World Health Organization International Clinical Trials Registry Platform), Update Search, 10-11-2013
- Condition:
  Alcohol-Related Disorders OR Alcoholism OR Alcohol
  Intervention:
  alcohol deterrents OR naltrexone OR Revia OR Vivitrol OR acamprosate OR Campral OR disulfiram OR Antabuse OR amitriptyline OR aripiprazole OR atomoxetine OR baclofen OR buspirone OR citalopram OR desipramine OR escitalopram OR fluoxetine OR fluvoxamine OR gabapentin OR imipramine OR nalmefene OR olanzapine OR ondansetron OR paroxetine OR prazosin OR quetiapine OR sertraline OR topiramate OR valproate OR Valproic Acid OR varenicline OR vilozaxine
  Limited to:
  Did not check box to look for trials in children.
  First Received: 1/8/2013 – 10/11/2013