# Results

This chapter begins with the results of our literature search and a general description of the included studies. We then present our findings by Key Question (KQ), grouped by transitional care intervention, in the categories defined in Table 2 (in Methods). Appendix C presents a table of intervention components organized by intervention.

After describing included studies, we present results by KQ. For each KQ, we give the key points, including the strength-of-evidence (SOE) grades. We then present a detailed synthesis of the literature. Appendix D includes the risk-of-bias assessment for all included studies, organized by intervention category.

In the remainder of this chapter, we present the results of interventions compared with usual care first, followed by trials comparing one transitional care intervention with another type of intervention (generally in a subsection labeled “comparative effectiveness”). In the text, we usually report results as relative risks (RRs) with 95% confidence intervals (CIs); this is specifically the case when trials reported the number of people in each group who were readmitted. When investigators reported the total number or readmissions per group (or gave hazard ratios or some other metric), we present the results as they had been presented in the trial. We mention statistical significance in text only for significant findings; no mention means that differences between groups are not significant.

Tables describing studies (Tables 4–9) are organized first in chronological order by year of publication and, when necessary for more than one study in a year, alphabetically by author. Generally, we present figures with meta-analyses and RR calculations for our primary outcomes (readmission rates and mortality). We document other meta-analyses in Appendix E (e.g., hospital days, quality of life) or Appendix F (sensitivity analyses).

Table 4 Characteristics of trials assessing home-visiting programs

Author, Year Setting | Intervention Category (N), Comparator (N) | Timing (m)^a^ | Baseline NYHA Class; Mean EF | Age (y) | Female (%) | Non-White (%) | Taking BB or ACEI at Discharge (%) | Co-occurring Condition(s) (%) | Risk of Bias
Rich et al., 1993^58^ US; single institution | Home-visiting program (63), Usual care (35) | 3 | NYHA mean: 2.8 | 79 | 59 | 50 | NR | DM: 31 MI: 23 | Med
Rich et al., 1995^57^ US; single institution | Home-visiting program (142), Usual care (140) | 3 | NYHA mean: 2.4 EF: 43% | 79 | 63 | 55 | ACEI: 59 BB: 12 | DM: 28 MI: 43 | Med
Stewart et al., 1998^51^ Australia; single institution | Home-visiting program (49), Usual care (48) | 6 | NYHA class III or IV: 48% | 75 | 52 | NR | ACEI: 81 BB: NR | DM: 22 IHD: 67 MI: 42 AF: 31 | Med
Jaarsma et al., 1999^47^ Netherlands; single institution | Home-visiting program (84), Usual care (95) | 1, 3 | NYHA III or IV: 100% LVEF: 34% | 73 | 42 | NR | ACEI or ARB: 70 BB: NR | DM: 30 | Med
Stewart et al., 1999^50^ Australia; single institution | Home-visiting program (100), Usual care (100) | 6 | NYHAIII or IV: 56% EF: 37% | 76 | 38 | NR | ACEI or ARB: 71 BB: 28 | DM: 34 IHD: 78 AF: 35 | Med
Pugh et al., 2001^52^ US; multicenter | Home-visiting program (27), Usual care (31) | 6 | NYHA III or IV: 51% | 74 | 57 | NR | NR | NR | High
Benatar et al., 2003^61^ US; multicenter | Home-visiting program (108), Telemonitoring (108) | 6 | NYHA mean class: 3.1 EF: 38% | 63 | 63 | 93 | ACEI or ARB: 76 BB: 53 | DM: 23 CAD or other cardiac disorders: 61 | Unc.
Kimmelstiel et al., 2004^53^ US; multicenter | Home-visiting program (97), Usual care (103) | 3 | NYHA II or III: 97% | 72 | 42 | NR | ACEI or ARB: 92 BB: 57 | DM: 48 | Med
Naylor et al., 2004^55^ US; multicenter | Home-visiting program (118), Usual care (121) | 1, 3, 6 | EF<30%: 57% | 76 | 57 | 36 | NR | DM: 38 CAD: 49 Pulmonary disease: 30 | Low
Sethares et al., 2004^48^ US; single institution | Home-visiting program (33), Usual care (37) | 3 | NYHA mean class: 3 EF: 40% | 76 | 53 | 8.5 | ACEI or ARB: 61 BB: 49 | NR | High
Thompson et al., 2005^60^ UK; multicenter | Home-visiting program (58), Usual care (48) | 6 | NYHA III or IV: 40% EF: 30% | 73 | 28 | NR | ACEI or ARB: 69 BB: 18 | DM: 21 MI: 52 AF: 30 chronic airways limitation: 24 | High
Aldamiz-Echevarría Iraúrgui et al., 2007^56^ Spain; single institution | Home-visiting program (137), Usual care (142) | 6 | EF: 50% | 76 | 61 | NR | ACEI or ARB: 84 BB: 12 | DM: 36 IHD: 30.5 AF: 49.6 | Med
Holland et al., 2007^59^ UK; multicenter | Home-visiting program (148), Usual care (143) | 6 | NYHA III or IV: 67% | 77 | 36 | NR | ACEI or ARB: 77 BB: 39 | NR | Med
Kwok et al., 2007^54^ Hong Kong; multicenter | Home-visiting program (44), Usual care (46) | 6 | EF <40%: 24% | 78 | 55 | 100 | ACEI or ARB: 57 BB: 22 | DM: 33 IHD: 47 MI: 23 AF: 30 COPD: 10 | Med
Triller et al., 2008^49^ US; multicenter | Home-visiting program (77), Usual care^b^ (77) | 6 | NR | 80 | 72 | 7 | ACEI or ARB: 47 BB: 62 | NR | Unc

a Timing of readmission outcome.

b Triller et al. compared pharmacist home visits among a population of patients receiving home nursing visits.49

ACEI = ACE inhibitor; AF = atrial fibrillation; ARB = angiotensin II receptor blocker; BB = beta-blocker; CAD = coronary artery disease; COPD = chronic obstructive pulmonary disease; DM = diabetes mellitus; EF = ejection fraction; HF = heart failure; IHD = ischemic heart disease; LVEF = left ventricular ejection fraction; m = months; Med = medium; MI = myocardial infarction; N = number (group size); NR = not reported; NYHA = New York Heart Association functional classification; QoL = quality of life; UK = United Kingdom; Unc. = unclear; US = United States; y = years.

Table 5 Characteristics of trials assessing structured telephone support

Author, Year, Setting | Intervention Category (N), Comparator (N) | Timing (m)^a^ | Baseline NYHA Class; Mean EF | Age (y) | Female (%) | Non-White (%) | Taking BB or ACEI at Discharge (%) | Co-occurring Condition(s) (%) | Risk of Bias
Rainville et al., 1999 71 US; single institution | STS (17), Usual care (17) | 6 | NYHA III or IV: 85% | 70 | 50 | NR | ACEI or ARB: 88 BB: 44 | NR | Med
Barth et al., 2001^62^ US; single institution | STS (17), Usual care (17) | 2 | NR | 75 | 53 | NR | NR | DM: 33 Any other cardiac disease: 68 | High
Jerant et al., 2001^70^ Jerant et al., 2003^76^ US; single institution | STS (12) , Usual care (12), Telemonitoring (13) | 6 | NYHA III or IV: 35% | 70 | 54 | 51 | ACEI or ARB: 68 BB: 38 | IHD: 27 | High
Riegel et al., 2002^63^ US; multicenter | STS (130), Usual care (228) | 3, 6 | NYHA III or IV: 97% EF: 43% | 72 | 51 | NR | ACEI or ARB: 54 BB: 17 | DM: 42 CAD: 65 AF: 24 COPD: 36 | Med
Laramee et al., 2003^65^ US; single institution | STS (141), Usual care (146) | 2 | NYHA III or IV: 35% | 70 | 46 | NR | ACEI or ARB: 82 BB: 63 | DM: 43 Prior MI: 42 IHD: 71 | Med
Tsuyuki et al., 2004^72^ Canada; multicenter | STS (140), Usual care (136) | 6 | NYHA III or IV: 37%: EF: 31.5% | 72 | 20 | NR | ACEI or ARB: 85 BB: 43 | NR | Med
Dunagan et al., 2005^68^ US: single institution | STS (76), Usual care (75) | 6 | NYHA III or IV: 80% EF <40%: 58% | 70 | 56 | 56 | ACEI or ARB: 71 BB: NR | NR | Med
Cabezas et al., 2006^73^ Spain; multicenter | STS (70), Usual care (64) | 2, 6 | NYHA III or IV: 10% EF: 51% | 75 | 56 | NR | ACEI or ARB: 72 BB: 7 | DM: 34 MI: 20 | Med
Riegel et al., 2006^64^ US; multicenter | STS (69), Usual care (65) | 1, 3, 6 | NYHA III or IV: 81% EF <40%; 55% | 72 | 54 | 100 | ACEI or ARB: 75 BB: 54 | DM: 59 IHD: 44 MI: 28 AF: 17 | Med
Wakefield et al., 2008^69^ Wakefield et al., 2009^75^ US; single center (VAMC) | STS (47), Videophone (52), Usual care (49) | 6 | NYHA class III or IV: 72% EF: 41% | 69 | 1 | 6 | NR | NR | Med
Duffy et al., 2010^74^ US; multicenter | STS (15), Usual care (17)^b^ | 6 | NR | 81 | 59 | 35 b | NR | NR | High
Domingues et al., 2011^67^ Brazil; single institution | STS (48), Usual care (63) | 3 | LVEF: 29% | 63 | 32 | 19 | NR | NR | Med
Angermann et al., 2012^66^ Germany; multicenter | STS (352), Usual care (363) | 6 | NYHA III or IV: 40% EF: 30% | 69 | 29 | NR | ACEI or ARB: 88 BB: 80 | DM: 36 CAD: 58 AF: 29 COPD: 19 | Med

a Both groups in Duffy et al.74 also received home health care co-intervention that included nursing home visits.

b Duffy et al.74 reported in text that >35 percent of participants were minorities but did not provide exact numbers.

ACEI = ACE inhibitor; AF = atrial fibrillation; ARB = angiotensin II receptor blocker; BB = beta-blockers; CAD = coronary artery disease; COPD = chronic obstructive pulmonary disease; DM = diabetes mellitus; EF = ejection fraction; HF = heart failure; IHD = ischemic heart disease; LVEF = left ventricular ejection fraction; m = months; MI = myocardial infarction; N = number (group size); NR = not reported; NYHA = New York Heart Association functional classification; STS = structured telephone support; US = United States; VAMC = Veterans Affairs Medical Center; Y = years

Table 6 Characteristics of trials assessing telemonitoring

Author, Year, Setting | Intervention Category(N), Comparator (N) | Timing (m)^a^ | Baseline NYHA Class; Mean EF | Age (y) | % Female | Non-White (%) | Taking BB or ACEI at Discharge (%) | Co-occurring Condition(s) (%) | Risk of Bias
Jerant et al., 2001^70^ Jerant et al., 2003^76^ US; single institution | Telemonitoring (13), Usual care (12), STS (12) | 6 | NYHA III or IV: 35% | 70 | 54 | 51 | ACEI or ARB: 68 BB: 38 | IHD: 27 | High
Benatar et al., 2003^61^ US; multicenter | Telemonitoring (108), Home-visiting program (108) | 6 | NYHA mean class: 3.1 EF: 38% | 63 | 63 | 93 | ACEI or ARB: 76 BB: 53 | DM: 23 CAD or other cardiac disorders: 61 | Unc
Goldberg et al., 2003^79^ US; multicenter | Telemonitoring (138), Usual care (142) | 6 | NYHA III-IV: 100% | 59 | 32 | 36 | ACEI: 74 ARB: 16 BB: 38 | DM: 41 MI: 39 AF: 35 | Med
Schwarz et al., 2008^78^ US; single institution | Telemonitoring (51), Usual care (51) | 3 | NYHA class III or IV: 79% | 78 | 52 | 19 | NR | DM: 50 MI: 51 AF: 30 COPD: 29 | Med
Woodend et al., 2008^81^ Canada; single institution | Telemonitoring (62), Usual care (59) | 3 | NYHA III or IV: 62% | 67 | 28 | NR | NR | Prior MI: 57 | High
Dar et al., 2009^80^ UK; multicenter | Telemonitoring (91), Usual care (91) | 6 | EF ≥40%: 39%^b^ | 72 | 34 | 20 (South Asian) | ACEI or ARB: 88 BB: 56 | DM: 36 CAD: 55 Prior MI: 48 COPD: 91 | Med
Dendale et al., 2012^77^ Belgium; multicenter | Telemonitoring (80), Usual care (80) | 6 | NYHA mean class: 3.0 LVEF: 35% | 76 | 35 | NR | NR | NR | Unc
Pekmezaris et al., 2012^82^ US; multicenter | Telemonitoring (83), Usual care (85)^c^ | 1, 3 | NR | 82 | 62 | 9 | NR | NR | Med

a Timing of readmission outcome.

b EF data reported in Dar et al. are based on data from 168 patients (92 percent of total sample).80

c In Pekmezaris et al., both groups received home health care, including nursing home visits.82

ACEI = ACE inhibitor; AF = atrial fibrillation; ARB = angiotensin II receptor blocker; BB = beta-blocker; CAD = coronary artery disease; COPD = chronic obstructive pulmonary disease; DM = diabetes mellitus; EF = ejection fraction; HF = heart failure; IHD = ischemic heart disease; LVEF = left ventricular ejection fraction; m = months; Med. = medium; MI = myocardial infarction; N = group size; NR = not reported; NYHA = New York Heart Association functional classification; UK = United Kingdom; Unc = unclear; US = United States; Y = years

Table 7 Characteristics of trials assessing outpatient clinic-based interventions

Author, Year, Setting | Intervention Category (N), Comparator (N) | Timing (m)^a^ | Baseline NYHA Class; Mean EF | Age (y) | Female (%) | Non-White (%) | Taking BB or ACEI at Discharge (%) | Co-occurring Condition(s) (%) | Risk of Bias
Ekman et al., 1998^83^ Sweden; single institution | Nurse-led clinic (79), Usual care (79) | 6 | NYHA mean class: 3.2 EF: 41%^c^ | 80 | 42 | NR | ACEI or ARB: 37 BB: 30 | DM: 28 AF: 41 Prior MI: 45 | Med
Oddone et al., 1999^91^ US; multicenter | Primary care clinic (222), Usual care (221) | 6 | NYHA III or IV: 53% | 65 | 1 | 34 | ACEI or ARB: 74 BB: 12 | NR | Med
McDonald et al., 2001^84^ McDonald et al., 2002^85^ Ledwidge et al., 2003^86^ Ireland; single institution | At 3 months^b^: MDS-HF clinic (51), Usual care (47) At 30 days: MDS-HF clinic (35), Usual care (35) | 1, 3^b^ | EF<45%: 63%^b^ | 71^b^ | 34^b^ | NR | ACEI or ARB: 61^b^ BB: NR | NR | Unc
Kasper et al., 2002^87^ US; multicenter | MDS-HF clinic (102), Usual care (98) | 6 | NYHA III: 59% (no patients with class IV) EF <45%: 88% | 64 | 40 | 35 | ACEI or ARB: 86 BB: 39 | DM: 40 | Low
Stromberg et al., 2003^88^ Sweden; multicenter | Nurse-led clinic (52), Usual care (54) | 3 | NYHA III or IV: 82% | 78 | 39 | NR | ACEI or ARB: 82 BB: 58 | DM: 24 IHD: 68 | Low
Ducharme et al., 2005^89^ Canada; single institution | MDS-HF clinic (115), Usual care (115) | 6 | NYHA III or IV: 91% EF: 35% | 69 | 28 | NR | ACEI or ARB: 80 BB: 43 | DM: 30 CAD: 66 Prior MI: 50 | Low
Liu et al., 2012^90^ Taiwan; single institution | MDS-HF clinic (53), Usual care (53) | 6 | NYHA III or IV: 62% EF: 28% | 61 | 35 | 100 | ACEI or ARB: 40 BB: 65 | DM: 46 | Low

a Timing of readmission outcome.

b Data come from the McDonald et al., 2002, publication;85 the percentages from companion studies differ slightly.84,86

c EF values reported in Ekman et al. are based on data from 99 patients (63 percent of total sample).83

ACEI = ACE inhibitor; AF = atrial fibrillation; ARB = angiotensin II receptor blocker; BB = beta-blocker; CAD = coronary artery disease; DM = diabetes mellitus; EF = ejection fraction; HF = heart failure; IHD = ischemic heart disease; m = months; MDS-HF = multidisciplinary heart failure clinic; Med. = medium; MI = myocardial infarction; N = group size; NR = not reported; NYHA = New York Heart Association functional classification; Unc. = unclear; US = United States; Y = years

Table 8 Characteristics of trials assessing primarily educational interventions

Author, Year, Setting | Intervention Category(N), Comparator (N) | Timing (m)^a^ | Baseline NYHA Class; Mean EF | Age (y) | Female (%) | Non-White (%) | Taking BB or ACEI at Discharge (%) | Co-occurring Condition(s) (%) | Risk of Bias
Koelling et al., 2005^95^ US; single institution | Primarily educational (107), Usual care (116) | 6 | EF: 27% | 65 | 42 | 22 | ACEI or alternative: 61 BB: 55 | CAD: 64 | Low
Linne et al., 2006^94^ Sweden; multicenter | Primarily educational (122), Usual care (108) | 6 | EF < 40%: 100% | 70 | 29 | NR | ACEI or ARB: 80 BB: 49 | NR | Unc
Nucifora et al., 2006^93^ Italy; single institution | Primarily educational (99), Usual care (101) | 6 | NYHA III or IV: 65% | 73 | 38 | NR | ACEI or ARB: 80 BB: 13 | DM: 26 IHD: 46 COPD: 27 | Med
Albert et al., 2007^92^ US; single institution | Primarily educational (37), Usual care (39) | 3 | EF <40%: 100% | 60 | 23 | 17 | ACEI or ARB: 88 BB: 56 | DM: 33 CAD: 66 MI: 45 AF: 37 | High

a Timing of readmission outcome.

ACEI = ACE inhibitor; AF = atrial fibrillation; ARB = angiotensin II receptor blocker; BB = beta-blocker; CAD = coronary artery disease; COPD = chronic obstructive pulmonary disease; DM = diabetes mellitus; EF = ejection fraction; HF = heart failure; IHD = ischemic heart disease; LVEF = left ventricular ejection fraction; m = months; Med. = medium; MI = myocardial infarction; N = group size; NR = not reported; NYHA = New York Heart Association functional classification; Unc = unclear; US = United States; VAMC = Veterans Affairs Medical Center; Y = years

Table 9 Characteristics of trials assessing other interventions

Author, Year, Setting | Intervention Category(N), Comparator (N) | Timing (m)^a^ | Baseline NYHA Class; Mean EF | Age (y) | Female (%) | Non-White (%) | Taking BB or ACEI at Discharge (%) | Co-occurring Condition(s) (%) | Risk of Bias
Riegel et al., 2004^96^ US; multicenter | Peer support (45), Usual care (43) | 1, 3 | NYHA III or IV: 64% EF: 45% | 73 | 58 | NR | NR | DM: 46 History of MI: 35 COPD: 25 | High
Davis et al., 2012^97^ US; single institution | Self-care teaching and cognitive training (63), Usual care (62) | 1 | NYHA III or IV: 53% EF: 34% | 59 | 53 | 69 | NR | DM: 39 AF: 26 COPD: 22 MCI: 100 | Med.

a Timing of readmission outcome.

ACEI = ACE inhibitor; AF = atrial fibrillation; ARB = angiotensin II receptor blocker; BB = beta-blocker; COPD = chronic obstructive pulmonary disease; DM = diabetes mellitus; EF = ejection fraction; HF = heart failure; m = months; MCI = mild cognitive impairment; Med. = medium; MI = myocardial infarction; N = group size; NR = not reported; NYHA = New York Heart Association functional classification; US = United States; Y = years

## Literature Search and Screening

Searches of all sources identified a total of 2,419 potentially relevant citations. We included 47 studies described in 53 publications. Figure 2 describes the flow of literature through the screening process according to PRISMA (Preferred Reporting Items for Systematic Reviews and Meta-Analyses) categories.46 Appendix B provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion. Only randomized controlled trials (RCTs) met the inclusion/exclusion criteria specified in Table 1 (Methods).

Figure 2 Disposition of articles about transitional care interventions for patients hospitalized for heart failure

Figure 2 is titled “Disposition of Articles.” The figure is a flow chart that summarizes the search and selection of articles. The figure displays a flowchart describing how potentially eligible records were screened and selected for inclusion in the review. A total of 2,419 records were identified from database searching and handsearches of reference lists: database searches yielded 402 records after removing duplicates, including 1,670 from MEDLINE, 135 from CINAHL, and 475 from the Cochrane Library, and handsearches yielded 139 records. Of the 2,419 records retrieved for initial screening, 2,017 did not meet eligibility criteria and were excluded after review of their titles and abstracts. Full-text articles were retrieved for the remaining 402 records and further assessed for eligibility. Of these, 349 were excluded for the following reasons: 41 for ineligible publication type, 62 for ineligible study design, 145 for ineligible populations, 30 for ineligible or no interventions, 4 for ineligible comparators, 33 for ineligible outcomes, and 34 for ineligible timing. Following full-text review, 53 articles representing 47 studies were considered eligible for the qualitative synthesis of the review, while 45 were included in the quantitative synthesis.

## Characteristics of Included Studies

We grouped trials of similar interventions based primarily on the mode and environment of delivery as described in Methods (Table 2). These included only RCTs: home-visiting programs (15 RCTs), structured telephone support (STS, 13 trials), telemonitoring (8 trials), outpatient clinic-based interventions (7 trials), and primarily educational interventions (4 trials). We also included two unique interventions in an “other” category; one featured individual peer support and one emphasized cognitive training for patients with coexisting mild cognitive impairment.

Most trials compared a transitional care intervention with usual care; only two directly compared more than one transitional care intervention. Usual care was somewhat heterogeneous across trials and often was not well described. In all tables, the timing for outcome measurement(s)—readmissions, deaths, or other outcomes—reflects a period of 6 months or less (i.e., meeting our inclusion criteria noted in Table 1 in Methods). Below we describe the characteristics of included trials by intervention category.

### Home-Visiting Programs

#### Characteristics of Trials

Fourteen RCTs compared a home-visiting program with usual care,47-60 and one trial comparing a home-visiting program with telemonitoring (Table 4).61 Sample sizes ranged from 58 to 339. Only one trial reported a readmission rate at 30 days.47

We rated all but five trials as medium or low risk of bias. We rated three trials as high risk of bias and two as unclear risk of bias;48,49,52,61 the primary problems were high risk of selection bias, measurement bias (readmission rates), and inadequate handling of missing data.

##### Population

The mean age of participants was similar across trials, ranging from 63 to 80 years. All trials enrolled both women and men; the percentage of women ranged from 28 to 72. The percentage of nonwhite participants ranged from 0 percent to 93 percent in the six trials that described patient race or ethnicity;48,52,55,57,58,61 one trial did not comment on race but was conducted among Hong Kong residents.54

Seven trials reported the percentage of patients who had moderate or severe heart failure (HF) (New York Heart Association [NYHA] class III or IV); 40 percent to 67 percent of patients had moderate or severe HF.47,50-53,59,60 Four trials reported the mean NYHA classification for patients: 2.8,^58^ 3.0,^48,61^ and 2.4^57^ (scores range from 1 to 4). One trial did not describe the HF severity among patients.49

Two trials commented on the percentage of patients with a reduced ejection fraction (EF): 57 percent of patients had an EF less than 35 percent in one trial,55 and 24 percent of patients had an EF less than 40 percent in another.54 One trial gave the mean EF for the population (50 percent) but no information on NYHA classifications or the percentage of patients with a reduced EF.56

Five trials did not describe the percentage of patients receiving a beta-blocker at discharge,47,51,52,55,58 12 percent to 62 percent of patients in other trials were prescribed a beta-blocker at discharge. Three of these trials did not report on the percentage of patients taking an angiotensin-converting-enzyme inhibitor (ACEI) or angiotensin receptor blocker (ARB) medication at discharge52,55,58; 47 percent to 92 percent of patients in other trials were on an ACEI or ARB at discharge.

In nine trials, 30 percent to 78 percent of patients had ischemic heart disease or coronary artery disease.51-57,60,61 In all other trials, 20 percent to 48 percent of patients had diabetes.

##### Interventions

Most trials delivered a series of home visits immediately following discharge. Five trials involved one comprehensive home visit following an index hospitalization;47,50,51,53,60 of these five trials, two specified that additional home visits would be provided if a person experienced more than two unplanned hospitalizations within 6 months.50,51 In most trials, nurses conducted the home visits; one trial evaluated home visits led by pharmacists;59 and one evaluated whether additional home visits by a pharmacist among patients already receiving home-nursing visits was associated with improved outcomes.49 In one trial, a physician accompanied the nurse on the first home visit.56 Most home visits began within 7 days of discharge; three trials included visits within 24 to 48 hours of discharge;55,57,58 and three trials specified that visits occurred within 14 days of discharge.48,52,59

All trials included education or training (or both) focused on self-care, diet, HF medications, and early recognition of symptoms. About half the trials delivered educational components both before discharge and during home visits. Two trials included planned, structured telephone calls in addition to home visits.47,52 Most interventions offered a “patient hotline” for questions or advice throughout the intervention.

In one trial, usual care referred to usual “home health” that included nursing home visits in both groups.49 Among other trials, descriptions of usual care tended to include “normal discharge planning,” “followup as usual,” or “care directed by inpatient team” with little other description provided.

##### Setting

One trial was conducted in Hong Kong,54 two in the United Kingdom,59,60 one in the Netherlands,47 one in Spain,56 and two by the same group of investigators in Australia.50,51 The remaining trials were conducted in the United States. Eight trials were multicenter; seven were single center.47,48,50,51,56-58

### Structured Telephone Support

#### Characteristics of Trials

Thirteen RCTs described in 15 publications compared STS with usual care (Table 5).62-74 One three-arm trial compared two modes of delivering STS (standard telephone versus videophone) with usual care.69,75 Trial sample size ranged from 32 to 715. Only one trial reported a readmission rate at 30 days.64

We rated all but three trials as medium risk of bias. We rated three trials as high risk of bias primarily for high risk of selection bias and measurement bias.

##### Population

The mean age of patients ranged from 63 to 81. One trial, conducted at a Veterans Affairs Medical Center (VAMC), enrolled primarily males (99 percent);69 all other trials included 20 percent to 59 percent women. One trial was conducted in a completely Hispanic population.64 Seven trials did not report the race or ethnicity of participants;62,63,65,66,71-73 all other trials enrolled 6 percent to 56 percent nonwhite participants.

Most trials included a majority of patients with moderate to severe HF; five trials included a minority of patients with moderate to severe HF.65,66,70,72,73 Two trials did not report HF disease severity.62,74 Four trials did not report the percentage of patients receiving HF pharmacotherapy (ACEI or ARB; beta-blocker) at discharge.62,67,69,74,75 All other trials included 54 percent to 86 percent of patients who were prescribed an ACEI or ARB and 7 percent to 63 percent of patients who were prescribed a beta-blocker. Most trials included patients with coexisting coronary artery disease or ischemic heart disease (20 percent to 79 percent); four trials did not describe the prevalence of coexisting heart disease among included patients.62,70,71,74 Approximately half of the trials reported information on coexisting diabetes; the prevalence of coexisting diabetes ranged from 32 percent to 59 percent.62-66,73

##### Interventions and Comparators

All trials involved a series of scheduled, structured telephone calls to patients following discharge. Most trials averaged one or two calls during the intervention period. In most trials, the first telephone contact was within 7 days of discharge; in one, the first call occurred at 2 weeks after discharge;72 and two trials did not describe the timing of the first call.70,74 Most calls were delivered by nurses; two trials focused on STS delivered by a pharmacist.71,73

All trials included patient education. In most trials, education or self-care training began as an inpatient and was reinforced after discharge during telephone followup, but five trials did not include an educational component before discharge.53,62-64,68,74 Most trials included a patient-initiated hotline for questions or additional support.62,65,66,68,69,71,73

The types of other components delivered (in addition to STS) varied across trials. One intervention involved nurse case management at the time of discharge; care coordination with primary care and individualized discharge planning was part of the intervention (e.g., obtaining needed services for patients such as physical therapy, and facilitating communication in the hospital among the family and providers).65 Two trials included an inpatient intervention that focused on optimizing evidence-based HF pharmacotherapy before discharge.71,72 Six trials included coordination between intervention personnel and the patient's outpatient care providers during the course of telephone support.62-66,69

Usual care was described as planned outpatient followup in four trials.65-67,69,75 One other trial was conducted among patients receiving home health following discharge: “usual care” included in-home nursing visits administered by the home-health agency without additional details.74

##### Setting

Most trials were conducted in the United States: three in multicenter settings63,64,74 and all others at a single center. Three trials were conducted in multicenter settings in Europe and Canada;66,72,73 one trial was conducted at a single center in Brazil.67

### Telemonitoring

#### Characteristics of Trials

Eight RCTs described in nine publications (Table 6) dealt with telemonitoring. Seven RCTs compared remote monitoring of clinical data (e.g., weight, vital signs) with usual care;70,76-82 one compared remote monitoring of clinical data with home nurse visits.61 Sample sizes ranged from 37 to 280 patients. Only one trial reported a readmission rate at 30 days.82

We rated four trials as medium risk of bias. We rated two trials as high risk of bias and two others as unclear risk of bias; the primary problems were inadequate handling of missing data and unclear fidelity to the protocol.

##### Population

The mean age of patients ranged from 59 to 82 years. Half of the trials enrolled fewer women than men (range, 28 percent to 35 percent women);77,79-81 the remainder included 52 percent to 63 percent women.61,70,76,78,82 One trial was conducted primarily in nonwhite patients (86 percent African American, 6 percent Hispanic, 1 percent Asian);61 the other trials included 9 percent to 51 percent nonwhite patients70,76,78-80,82 or did not report information on race.77,81

Most trials enrolled a majority of patients with moderate to severe HF based on NYHA classification (class III or IV). In one trial, a majority of patients had less severe HF (65 percent with NYHA class II HF);70,76 two trials did not report baseline disease severity based on NYHA classification.80,82

Four trials described the percentage of patients on an ACEI or ARB at discharge (68 percent to 88 percent of patients) and the percentage of patients on a beta-blocker at discharge (38 percent to 56 percent of patients).61,70,79,80 Three trials did not report information on pharmacotherapy at discharge,77,81,82 and one trial reported the mean number of “heart medications” at discharge (5.5 medications) without defining which medications were counted.78

The proportion of patients with coronary artery disease or prior myocardial infarction (MI) ranged from 27 percent to 61 percent in most trials.61,70,76,78-81 The proportion of patients with diabetes ranged from 23 percent to 50 percent in four RCTs.61,78-80

##### Interventions and Comparators: Remote Monitoring of Clinical Data

Five RCTs evaluated remote clinical data monitoring using equipment installed in patients' homes that transmitted clinical data to a central site.61,77-80 Remote monitoring equipment was generally either sent home with a patient from the hospital or delivered within 1 to 3 weeks of discharge. In four of these RCTs, nurses or physicians (or both) contacted patients when weights or vital signs were outside protocol-defined parameters.61,78-80 In three RCTs, patients also answered questions about symptoms (e.g., shortness of breath, edema) through the remote monitoring system.78-80 In one RCT, alerts about abnormal clinical data were sent directly to the primary care clinician and HF clinic.77

Four RCTs compared remote monitoring of clinical data with usual care.77-80 Usual care was defined as standard care from primary care clinicians or cardiologists (or both) in three trials;77-79 in one trial, usual care included an initial home visit to deliver education about HF self-monitoring, telephone support, and care from a specialized HF clinician.80 One trial randomized patients to either home nursing visits or nurse remote monitoring.61

##### Interventions and Comparators: Remote Monitoring With Video Clinical Visits

Three trials used specialized equipment to allow for video assessments and interactions with patients.70,76,81,82 The equipment could also check clinical data such as blood pressure or included stethoscopes to allow remote heart and lung auscultation. The specialized equipment was generally delivered to patients' homes within 48 hours to 7 days of discharge from the hospital.

In one trial, the intervention group was instructed to monitor weight and blood pressure daily; this information was then transmitted to a central site and monitored by a nurse who also completed video conferences with the patients. Outcomes for this group were compared with those for usual care.81 Another RCT had three arms and compared (1) video nursing visits including video interaction and a remote stethoscope with (2) telephone nursing visits and with (3) usual care; both intervention groups also had access to a nurse hotline for questions or concerns.70,76 In both of these trials, usual care was defined as directed by a primary care physician or cardiologist. In one usual-care group, patients also had a telephone number with which to reach an advanced practice nurse with questions about their care;81 patients in the other usual-care group received two nurse home visits (after discharge and at 60 days), during which standard education and clinical assessment were conducted.70,76

One trial evaluated adding video nursing visits to home nursing visits through a home health care agency; the comparison was usual home nursing visits without additional video visits.82 The equipment in this trial allowed for blood pressure checks and stethoscope examination during the video visits.82 In both groups, a nurse determined the frequency of home visits; in addition, all nurses followed standardized disease management guidelines to manage patients.

##### Interventions and Comparators: Educational Components

All trials included an educational component; most delivered education after discharge. One trial delivered education before discharge about general self-care, weight monitoring, and low-sodium diets.79 In five trials, nurses delivered general HF self-care education after discharge by telephone, video, or in person.70,76,77,80 ,81,82 Educational content included weight monitoring in four trials,70,76-79 low-sodium diets in five trials,61,70,76,77,79,82 medication education and adherence promotion in four trials,61,70,76,77,82 and exercise promotion in one trial.77

##### Setting

Five trials were conducted in the United States; two were at a single center,70,76,78 and the remainder were multicenter.61,79,82 Three trials were conducted outside the United States: one at a single institution in Canada,81 one in a multicenter setting in Belgium,77 and one in a multicenter setting in the United Kingdom.80

### Clinic-Based Interventions

#### Characteristics of Trials

Seven RCTs described in nine publications (Table 7) tested interventions in three main types of outpatient clinics. Six trials compared interventions in HF specialty clinics;83-90 four were in multidisciplinary (MDS) clinics (denoted MDS-HF) and two were in nurse-led clinics. A single trial compared enhanced access (increased access) to primary care with usual care.91 Sample sizes ranged from 98 to 443. One trial reported a readmission rate at 30 days.84

Of these seven trials, we rated six as low or medium risk of bias; we rated one trial as unclear, primarily because the investigators did not describe the validity of their measures of health care use well.

##### Population

The mean age of patients ranged from 61 to 80 years. The percentage of female patients ranged from 39 percent to 42 percent in most trials; one trial focused on increased primary care access for HF patients was conducted in a VAMC setting (1 percent were women). Four trials did not include information on race or ethnicity. One trial was conducted only among Taiwanese patients;90 the percentage of nonwhite subjects in two U.S. trials was approximately 34 percent.87,91 Most trials enrolled a majority of subjects with moderate to severe HF based on NYHA classification. The percentage of patients on pharmacotherapy at discharge ranged from 37 percent to 86 percent for an ACEI or ARB and 12 percent to 65 percent for beta-blockers. Most trials included populations with a variety of coexisting chronic conditions: 24 percent to 46 percent of patients had diabetes, and 46 percent to 71 percent of patients had a prior history of MI. Two trials reported no information on coexisting diabetes, cardiac disease, or respiratory disorders.84-86,91

##### Interventions and Comparators

All trials involved a series of scheduled outpatient clinic visits following discharge, regular structured telephone calls to patients beginning within 7 days after the hospital discharge or enrollment, and individualized care planning. These interventions did not include regularly scheduled home visits as a primary component; none included telemonitoring. All trials provided a brief description of usual care that included “management in accordance with current clinical practice” or stated that patients received conventional followup in primary health care.

Among the six trials evaluating HF clinic interventions, four were described as MDS-HF clinic interventions;84-87,89,90 they involved more emphasis on physician contact and access to a multidisciplinary care team (cardiology, nurses, dieticians, pharmacists) than nurse-led clinics. The two trials described as nurse-led focused more on patient education delivered by nurses during scheduled clinic appointments than on multidisciplinary management.83,88

In general, most trials included an educational component. Two trials included education on self-care delivered before discharge and education reinforcement during telephone followup.85,91

One trial focused on enhanced access to primary care.91 Three services coordinated care with a patient's primary care physician by scheduling appointments for acute needs or alerting physicians to changes in symptoms.83,85,90

##### Setting

Three trials were conducted in North America,87,89,91 three in Europe,83-86,88 and one in Asia.90 Four trials were at a single center83,84,89,90 and three were conducted in a multicenter setting.87,88,91

### Primarily Educational Interventions

#### Characteristics of Trials

Four RCTs compared primarily educational interventions with usual care (Table 8).92-95 Sample sizes ranged from 76 to 230. No trial reported a 30-day readmission rate. We rated one trial as low risk of bias and one as medium risk of bias. We rated one trial as high risk of bias and one as unclear risk of bias, primarily because of potential for measurement bias and inadequate handling of missing data, respectively.

##### Population

Mean age ranged from 60 to 73 years. Trials included 23 percent to 42 percent women. Two trials described the race or ethnicity of patients (17 percent and 22 percent nonwhite).92,95 Three trials included patients with an EF of <40 percent,92,94,95 and one trial included a majority of patients with moderate to severe HF.93 The majority of patients were on an ACEI or ARB at discharge (60 percent to 88 percent). Approximately half of patients in three trials were on a beta-blocker at discharge.92,94,95

One trial did not describe the prevalence of coexisting conditions among patients.94 Two trials reported prevalence rates of diabetes of 26 percent and 33 percent.92,93 Three trials included populations among whom 46 percent to 66 percent of patients had coronary artery disease.92,93,95

##### Interventions and Comparator

All trials involved primarily educational interventions aimed at preventing HF readmission; however, they differed in the mode of delivery and timing of education in relationship to the index HF hospitalization. One trial compared the effects of a 1-hour in-person patient education program with usual discharge care; no other components were delivered after discharge.95 Another trial featured intensive education about HF symptoms and treatment administered by a nurse ahead of discharge. In addition, one telephone call was conducted 3 to 5 days after discharge with the goal of reinforcing education, a nurse hotline was available for questions, and education was reinforced at scheduled outpatient visits (15 days, 1 and 6 months).93

Two trials investigated the effects of HF education delivered via technology.92,94 One study included education before discharge focused on HF symptoms and treatment that was delivered via CD; the same educational CD was repeated 2 weeks after discharge (patients returned to the hospital to view the CD).94 Another study evaluated the effects of a 60-minute, six-chapter video on HF that was intended to be viewed at home.92

##### Setting

Two single-center trials were conducted in the United States92,95 and one in Italy.93 One multicenter study was conducted in Sweden.94

### Other Interventions

#### Characteristics of Trials

Two RCTs evaluated unique interventions that did not fit into any other category (Table 9). One used peer support for patients with HF following discharge,96 and the other examined the effect of cognitive training on patients with HF and coexisting cognitive dysfunction.97 Sample sizes were 88 and 125, respectively. Both trials reported a 30-day readmission rate. We rated one trial as medium risk of bias and the other as high risk of bias, primarily because of a high risk of selection bias and inadequate handling of missing data.

##### Population

Mean age was 73 years (peer support) and 59 years (cognitive training). Approximately one-half the patients in both trials were women. Only the trial assessing cognitive training described patient race or ethnicity (69 percent nonwhite).97 Both trials enrolled a majority of patients with moderate to severe HF. Neither study reported on the percentage of patients taking an ACEI or beta-blocker at discharge. Patients with coexisting diabetes made up 46 percent or 39 percent of the study populations. The trial assessing cognitive training screened patients for inclusion with the Montreal Cognitive Assessment;98 patients were included if they had a score suggesting mild cognitive impairment (score between 17 and 25 out of 30; scores less than 17 suggest dementia).

##### Interventions and Comparators

One trial focused on peer monitoring as a means of social support and mentoring on self-care management for patients with HF.96 The investigators recruited nine patients with HF and trained them as mentors; mentors were described as elderly men and women with mild to moderate HF. Patients randomized to peer support chose the gender and geographic location of their mentor. Contact began during the index hospitalization (in person) or immediately after discharge via telephone contact. Mentoring occurred during home visits, telephone calls, and joint outings; weekly contact was encouraged for the 30 days following discharge and then at least monthly for 3 months. Usual care was described as inpatient education on HF.

The other trial focused on dealing with impairments in memory and executive function through environmental manipulations and training strategies and on improving self-confidence related to the ability to handle self-care.97 Specifically, during the hospitalization, each patient was given a spiral workbook with pictograms and space to personalize a self-care schedule focused on their medication schedule and future appointments. Patients were provided with typical HF self-care problems and a case manager helped them to solve problems; an audiotape of the sessions was given to patients at discharge. One telephone call was conducted after discharge (24 to 72 hours) for a teach-back session.97 Usual care was described as “standard discharge teaching for HF, including verbal review of a HF patient education booklet.”

##### Setting

Both trials occurred in the United States. The study assessing peer support was conducted in a multicenter setting,96 and the trial assessing cognitive training was conducted at a single center.97

## KQ 1 Transitional Care Interventions and Health Care Utilization Outcomes

### Key Points: All-Cause Readmissions

- A high-intensity home-visiting program (e.g., first visit within 24 hours and multiple planned home visits) reduced all-cause readmission at 30 days (low SOE). A lower-intensity home-visiting program did not reduce all-cause readmission at 30 days (low SOE).
- Home-visiting programs and MDS-HF clinic interventions reduced all-cause readmission over 3 to 6 months (high SOE for both).
- The following intervention categories did not reduce all-cause readmission over 3 to 6 months: STS (moderate SOE), telemonitoring (moderate SOE), and nurse-led clinic interventions (low SOE).
- Evidence was insufficient to determine the efficacy of the following intervention categories at any time point: the primary care clinic intervention, primarily educational interventions, and cognitive training.

### Key Points: Heart Failure–Specific Readmissions

- Two intervention categories reduced HF-specific readmission over 3 to 6 months: Home-visiting programs (moderate SOE) and STS (high SOE).
- Telemonitoring interventions did not reduce HF-specific readmission over 3 to 6 months (moderate SOE).
- Evidence was insufficient to determine the efficacy of the following interventions in reducing HF-specific readmission either at 30 or at any time point: MDS-HF clinic interventions, nurse-led clinic interventions, and primarily educational interventions.

### Key Points: Composite All-Cause Readmission or Death

- Home-visiting programs reduced the composite outcome (all-cause readmission or death) at 30 days (low SOE) and over 3 to 6 months (moderate SOE).
- The following intervention categories did not reduce the composite outcome: STS (low SOE), MDS-HF (moderate SOE), and primarily educational interventions (low SOE).
- Evidence was insufficient to determine the efficacy of nurse-led clinic interventions in reducing the composite outcome.

### Key Points: Emergency Room Visits, Acute Care Visits, Hospital Days

- Few trials reported rates of emergency room (ER) or acute care visits.
- STS interventions did not increase or decrease ER visits over 3 to 6 months (low SOE).
- Evidence was insufficient to determine whether other intervention categories increased or decreased ER or acute care visits at any time point.
- The following interventions showed efficacy in reducing the number of hospital days of subsequent readmissions over 3 to 6 months: home-visiting programs (low SOE) and STS (moderate SOE).

### Key Points: Comparative Effectiveness

- Direct evidence was insufficient to determine whether one type of transitional care intervention was more or less efficacious than any other type of intervention for any health care utilization outcome.

### Detailed Synthesis: Transitional Care Interventions Compared With Usual Care

#### All-Cause Readmissions: Transitional Care Interventions Compared With Usual Care

Figure 3 presents our meta-analysis and forest plot of trials reporting all-cause readmission (number of people readmitted) stratified by intervention category and outcome timing. We present detailed results by intervention category and outcome timing below.

Figure 3 All-cause readmission for transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and forest plot of individual trials

C_event = number of people readmitted in the control (usual care) group; N = sample size; T event = number of people readmitted in the intervention group.

Figure 3 is titled “All-cause readmission for transitional care interventions compared with usual care, by intervention category and outcome timing: meta-analysis and forest plot of individual Trials.” The figure displays forest plots of trials reporting all-cause readmissions for transitional care interventions versus usual care, by intervention category and outcome timing. The results shown in this figure are described further in “Detailed Synthesis: All-cause readmission: Transitional interventions compared with usual care.” Home-Visiting Programs: “At 30 days, our meta-analysis (two trials) found no difference in the risk of all-cause readmissions between the patients receiving home visits and those receiving usual care (RR, 0.54; 95% CI, 0.21 to 1.37). However, there was considerable statistical heterogeneity between these two trials (I2 =74.4%) and also important clinical differences in the intervention delivered.” “Over 3 to 6 months, our meta-analysis (nine trials) found that patients receiving home visits had a reduced risk of all-cause readmission (RR, 0.75; 95% CI, 0.66 to 0.86). Structured Telephone Support: “One trial (N= 134) reported all-cause readmission at 30 days; the readmission rate did not differ between patients receiving structured telephone support and those receiving usual care (RR, 0.80; 95% CI, 0.38 to 1.65). Over 3 to 6 months, our meta-analysis (eight trials) found no difference in the relative risk of all-cause readmission between patients receiving structured telephone support and those receiving usual care (RR, 0.92; 95% CI, 0.77 to 1.10). “ Telemonitoring: “One trial (N=168) reported all-cause readmission at 30 days; the risk of all-cause readmission among patients receiving telemonitoring and those receiving usual care did not differ (RR, 1.02; 95% CI, 0.64 to 1.63). Over 3 to 6 months, our meta-analysis (three trials) found no difference in the risk of readmission between patients receiving telemonitoring and those receiving usual care (RR, 1.11; 95% CI, 0.87 to 1.42).” Clinic-based Interventions: “Given heterogeneity in the interventions among the clinic-based interventions, we pooled data separately by clinic setting: multidisciplinary HF (MDS-HF) clinic, nurse-led HF clinic, and primary care clinic. Among the MDS-HF interventions, our meta-analysis (two trials) found that patients receiving the intervention had a lower risk of all-cause readmission compared with patients receiving usual care (RR 0.70; 95% CI, 0.55 to 0.89). Over three to six month, our meta-analysis (two trials) found that patients receiving a nurse-led clinic-based intervention and those receiving usual care had a similar risk of all-cause readmission (RR, 0.88; 95% CI, 0.57 to 1.37). One trial (N=443) found that patients with HF who had increased (or enhanced) access to primary care (through a Department of Veterans Affairs [VA] health care setting) following discharge had a higher risk of all-cause readmission than the control group (RR, 1.27; 95% CI, 1.05 to 1.54).” Primarily Educational Interventions: “One trial found no difference in the risk of all-cause readmission at 6 months between patients receiving intensive pre-discharge education and controls (RR, 1.14; 95% CI, 0.84 to 1.54).” Other Interventions: “One trial (N=125) of cognitive training among patients with HF and coexisting cognitive dysfunction found no difference in the risk of 30-day readmission between patients receiving the intervention and controls (RR 1.15; 95% CI, 0.84 to 1.54).”

##### Home-Visiting Programs

At 30 days, our meta-analysis (two trials) found no difference in the risk of all-cause readmission between the patients receiving home visits and those receiving usual care (RR, 0.54; 95% CI, 0.21 to 1.37).47,55 However, the statistical heterogeneity between these two trials was considerable (I^2^ =74.4 %), and they also had important clinical differences in the intervention delivered. Although both trials included comprehensive inpatient education and individualized discharge planning, the interventions differed in the timing of the first home visit and total number of planned home visits.

In the trial by Naylor et al., an advanced practice nurse visited patients at home within 24 hours of discharge, and a total of eight home visits were planned. In the trial by Jaarsma et al., patients were called within 7 days following discharge to schedule a home visit; most visits were scheduled within 10 days of discharge and no additional visits were planned. The trial by Naylor et al., which evaluated a more intensive intervention, found a lower risk of readmission for patients receiving home visits than for patients in the control group (RR, 0.34; 95% CI, 0.19 to 0.62).55 The trial by Jaarsma et al. found no difference in all-cause readmission between patients receiving the home visit and patients in the control group (RR, 0.89; 95% CI 0.43 to 1.85).47

Over 3 to 6 months, our meta-analysis (nine trials) found that patients receiving home visits had a significantly reduced risk of all-cause readmission (RR, 0.75; 95% CI, 0.66 to 0.86).47,51,54-60

Two trials reported the number of total readmissions per group (rather than people readmitted) at 6 months. In one trial (N=200), patients receiving home visits had significantly fewer unplanned readmissions (68) than those receiving usual care (118) (p=0.031).50 In another trial (N=200), all-cause readmissions did not differ between patients receiving home visits and those receiving usual care (measured as mean readmissions per patient-year alive: RR, 0.89; p=0.61).53

##### Structured Telephone Support

One trial (N= 134) reported all-cause readmission at 30 days; the readmission rate did not differ between patients receiving STS and those receiving usual care (RR, 0.80; 95% CI, 0.38 to 1.65).64

Over 3 to 6 months, our meta-analysis (eight trials) found no difference in the relative risk of all-cause readmission between patients receiving STS and those receiving usual care (RR, 0.92; 95% CI, 0.77 to 1.10).63-65,67,68,72,73

##### Telemonitoring

One trial (N=168) reported all-cause readmissions at 30 days; the risk of all-cause readmission among patients receiving telemonitoring and those receiving usual care did not differ (RR, 1.02; 95% CI, 0.64 to 1.63).82

Over 3 to 6 months, our meta-analysis (three trials) found no difference in the risk of readmission between patients receiving telemonitoring and those receiving usual care (RR, 1.11; 95% CI, 0.87 to 1.42).78,80,82

Four telemonitoring trials reported the total number of readmissions per group (rather than the number of people readmitted). All-cause readmissions did not differ between patients receiving telemonitoring and those receiving usual care at 30 days,76 3 months,81 or 6 months.76,77,79

##### Clinic-Based Interventions

Given the diversity in interventions among the clinic-based interventions, we pooled data separately by clinic setting: MDS-HF clinic, nurse-led HF clinic, and primary care clinic. Among the MDS-HF interventions, our meta-analysis (two trials) found that patients receiving the intervention had a significantly lower risk of all-cause readmission than patients receiving usual care (RR, 0.70; 95% CI, 0.55 to 0.89).

Over 3 to 6 months, our meta-analysis (two trials) found that patients receiving a nurse-led clinic intervention and those receiving usual care had a similar risk of all-cause readmission (RR, 0.88; 95% CI, 0.57 to 1.37).83,88

One trial (N=443) found that HF patients with better access to primary care following discharge through a VAMC setting had a significantly higher risk of all-cause readmission than patients in the control group (RR, 1.27; 95% CI, 1.05 to 1.54).91

##### Primarily Educational Interventions

One trial (N= 200) found no difference in the risk of all-cause readmission at 6 months between patients receiving intensive predischarge education and controls (RR 1.14; 95% CI, 0.84 to 1.54).93

##### Other Interventions

One trial (N=125) of cognitive training among patients with HF and coexisting cognitive dysfunction found no difference in the risk of 30-day readmission between patients receiving the intervention and controls (RR, 1.15; 95% CI, 0.58 to 2.28).97

#### Heart Failure-Specific Readmissions: Transitional Care Interventions Compared With Usual Care

Our meta-analysis of trials reporting HF-specific readmissions (number of people readmitted) is shown in Figure 4. We present detailed results by intervention category and outcome timing below.

Figure 4 HF-specific readmission for transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and forest plot of individual trials

N= sample size; Treatment (HF readmissions) = number of people in the intervention group who were readmitted; Usual care (HF readmissions) = number of people in the usual care group who were readmitted

Figure 4 is titled “HF readmissions for transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and Forest Plot of Individual Trials”. The figure displays a forest plots of trials reporting HF readmissions (number of people readmitted). The figure is described further in the “Detailed Synthesis: Heart Failure Readmission: Transitional Care Interventions Compared with Usual Care” section. Home-visiting program: “At 3 months, one trial (N=282) found that patients receiving home visits had a reduced risk of HF readmissions compared with controls (RR, 0.51; 95% CI, 0.31 to 0.82). One other trial (N=200) reported the total number of readmissions per group (rather than the number of patients readmitted) at 3 months; patients receiving home visits had fewer total HF readmissions than did patients receiving usual care (measured as readmissions per patient year alive, RR, 0.54; p<0.001).” Structured Telephone Support: “One trial (N=134) found no difference in the risk of HF readmissions between patients receiving STS and those receiving usual care at 30 days (RR, 0.63; 95% CI, 0.84 to 1.54). Over 3 to 6 months, our meta-analysis (nine trials) found that people receiving STS had a lower risk of HF readmissions than controls (RR 0.74, 95% CI, -0.61 to 0.90).” Telemonitoring: “At 6 months, one trial (N=182) found no difference in the risk of HF readmission between patients receiving telemonitoring and controls (RR, 1.70; 95% CI, 0.82 to 3.51). Two additional trials reported the total number of readmissions per group (rather than patients readmitted); neither study found a difference between these two groups.” Clinic-based Interventions: “Two clinic based interventions reported HF readmissions at 6 months, one MDS-HF clinic intervention and one nurse-led clinic intervention. The MDS-HF trial (N=106) found no difference in the risk of HF readmission between patients receiving the intervention and those receiving usual care (RR, 0.70; 95% CI, 0.29 to 1.70). The trial of nurse-led clinic intervention (N=158) also found no difference in the risk of HF readmission between the intervention and control groups (RR, 0.95; 95% CI, 0.68 to 1.32).” Primarily Educational Interventions: “One trial (N=123) found a lower risk of HF readmission among patients receiving face-to-face intensive HF education before discharge compared to those receiving usual care at 3 months (RR, 0.53; 95% CI, 0.31 to 0.90).”

##### Home-Visiting Program

At 3 months, one trial (N=282) found that patients receiving home visits had a significantly lower risk of HF-specific readmissions than controls (RR, 0.51; 95% CI, 0.31 to 0.82).57 Another trial (N=200) reported the total number of readmissions per group (rather than the number of patients readmitted) at 3 months; patients receiving home visits had significantly fewer total HF-specific readmissions than did patients receiving usual care (measured as readmissions per patient-year alive, RR, 0.54; p<0.001).53

##### Structured Telephone Support

One trial (N=134) found no difference in the risk of HF-specific readmission between patients receiving STS and those receiving usual care at 30 days (RR, 0.63; 95% CI, 0.84 to 1.54).64 Over 3 to 6 months, our meta-analysis (nine trials) found that people receiving STS had a significantly lower risk of HF readmission than controls (RR, 0.74; 95% CI, 0.61 to 0.90).63-68,71-73

##### Telemonitoring

At 6 months, one trial (N=182) found no difference in the risk of HF-specific readmission between patients receiving telemonitoring and controls (RR, 1.70; 95% CI, 0.82 to 3.51).80 Two trials reported the total number of readmissions per group (rather than patients readmitted); neither study found a difference between these two groups.77,79

##### Clinic-Based Interventions

Two clinic-based interventions reported HF-specific readmissions at 6 months—one in an MDS-HF clinic and the other in a nurse-led clinic. The MDS-HF trial (N=106) found no difference in the risk of HF-specific readmission between patients receiving the intervention and those receiving usual care (RR, 0.70; 95% CI, 0.29 to 1.70).90 The nurse-led clinic trial (N=158) also found no difference in the risk of HF-specific readmission between the intervention and control groups (RR, 0.95; 95% CI, 0.68 to 1.32).83

##### Primarily Educational Interventions

One trial (N=123) found a significantly lower risk of HF-specific readmission among patients receiving face-to-face intensive HF education before discharge compared with those receiving usual care at 3 months (RR, 0.53; 95% CI, 0.31 to 0.90).95 A sensitivity analysis, for which we added a second educational intervention trial rated as high risk of bias, showed attenuated effect in the risk of HF-specific readmission between patients receiving an educational intervention and those receiving usual care that was no longer statistically significant (RR, 0.76; 95% CI, 0.36 to 1.63; Appendix F).92,95

##### Other Interventions

One trial (N=88) assessing peer support among patients recently discharged for HF (rated high risk of bias) found a higher risk of HF-specific readmission among the intervention group than among the control group at 30 days and 3 months; the authors stated that the differences were not statistically significant (p-value or CIs not reported).96

#### Composite All-Cause Readmission or Death: Transitional Care Interventions Compared With Usual Care

Our meta-analysis of trials reporting the composite outcome is shown in Figure 5. We present detailed results by intervention category and outcome timing below.

Figure 5 Composite all-cause readmission or death for transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and forest plot of individual trials

N= sample size; Treatment events= number of people readmitted in the intervention group; Usual Care Events= number of people readmitted in the usual care group.

Figure 5 is titled, “Composite all-cause readmission or death for transitional care interventions compared with usual care, by intervention category and outcome timing: meta-analysis and forest plot of Individual trials.” The figure displays forest plots of trials reporting composite all-cause readmission or death for transitional care interventions versus usual care, by intervention category and outcome timing. This figure is described further in the “Combined All-cause Readmission or Death: Transitional Care Interventions Compared with Usual Care” section. Home-visiting Programs: “Our meta-analyses (three RCTs) found a reduced risk of the composite outcome in patients receiving home visits compared to controls (RR, 0.78; 95% CI, 0.65 to 0.94).” Structured Telephone Support: “Over 3 to 6 months, our meta-analysis (3 trials) found no difference in the risk of the composite outcome between patients receiving STS and controls (RR, 0.81; 95% CI, 0.58 to 1.12).” Clinic-based Interventions: “Our meta-analysis (two trials) showed that patients receiving MDS outpatient care experienced a trend toward reduced risk of the composite outcome compared to controls that was not statistically significant (RR, 0.80; 95% CI, 0.63 to 1.02). One trial (N=106) assessing a nurse-led HF clinic found that patients receiving the intervention experienced a trend towards reduced risk of the composite outcome (that was not statistically significant) compared to controls (RR, 0.66; 95% CI, 0.43 to 1.01).” Primarily Educational Interventions: “Our meta-analysis (two trials) found no difference in the risk of the composite outcome between patients receiving an educational intervention and patients receiving usual care (RR, 0.92; 95% CI, 0.58 to 1.47).”

##### Home-Visiting Programs

Our meta-analyses (three RCTs) found a significantly lower risk of the composite outcome among patients receiving home visits than among controls (RR, 0.78; 95% CI, 0.65 to 0.94).50,56,60 One other trial (N=239) presented the estimated proportion of patients alive and with no hospital readmissions at various points after the intervention.55 Patients in the intervention group were more likely to be alive with no hospitalizations than those receiving usual care at 30 days (hazard ratios 0.869 [standard error 0.033] versus 0.737 [0.041]), 3 months (0.071 [0.045] versus 0.558 [0.047]), and 6 months (0.600 [0.047] versus 0.444 [0.047]); p-values were not reported.

##### Structured Telephone Support

Over 3 to 6 months, our meta-analysis (three trials) found no difference in the risk of the composite outcome between patients receiving STS and controls (RR, 0.81; 95% CI, 0.58 to 1.12).66-68

##### Clinic-Based Interventions

Our meta-analysis (two trials) showed no difference in the risk of the composite outcome between patients receiving MDS-HF clinic care and controls (RR, 0.80; 95% CI, 0.63 to 1.02).87,90 One trial (N=106) assessing a nurse-led clinic intervention found a lower risk of readmission in patients receiving the intervention compared with controls (RR, 0.66; 95% CI, 0.43 to 1.01).88

##### Primarily Educational Interventions

Our meta-analysis (two trials) found no difference in the risk of the composite outcome between patients receiving an educational intervention and patients receiving usual care (RR, 0.92; 95% CI, 0.58 to 1.47, I^2^ 83.9).93,95 Despite the heterogeneity, we considered the interventions similar enough in terms of included population and intervention components to justify combining in a meta-analysis. The trial by Koelling et al. included a 1-hour individual teaching session with a nurse educator before discharge and focused on self-care behaviors, with no additional followup after discharge; patients receiving this intervention experienced a lower risk of the composite outcome than controls.95 The trial by Nucifora et.al included a similar predischarge educational intervention and one nurse telephone followup after discharge with the goal of reinforcing education.93 Baseline population characteristics between patients in these two trials did not differ in any obvious way. The trials were conducted in different settings (Italy; the United States), and differences in usual care (not reported in detail) may explain the inconsistent results.

#### Emergency Room or Acute Care Visits: Transitional Care Interventions Compared With Uual Care

Few trials reported on the number of patients seeking emergency care or acute care visits. All trials categorized these visits as “emergency department” or ER visits. We found no trials reporting acute care visits separately.

##### Home-Visiting Program

Three home-visiting trials reported on ER visits; all reported on different lengths of followup and used different methods to calculate the rate of ER visits. One of these trials (N=179) found that the number of patients who had an ER visit did not differ between those receiving home visits and those receiving usual care at 30 days (5 percent versus 4 percent, p-value NR) or at 3 months (17 percent versus 22 percent, p-value NR).47 At 6 months, another trial (N=97) found significantly fewer total ER visits per group among patients receiving home visits than among those receiving usual care (48 versus 87 visits, p=0.05).51 Finally, one trial (N=58), rated high risk of bias, found no difference in mean ER visits per patient over 6 months between patients in the intervention and control groups.52

##### Structured Telephone Support

Six STS trials provided data on ER visits at different time points and using different methods. At 3 months, one trial (N=111) found no difference in the total number of ER visits among patients receiving STS and patients receiving usual care (RR, 0.66; 95% CI, 0.21 to 2.05; p=0.67).67 Two trials reported on the number of ER visits at 6 months; neither found a difference between patients receiving STS and those receiving usual care. In one trial (N=276), 22.1 percent of patients receiving STS and 27.9 percent of patients receiving usual care had at least one ER visit (p=0.266).72 Another trial (N= 358) reported the mean number of ER visits per person in each group; those receiving STS had 0.14 visits (standard deviation [SD], 0.45) and those receiving usual care had 0.11 visits (SD, 0.34) (p=0.58).63 One trial (N=37), rated high risk of bias, found that patients receiving STS had fewer ER visits related to HF over 6 months than controls; however, the number of all-cause ER visits did not differ between the intervention and control groups.70

##### Telemonitoring

No trial assessing a telemonitoring intervention found either an increase or a decrease in ER visits in patients receiving the intervention compared with those receiving usual care. At 3 months in one trial (N=102), the average number of ER visits per patient did not differ between the telemonitoring group (0.34) and the control group (0.38) (p=0.73).78 Two trials, rated high risk of bias, did not find a difference in total ER visits at 3 months between patients receiving telemonitoring and those receiving usual care.70,81

At 6 months, one trial (N=182) found that the total number of ER visits was lower in the intervention group (20) than in the control group (32); the authors stated that the difference was not significant.80 The authors of one trial (N=280, rated high risk of bias) reported no difference in ER visits between intervention and control groups at 6 months (data not provided).79 One trial (N=37), rated high risk of bias, found that patients receiving telemonitoring had fewer CHF-related ER visits over 6 months than controls; however, the number of all-cause ER visits did not differ between the intervention and control group.70

##### Clinic-Based Interventions

In one trial (N= 230), at 6 months, the percentage of patients seen in the ER did not differ between patients receiving MDS-HF clinic management and those receiving usual care (HR, 0.97; 95% CI, 0.70 to 1.36).89

##### Primarily Educational Interventions

One trial (N=76) found that the percentage of patients seen in the ER did not differ at 3 months between patients receiving video HF education and those receiving usual care (38 percent versus 33 percent; p=0.68).92

#### Hospital Days (of Subsequent Readmissions): Transitional Care Interventions Compared With Usual Care

##### Home-Visiting Programs

At 30 days, one trial (N=179) found no difference in the mean number of readmission hospital days between patients receiving home visits (2.2 days; SD, 7) and those receiving usual care (2.3 days; SD, 7).47

Our meta-analysis (four trials; see Appendix E) found no difference in the mean number of hospital days per person accumulated over 3 months between people receiving home visits and those receiving usual care (weighted mean difference [WMD], -1.17; 95% CI, -2.44 to 0.09).47,53,57,58 At 6 months, three trials reported the total number of hospital days accumulated per group (along with a p-value).50,51 ,60 All found that patients receiving home visits accumulated fewer readmission days than controls (Table 10).

Table 10 Hospital days accumulated over 6 months: Home visiting versus usual care

Author, Year | Sample Size | Home-Visiting Hospital Days | Usual Care Hospital Days | P-Value
Stewart et al., 1998^51^ | Home visiting (49) Usual care (48) | 261 | 452 | 0.05
Stewart et al., 1999^50^ | Home visiting (100) Usual care (100) | 875 | 1476 | 0.04^a^
Thompson et al., 2005^60^ | Home visiting (58) Usual care (48) | 108 | 459 | <0.01^b^

a Excluding “planned” admissions (e.g., for surgical procedures, other planned admissions).

b Adjusted for the number of events per patient per month of followup.

##### Structured Telephone Support

At 30 days, one trial (N=134) found no difference in the mean hospital days accumulated between patients receiving STS and controls (WMD, -0.95; 95% CI, -2.43 to 0.53).64

Our meta-analysis (five trials; Appendix E) found that patients receiving STS accumulated significantly fewer total hospital days over 3 to 6 months than did patients receiving usual care (WMD, -2.49; 95% CI, -3.39 to -1.04).63-65,72,73

##### Telemonitoring

No RCT comparing telemonitoring with usual care found a reduction in length of hospital stay or total accumulated hospital days at any time point.

One trial (N=168) found no difference in mean length of hospital stay per patient readmitted both at 30 days (telemonitoring, 1.9 days [SD, 4.4]; control: 1.8 days [SD, 12.2]) and at 90 days (telemonitoring: 4.9 days [SD, 8.2]; usual care: 4.8 [SD, 10.2].82 Another trial (N=121), rated high risk of bias, found no difference in mean length of hospital stay per person readmitted among patients receiving telemonitoring and controls (2.69 days versus 3.75 days; NS per authors).81

At 6 months, one trial (N=182) found no difference in median duration of readmission hospital stay between intervention and control groups (17 days versus 13 days; p=0.99).80 Two trials, rated high70 or unclear risk of bias,77 each found no difference in mean length of hospital stay at 6 months between intervention and control arms.

##### Clinic-Based Interventions

One trial (N=230) found that patients receiving MDS-HF management had significantly fewer total hospital days at 6 months than did patients receiving usual care (HR, 0.61; 95% CI, 0.39 to 0.95).89

At 3 months, one trial (N=106) found that patients receiving care in a nurse-led HF clinic had significantly fewer hospital days per group than patients receiving usual care (350 days versus 592; p=0.045).88 At 6 months, another nurse-led clinic trial (N=158) found no difference in mean hospital days per patient among patients receiving the intervention (26 days; SD, 31) and those receiving usual care (18 days; SD, 19) (p-value NS per investigators).83

One trial (N=443) evaluating increased access to primary care in a VA setting found that patients receiving the primary care intervention had a significantly higher mean hospital length of stay at 6 months than did patients receiving usual care (9.1 versus 7.3 days; p=0.04).91

##### Primarily Educational Interventions

One trial (N=200) found no difference in the mean length of hospital stay over 6 months for patients receiving intensive predischarge education and those receiving usual care (20 days versus 15 days; p=NS per authors).93

##### Other Interventions

The trial (N=88; rated high risk of bias) assessing the efficacy of peer support for HF patients found no difference in the mean number of all-cause hospital days per patient among those receiving peer support and patients receiving usual care at 30 days (0.87 days versus 1.2 days; p=NS per authors) and at 3 months (1.8 days versus 2.1 days, respectively; p=NS per authors).96

### Detailed Synthesis: Comparative Effectiveness of Transitional Care Interventions

#### Telemonitoring Versus Home Visiting

A single trial (N= 216, rated unclear risk of bias) compared telemonitoring with a home-visiting program. At 3 months, the telemonitoring group had significantly fewer total HF readmissions than the group receiving home visits (13 versus 24 readmissions; p≤0.001).61 Similarly, the telemonitoring group had significantly fewer HF readmissions at 6 months than the group receiving home visits (38 versus 63 readmissions; p≤0.05).61 The group receiving telemonitoring also accumulated significantly fewer hospital days at 3 months than the group receiving home visits (49.5 versus 105.0 days; p≤0.001).61

#### Telemonitoring Versus Structured Telephone Support

One trial (N= 37, rated high risk of bias) had three arms: (1) telemonitoring (video nursing visits), (2) STS, and (3) usual care. Neither all-cause nor HF readmissions differed among groups over 6 months.70 Mean ER visits and mean length of stay did not differ over 6 months between the telemonitoring and STS groups.70

## KQ 2 Transitional Care Interventions and Health and Social Outcomes

### Key Points: Mortality

- Home-visiting programs, STS, and MDS-HF clinic interventions were efficacious in reducing mortality over 3 to 6 months (moderate SOE for each category).
- Evidence was insufficient to determine whether home-visiting programs affected mortality at 30 days.
- Three categories of interventions did not reduce mortality rates over 3 to 6 months: telemonitoring, nurse-led clinic interventions, and primarily educational interventions (low SOE for each category).
- Evidence was insufficient to determine whether the following intervention categories affected mortality at any time point: the primary care clinic intervention and cognitive training.

### Key Points: Quality of Life and Function

- Home-visiting programs improved HF-specific quality of life (measured by the Minnesota Living with Heart Failure Questionnaire [MLWHFQ]) at 3 months (low SOE). Evidence was insufficient to determine whether home-visiting programs improved HF-specific quality of life at 6 months (due to imprecision and inconsistent findings).
- STS did not improve HF-specific quality of life compared with usual care at 3 or 6 months (low SOE).
- Evidence was insufficient to determine whether telemonitoring, primarily educational interventions, and clinic-based interventions affected quality-of life outcomes at 3 or 6 months following an inpatient admission.
- Too few trials reported other quality-of-life outcomes or functional status outcomes using the same scales at similar time points to assess whether interventions improved these types of outcomes.

### Key Points: Caregiver and Self-Care Burden

- No trial assessing the efficacy of a transitional care intervention reported outcomes on caregiver or self-care burden.

### Key Points: Comparative Effectiveness

- Direct evidence was insufficient to determine whether one type of transitional care intervention was more or less efficacious than any other type of intervention for any health or social outcome.

### Detailed Synthesis: Transitional Care Interventions Compared With Usual Care

#### Mortality: Transitional Care Interventions Versus Usual Care

Figure 6 presents our meta-analysis of trials reporting mortality stratified by intervention category and the outcomes measurement points. We present detailed results by intervention category and outcome timing below.

Figure 6 Mortality among patients receiving transitional care interventions compared with usual care, by intervention category and outcome timing: Meta-analysis and forest plot of individual trials

N = sample size; Treatment deaths = number of people who died in the intervention group; Usual Care deaths = number of people who died in the usual care group.

Figure 6 is titled “Mortality among patients receiving transitional care interventions compared with usual care, by intervention category and outcome timing: meta-analysis and forest plot of individual trials.” The figure displays forest plots of trials reporting mortality for patients receiving transitional care interventions versus usual care, by intervention and outcome timing. This figure is described further in the “Mortality: Transitional Care Interventions versus Usual Care” section. Home-visiting Programs: “One trial (N=239) reported mortality rates at 30 days; there was no difference in mortality between the intervention and control groups (RR, 1.03; 95% CI, 0.15 to 7.16). Over 3 to 6 months, our meta-analysis (eight trials) found reduced risk of mortality reduced among patients receiving home visits compared to those receiving usual care (RR, 0.77; 95% CI, 0.60 to 0.996). “ Structured Telephone Support: “Our meta-analysis (six trials) found reduced risk of mortality among patients receiving STS compared to controls (RR, 0.69; 95% CI, 0.51 to 0.92).” Telemonitoring: “Our meta-analysis (three trials) found no difference in mortality over 3 to 6 months, between patients receiving telemonitoring and those receiving usual care (RR, 0.93; 95% CI, 0.25 to 3.48; I2 84 percent).” Clinic-based Interventions: “ Our meta-analysis (three trials) found that the MDS-HF clinic patients had reduced risk of mortality compared to control patients (RR, 0.56; 95% CI, 0.34 to 0.92).Our meta-analysis (two trials) assessing nurse-led HF clinic interventions found no difference in mortality over 3 to 6 months between patients receiving the intervention and patients receiving usual care (RR, 0.59; 95% CI, 0.12 to 3.03, I2 83.8%). The trial assessing increased access to primary care (N= 443) found a trend towards increased mortality in the intervention group compared with controls that was not statistically significant (RR, 1.52; 95% CI, 0.88 to 2.63).” Primarily Educational Interventions: “Our meta-analysis (two trials) found no difference in mortality between patients receiving an educational intervention and those receiving usual care (RR, 1.20; 95% CI, 0.52 to 2.76).” Other Interventions: “One trial assessing cognitive training among patients with HF and co-existing mild cognitive dysfunction found that the group receiving the intervention experienced a trend towards reduced mortality that was not statistically significant (RR, 0.07; 95% CI, 0.00 to 1.12).”

##### Home-Visiting Programs

One trial (N=239) reported mortality rates at 30 days; mortality did not differ between the intervention and control groups (RR, 1.03; 95% CI, 0.15 to 7.16).55 Over 3 to 6 months, our meta-analysis (eight trials) found a significantly lower risk of mortality among patients receiving home visits than among those receiving usual care (RR, 0.77; 95% CI, 0.60 to 0.996).50,51,53-57,59

##### Structured Telephone Support

Our meta-analysis (six trials) found a significantly lower risk of mortality among patients receiving STS than among controls (RR, 0.69; 95% CI, 0.51 to 0.92).64-66,68,69,73 Wakefield et al. evaluated the efficacy of two STS applications, one delivered by telephone and one by videophone, both compared with usual care.69 In our meta-analysis, we included only the telephone arm (compared with usual care) as it is similar to other included trials assessing STS. The STS arm using videophone did not lower the risk of mortality compared with usual care.69

##### Telemonitoring

Our meta-analysis (three trials) found no difference in mortality over 3 to 6 months between patients receiving telemonitoring and those receiving usual care (RR, 0.93; 95% CI, 0.25 to 3.48; I^2^ 84 percent).78-80 These trials produced inconsistent findings. One found a significant improvement in mortality for patients receiving telemonitoring compared with patients receiving usual care;79 another found a significant increase in mortality in the intervention group.80 The third found no difference between the intervention and control group.78 Studies used similar equipment in patient populations that appeared comparable; the UK study by Goldberg et al. (which produced a mortality benefit) also included one initial home visit when staff were setting up the telemonitoring equipment.79 Patients may have benefited from the in-home assessment or usual care may have differed. A sensitivity analysis, which included two additional trials rated as unclear or high risk of bias, did not change the overall results (Appendix E).

##### Clinic-Based Interventions

Our meta-analysis (three trials) found that the MDS-HF clinic patients had a significantly lower risk of mortality over 3 to 6 months than control patients (RR, 0.56; 95% CI, 0.34 to 0.92).87,89,90 Our meta-analysis (two trials) found no difference in mortality over 3 to 6 months between patients receiving nurse-led clinic interventions and patients receiving usual care (RR, 0.59; 95% CI, 0.12 to 3.03; I^2^ 83.8%).83,88 Despite the significant heterogeneity, we judged these trials to be similar enough to combine in a meta-analysis. Both trials assessed similar, nurse-directed clinic interventions at a single institution in Sweden; the interventions featured similar components such as psychosocial support, individualized education, and coordination with a cardiologist.83,88 The trial assessing increased access to primary care in a VAMC (N= 443) found no difference in mortality between the intervention and control groups (RR, 1.52; 95% CI, 0.88 to 2.63).91

##### Primarily Educational Interventions

Our meta-analysis (two trials) found no difference in mortality between patients receiving an educational intervention and those receiving usual care (RR, 1.20; 95% CI, 0.52 to 2.76).93,95

##### Other Interventions

One trial assessing cognitive training among patients with HF and coexisting mild cognitive dysfunction found that the group receiving the intervention experienced reduced mortality compared with patients receiving usual care (RR, 0.07; 95% CI, 0.00 to 1.12).97

#### Quality of Life or Functional Status

Table 11 describes the common quality of life and functional status measures used in this literature. Overall, the types of measure used varied considerably across categories of interventions and at each eligible point of measuring outcomes. Few trials reported on measurements of functional status; for each category of interventions, we present our data synthesis of quality of life and functional status measures together.

Table 11 Quality of life or function measures used in the included trials

Abbreviated Name | Complete Name | Range of Scores | Improvement Indicated By
MLWHFQ | Minnesota Living With Heart Failure Questionnaire | 0-105 | Decrease
NYHA | New York Heart Association Classification | II-IV | Decrease
6MWT | Six-Minute Walk Test | 0-400+ meters^a^ | Increase
EuroQoL or EQ-5D | European Quality of Life-5 Dimensions | 0-100 | Increase
SF-12 | Medical Outcomes Study Short Form (12 items) | 0-100 | Increase
SF-36 | Medical Outcomes Study Short Form (36 items) | 0-100 | Increase

a This is the distance a person can walk within 6 minutes on a flat surface. An improvement of 54 meters is considered clinically significant.99

##### Home-Visiting Programs

Seven trials reported on at least one quality of life or functional status measure. One trial (N=226) found that quality of life measured with the MLWHFQ did not differ between intervention and control groups at 2 weeks.55 Our meta-analysis (two trials; Appendix E) found that patients receiving home visits had significantly better HF-specific quality of life than controls as measured by the MLWHFQ at 3 months (standardized mean difference [SMD], -0.26; 95% CI, -0.47 to -0.05) but not at 6 months (SMD, -0.04; 95% CI, -0.35 to 0.26).55,59 At six months, these two trials found inconsistent results and there was moderate statistical heterogeneity. Although both of these trials measured MLWHFQ, one of them reported the results on a log scale,55 placing scores into categories (from 1-5) and assigning “0” to patients who died. For this reason, we did not use a WMD in the meta-analysis but instead calculated an SMD. One additional trial (N=200) found significant improvement in MLWHFQ scores at 3 months in patients receiving home visits compared with those receiving usual care (change from baseline: -19 versus -1; p=0.04).50

Table 12 summarizes the results of other quality of life or functional status measures reported by trials assessing a home-visiting program. In one trial, patients receiving home visits had improved quality of life at 3 months as measured by the MLWHFQ and SF-36 physical health score.50 Three additional trials found no improvement in any measure of quality of life or function at 3 or 6 months.

Table 12 Results of quality of life and function: Home visiting versus usual care

Study | Arm (N) | Outcome Measures(s) | Baseline Value | Change From Baseline (or End of Treatment Mean) | P-Value^a^
Stewart et al., 1999^50^ | HV (100) UC (100) | MLWHFQ | HV: 65 (47 to 70) UC: 62 (49 to 73) | 3 months (median change and IQR): HV: -19 (-41 to 1); UC: -1 (-29 to 10) | 0.04
Stewart et al., 1999^50^ | HV (100) UC (100) | | | 6 months: HV: -17 (-35 to -8); UC: -12 (-35 to -8) | 0.30
Stewart et al., 1999^50^ | HV (100) UC (100)
Stewart et al., 1999^50^ | HV (100) UC (100) | SF-36 physical health score | HV: 26 (21 to 32) UC: 23 (18 to 28) | 3 months: HV: 16 (5 to 2.7); UC: 3 (-8 to 14) | 0.02
Stewart et al., 1999^50^ | HV (100) UC (100) | | | 6 months : HV: 17 (3 to 27); UC: 15 (3 to 31) | 0.53
Stewart et al., 1999^50^ | HV (100) UC (100)
Stewart et al., 1999^50^ | HV (100) UC (100) | SF-36 mental health score | HV: 58 (48 to 76) UC: 56 (37 to 68) | 3 months : HV: 10 (-19 to 19); UC: 6 (-9 to 31) | 0.48
Stewart et al., 1999^50^ | HV (100) UC (100) | | | 6 months: HV: 7 (-15 to 31); UC: 19 (10 to 31) | 0.46
Thompson et al., 2005^60^ | HV (58) UC (48) | MLWHFQ | NR | 6 months (change from baseline): HV: -14.2; UC: -13.7 | NS
Thompson et al., 2005^60^ | HV (58) UC (48) | SF-36 | NR | SF-36 (change from baseline for 8 sub-scores; authors presented data in figure only) | NS
Holland et al., 2007^59^ | HV (148) UC (143) | EQ-5D | HV: 0.58 (SD 0.32) UC: 0.57 (SD 0.34) | 3 months (mean score and SD): HV: 0.54 (0.33); UC: 0.51 (0.37) | NS
Holland et al., 2007^59^ | HV (148) UC (143) | | | 6 months: HV: 0.58 (0.29); UC: 0.52 (0.34) | 0.07
Kwok et al., 2008^54^ | HV (44) UC (46) | 6MWT | HV: 120.7 m (SD 62.0) UC: 118.5 m (SD 62.5) | 6 months (changes in from baseline): HV: 44 (-15, 84) UC: 25 (-22, 69) | NS

a p-value is for result indicated—i.e., either change from baseline or difference in mean scores.

HV = home visiting; IQR = interquartile range; MLWHFQ = Minnesota Living with Heart Failure Questionnaire; 6MWT = 6-minute walk test; NR = not reported; NS = not significant; SD, standard deviation; SF-36= Medical Outcomes Study Short Form (36 items); UC = usual care.

Two trials rated high risk of bias found no difference in function measured by the 6-minute walk test between patients receiving home visits and those receiving usual care; one measured function at 30 days48 and the other at 6 months.52

##### Structured Telephone Support

Our meta-analysis (two trials; Appendix E) found no difference in MLWHFQ scores among patients receiving STS and those receiving usual care at either 3 months (WMD, -3.78; 95% CI, -10.39 to 2.83) or 6 months (WMD, -7.14; 95% CI, -21.07 to 6.78).64,69 Wakefield and colleagues included STS delivered by standard telephone or by videophone (without telemonitoring);69 we included only the comparison between telephone-based STS and usual care.

Three additional trials reported on quality of life at 6 months (Table 13). In one trial, patients receiving STS had significantly better NYHA classification and SF-36 physical functioning subscale and physical health summary measure scores at 3 months than patients receiving usual care.66 Another reported on physical and emotional subscales of the MLWHFQ and on physical and mental health summary measures of the SF-12; patients receiving STS had significantly better scores on the SF-12 physical scale than controls at 6 months, but all other comparisons were not significant.68

Table 13 Results of quality of life and function: Structured telephone care versus usual care

Study | Arm (N) | Outcome Measures(s) | Baseline Value | Change From Baseline (or End of Treatment Mean) | P-Value^a^
Barth, 2001^62^ | STS (17) UC (17) | MLWHFQ | MLWHFQ total score: | Change from baseline (SD) at 2 months: | NS^c^
Barth, 2001^62^ | STS (17) UC (17) | MLWHFQ
Barth, 2001^62^ | STS (17) UC (17) | MLWHFQ | STS: 50.9 (16.3); UC; 49.7 (15.7) | STS: 8.2 (4.3); UC: NR (NS per authors)
Dunagan et al., 2005^68^ | STS (64) UC (66) | MLWHFQ SF-12 | Mean (SD) | Change from baseline (SD) at 6 months
Dunagan et al., 2005^68^ | STS (64) UC (66) | MLWHFQ SF-12 | MLWHFQ physical scale: STS: 23.6 (10.8); UC: 23.0 (11.3) | MLWHFQ physical scale: STS: 9.3 (8.9); UC: 5.2 (10.4) | 0.33
Dunagan et al., 2005^68^ | STS (64) UC (66) | MLWHFQ SF-12
Dunagan et al., 2005^68^ | STS (64) UC (66) | MLWHFQ SF-12 | MLWHFQ emotional scale: STS: 46.2 (11.9); UC:46.6 (11.2) | MLWHFQ emotional scale: STS: 2.7 (6.0); UC:2.4 (6.8) | 0.90
Dunagan et al., 2005^68^ | STS (64) UC (66) | MLWHFQ SF-12
Dunagan et al., 2005^68^ | STS (64) UC (66) | MLWHFQ SF-12 | SF-12 physical scale: STS: 24.1 (10.1); UC: 24.9 (11.3) | SF-12 physical scale: STS: 1.2 (9.9); UC: -2.7 (10.7) | 0.028
Dunagan et al., 2005^68^ | STS (64) UC (66) | MLWHFQ SF-12
Dunagan et al., 2005^68^ | STS (64) UC (66) | MLWHFQ SF-12 | SF-12 mental scale: STS: 46.2 (11.9); UC: 46.6 (11.2) | SF12 mental scale: STS: 7.3 (12.7); UC: 5.5 (11.7) | 0.20
Lopez Cabezas et al., 2006^73^ | STS (70) UC (64) | EuroQoL | NR | 2 months: mean (SD) STS: 62.3 (17.3) UC: 65.0 (17.6) | NS^b^
Lopez Cabezas et al., 2006^73^ | STS (70) UC (64) | EuroQoL | NR | 6 months: mean (SD) STS: 62.9 (14.9) UC: 62.8 (14.1) | NS^b^
Angermann et al., 2012^66^ | STS (352) UC (363) | NYHA class | % with NYHA III or IV: STS 40% UC 36% | NYHA class at 3 months Worsened: HV 17%; UC 10% Unchanged: HV 49%; UC 52% Improved: HV 33%; UC 38% | 0.05^b^
Angermann et al., 2012^66^ | STS (352) UC (363) | SF-36 | STS: mean (SD) Physical function.: 48 (30) Physical health: 36 (11) Mental health: 44 (12) | Mean change (SD) at 3 months Physical function: STS: +2.8 (10.0); UC +1.3 (9.9) | 0.03
Angermann et al., 2012^66^ | STS (352) UC (363) | | UC: mean (SD) Physical function.: 44 (29) Physical health: 36 (11) Mental health: 44 (12) | Physical health: STS: +5.9 (25.8); UC +1.8 (24.7) | 0.03
Angermann et al., 2012^66^ | STS (352) UC (363) | | UC: mean (SD) Physical function.: 44 (29) Physical health: 36 (11) Mental health: 44 (12) | Mental health: STS: +2.3 (12.4); UC +2.3 (12) | 0.57

a All p-values in this column are for the difference in change from baseline between groups unless noted otherwise.

b p-value for overall trend (improvement) is based on logistic regression.

c As reported by authors. The authors did not specifically report a p-value for the difference in mean change at 2 months between intervention and control groups. They did, however, report that the change from baseline to 2 months was p<0.00 for change from baseline (improvement) in STS group and “not significant” for the usual care group.

MLWHFQ = Minnesota Living with Heart Failure Questionnaire; NR = not reported; NS = not significant; NYHA = New York Heart Association Classification; SD = standard deviation; SF-12 = Medical Outcomes Study Short Form (12 items); STS = structured telephone support; UC = usual care.

##### Telemonitoring

In one trial (N=102), patients receiving telemonitoring and those receiving usual care did not differ in mean MLWHFQ scores at 3 months (27.4 versus 27.3, respectively, p=0.99 for difference in mean scores between groups).78 Another trial (N=182) reported no difference in MLWHFQ or European Quality of Life-5 Dimensions outcomes at 6 months between intervention and control groups (authors did not provide data).80

##### Clinic-Based Interventions

At 6 months, one trial (N=200) found that patients receiving care through an MDS-HF clinic experienced significantly greater improvement on the total MLWHFQ score than patients receiving usual care (change from baseline -28.3 versus -15.7; p=0.01).87 In the same trial, patients receiving care in the MDS-HF clinic also experienced significantly greater improvement in NYHA functional class than did controls (25 percent of intervention group and 43 percent of the usual care group had NYHA class III or IV at 6 months; p=0.03 [test for trend]).87

The one trial (N=443) assessing enhanced access to primary care found no difference between intervention and control groups in mean scores on the SF-36 mental and physical summary measures at 6 months (p=0.2 for both).91

##### Primarily Educational Interventions

Two trials evaluating a primarily educational intervention reported quality of life measured with the MLWHFQ at 6 months but produced inconsistent findings. In one trial (N=223), total MLWHFQ scores were significantly better among patients receiving predischarge, in-person education than among those receiving usual care (14 [SD, 20] versus 10 [SD, 16]; p<0.0001].93 In another trial (N=149), patients receiving discharge education did not improve compared with patients receiving usual care (41 [SD, 22] versus 42 [SD, 25]; p-value not reported).95

##### Other Interventions

Neither trial in this category reported on a quality-of-life or functional status outcome.

### Detailed Synthesis: Comparative Effectiveness of Transitional Care Interventions

#### Telemonitoring Compared With Home-Visiting Program

One trial (N=216, rated unclear risk of bias) compared a telemonitoring program with a home-visiting program. At 3 months, MLWHFQ scores did not differ between the groups (telemonitoring mean score: 51.64 [SD, 17.36]; home-visiting mean score: 57.72 [SD, 16.24]; p=0.47).61

## KQ 3 Components of Effective Interventions

We defined effective interventions as: (1) intervention categories (defined in Table 2 in Methods) that reduced either all-cause readmission (from our meta-analyses for KQ 1) or the composite endpoint of all-cause readmission or death; (2) intervention categories that reduced mortality (from our meta-analyses for KQ 2); or (3) individual trials in other categories that were efficacious for reducing all-cause readmissions, mortality, or the composite endpoint. Few trials reported outcomes at 30 days. Below we describe the components of interventions that showed efficacy at any eligible time point (up to 6 months following an index hospitalization for HF).

For all included trials, we abstracted information about the intervention components as the authors had described them. We considered intervention “components” as any part of the intervention that could be separated out and that could influence efficacy. Across trials, authors provided varying levels of detail about interventions and components. Evidence tables (Appendix C) give the full data abstraction of intervention components of all included trials.

Here we focus on the content (e.g., education, exercise recommendations) and process (e.g., care coordination) components of interventions. We evaluate intensity, delivery personnel, and mode of delivery separately in KQ 4; we also mention mode of delivery (e.g., whether the intervention is delivered in person) in KQ 3 because we cannot separate mode of delivery from some intervention components (e.g., use of home visits or coordination of care with providers).

### KQ 3a Intervention Components

#### All-Cause Readmissions and Composite All-Cause Readmission or Death

Table 14 summarizes the components that we identified in the articles describing efficacious interventions that reduced all-cause readmission or the composite endpoint at either 30 days or over 3 to 6 months (or both). The main categories were home-visiting programs and MDS-HF clinic interventions. One education trial (a nursing education session) also was efficacious (for the composite endpoint at 6 months) and two trials of STS were efficacious in reducing all-cause readmission at 6 months.

Table 14 KQ 3, Components of effective interventions: All-cause readmissions or composite (all-cause readmission or death) outcome

Author, Year | Category | Primary Mode of Delivery | Self-Care Management Promotion | Weight- monitoring Education | Diet/Sodium Restriction Education | Promotion of Medication Adherence | Exercise Education or Promotion | Unspecified HF Education | Medication Reconciliation
Ducharme et al., 2005^89^ | MDS-HF | Face-to-face | x | x | x | x | ─ | x | x
Liu et al., 2012^90^ | MDS-HF | Face-to-face | x | ─ | ─ | x | ─ | ─ | x
Rich et al., 1993^58^ | HV | Face-to-face | x | x | x | x | ─ | x | x
Rich et al., 1995^57^ | HV | Face-to-face | x | x | x | x | ─ | x | x
Stewart et al., 1998^51^ | HV | Face-to-face | x | ─ | ─ | x | ─ | ─ | ─
Jaarsma et al., 1999^47^ | HV | Face-to-face | x | ─ | x | x | ─ | x | ─
Stewart et al., 1999^50^ | HV | Face-to-face | x | x | ─ | x | x | ─ | ─
Kimmelstiel et al., 2004^53^ | HV | Face-to-face | x | x | x | x | ─ | x | ─
Naylor et al., 2004^55^ | HV | Face-to-face | x | x | x | x | ─ | ─ | x
Thompson et al., 2005^60^ | HV | Face-to-face | x | x | x | x | x | x | x
Aldamiz-Echevarría Iraúrgui et al., 2007^56^ | HV | Face-to-face | x | x | x | x | ─ | x | x
Holland et al., 2007^59^ | HV | Face-to-face | x | x | x | x | x | x | x
Kwok et al., 2008^54^ | HV | Face-to-face | x | ─ | x | x | x | ─ | x
Dunagan et al., 2005^68^ | STS | Telephone | x | x | x | x | x | | x
Lopez Cabezas et al., 2006^73^ | STS | Telephone | ─ | ─ | x | x | ─ | x | ─
Koelling et al., 2005^95^ | Edu | Face-to-face | X | x | x | x | x | ─ | ─

Author, Year | Category | Setting/ Timing of Education (Pre-d/c, Post-d/c or Both) | Transition Coach/ Case Management* | Coordination w/ Outpatient Provider While Inpatient | Individualized Discharge Plan | Planned Telephone Follow-up Post Discharge | Timing of First Telephone Follow-up (Days) | Series of Scheduled Calls | Patient Hotline | Timing of First Home Visit (Days) | Number of Scheduled Home Visits | Medication Reconciliation During Home Visit
Ducharme et al., 2005^89^ | MDS-HF | Post-d/c | ─ | ─ | ─ | x | ≤ 3 | x | ─ | ─ | ─ | ─
Liu et al., 2012^90^ | MDS-HF | Both | x | ─ | x | x | ≤ 7 | x | x | ─ | ─ | ─
Rich et al., 1993^58^ | HV | Both | x | x | x | As needed | ─ | x | <7 | >3 | x | x
Rich et al., 1995^57^ | HV | Both | x | x | x | As needed | ─ | x | <2 | >3 | x | x
Stewart et al., 1998^51^ | HV | Both | x | ─ | ─ | ─ | ─ | ─ | | < 7 | 1 | x
Jaarsma et al., 1999^47^ | HV | Both | ─ | ─ | x | x | ≤ 7 | ─ | x | < 7 | 1 | ─
Stewart et al., 1999^50^ | HV | Post-d/c | x | ─ | ─ | ─ | ─ | ─ | | > 7 | 1 | ─
Kimmelstiel et al., 2004^53^ | HV | Post-d/c | ─ | ─ | ─ | ─ | ─ | x | x | <7 | 1 | x
Naylor et al., 2004^55^ | HV | Both | x | x | x | ─ | ─ | ─ | x | < 1 | 8 | x
Thompson et al., 2005^60^ | HV | Both | x | ─ | ─ | ─ | ─ | ─ | x | > 7 | 1 | ─
Aldamiz-Echevarría Iraúrgui et al., 2007^56^ | HV | Post-d/c | ─ | ─ | ─ | ─ | ─ | ─ | x | < 2 | 2 to 3 | x
Holland et al., 2007^59^ | HV | Post-d/c | ─ | ─ | ─ | ─ | ─ | ─ | ─ | < 14 | 2 | x
Kwok et al., 2008^54^ | HV | Both | x | ─ | ─ | ─ | ─ | ─ | x | < 7 | 6 | x
Dunagan et al., 2005^68^ | STS | Post-d/c | ─ | ─ | ─ | x | ≤ 7 | x | x | ─ | ─ | ─
Lopez Cabezas et al., 2006^73^ | STS | Both | ─ | ─ | ─ | x | > 7 | x | x | ─ | ─ | ─
Koelling et al., 2005^95^ | Edu | Pre-d/c | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─

Author, Year | Category | Unspecified HF Education/ Promotion During Home Visit | Symptom Checklist or Clinical Assessment During Home Visit (e.g. History, Symptoms) | Physical Exam During Home Visit | Home Visiting Personnel Coordinates Care or Collaborates With Outpatient Provider | Timing of First Clinic Visit Post Discharge (Days) | Consultation With a Dietician | Clinic Personnel on-Call/ Available for Acute Symptom Management (Outside of Scheduled Appt) | Clinical Pharmacist Visit/ Consultation | Medication Optimization; Predischarge or During Intervention
Ducharme et al., 2005^89^ | MDS-HF | ─ | ─ | ─ | ─ | ≤ 14 | x | x | x | x
Liu et al., 2012^90^ | MDS-HF | ─ | ─ | ─ | ─ | ≤ 7 | x | x | ─ | x
Rich et al., 1993^58^ | HV | x | ─ | x | ─ | ─ | ─ | ─ | ─ | x
Rich et al., 1995^57^ | HV | x | ─ | x | ─ | ─ | ─ | ─ | ─ | x
Stewart et al., 1998^51^ | HV | x | ─ | | x | ─ | ─ | ─ | ─ | ─
Jaarsma et al., 1999^47^ | HV | x | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─
Stewart et al., 1999^50^ | HV | x | x | x | x | ─ | ─ | ─ | ─ | ─
Kimmelstiel et al., 2004^53^ | HV | x | x | | x | ─ | ─ | ─ | ─ | ─
Naylor et al., 2004^55^ | HV | x | x | ─ | x | ─ | ─ | ─ | ─ | ─
Thompson et al., 2005^60^ | HV | x | x | x | ─ | ─ | ─ | x | ─ | x
Aldamiz-Echevarría Iraúrgui et al., 2007^56^ | HV | x | x | x | ─ | ─ | ─ | ─ | ─ | x
Holland et al., 2007^59^ | HV | x | x | ─ | x | ─ | ─ | ─ | ─ | x
Kwok et al., 2008^54^ | HV | ─ | x | x | x | Unclear | ─ | ─ | ─ | x
Dunagan et al., 2005^68^ | STS | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─
Lopez Cabezas et al., 2006^73^ | STS | ─ | ─ | ─ | ─ | ≥ 14 | ─ | ─ | x | x
Koelling et al., 2005^95^ | Edu | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─

Note: x = this component was part of the study intervention. “─”= this component was not included in the intervention. appt = appointment; d/c = discharge; Edu = primarily educational; HV= home visits; MDS = multidisciplinary; MDS-HF = multidisciplinary heart failure; Med = medium; STS = structured telephone support; UC = usual care.

##### Shared Components of Home-Visiting and MDS-HF Clinic Interventions

Both home-visiting programs and MDS-HF clinic interventions are multicomponent, complex interventions. No single-component intervention (including predischarge only) reduced all-cause readmission rates. As a whole, these two categories of interventions shared the following components:

- HF education, emphasizing self-care, recognition of symptoms, and weight monitoring.
- HF pharmacotherapy, emphasizing patient education about medications; promotion of adherence to medication regimens; promotion of evidence-based HF pharmacotherapy before discharge or during followup (or both).
- Face-to-face contact following discharge: via home-visiting personnel, MDS-HF clinic personnel, or both. In most cases, this contact occurred within 7 days of discharge.
- Streamlined mechanisms to contact care delivery personal (clinic personnel or visiting nurses or pharmacists) outside of scheduled visits (e.g., patient hotline).
- Mechanisms for medication adjustment after discharge. In most cases, home-visiting personnel either directly recommended medication adjustment or assisted with coordination of care (e.g., with primary care provider or cardiologist) to facilitate timely medication adjustment, based on a patient's needs (rather than advising patients to call for help themselves).

##### Components of Individual Studies in Other Categories That Were Effective

Two STS trials reduced all-cause readmissions (Lopez Cabezas et al., 2006^73^ and Dunagan et al., 2005^68^); one other trial assessed a primarily nurse-based educational intervention that reduced the composite endpoint (Koelling et al., 2005).95 Table 14 also includes components of these interventions.

All three trials included a face-to-face inpatient education session before hospital discharge. Both STS trials had two additional components: promotion of medication adherence during scheduled calls and a patient hotline for questions or advice outside of scheduled calls. One STS trial also had the following components: nurse-directed diuretic adjustment during telephone followup; and flexibility of intervention based on patient need (e.g., 24 percent of patients received at least one home visit, and 24 percent were provided with a home bathroom scale).73 The educational session trial included an hour-long visit with a nurse educator that focused on the following: mechanism of action of HF medications, specific guidance on sodium and water restriction, and comprehensive guidance on self-care management (e.g., daily weight monitoring, smoking cessation, actions to take if symptoms worsened).95 In addition to the teaching session, patients receiving the intervention were given guidelines written in layman's terms.

#### Mortality

We found a wider range of intervention types that reduced mortality (as contrasted with the types of interventions that improved all-cause readmissions) within 6 months following an index hospital admission. Components of interventions that reduced mortality are summarized in Table 15.

Table 15 KQ 3—Components of effective interventions: Mortality

Author, Year | Category | Primary Mode of Delivery | Self-Care Management Education/ Promotion | Weight-Monitoring Education or Promotion | Diet/Sodium Restriction Education or Promotion | Promotion of Medication Adherence | Exercise Education or Promotion | Other or Unspecified HF Education | Medication Reconciliation
Kasper et al., 2002^87^ | MDS-HF | Face-to-face | x | ─ | ─ | ─ | ─ | x | ─
Ducharme et al., 2005^89^ | MDS-HF | Face-to-face | x | x | x | x | ─ | x | x
Liu et al., 2012^90^ | MDS-HF | Face-to-face | x | ─ | ─ | x | ─ | ─ | x
Rich et al., 1993^58^ | HV | Face-to-face | x | x | x | x | ─ | x | x
Rich et al., 1995^57^ | HV | Face-to-face | x | x | x | x | ─ | x | x
Stewart et al., 1998^51^ | HV | Face-to-face | x | ─ | ─ | x | ─ | ─ | ─
Jaarsma et al., 1999^47^ | HV | Face-to-face | x | ─ | x | x | ─ | x | ─
Stewart et al., 1999^50^ | HV | Face-to-face | x | x | ─ | x | x | ─ | ─
Kimmelstiel et al., 2004^53^ | HV | Face-to-face | x | x | x | x | ─ | x | ─
Naylor et al., 2004^55^ | HV | Face-to-face | x | x | x | x | ─ | ─ | x
Thompson et al., 2005^60^ | HV | Face-to-face | x | x | x | x | x | x | x
Aldamiz-Echevarría Iraúrgui et al., 2007^56^ | HV | Face-to-face | x | x | x | x | ─ | x | x
Holland et al., 2007^59^ | HV | Face-to-face | x | x | x | x | x | x | x
Kwok et al., 2008^54^ | HV | Face-to-face | x | ─ | x | x | x | ─ | x
Rainville et al., 1999^71^ | STS | Telephone | ─ | x | ─ | x | ─ | x | ─
Riegel et al., 2002^63^ | STS | Telephone | x | ─ | x | x | ─ | x | x
Dunagan et al., 2005^68^ | STS | Telephone | x | x | x | x | x | | x
Lopez Cabezas et al., 2006^73^ | STS | Telephone | ─ | ─ | x | x | ─ | x | ─
Riegel et al., 2006^64^ | STS | Telephone | x | | x | x | ─ | x | ─
Wakefield et al., 2008^69^ Wakefield et al., 2009^75^ | STS | Telephone | x | x | x | x | ─ | ─ | ─
Wakefield et al., 2008^69^ Wakefield et al., 2009^75^ | STS | Video-phone | x | x | x | x | ─ | ─ | ─
Angermann et al., 2012^66^ | STS | Telephone | x | x | x | x | x | x | ─
Davis et al., 2012 | Other | Face-to-face | x | x | x | x | ─ | ─ | ─
Stromberg et al., 2003^88^ | Clinic (nurse) | Face-to-face | x | x | x | x | ─ | ─ | ─
Goldberg et al., 2003^79^ | TM | TM | x | x | x | ─ | ─ | ─ | ─

Author, Year | Category | Setting/ Timing of Education (Pre-d/c, Post-d/c or Both) | Transition Coach or Coordination Between Inpatient/ Outpatient Providers | Planned Telephone Followup After Discharge | Timing of First Phone or TM Followup (Days) | Telephone Followup Conducted by Same Personnel Delivering Inpatient Intervention Component | Series of Structured Calls | Patient Hotline (e.g. Patients Can Call Anytime for Help) | Timing of First Clinic Visit After Discharge | Consult With Nut-Rationist | Clinic Personnel On-Call/ Available for Outside of Clinic Hours | Outpatient Clinical Pharmacist Visit
Kasper et al., 2002^87^ | MDS-HF | x | x | ─ | ─ | ─ | ─ | x | ─ | ─ | ─ | ─
Ducharme et al., 2005^89^ | MDS-HF | Post-d/c | ─ | x | ≤ 3 | ─ | x | ─ | ≤ 14 | x | x | x
Liu et al., 2012^90^ | MDS-HF | Both | x | x | ≤ 7 | Unclear | x | x | ≤ 7 | x | x | ─
Rich et al., 1993^58^ | HV | Both | x | As needed | ─ | ─ | x | <7 | ─ | ─ | ─ | ─
Rich et al., 1995^57^ | HV | Both | x | As needed | ─ | ─ | x | <2 | ─ | ─ | ─ | ─
Stewart et al., 1998^51^ | HV | Both | x | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─
Jaarsma et al., 1999^47^ | HV | Both | ─ | x | ≤ 7 | ─ | ─ | x | ─ | ─ | ─ | ─
Stewart et al., 1999^50^ | HV | Post-d/c | x | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─
Kimmelstiel et al., 2004^53^ | HV | Post-d/c | ─ | ─ | ─ | ─ | x | x | ─ | ─ | ─ | ─
Naylor et al., 2004^55^ | HV | Both | x | ─ | ─ | ─ | ─ | x | ─ | ─ | ─ | ─
Thompson et al., 2005^60^ | HV | Both | x | ─ | ─ | ─ | ─ | x | ─ | ─ | x | ─
Aldamiz-Echevarría Iraúrgui et al., 2007^56^ | HV | Post-d/c | ─ | ─ | ─ | ─ | ─ | x | ─ | ─ | ─ | ─
Holland et al., 2007^59^ | HV | Post-d/c | | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─
Kwok et al., 2008^54^ | HV | Both | x | ─ | ─ | ─ | ─ | x | Unclear | ─ | ─ | ─
Rainville et al., 1999^71^ | STS | Both | x | x | ≤ 2 | x | x | x | ─ | ─ | ─ | ─
Riegel et al., 2002^63^ | STS | Post-d/c | ─ | x | ≤ 7 | ─ | x | ─ | ─ | ─ | ─ | ─
Dunagan et al., 2005^68^ | STS | Post-d/c | ─ | x | ≤ 7 | ─ | x | x | ─ | ─ | ─ | ─
Lopez Cabezas et al., 2006^73^ | STS | Both | ─ | x | > 7 | x | x | x | ─ | ─ | ─ | x
Riegel et al., 2006^64^ | STS | Post-d/c | ─ | x | ≤ 7 | ─ | x | ─ | ─ | ─ | ─ | ─
Wakefield et al., 2008^69^ Wakefield et al., 2009^75^ | STS | Both | ─ | x | ≤ 7 | ─ | x | x | ─ | ─ | ─ | ─
Wakefield et al., 2008^69^Wakefield et al., 2009^75^ | STS | Both | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─
Angermann et al., 2012^66^ | STS | Both | x | x | ≤ 7 | x | x | x | ─ | ─ | ─ | ─
Davis et al., 2012 | STS | Both | ─ | x | ≤ 7 | x | ─ | ─ | ─ | ─ | ─ | ─
Stromberg et al., 2003^88^ | Clinic (nurse) | Post-d/c | ─ | ─ | ─ | ─ | ─ | ─ | >14 | x | x | x
Goldberg et al., 2003^79^ a | TM | Pre-d/c | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─ | ─

a Telemonitoring components also included: first telehealth contact >7 days after discharge, telemonitoring device included an automated adherence reminder, transmitted vital signs and symptoms, and service coordinated care with outpatient provider(s).

Note: x = this component was part of the study intervention. “─”= this component was not included in the intervention.

d/c = discharge; HF = heart failure; MDS = multidisciplinary; MDS-HF = multidisciplinary heart failure; Med = Medium; Pharm = pharmacist; STS = structured telephone support; TM = telemonitoring.

##### Shared Components of Structured Telephone Support and MDS Clinic Interventions

As with all-cause readmission, STS and MDS clinic interventions are multicomponent. No single-component intervention reduced mortality. As a whole, these two categories of interventions shared the following components:

- HF education, emphasizing self-care, recognition of symptoms, and weight monitoring.
- A series of scheduled, structured visits (via telephone, home visits, or clinic followup) that reinforced education and monitored for HF symptoms.
- A mechanism to contact providers easily outside of scheduled visits (e.g., patient hotline).

##### Components of Individual Studies in Other Categories That Were Effective

Three trials from other categories showed efficacy in reducing mortality: one telemonitoring trial,79 one study of cognitive training in HF patients with cognitive dysfunction,97 and one nurse-led HF clinic intervention.88 These intervention types involved different sets of components, but all focused on transitioning self-care management back to the patient. Components included giving inpatient education training on self-care;97 implementing a series of nurse-led clinic visits featuring self-care education, training, and monitoring;88 or encouraging daily weights and response to symptom questions via telemonitoring.79 To some degree, all three interventions involved flexibility to individualize care (e.g., by coordinating with the patient's physician79 or individualizing self-care training88,97). The telemonitoring trial specified that coordination of care with the patient's outpatient provider was a component of the intervention.79

### KQ 3b Necessity of Particular Components in Effective Interventions

Given the heterogeneity of interventions, we had insufficient detail across all interventions to determine whether certain components are necessary beyond what was addressed in KQ 3a. One intervention that reduced the composite outcome was delivered during the index hospitalization; no components were delivered after discharge.95 In all other cases, efficacious interventions were delivered either both before and after discharge or in the postdischarge setting.

For all-cause readmissions (and the composite endpoint), four elements seem to be necessary. They are (1) education focused on self-care (delivered face-to-face); (2) early contact following discharge (e.g., home visit or outpatient followup); (3) a mechanism for patients to contact intervention personnel easily for problems or symptoms (e.g., availability of a patient hotline); and (4) flexibility in the intervention that allows tailoring the intervention to patient's needs (e.g., early adjustment of medications based on symptoms)

That these seem “necessary” for demonstrated utility in affecting key outcomes does not mean that they are “sufficient,” certainly not as single components.

For mortality, including training or reinforcement on self-care (e.g., daily weights) and reinforcing these skills over time both seem necessary. Like interventions that reduced all-cause readmissions, interventions that reduced mortality rates included instructions (or a patient hotline) on who and when to call when symptoms worsen.

### KQ 3c Benefits of Particular Components in Multicomponent Interventions

We did not find any direct evidence to determine whether specific components add benefit. That is, no trials directly compared the delivery of an intervention having a specific component with the same intervention but lacking that specific component. When we attempted to use indirect evidence, the diversity of components in the interventions across categories (and within intervention categories) limited our ability to isolate specific factors that added benefit. Separating out individual components from the overall type (or “bundles”) of interventions that showed efficacy (KQs 1 and 2) was not possible.

## KQ 4 Intensity, Delivery Personnel, Method of Communication

To assess whether the efficacy of interventions varied based on intensity, delivery personnel, or method of communication, we assessed variation both across and within intervention categories (when variation was present). We did not pool trials in a meta-analysis from different intervention categories to assess the impact of these variables because many other factors (e.g., different intervention components) differed too much across categories.

For the KQ 4 analyses, we used trials in our main analyses for either of the two primary outcomes (all-cause readmission and mortality)—i.e., trials rated as medium or low risk of bias. Appendix C (Tables C1-C13) describes the subquestions of interest: intensity, primary delivery personnel, and method of communication for these trials. For some categories of interventions, variation was insufficient within categories or we had too few trials to conduct any meaningful stratified analyses. These limitations differed by subquestion; for each subquestion below, we address only the intervention categories with sufficient variation or sufficient number of trials to assess whether efficacy differed by these factors.

### Key Points: Intensity

- In general, intervention categories that included higher-intensity interventions (i.e., home-visiting programs, STS, MDS-HF clinic interventions) reduced all-cause readmission or mortality. By contrast, categories with lower-intensity interventions (i.e., primarily educational interventions, nurse-led HF clinic interventions) did not affect these two outcomes in any meaningful way.
- Within categories, subgroup analyses found that higher intensity home-visiting programs reduced all-cause readmission at 30 days, whereas lower intensity programs did not (low SOE). STS interventions had no significant differences based on intensity. Subgroup analyses were not possible for other categories of interventions because of either lack of variation or too few trials reporting outcomes at similar time points.

### Key Points: Delivery Personnel

- The two categories of interventions that reduced all-cause readmission and mortality—home-visiting programs and MDS-HF clinic interventions—were more likely to include teams of providers delivering the intervention (e.g., home visits conducted by a nurse and pharmacist together). STS interventions reduced mortality (but not all-cause readmission); primarily nurses or pharmacists delivered STS interventions (and not teams of providers).
- Within categories, evidence was insufficient to make definitive conclusions about whether specific delivery personnel had more (or less) impact in reducing all-cause readmissions or mortality.

### Key Points: Method of Communication

- Across intervention categories, interventions were delivered primarily face-to-face or via technology (telephone, telemonitoring, video visits). The two categories of interventions delivered primarily face-to-face did reduce all-cause readmissions—namely, home-visiting programs and MDS-HF clinic interventions. For these two categories, method of delivery did not vary within each category. STS showed efficacy in reducing mortality; some of these interventions included a face-to-face component (e.g., predischarge educational intervention). In general, interventions delivered primarily remotely (i.e., telemonitoring, STS) did not reduce all-cause readmissions.
- Only STS interventions varied in their method of communication. Our subgroup analyses for reducing either all-cause readmission or mortality found no significant differences by method of communication at any time point.

### Detailed Synthesis

#### KQ 4a Intensity

For most interventions, we defined intensity as the duration, frequency, or periodicity of patient contact, and we categorized each intervention as low, medium, or high intensity. Given the heterogeneity of intensity across included interventions; however, we were unable to develop a single measure of intensity to apply to trials across all intervention categories.

We considered resource use as a dimension of intensity. For example, we included factors such as the total number of intervention components in the determination of intensity. We reserved the low-intensity category for interventions that included one episode of patient contact or that required few resources (e.g., no additional components, such as time spent coordinating care). We considered the majority of interventions to be of medium or high intensity; most were multicomponent and included repeated patient contacts.

##### Intensity Across Intervention Categories

Certain categories (as a whole) are higher intensity than others. The MDS-HF clinic interventions were all classified as high intensity. Two categories included no trials classified as high intensity: primarily educational interventions and trials in the “other” category. Trials involving home-visiting interventions and STS included a mix of medium- and high-intensity interventions. Overall, the home-visiting category included more trials classified as high intensity (five of six interventions) than the STS category (four of six).

Our meta-analysis (KQs 1 and 2) showed that trials involving higher-intensity interventions (i.e., home-visiting programs, STS, MDS-HF clinic interventions) reduced all-cause readmissions or mortality. By contrast, trials with lower-intensity interventions (i.e., primarily educational interventions, nurse-led HF clinic interventions) did not.

##### Intensity Within Intervention Categories

###### Home-Visiting Programs

Table 16 displays the intensity, delivery personnel, and method of communication for the 11 trials that we rated as either low or medium risk of bias (listed in chronological order). All were multicomponent, relatively complex interventions. We used the number of home visits (one visit or a series of visits) and the inclusion of other components (e.g., predischarge educational session, individualized discharge planning) to determine whether interventions were of medium or high intensity. We classified five as high intensity and six as medium intensity.

Table 16 Intensity, delivery personnel, and method of communication in trials assessing home-visiting programs compared with usual care

Author, Year | Intensity | Delivery Personnel | Method of Communication
Rich et al., 1993^58^ | High | Multidisciplinary | Face-to-face
Rich et al., 1995^57^ | High | Multidisciplinary | Face-to-face
Stewart et al., 1998^51^ | Medium | Multidisciplinary | Face-to-face
Jaarsma et al., 1999^47^ | Medium | Nurse | Face-to-face
Stewart et al., 1999 50 | Medium | Nurse | Face-to-face
Pugh et al., 2001^52^ | Medium | Nurse | Face-to-face
Kimmelstiel et al., 2004^53^ | Medium | Nurse | Face-to-face
Naylor et al., 2004^55^ | High | Nurse | Face-to-face
Aldamiz-Echevarría Iraúrgui et al., 2007^56^ | High | Multidisciplinary | Face-to-face
Holland et al., 2007^59^ | Medium | Pharmacist | Face-to-face
Kwok et al., 2007^54^ | High | Nurse | Face-to-face

###### All-Cause Readmissions

Eight trials reported all-cause readmission rates; among these, we rated five as high intensity54-58 and three as medium intensity.47,51,59 Higher-intensity home-visiting programs reduced all-cause readmissions at 30 days; lower-intensity interventions did not (Appendix E). This issue is also discussed in KQ 1. At measurements over 3 to 6 months, our analysis stratified by intensity found no significant difference between high-intensity and medium-intensity approaches (Appendix E). Our ability to draw definitive conclusions about impacts over 3 to 6 months is limited by lack of precision (wide and overlapping CIs); too few trials reported outcomes at the same time point to permit us to assess adequately whether efficacy of home-visiting programs differed by intensity.

###### Mortality

Eight trials reported mortality, among these, we rated four as high intensity54-57 and four as medium intensity.50,51,53,59 Intensity did not differ at any outcome time point (Appendix E). As with all-cause readmissions, however, lack of precision (wide and overlapping CIs) limited our ability to draw any definitive conclusions.

###### Structured Telephone Support

Table 17 displays the intensity, delivery personnel, and method of communication for 10 STS trials that we rated as low or medium risk of bias (chronological order). Determining whether trials varied sufficiently in the periodicity or frequency of telephone support was difficult. Trials included similar numbers of planned telephone calls at each time point (e.g., weekly for 1 month following hospitalization, then biweekly for 2 months or 3 months). Often, interventions specified that calls could occur more frequently based on need or the availability of a patient hotline for questions or concerning symptoms.

Table 17 Intensity, delivery personnel, and method of communication in trials assessing structured telephone support compared with usual care

Author, Year | Intensity | Delivery Personnel | Method of Communication
Rainville et al., 1999 71 | Medium | Pharmacist | Telephone; Face-to-face
Riegel et al., 2002^63^ | Medium | Nurse | Telephone
Laramee et al., 2003^65^ | High | Non-nurse case manager | Telephone; Face-to-face
Tsuyuki et al., 2004^72^ | High | Nurse | Telephone
Dunagan et al., 2005^68^ | High | Nurse | Telephone
Cabezas et al., 2006^73^ | Medium | Pharmacist | Telephone; Face-to-face
Riegel et al., 2006^64^ | Medium | Nurse | Telephone
Wakefield et al., 2008^69^ Wakefield et al., 2009^75^ | Medium | Nurse | Group 1: Telephone Group 2: Videophone
Domingues et al., 2011^67^ | Low | Nurse | Telephone
Angermann et al., 2012^66^ | High | Nurse | Telephone; Face-to-face

Whether interventions included additional components other than STS also varied across these trials (e.g., intensive inpatient education). When interventions included STS and additional components that required face-to-face contact with patients or time spent coordination of care with a clinician in response to a patient's symptoms, we classified those interventions as high intensity (four trials).65,66,68,72 We rated one trial as low intensity; it included a series of telephone calls (<8 per person over 3 months) with no other components (e.g., no care coordination or face-to-face contact).67 The remaining interventions were considered medium intensity.

###### All-Cause Readmissions

As reported for KQ 1, STS interventions did not decrease all-cause readmission at any time point. Our analysis stratified by intensity found no significant difference between in high-intensity and medium-intensity trials at any point (Appendix E). Confidence intervals were wide and overlapped in all cases.

###### Mortality

Reductions in mortality rates did not differ between high-intensity and medium-intensity trials at any time point (Appendix E). Confidence intervals were wide and overlapped in all cases.

###### Telemonitoring

Table 18 displays the intensity, delivery personnel, and method of communication for four trials that we rated low or medium risk of bias. Intensity varied little across these trials; we considered two as high intensity and two as medium intensity. The two high-intensity trials involved components other than remote monitoring alone; one used both video visits and remote monitoring,80 and one included an individualized weight goal along with direct communication with a clinician when the patient fell outside of his or her normal weight range.79 Three trials reported all-cause readmissions (number of people readmitted);78,80,82 three trials reported data on mortality.78-80 Because of lack of precision and little variation in intensity, meaningful subgroup analyses were not possible.

Table 18 Intensity, delivery personnel, and method of communication in trials assessing telemonitoring compared with usual care

Author, Year | Intensity | Delivery Personnel | Method of Communication
Goldberg et al., 2003^79^ | High | Nurse | Remote monitoring
Schwarz et al., 2008^78^ | Medium | Nurse | Remote monitoring
Dar et al., 2009^80^ | High | Nurse | Remote monitoring
Pekmezaris et al., 2012^82^ | Medium | Nurse | Video visits

###### Outpatient Clinic-Based Interventions

Given heterogeneity among the clinic-based interventions, we pooled data separately in KQ 1 and KQ 2 for MDS-HF clinic interventions, nurse-led HF clinic interventions, and the primary care clinic intervention. These categories directly matched stratification by intensity, delivery personnel, and method of communication. Therefore, we did not conduct new analyses to stratify interventions by these factors.

In terms of intensity, we considered MDS-HF clinic interventions to be high intensity and the nurse-led and primary care interventions medium intensity. We determined intensity primarily on resource use (e.g., planned contact with multiple providers in a specialty clinic during each patient visit). The periodicity or frequency of clinic visits did not vary in any clear ways; most interventions increased clinic visit frequency based on a patient's need (i.e., they were tailored based on clinical status) in addition to planned visits.

###### All-Cause Readmissions

As described in KQ 1, high-intensity MDS-HF interventions reduced all-cause readmission at 6 months. The medium-intensity nurse-led HF clinic83 and the primary care clinic intervention91 did not.

###### Mortality

As described in KQ 2, both of the high-intensity MDS-HF interventions and one medium-intensity nurse-led HF intervention reduced mortality at 6 months. The primary care clinic based intervention did not.

###### Primarily Educational Interventions

Table 19 displays the intensity, delivery personnel, and method of communication for the two trials rated as low or medium risk of bias. Two primarily educational interventions reported mortality; we rated one as low intensity95 and the other as medium intensity.93 Both assessed inpatient educational interventions; the trial by Nucifora et al. included additional components (e.g., telephone contact following discharge to reinforce education).93 One trial reported on all-cause readmissions; both reported mortality at 6 months.

Table 19 Intensity, delivery personnel, and method of communication in trials assessing primarily educational interventions compared with usual care

Author, Year | Intensity | Delivery Personnel | Method of Communication
Koelling et al., 2005^95^ | Low | Nurse | Face-to-face
Nucifora et al., 2006^93^ | Medium | Nurse | Face-to-face

Our meta-analysis of these two trials showed that neither intervention reduced mortality. Lack of precision (wide and overlapping CIs) and different lengths of followup limited our ability to draw definitive conclusions.

#### KQ 4b Delivery Personnel

##### Delivery Personnel Across Intervention Categories

Nurses or MDS teams were the primary personnel for most interventions; pharmacists delivered a few home-visiting and STS interventions. The two categories of interventions that reduced all-cause readmissions (home-visiting; MDS-HF clinic) were more likely to use teams of clinicians to deliver the interventions (e.g., home visits conducted by a nurse and pharmacist together). For mortality, the efficacious intervention categories varied in primary delivery personnel. MDS-HF clinic interventions (delivered by MDS teams) and STS interventions (delivered primarily by nurses or pharmacists) both reduced mortality.

##### Delivery Personnel Within Intervention Categories

###### Home-Visiting Programs

Table 16 (above) listed the included 11 home-visiting trials and delivery personnel. When more than one delivery person was involved in a major intervention component, we considered home-visiting interventions to be MDS (e.g., physician accompanies nurse on home visit or adjusts medications before discharge). We considered four interventions to be delivered primarily by MDS teams.51,56-58 A pharmacist delivered one intervention;59 primarily nurses delivered the interventions in the remaining trials.

###### All-Cause Readmissions

Seven trials reported all-cause readmission rates. At 30 days, variation was insufficient to determine whether delivery personnel influenced reductions in all-cause readmission. Over 3 to 6 months, our subgroup analyses found no significant difference by delivery personnel (Appendix E). However, lack of precision and disparity in when outcomes were measured limited our ability to draw definitive conclusions.

###### Mortality

Seven home-visiting trials reported mortality. At 30 days, variation at 30 days was insufficient to determine whether delivery personnel influenced reductions in mortality. Over 3 to 6 months, our subgroup analysis found no significant differences by delivery personnel (Appendix E).

###### Structured Telephone Support

Table 17 (above) listed the 10 included trials and delivery personnel. Nurses conducted the majority of STS interventions. Pharmacists conducted two interventions,71,73 and a non-nurse case manager delivered one.65

###### All-Cause Readmissions

Among trials assessing STS interventions, our subgroup analysis found no difference in all-cause readmission by delivery personnel (Appendix E). Delivery personnel did not vary much at each time point; confidence intervals were wide and overlapped. Overall, of 10 trials, two trials found a statistically significant reduction in all-cause readmissions: one intervention was delivered by a nurse68 and one was delivered by a pharmacist.73

###### Mortality

Mortality rates did not differ by delivery personnel (Appendix E). Delivery personnel varied little at each time point (Appendix E).

###### Clinic-Based Interventions

The MDS-HF interventions included a range of clinicians who had contact with patients during clinic visits. The nurse-led interventions primarily involved education and symptom monitoring from nurses. The primary-care intervention involved increased access to a primary care clinic, including contact with a primary care physician and clinic nurse.

###### All-Cause Readmissions

As described in KQ 1, the MDS-HF interventions did reduce all-cause readmissions at 6 months. Neither the nurse-led83 nor the primary care intervention91 decreased readmissions.

###### Mortality

As described in KQ 2, both the MDS-HF interventions and one of the nurse-led interventions reduced mortality at 6 months. The medium-intensity primary care intervention did not reduce mortality.

#### KQ 4c Method of Communication

##### Method of Communication Across Intervention Categories

Across intervention categories, interventions were delivered primarily face-to-face or via technology (telephone, telemonitoring, video visits). Home-visiting programs and MDS-HF interventions, which are delivered primarily face-to-face, reduced all-cause readmissions; for these two categories, method of delivery did not vary within each category. STS also reduced mortality; some of the STS interventions included a face-to-face component (e.g., an educational intervention before discharge). In general, interventions primarily delivered remotely (i.e., telemonitoring, STS) were not efficacious in reducing all-cause readmission rates.

##### Method of Communication Within Intervention Categories

Only STS interventions varied in their method of communication. Other categories did not differ materially in their primary method of communication. STS interventions were delivered primarily via a series of structured calls to patients. Four STS interventions also had a face-to-face intervention (usually education before discharge).65,66,71,73 Efficacy for either all-cause readmission or mortality did not differ among trials with a face-to-face component compared with those with primarily the telephone contact (Appendix E); CIs were wide and overlapped. Lack of precision (wide, overlapping CIs) and dissimilar points for measuring outcomes limited our ability to draw definitive conclusions.

One STS intervention directly compared two modes of delivery: standard telephone support and videophone (without telemonitoring technology), along with usual care. All-cause readmission did not differ in the three groups over 3 to 6 months.69

## KQ 5 Subgroups

This KQ evaluated whether transitional care interventions differed in either benefits or harms for subgroups of patients. For this question, we searched for subgroup analyses reported by individual trials that focused on whether a particular intervention had more (or less) efficacy in reducing readmissions or mortality based on patient age, sex, race, ethnicity, socioeconomic status, disease severity (left ventricular ejection fraction or NYHA classification), or coexisting conditions.

### Key Points

- Two trials, one home-visiting program and one primarily educational intervention, reported readmission rates for subgroups of patients
- No trial reported on mortality by subgroups.

### Detailed Synthesis

#### Home-Visiting Programs

Rich and colleagues categorized patients as being at low, moderate, or high risk for readmission.58 They used a combination of markers of disease severity and coexisting conditions: four or more prior hospitalizations within 5 years of randomization, previous history of HF, hypocholesterolemia (total cholesterol <150 mg/dL), and right bundle-branch block on the admitting electrocardiogram. Patients with none of these factors were considered low risk and excluded from the study; patients with one risk factor were considered moderate risk; those with two or more risk factors were considered to be at high risk for readmission.

Among the moderate-risk subgroup, fewer people receiving home visits were readmitted than people not receiving home visits (27.5 percent versus 47.6 percent; p=0.10). Among the high-risk subgroup, the percentage of patients readmitted over 90 days did not differ between the intervention and control groups (43.5 percent versus 42.9 percent; p-value NS).

#### Primarily Educational Interventions

One trial assessing a 1-hour, face-to-face inpatient educational session reported the relative risk of a composite endpoint—all-cause readmission or death at 6 months—for patient subgroups based on age, sex, race, or presence of coronary disease.95 The p-values for relative risks were not significant for each comparison (age ≥ 65 versus < 65; sex; black versus white race; presence versus absence of coronary disease).95