# References

1 Centers for Medicare & Medicaid Service, Office of Information Services (OIS). Medicare Ranking for All Short-Stay Hospitals by Discharges. Fiscal Year 2005 Versus 2004. 2006. www.cms.hhs.gov/MedicareFeeforSvcPartsAB/Downloads/SSDischarges0405.pdf. December 18, 2012.
2 Jencks SF, Williams MV, Coleman EA. Rehospitalizations among patients in the Medicare fee-for-service program. N Engl J Med. Apr. 2. 2009;360(14):1418-28. Epub: 2009/04/03. [pmid: 19339721].
3 Bernheim SM, Grady JN, Lin Z, et al. National patterns of risk-standardized mortality and readmission for acute myocardial infarction and heart failure. Update on publicly reported outcomes measures based on the 2010 release. Circ Cardiovasc Qual Outcomes. Sep. 2010;3(5):459-67. Epub: 2010/08/26. [pmid: 20736442].
4 Bueno H, Ross JS, Wang Y, et al. Trends in length of stay and short-term outcomes among Medicare patients hospitalized for heart failure, 1993-2006. JAMA. Jun. 2. 2010;303(21):2141-7. Epub: 2010/06/03. [pmid: 20516414].
5 Dharmarajan K, Hsieh AF, Lin Z, et al. Diagnoses and timing of 30-day readmissions after hospitalization for heart failure, acute myocardial infarction, or pneumonia. JAMA. Jan. 23. 2013;309(4):355-63. Epub: 2013/01/24. [pmid: 23340637].
6 Allen LA, Tomic KE, Smith DM, et al. Rates and predictors of 30-day readmission among commercially insured and Medicaid-enrolled patients hospitalized with systolic heart failure. Circ Heart Fail. Nov. 1. 2012;5(6):672-9. Epub: 2012/10/18. [pmid: 23072736].
7 Naylor MD, Aiken LH, Kurtzman ET, et al. The care span: the importance of transitional care in achieving health reform. Health Aff (Millwood). Apr. 2011;30(4):746-54. Epub: 2011/04/08. [pmid: 21471497].
8 Stauffer BD, Fullerton C, Fleming N, et al. Effectiveness and cost of a transitional care program for heart failure: a prospective study with concurrent controls. Arch Intern Med. Jul. 25. 2011;171(14):1238-43. Epub: 2011/07/27. [pmid: 21788541].
9 Centers for Medicare & Medicaid Services. Readmissions Reduction Program. August. 2. 2013. www.cms.gov/Medicare/Medicare-Fee-for-Service-Payment/AcuteInpatientPPS/Readmissions-Reduction-Program.html. September 6, 2013.
10 Roger VL, Go AS, Lloyd-Jones DM, et al. Heart disease and stroke statistics--2012 update: a report from the American Heart Association. Circulation. Jan. 3. 2012;125(1):e2-e220. Epub: 2011/12/20. [pmid: 22179539].
11 Heidenreich PA, Trogdon JG, Khavjou OA, et al. Forecasting the future of cardiovascular disease in the United States: a policy statement from the American Heart Association. Circulation. Mar. 1. 2011;123(8):933-44. Epub: 2011/01/26. [pmid: 21262990].
12 Lloyd-Jones DM, Larson MG, Leip EP, et al. Lifetime risk for developing congestive heart failure: the Framingham Heart Study. Circulation. Dec. 10. 2002;106(24):3068-72. Epub: 2002/12/11. [pmid: 12473553].
13 Kalogeropoulos A, Georgiopoulou V, Kritchevsky SB, et al. Epidemiology of incident heart failure in a contemporary elderly cohort: the health, aging, and body composition study. Arch Intern Med. Apr. 13. 2009;169(7):708-15. Epub: 2009/04/15. [pmid: 19365001].
14 Roger VL, Weston SA, Redfield MM, et al. Trends in heart failure incidence and survival in a community-based population. JAMA. Jul. 21. 2004;292(3):344-50. Epub: 2004/07/22. [pmid: 15265849].
15 Levy D, Kenchaiah S, Larson MG, et al. Long-term trends in the incidence of and survival with heart failure. N Engl J Med. Oct. 31. 2002;347(18):1397-402. Epub: 2002/11/01. [pmid: 12409541].
16 Chen J, Normand SL, Wang Y, et al. National and regional trends in heart failure hospitalization and mortality rates for Medicare beneficiaries, 1998-2008. JAMA. Oct. 19. 2011;306(15):1669-78. Epub: 2011/10/20. [pmid: 22009099].
17 Kociol RD, Peterson ED, Hammill BG, et al. National survey of hospital strategies to reduce heart failure readmissions: findings from the Get With the Guidelines-Heart Failure registry. Circ Heart Fail. Nov. 1. 2012;5(6):680-7. Epub: 2012/08/31. [pmid: 22933525].
18 Goldfield NI, McCullough EC, Hughes JS, et al. Identifying potentially preventable readmissions. Health Care Financ Rev. Fall. 2008;30(1):75-91. Epub: 2008/12/02. [pmid: 19040175].
19 Medicare Payment Advisory Committee (MedPAC). Report to the Congress: Promoting Greater Efficiency in Medicare. June. 2007. www.medpac.gov/documents/Jun07_EntireReport.pdf.
20 Konstam MA. Home monitoring should be the central element in an effective program of heart failure disease management. Circulation. Feb. 14. 2012;125(6):820-7. Epub: 2012/02/15. [pmid: 22331919].
21 Krumholz HM. Post-hospital syndrome--an acquired, transient condition of generalized risk. N Engl J Med. Jan. 10. 2013;368(2):100-2. Epub: 2013/01/11. [pmid: 23301730].
22 Krumholz HM, Lin Z, Keenan PS, et al. Relationship between hospital readmission and mortality rates for patients hospitalized with acute myocardial infarction, heart failure, or pneumonia. JAMA. 2013;309(6):587-93. [pmid: 23403683].
23 Naylor MD, Kurtzman ET, Grabowski DC, et al. Unintended consequences of steps to cut readmissions and reform payment may threaten care of vulnerable older adults. Health Aff (Millwood). July. 1. 2012;31(7):1623-32. [pmid: 22722702].
24 Coleman EA, Boult C. Improving the quality of transitional care for persons with complex care needs. J Am Geriatr Soc. Apr. 2003;51(4):556-7. Epub: 2003/03/27. [pmid: 12657079].
25 Jessup M, Abraham WT, Casey DE, et al. 2009 focused update: ACCF/AHA Guidelines for the Diagnosis and Management of Heart Failure in Adults: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines: developed in collaboration with the International Society for Heart and Lung Transplantation. Circulation. Apr. 14. 2009;119(14):1977-2016. Epub: 2009/03/28. [pmid: 19324967].
26 Agvall B, Alehagen U, Dahlstrom U. The benefits of using a heart failure management programme in Swedish primary healthcare. Eur J Heart Fail. Feb. 2013;15(2):228-36. Epub: 2012/10/31. [pmid: 23109650].
27 Lindenfeld J, Albert NM, Boehmer JP, et al. Executive Summary: HFSA 2010 Comprehensive Heart Failure Practice Guideline. J Card Fail. Jun. 2010;16(6):475-539.
28 The Joint Commission. A Comprehensive Review of Development and Testing for National Implementation of Hospital Core Measures. Oak Brook Terrace, IL. 2010. November. www.jointcommission.org/accreditation/accreditation_main.aspx. February 14, 2014.
29 Bonow RO, Ganiats TG, Beam CT, et al. ACCF/AHA/AMA-PCPI 2011 performance measures for adults with heart failure: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Performance Measures and the American Medical Association-Physician Consortium for Performance Improvement. Circulation. May. 15. 2012;125(19):2382-401. Epub: 2012/04/25. [pmid: 22528524].
30 Medicare Payment Advisory Commission. Report to the Congress: promoting greater efficiency in Medicare. Medicare Payment Advisory Commission. Washington, DC. 2007. http://unc.summon.serialssolutions.com/link/0/eLvHCXMwTV3LCsJADFwEwYuXgu7VH9hit_vKtdIiKCJSpdd9Hgti_x_TVcFbcgskzDB5EEJ2jgebpBUiIJ3NgymuAFnICGc817mf-2jq80m3jej_0LwryCKOG3Lv2v5wZN9nAMxy2ANzCYkk1KhGJJpKxhSRnE1SwcRoBaDQcpVwMqnkIdlKei2kBh65cV5bWW3J2s5L4-OUj8sCJcuEGY50Rl2KEVCyGoDfLgNcP27xc8tXvoAqnxNFkM8FwqpSvgEFdjj2.
31 Takeda A, Taylor SJ, Taylor RS, et al. Clinical service organisation for heart failure. Cochrane Database Syst Rev. 2012;(9):CD002752. Epub: 2012/09/14. [pmid: 22972058].
32 Inglis SC, Clark RA, Cleland JG. Telemonitoring in patients with heart failure. N Engl J Med. Mar. 17. 2011;364(11):1078-9. [pmid: 21410377].
33 Hansen LO, Young RS, Hinami K, et al. Interventions to reduce 30-day rehospitalization: a systematic review. Ann Intern Med. Oct. 18. 2011;155(8):520-8. Epub: 2011/10/19. [pmid: 22007045].
34 Lainscak M, Blue L, Clark AL, et al. Self-care management of heart failure: practical recommendations from the Patient Care Committee of the Heart Failure Association of the European Society of Cardiology. Eur J Heart Fail. Feb. 2011;13(2):115-26. Epub: 2010/12/15. [pmid: 21148593].
35 Riegel B, Moser DK, Anker SD, et al. State of the science: promoting self-care in persons with heart failure: a scientific statement from the American Heart Association. Circulation. Sep. 22. 2009;120(12):1141-63. Epub: 2009/09/02. [pmid: 19720935].
36 Raman G, DeVine D, Lau J. Non-pharmacological interventions for post-discharge care in heart failure. Technology assessment report. Prepared by the Tufts-New England Medical Center Evidence-based Practice Center (EPC). Contract No. 290-02-0022. Rockville, MD. Agency for Healthcare Research and Quality. February. 29. 2008.
37 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews AHRQ Publication No. 12-EHC047-EF. Rockville, MD. March. 2012. www.effectivehealthcare.ahrq.gov.
38 West SL, Gartlehner G, Mansfield AJ, et al. Comparative effectiveness review methods: Clinical heterogeneity. Methods Research Report (Prepared by RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I) AHRQ Publication No. 11-EHC019-EF. Rockville, MD. Agency for Healthcare Research and Quality. September. 2010.
39 Sutton AJ, Abrams KR, Jones DR, et al. Methods for Meta-Analysis in Medical Research (Wiley Series in Probability and Statistics - Applied Probability and Statistics Section). London. Wiley. 2000.
40 Cohen J. Statistical Power Analysis for the Behavioral Sciences. 2nd ed. Hillsdale, NJ. Erlbaum. 1988.
41 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun. 15. 2002;21(11):1539-58. Epub: 2002/07/12. [pmid: 12111919].
42 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep. 6. 2003;327(7414):557-60. Epub: 2003/09/06. [pmid: 12958120].
43 Schünemann HJ, Oxman AD, Vist GE, et al. Chapter 12: Interpreting results and drawing conclusions. Higgins JPT, Green ST, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011.
44 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. Epub: 2009/07/15. [pmid: 19595577].
45 Atkins D, Chang S, Gartlehner G, et al. Chapter 6: Assessing the Applicability of Studies When Comparing Medical Interventions. AHRQ Publication No. 11-EHC019-EF. Agency for Healthcare Research and Quality. January. 11. 2011. www.effectivehealthcare.ahrq.gov.
46 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA Statement. Open Med. 2009;3(3):21.
47 Jaarsma T, Halfens R, Huijer Abu-Saad H, et al. Effects of education and support on self-care and resource utilization in patients with heart failure. Eur Heart J. May. 1999;20(9):673-82. Epub: 1999/04/20. [pmid: 10208788].
48 Sethares KA, Elliott K. The effect of a tailored message intervention on heart failure readmission rates, quality of life, and benefit and barrier beliefs in persons with heart failure. Heart Lung. Jul-Aug. 2004;33(4):249-60. Epub: 2004/07/15. [pmid: 15252415].
49 Triller DM, Hamilton RA. Effect of pharmaceutical care services on outcomes for home care patients with heart failure. Am J Health Syst Pharm. Nov. 1. 2007;64(21):2244-9. Epub: 2007/10/26. [pmid: 17959576].
50 Stewart S, Marley JE, Horowitz JD. Effects of a multidisciplinary, home-based intervention on unplanned readmissions and survival among patients with chronic congestive heart failure: a randomised controlled study. Lancet. Sep. 25. 1999;354(9184):1077-83. Epub: 1999/10/06. [pmid: 10509499].
51 Stewart S, Pearson S, Horowitz JD. Effects of a home-based intervention among patients with congestive heart failure discharged from acute hospital care. Arch Intern Med. May. 25. 1998;158(10):1067-72. Epub: 1998/05/30. [pmid: 9605777].
52 Pugh LC, Havens DS, Xie S, et al. Case management for elderly persons with heart failure: the quality of life and cost outcomes. Medsurg Nurs. 2001;10(2):71-8.
53 Kimmelstiel C, Levine D, Perry K, et al. Randomized, controlled evaluation of short- and long-term benefits of heart failure disease management within a diverse provider network: the SPAN-CHF trial. Circulation. Sep. 14. 2004;110(11):1450-5. Epub: 2004/08/18. [pmid: 15313938].
54 Kwok T, Lee J, Woo J, et al. A randomized controlled trial of a community nurse-supported hospital discharge programme in older patients with chronic heart failure. J Clin Nurs. Jan. 2008;17(1):109-17. Epub: 2007/12/20. [pmid: 18088263].
55 Naylor MD, Brooten DA, Campbell RL, et al. Transitional care of older adults hospitalized with heart failure: a randomized, controlled trial. J Am Geriatr Soc. May. 2004;52(5):675-84. Epub: 2004/04/17. [pmid: 15086645].
56 Aldamiz-Echevarría Iraúrgui B, Muñiz J, Rodríguez-Fernández JA, et al. Randomized controlled clinical trial of a home care unit intervention to reduce readmission and death rates in patients discharged from hospital following admission for heart failure. Rev Esp Cardiol. 2007;(9):914-22. CN-00612373. [pmid: 17915147].
57 Rich MW, Beckham V, Wittenberg C, et al. A multidisciplinary intervention to prevent the readmission of elderly patients with congestive heart failure. N Engl J Med. Nov. 2. 1995;333(18):1190-5. Epub: 1995/11/02. [pmid: 7565975].
58 Rich MW, Vinson JM, Sperry JC, et al. Prevention of readmission in elderly patients with congestive heart failure: results of a prospective, randomized pilot study. J Gen Intern Med. Nov. 1993;8(11):585-90. Epub: 1993/11/01. [pmid: 8289096].
59 Holland R, Brooksby I, Lenaghan E, et al. Effectiveness of visits from community pharmacists for patients with heart failure: HeartMed randomised controlled trial. BMJ. May. 26. 2007;334(7603):1098. Epub: 2007/04/25. [pmid: 17452390].
60 Thompson DR, Roebuck A, Stewart S. Effects of a nurse-led, clinic and home-based intervention on recurrent hospital use in chronic heart failure. Eur J Heart Fail. Mar. 16. 2005;7(3):377-84. Epub: 2005/02/19. [pmid: 15718178].
61 Benatar D, Bondmass M, Ghitelman J, et al. Outcomes of chronic heart failure. Arch Intern Med. Feb. 10. 2003;163(3):347-52. Epub: 2003/02/13. [pmid: 12578516].
62 Barth V. A nurse-managed discharge program for congestive heart failure patients: outcomes and costs. Home Health Care Manag Pract. 2001;(6):436-43. CN-00773514.
63 Riegel B, Carlson B, Kopp Z, et al. Effect of a standardized nurse case-management telephone intervention on resource use in patients with chronic heart failure. Arch Intern Med. Mar. 25. 2002;162(6):705-12. Epub: 2002/03/26. [pmid: 11911726].
64 Riegel B, Carlson B, Glaser D, et al. Randomized controlled trial of telephone case management in Hispanics of Mexican origin with heart failure. J Card Fail. Apr. 2006;12(3):211-9. Epub: 2006/04/21. [pmid: 16624687].
65 Laramee AS, Levinsky SK, Sargent J, et al. Case management in a heterogeneous congestive heart failure population: a randomized controlled trial. Arch Intern Med. Apr. 14. 2003;163(7):809-17. Epub: 2003/04/16. [pmid: 12695272].
66 Angermann CE, Stork S, Gelbrich G, et al. Mode of action and effects of standardized collaborative disease management on mortality and morbidity in patients with systolic heart failure: the Interdisciplinary Network for Heart Failure (INH) study. Circ Heart Fail. Jan. 2012;5(1):25-35. Epub: 2011/10/01. [pmid: 21956192].
67 Domingues FB, Clausell N, Aliti GB, et al. Education and telephone monitoring by nurses of patients with heart failure: randomized clinical trial. Arq Bras Cardiol. Mar. 2011;96(3):233-9. Epub: 2011/02/11. [pmid: 21308343].
68 Dunagan WC, Littenberg B, Ewald GA, et al. Randomized trial of a nurse-administered, telephone-based disease management program for patients with heart failure. J Card Fail. Jun. 2005;11(5):358-65. Epub: 2005/06/11. [pmid: 15948086].
69 Wakefield BJ, Ward MM, Holman JE, et al. Evaluation of home telehealth following hospitalization for heart failure: a randomized trial. Telemed J E Health. Oct. 2008;14(8):753-61. Epub: 2008/10/29. [pmid: 18954244].
70 Jerant AF, Azari R, Nesbitt TS. Reducing the cost of frequent hospital admissions for congestive heart failure: a randomized trial of a home telecare intervention. Med Care. Nov. 2001;39(11):1234-45. Epub: 2001/10/19. [pmid: 11606877].
71 Rainville EC. Impact of pharmacist interventions on hospital readmissions for heart failure. Am J Health Syst Pharm. Jul. 1. 1999;56(13):1339-42. Epub: 2000/02/22. [pmid: 10683133].
72 Tsuyuki RT, Fradette M, Johnson JA, et al. A multicenter disease management program for hospitalized patients with heart failure. J Card Fail. Dec. 2004;10(6):473-80. Epub: 2004/12/16. [pmid: 15599837].
73 Lopez Cabezas C, Falces Salvador C, Cubi Quadrada D, et al. Randomized clinical trial of a postdischarge pharmaceutical care program vs regular follow-up in patients with heart failure. Farm Hosp. Nov-Dec. 2006;30(6):328-42. Epub: 2007/02/15. [pmid: 17298190].
74 Duffy JR, Hoskins LM, Dudley-Brown S. Improving outcomes for older adults with heart failure: a randomized trial using a theory-guided nursing intervention. J Nurs Care Qual. Jan-Mar. 2010;25(1):56-64. Epub: 2009/06/11. [pmid: 19512945].
75 Wakefield BJ, Holman JE, Ray A, et al. Outcomes of a home telehealth intervention for patients with heart failure. J Telemed Telecare. 2009;15(1):46-50. Epub: 2009/01/14. [pmid: 19139220].
76 Jerant AF, Azari R, Martinez C, et al. A randomized trial of telenursing to reduce hospitalization for heart failure: patient-centered outcomes and nursing indicators. Home Health Care Serv Q. 2003;22(1):1-20. Epub: 2003/05/17. [pmid: 12749524].
77 Dendale P, De Keulenaer G, Troisfontaines P, et al. Effect of a telemonitoring-facilitated collaboration between general practitioner and heart failure clinic on mortality and rehospitalization rates in severe heart failure: the TEMA-HF 1 (TElemonitoring in the MAnagement of Heart Failure) study. Eur J Heart Fail. Mar. 2012;14(3):333-40. Epub: 2011/11/03. [pmid: 22045925].
78 Schwarz KA, Mion LC, Hudock D, et al. Telemonitoring of heart failure patients and their caregivers: a pilot randomized controlled trial. Prog Cardiovasc Nurs. Winter. 2008;23(1):18-26. Epub: 2008/03/11. [pmid: 18326990].
79 Goldberg LR, Piette JD, Walsh MN, et al. Randomized trial of a daily electronic home monitoring system in patients with advanced heart failure: the Weight Monitoring in Heart Failure (WHARF) trial. Am Heart J. Oct. 2003;146(4):705-12. Epub: 2003/10/18. [pmid: 14564327].
80 Dar O, Riley J, Chapman C, et al. A randomized trial of home telemonitoring in a typical elderly heart failure population in North West London: results of the Home-HF study. Eur J Heart Fail. 2009;(3):319-25. CN-00681894. [pmid: 19174529].
81 Woodend AK, Sherrard H, Fraser M, et al. Telehome monitoring in patients with cardiac disease who are at high risk of readmission. Heart Lung. Jan-Feb. 2008;37(1):36-45. Epub: 2008/01/22. [pmid: 18206525].
82 Pekmezaris R, Mitzner I, Pecinka KR, et al. The impact of remote patient monitoring (telehealth) upon Medicare beneficiaries with heart failure. Telemed J E Health. Mar. 2012;18(2):101-8. Epub: 2012/01/31. [pmid: 22283360].
83 Ekman I, Andersson B, Ehnfors M, et al. Feasibility of a nurse-monitored, outpatient-care programme for elderly patients with moderate-to-severe, chronic heart failure. Eur Heart J. Aug. 1998;19(8):1254-60. Epub: 1998/09/18. [pmid: 9740348].
84 McDonald K, Ledwidge M, Cahill J, et al. Elimination of early rehospitalization in a randomized, controlled trial of multidisciplinary care in a high-risk, elderly heart failure population: the potential contributions of specialist care, clinical stability and optimal angiotensin-converting enzyme inhibitor dose at discharge. Eur J Heart Fail. Mar. 2001;3(2):209-15. Epub: 2001/03/14. [pmid: 11246059].
85 McDonald K, Ledwidge M, Cahill J, et al. Heart failure management: multidisciplinary care has intrinsic benefit above the optimization of medical care. J Card Fail. Jun. 2002;8(3):142-8. Epub: 2002/07/26. [pmid: 12140806].
86 Ledwidge M, Barry M, Cahill J, et al. Is multidisciplinary care of heart failure cost-beneficial when combined with optimal medical care?. Eur J Heart Fail. 2003;(3):381-9. CN-00456908. [pmid: 12798838].
87 Kasper EK, Gerstenblith G, Hefter G, et al. A randomized trial of the efficacy of multidisciplinary care in heart failure outpatients at high risk of hospital readmission. J Am Coll Cardiol. Feb. 6. 2002;39(3):471-80. Epub: 2002/02/02. [pmid: 11823086].
88 Stromberg A, Martensson J, Fridlund B, et al. Nurse-led heart failure clinics improve survival and self-care behaviour in patients with heart failure: results from a prospective, randomised trial. Eur Heart J. Jun. 2003;24(11):1014-23. Epub: 2003/06/06. [pmid: 12788301].
89 Ducharme A, Doyon O, White M, et al. Impact of care at a multidisciplinary congestive heart failure clinic: a randomized trial. CMAJ. Jul. 5. 2005;173(1):40-5. Epub: 2005/07/06. [pmid: 15997043].
90 Liu MH, Wang CH, Huang YY, et al. Edema index-guided disease management improves 6-month outcomes of patients with acute heart failure. Int Heart J. 2012;53(1):11-7. Epub: 2012/03/09. [pmid: 22398670].
91 Oddone EZ, Weinberger M, Giobbie-Hurder A, et al. Enhanced access to primary care for patients with congestive heart failure. Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. Eff Clin Pract. Sep-Oct. 1999;2(5):201-9. Epub: 2000/01/06. [pmid: 10623052].
92 Albert NM, Buchsbaum R, Li J. Randomized study of the effect of video education on heart failure healthcare utilization, symptoms, and self-care behaviors. Patient Educ Couns. Dec. 2007;69(1-3):129-39. Epub: 2007/10/05. [pmid: 17913440].
93 Nucifora G, Albanese MC, De Biaggio P, et al. Lack of improvement of clinical outcomes by a low-cost, hospital-based heart failure management programme. J Cardiovasc Med (Hagerstown). Aug. 2006;7(8):614-22. Epub: 2006/07/22. [pmid: 16858241].
94 Linne AB, Liedholm H. Effects of an interactive CD-program on 6 months readmission rate in patients with heart failure - a randomised, controlled trial [NCT00311194]. BMC Cardiovasc Disord. 2006;6:30. Epub: 2006/06/27. [pmid: 16796760].
95 Koelling TM, Johnson ML, Cody RJ, et al. Discharge education improves clinical outcomes in patients with chronic heart failure. Circulation. Jan. 18. 2005;111(2):179-85. Epub: 2005/01/12. [pmid: 15642765].
96 Riegel B, Carlson B. Is individual peer support a promising intervention for persons with heart failure?. J Cardiovasc Nurs. May-Jun. 2004;19(3):174-83. Epub: 2004/06/12. [pmid: 15191260].
97 Davis KK, Mintzer M, Dennison Himmelfarb CR, et al. Targeted intervention improves knowledge but not self-care or readmissions in heart failure patients with mild cognitive impairment. Eur J Heart Fail. Sep. 2012;14(9):1041-9. Epub: 2012/06/28. [pmid: 22736737].
98 Nasreddine ZS, Phillips NA, Bedirian V, et al. The Montreal Cognitive Assessment, MoCA: a brief screening tool for mild cognitive impairment. J Am Geriatr Soc. Apr. 2005;53(4):695-9. Epub: 2005/04/09. [pmid: 15817019].
99 Rodriguez-Barrientos R, López-Alcalde J, Rodríguez-Fernández C, et al. Short-course versus long-course therapy of the same antibiotic for community-acquired pneumonia in adolescent and adult outpatients. Cochrane Database of Systematic Reviews. 2011;(4):CD009070.
100 Hunt SA, Abraham WT, Chin MH, et al. 2009 focused update incorporated into the ACC/AHA 2005 Guidelines for the Diagnosis and Management of Heart Failure in Adults: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines: developed in collaboration with the International Society for Heart and Lung Transplantation. Circulation. Apr. 14. 2009;119(14):e391-479. Epub: 2009/03/28. [pmid: 19324966].
101 Heart Failure Society of America. Executive summary: HFSA 2006 Comprehensive Heart Failure Practice Guideline. J Card Fail. Feb. 2006;12(1):10-38. Epub: 2006/02/28. [pmid: 16500578].
102 Pandor A, Gomersall T, Stevens JW, et al. Remote monitoring after recent hospital discharge in patients with heart failure: a systematic review and network meta-analysis (Provisional abstract). Database of Abstracts of Reviews of Effects. 2013;(3). epub. DARE-12013029243.
103 Inglis Sally C, Clark Robyn A, McAlister Finlay A, et al. Structured telephone support or telemonitoring programmes for patients with chronic heart failure. Cochrane Database of Systematic Reviews. 2010;(8):CD007228. [pmid: 20687083].
104 Kansagara D, Englander H, Salanitro A, et al. Risk prediction models for hospital readmission: a systematic review. JAMA. Oct. 19. 2011;306(15):1688-98. Epub: 2011/10/20. [pmid: 22009101].
105 Krumholz HM, Currie PM, Riegel B, et al. A taxonomy for disease management: a scientific statement from the American Heart Association Disease Management Taxonomy Writing Group. Circulation. Sep. 26. 2006;114(13):1432-45. Epub: 2006/09/06. [pmid: 16952985].