# Methods

The methods for this review of transition care for heart failure (HF) patients follow those specified for the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center (EPC) program. This guidance is codified in the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter, Methods Guide, available at http://www.effectivehealthcare.ahrq.gov/methodsguide.cfm).

## Topic Refinement and Review Protocol

During the topic development and refinement processes, we engaged in a public process to develop a draft and final protocol for the systematic review process. We generated an analytic framework, preliminary Key Questions (KQs), and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions, comparators, outcomes, timing, settings). The processes were guided by the information provided by the topic nominator, a scan of the literature, methods and content experts, and Key Informants. We worked with six Key Informants during the topic refinement; three were subsequently members of our Technical Expert Panel (TEP) for this report. Key Informants and a total of eight TEP members participated in conference calls and discussions through email to review the analytic framework, KQs, and PICOTS, discuss the preliminary assessment of the literature, provide input on the information and categories included in evidence tables, and comment on the data analysis plan.

Our KQs were posted for public comment on AHRQ's Effective Health Care Web site from February 22, 2013, through March 21, 2013; we revised them as needed after review of the comments and discussion with AHRQ and the TEP, primarily for clarity and readability. We then drafted a protocol, which was also posted on the Effective Health Care Web site on June 10, 2013.

## Literature Search Strategy

### Search Strategy

We searched MEDLINE^®^, the Cochrane Library, and the Cumulative Index to Nursing and Allied Health Literature (CINAHL)^®^ from July 1, 2007 to May 9, 2013. We also used a previous AHRQ Technology Assessment on a similar topic to identify randomized controlled trials (RCTs) published before 2007.^36^ Appendix A presents the full search strategy.

We used either Medical Subject Headings (MeSH) or major headings as search terms when available or key words when appropriate, focusing on terms to describe the relevant population and interventions of interest. We reviewed our search strategy with the TEP and incorporated their input into our search strategy. An experienced information scientist (an EPC librarian) conducted the searches; another information scientist at the EPC peer-reviewed them. We conducted quality checks to ensure that our searches identified known studies (i.e., studies identified during topic nomination and refinement).

Using the previously published AHRQ Technology Assessment on Non-Pharmacological Interventions for Postdischarge Care in Heart Failure, we identified relevant studies published from 1990 through July 1, 2007.^36^ Its start date (1990) reflects the timing of advances in the medical management of HF, including the increased use of beta-blockers. We applied our current inclusion and exclusion criteria to RCTs in this earlier publication; our criteria are similar but narrower in scope—that is, limited to outcomes (readmissions, deaths, or other outcomes) timings occurring no more than 6 months from the index hospitalization.

We also searched MEDLINE, the Cochrane Library, and CINAHL for nonrandomized trials or prospective cohort studies of transitional care interventions that measured caregiver or self-care burden from 1990 to May 5, 2013. The previous review did not include these outcomes. We considered observational studies to ensure that we captured relevant literature addressing these potential consequences of transitional care interventions that RCTs may be less likely to report.

We searched for unpublished studies relevant to this review using ClinicalTrials.gov and the World Health Organization's International Clinical Trials Registry Platform.

We manually searched reference lists of pertinent reviews, included trials, and background articles on this topic to look for any relevant citations that our searches might have missed. We imported all citations into an EndNote® X4 electronic database.

We updated the database searches through October 29, 2013 (of the same databases), while the report was undergoing peer review. We investigated any literature suggested by peer reviewers or public comment respondents and, if found appropriate, incorporated the publications into the final review. We determined appropriateness of the publications by the same inclusion and exclusion criteria as we applied to the original searches.

### Inclusion and Exclusion Criteria

We developed eligibility (inclusion and exclusion) criteria with respect to PICOTS, study designs, and study durations for each KQ (Table 1). The focus of this review is on the primary outcomes of readmission rates and mortality. Specifically, we included the following primary outcomes: all-cause readmission, HF-specific readmission, composite all-cause readmission or death, and all-cause mortality. We also evaluated the following outcomes when studies assessing readmission rates or mortality reported them: emergency room visits, acute care visits, hospital days (of subsequent readmissions), quality of life, functional status, caregiver or self-care burden. We were specifically interested in validated measures of caregiver outcomes and outcomes specific to patient self-care burden; however, we also sought evidence on burden of treatment in general (experienced by patients or caregivers) associated with transitional care interventions (e.g., confusion regarding medical information, stress or difficulty related to frequent outpatient appointments). We cast a broad net and initially included any outcomes that might be relevant in both RCTs and observational studies. During full-text review, we specifically excluded outcomes that measured patient satisfaction and self-care knowledge.

Table 1 Inclusion/exclusion criteria for studies of transitional care interventions for patients hospitalized for heart failure

Category | Criteria
Category | Inclusion | Exclusion
Population | - Adults (ages 18 years or older) with HF requiring inpatient admission; - Recruited during or immediately following an index hospitalization for HF^a^ | Children and adolescents under 18
Interventions | Any transitional care interventions aimed at reducing readmissions, including one or more of the following components:; - Education to patient or caregiver (or both), delivered pre- or postdischarge (or both); - Discharge planning; - Appointment scheduling before discharge; - Increased planned or scheduled outpatient clinic visits (primary care, multidisciplinary HF); - Home visits; - Telemonitoring (including remote clinical visits); - Telephone support; - Transition coach or case management; - Interventions to increase provider continuity (same provider-continuity between inpatient and outpatient care) | - proBNP guided therapy; - Pharmacotherapy (e.g., randomized trials of using a medication compared with placebo); - Physician training (e.g., continuing medical education on evidence-based treatment for HF patient management); - Surgical interventions or invasive procedures (e.g., left ventricular assist device, ultrafiltration, dialysis); - Technology aimed at guiding evaluation of patient volume status (e.g., pulmonary artery pressure sensor, segmental multifrequency bioelectrical impedance analysis); - Hospital-at-home interventions
Comparators | - Usual care, routine care, or standard care (as defined by the primary studies); - Comparison of one intervention with another eligible intervention | Comparison of one intervention with an excluded intervention.
Outcomes^b^ | KQ 1: Readmission rates or the composite outcome (all-cause readmission or death), emergency room visits, acute care visits, all-cause hospital days (of subsequent readmissions) KQ 2: Mortality, quality of life, functional status^c^ caregiver or self-care burden KQ 3: All-cause readmissions, mortality, and the composite outcome (all-cause readmission or death) KQ 4: All-cause readmission and mortality KQ 5. Subgroups: any outcome eligible for KQ 1 or KQ 2 | Trials that reported only an eligible quality-of-life or functional status outcome (and no readmission or mortality rate) were excluded from the analysis unless they were a companion to a trial that measured readmission rates. Other composite endpoints (e.g., all-cause readmission or emergency room visits) were excluded.
Timing of outcome measurement Length of followup | - Outcomes (readmissions, deaths, or other outcomes) occurring no more than 6 months from the index hospitalization; - Followup must be at least 30 days | - Outcomes measured at any time after 6 months; - Followup is less than 30 days
Time period | Studies published from 1990 to October 29, 2013 | Studies published earlier than 1990
Settings | - Interventions occurring during the index hospitalization, before discharge; - Interventions initiated as an outpatient following the index hospitalization; - Interventions bridging the transition from inpatient to outpatient care | All other settings (e.g., discharge to a skilled nursing facility or rehabilitation center)
Publication language | English | All other languages
Admissible evidence (study design and other criteria) | - Original research; - Eligible study designs include the following:; – For all KQs, randomized controlled trials; – For caregiver burden and self-care burden, nonrandomized controlled trials or prospective cohort studies with an eligible comparison group | - Case series; - Case reports; - Nonsystematic reviews; - Systematic reviews; - Editorials; - Letters to the editor; - Case-control studies; - Retrospective cohort studies; - Studies with historical, rather than concurrent, control groups

a During data abstraction we required that populations had been recruited during or within 1 week of an index hospitalization. If the study authors did not reported this clearly, we contacted them to obtain additional information. When we could not verify whether the majority of the population had been recruited during this time period, we excluded the study.

b We did not consider results presented only in figures (e.g., Kaplan-Meier curves) as eligible for inclusion when the investigators did not clearly report results for an eligible outcome timing (readmission rate no more than 6 months from the index hospitalization).

c Eligible quality of life and functional status measures included the Minnesota Living With Heart Failure Questionnaire (MLWHFQ), the Quality of Life Index – Cardiac Version, Kansas City Heart Failure Questionnaire, 6-minute walk test, change in the New York Heart Association (NYHA) classification from baseline, Medical Outcomes Study Short Form with 36 items (SF-36), 12-Item Short form Health Survey (SF-12) and EuroQoL (or EQ-5D).

HF = heart failure; KQ = Key Question; proBNP = probrain natriuretic peptide; PICOTS = populations, interventions, comparators, outcomes, timing, and setting.

### Study Selection

Two members of the research team independently reviewed all titles and abstracts (identified through searches) for eligibility against our inclusion/exclusion criteria (Table 1); we retrieved any publications marked for inclusion by either reviewer for evaluation of the full text. For titles and abstracts that lacked adequate information to determine inclusion or exclusion, we retrieved the full text for review. Then two investigators independently reviewed the full texts to determine final inclusion or exclusion. The reviewers resolved any disagreements by discussion and consensus or by consulting a third member of the review team.

All results in both review stages were tracked in an EndNote^®^ database. We recorded the principal reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix B).

### Data Extraction

For studies that met our inclusion criteria, we designed and used structured data extraction forms to gather pertinent information from each article, including characteristics of study populations, settings, interventions, comparators, study designs, methods, and results. One investigator extracted the relevant data from each included article; all data abstractions were reviewed for completeness and accuracy by a second member of the team. We recorded intention-to-treat (ITT) results if available. All data abstraction was performed using Microsoft Excel® software.

## Risk-of-Bias Assessment of Individual Studies

To assess the risk of bias (internal validity) of studies, we used predefined criteria based on the AHRQ Methods Guide. These criteria included questions to assess selection bias, confounding, performance bias, detection bias, and attrition bias (i.e., those about adequacy of randomization, allocation concealment, similarity of groups at baseline, masking, attrition, use of ITT analysis, method of handling dropouts and missing data, reliability and validity of outcome measures, and treatment fidelity).37 Appendix D provides the specific questions used for evaluating the risk of bias of all included studies. It also includes a table showing the responses to these questions and risk-of-bias ratings for each study and explains the rationale for all ratings that were either high or unclear.

In general terms, results from a low risk-of-bias study are considered to be valid. A study with moderate risk of bias is susceptible to some risk of bias but probably not enough to invalidate its results. A study assessed as high risk of bias has significant risk of bias (e.g., stemming from serious errors in design, conduct, or analysis) that may invalidate its results. To assess publication bias, we looked for evidence of unpublished literature through searches of gray literature (ClinicalTrials.gov). We also reviewed (when available) the original protocols for included trials to assess for selective outcome reporting.

We determined the risk-of-bias rating using the responses to all questions assessing the various types of bias listed above. To receive a low risk-of-bias rating, we required favorable responses to most questions, and any unfavorable responses had to be relatively minor (e.g., lack of provider masking in home-visiting programs, which is generally not considered possible). We gave medium risk-of-bias ratings to studies that did not meet criteria for low or high risk of bias. We rated studies as medium risk of bias that we determined to have more than one unfavorable response and that were not considered to have major methodological shortcomings, but had shortcomings which may introduce some bias. We gave high risk-of-bias ratings to studies that we determined to have a major methodological shortcoming in one or more categories based on our qualitative assessment. Common methodological shortcomings contributing to high risk-of-bias ratings were high rates of attrition or differential attrition, inadequate methods used to handle missing data, lack of ITT analysis, and unclear or invalid measures of readmission or mortality rates. When assessing measurement bias related to readmission ascertainment, we considered whether a study had access to all potential readmission data (versus readmissions collected from only a single institution's database). When investigators used data from only a single institution to measure readmission rates (without at least collecting additional data on admissions to other institutions from patients or caregivers), we considered this a major methodological shortcoming (e.g., high risk of measurement bias). We rated studies as unclear risk of bias when information provided was inadequate for judging the validity of outcome measures (primarily readmission rates and mortality).

Two independent reviewers assessed the risk of bias for each study. Disagreements between reviewers were resolved by discussion and consensus or by consulting a third member of the team.

We did not use studies deemed high or unclear risk of bias in our main analyses; we included them only in sensitivity analyses. These studies are represented in the counts of included studies.

## Categorization of Interventions

We grouped studies of similar interventions for our evidence synthesis. We categorized interventions into six types defined in Table 2 based primarily on the mode and environment of delivery. In our judgment, this method of categorization would best address the needs of multiple stakeholders that may be interested in interventions that could be implemented in specific health care settings. One investigator categorized the intervention, and a second team member reviewed the categorization. Disagreements were resolved by consensus.

Table 2 Categories and definitions of transitional care interventions

Category | Definition
Home-visiting programs | Home visits by clinicians such as nurses or pharmacists, who deliver education, reinforce self-care instructions, perform physical examination, or provide other care (e.g., physical therapy, medication reconciliation). These interventions are often referred to as nurse case management interventions but they also can include home visits by a pharmacist or multidisciplinary team.
Structured telephone support | Monitoring, education, or self-care management (or various combinations) using simple telephone technology after discharge in a structured format (e.g., series of scheduled calls with a specific goal, structured questioning, or use of decision support software).
Telemonitoring | Remote monitoring of physiological data (e.g., electrocardiogram, blood pressure, weight, pulse oximetry, respiratory rate) with digital, broadband, satellite, wireless, or Bluetooth transmission to a monitoring center, with or without remote clinical visits (e.g., video monitoring).
Outpatient clinic-based interventions | Services provided in one of several different types of outpatient clinics—multidisciplinary HF, nurse-led HF, or primary care clinic. The clinic-based intervention can be managed by a nurse or other provider and may also offer unstructured telephone support (e.g., patient hotline) outside clinic hours.
Primarily educational interventions | Patient education (and self-care training) delivered before discharge or upon discharge by various delivery personnel or modes of delivery: in-person, interactive CD-ROM, video education. Interventions in this category do not feature home visiting, or structured telephone support. They are not delivered primarily through a clinic-based intervention (described above). Follow-up telephone calls may occur to ascertain outcomes (e.g., readmission rates) but not to monitor patients' physiological data.
Other | Unique interventions or interventions that did not fit into any of the other categories (e.g., individual peer support for HF patients).

CD-ROM = compact disc read-only memory; HF = heart failure.

Most studies included components delivered both during hospitalization and after discharge. Most studies included components delivered both during hospitalization and after discharge. We did not use timing of intervention delivery as a primary categorization scheme, but we did abstract detailed information regarding the timing of intervention components in relationship to the index hospitalization. Appendix C provides more information on components of interventions.

## Data Synthesis

We conducted meta-analyses of outcomes reported by multiple studies that were homogeneous enough to justify combining their results. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies under consideration following established guidance.38 We did this by qualitatively assessing the PICOTS of the included studies, looking for similarities and differences. When quantitative synthesis was not appropriate (e.g., because of clinical heterogeneity, insufficient numbers of similar studies, or insufficiency or variation in outcome reporting), we synthesized the data qualitatively.

For analyses of the efficacy of transitional care interventions, our main analyses include trials comparing an intervention with usual care (or treatment as usual) control groups. In some cases, “usual care” refers to usual home health care (e.g., home-visiting program); when this was a cointervention, we included it along with usual care in our analysis. For readmission and mortality outcomes, we stratified analyses for each intervention category by outcome timing, separating rates reported at 30 days from those beyond 30 days (i.e., rates reported over 3 to 6 months were combined).

For all readmission rates, we distinguished measures of the numbers of people readmitted versus measures of the total readmissions per group. We ran meta-analyses of trials that reported the number of people readmitted in each group. When the only information available was on the total number of readmissions (and not the total number of people readmitted), we contacted authors requesting additional data. When we could not obtain information on the number of people readmitted, we did not include these trials in meta-analyses for number of people readmitted; instead, we included these results in a qualitative synthesis.

We used random-effects models (DerSimonian and Laird) to estimate pooled effects.39 For binary outcomes (e.g., readmission rates, mortality), we calculated the relative risk (RR) and 95% confidence interval (CI). When necessary, we calculated rates using the number of all randomized patients as the denominator to reflect a true ITT analysis. For continuous outcomes (e.g., scales of quality of life or function) measured with the same scale (e.g., Minnesota Living With Heart Failure Questionnaire [MLWHF]), we report the weighted mean difference between intervention and control subjects. When we had to combine multiple scales in one meta-analysis, we used the standardized mean difference (SMD), Cohen's d. A Cohen's d of zero means that the intervention and control groups have equivalent effects; a small effect size is 0.20, medium effect size is 0.50, and large effect size is 0.80.^40^ Forest plots graphically summarize results of individual trials and of the pooled analyses (Appendix E).

For KQ 4, we assessed whether the efficacy of interventions differed based on intensity, delivery personnel, and method of communication both across intervention categories and within categories of interventions. When appropriate, we conducted meta-analyses stratified by intensity, delivery personnel, and method of communication within each intervention category.

Given the heterogeneity of included interventions, we were unable to develop a single measure of intensity that could be applied to all interventions. For most interventions, we defined intensity as the duration, frequency, or periodicity of patient contact, categorizing each intervention as low, medium, or high intensity. We also considered resource use as a dimension of intensity. For example, we included factors such as the total number of intervention components in the determination of intensity. We reserved the low-intensity category for interventions that included one episode of patient contact or that required few resources (e.g., no additional components, such as time spent coordinating care). We considered the majority of interventions to be medium or high intensity; most were multicomponent and included repeated patient contacts.

Few trials reported readmission rates separately by patient subgroups. For that reason, we were unable to conduct any meta-analysis. We present this information qualitatively.

For each meta-analysis in KQ 1 and KQ 2, we conducted sensitivity analyses by adding trials excluded for having high or unclear risk of bias and calculated a pooled effect to determine whether including them would have changed conclusions. Appendix F documents these sensitivity analyses; we mention them in the results section only when they changed our overall findings. We did not conduct sensitivity analyses for the subgroup comparisons in KQ 4 (intensity, delivery personnel and method of communication).

We calculated the chi-squared statistic and the I^2^ statistic (the proportion of variation in study estimates attributable to heterogeneity) to assess statistical heterogeneity in effects between studies.41,42 An I^2^ from 0 to 40 percent might not be important, 30 percent to 60 percent may represent moderate heterogeneity, 50 percent to 90 percent may represent substantial heterogeneity, and ≥75 percent represents considerable heterogeneity.41 The importance of the observed value of I^2^ depends on the magnitude and direction of effects and on the strength of evidence (SOE) for heterogeneity (e.g., p value from the chi-squared test, or a confidence interval for I^2^). Whenever we include a meta-analysis with considerable statistical heterogeneity in this report, we explain our reasoning considering the magnitude and direction of effects.41

In addition, we calculated the number needed to treat (NNT) for readmission and mortality outcomes when interventions were efficacious. We derived the NNTs from the RR and median usual care event rates using the methods described in the Cochrane Handbook.43 Meta-analyses were conducted using Stata^®^ version 11.1 (StataCorp LP, College Station, TX).

KQ 3 asks primarily “What are the components of effective interventions?” and “Are particular components necessary?” The aim of KQ 3 was to describe the components of effective interventions; it is intended as a descriptive question to provide information about the interventions that work for providers, health systems, etc. who may want to implement transitional care interventions. We considered “necessary” to mean that a particular component (e.g., inpatient education) was included in every effective intervention but was not necessarily sufficient (i.e., the component could be included in some interventions that were not efficacious). To address the first issue, we extracted detailed information on intervention components. We focused on content (e.g., specific educational content) and process (e.g., timing of first home visit following discharge), based on previous literature suggesting important components in HF treatment and transitional care.24,33,36 We describe common components and combinations of components for all interventions that were efficacious in reducing all-cause readmissions, mortality, or the composite endpoint (all-cause readmission or death).

For KQ 3, we defined effective interventions as: (1) intervention categories (defined in Table 2) that reduced either all-cause readmissions or the composite endpoint (from our meta-analyses for KQ 1); (2) intervention categories that reduced mortality rates as shown in our meta-analyses; and (3) individual trials in other categories that reduced all-cause readmission, mortality, or the composite endpoint. Few trials reported outcomes at 30 days; for KQ 3 we describe the components of interventions that showed efficacy at any eligible time point up to 6 months following an index hospitalization for HF. For KQ 3, we focused on all-cause readmissions (rather than HF-specific readmission rates) for two reasons: (1) this outcome is relevant to stakeholders who are seeking to develop programs that reduce readmission rates in the context of CMS's decision to reduce reimbursement for excessive risk-standardized readmission rates;9 (2) the majority of early readmissions in HF patients are for diverse indications (e.g., renal disorders, pneumonia, arrhythmias, and septicemia/shock).5 We also included mortality as an outcome for two reasons: (1) addressing current uncertainty about the proportion of readmissions that are preventable is critical to the broad issue; (2) considering lower mortality as an outcome acknowledges the fact that some readmissions are warranted.

## Strength of the Body of Evidence

We graded the SOE of the accumulated evidence on a given issue to answer the specific KQs on the benefits and harms of the interventions in this review; we used the guidance established for the EPC program.44 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: risk of bias (includes study design and aggregate quality), consistency, directness, and precision of the evidence. It also considers other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias. Table 3 defines the grades of evidence that we assigned.

Table 3 Definitions of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Source: Owens et al.44

Two reviewers assessed each domain for each key outcome and resolved differences by consensus. For each assessment, one of the two reviewers was always an experienced EPC investigator. To give high SOE grades, we required consistent, direct, and precise evidence from studies with aggregate low risk of bias. An unfavorable assessment for any one of the four key domains (e.g., inconsistency, indirectness, imprecision, or medium aggregate risk of bias) typically resulted in downgrading to moderate SOE. Two unfavorable assessments typically resulted in downgrading to low SOE. We allowed reviewers to include the optional domains listed above (e.g., dose-response association, publication bias), if relevant, and to upgrade or downgrade the SOE for those domains if appropriate. When only one study reported an outcome of interest (with unknown consistency and imprecision), we usually graded the SOE as insufficient; when similar interventions had consistent results at other time points we graded the SOE as low.

We graded SOE for the following outcomes: all-cause readmissions rate, HF-specific readmission rates, composite endpoint, mortality, emergency room visits, length of hospital stay (of subsequent readmissions), and commonly reported measures of quality of life or functional status. We graded the SOE separately for each time point following an index hospitalization. For readmission rates, we graded the evidence for rates that were specific to the number of people readmitted (not total number of readmissions per group); however, we considered outcome measures of total readmission per group when assessing the consistency of evidence. We did not grade the SOE for results specific to KQ 3 (components of effective interventions), KQ 4 (intensity, delivery personnel, method of communication), or KQ 5 (subgroups). Appendix G presents tables showing our assessments for each domain and the resulting SOE grades KQs 1 and 2, organized by intervention category.

## Applicability

We assessed applicability of the evidence following guidance from the Methods Guide.45 We used the PICOTS framework to explore factors that affect applicability. Some factors identified a priori that may limit the applicability of evidence include the following: age of enrolled populations; sex of enrolled populations; race or ethnicity of enrolled populations; few studies enrolling subjects who are uninsured or lack social support; and setting (e.g., trials conducted outside the United States).

## Peer Review and Public Commentary

This report received extensive external peer review and was posted for public comment October 29, 2013, to November 26, 2013. We addressed all comments in the final report, making revisions as needed; a disposition of comments report will be publicly posted 3 months after release of the final report.