# Glossary of Terms

Term or Scale: Definition
Heart failure (HF): A condition in which the heart muscle cannot pump sufficient blood to oxygenate the body's need for blood and oxygen. The most common hospital discharge diagnosis among the elderly in the US.1
Quality of life (QOL): A multidimensional, broad-ranging concept that can be defined as an individual's perception of their position in life in the context of the culture and value systems in which they live. Factors such as physical health, mental health, and social relationships can affect a person's QOL.2
Minnesota Living With Heart Failure Questionnaire (MLWHFQ): QOL measure for individuals with HF with a range of scores from 0-105, with decreasing scores indicating improvement.
6-Minute Walk Test: Measure of functional status that tests functional exercise capacity in a variety of populations. This is the distance a person can walk within 6 minutes on a flat surface, with a range of 0-400+ meters. Increasing distances indicate improvement, and an improvement of 54 meters is considered clinically significant.3
New York Heart Association (NYHA) Classification: Classification system for heart failure disease severity. Patients are classified in one of four categories based on the degree to which they are limited during physical activity by cardiac symptoms (e.g., fatigue, palpitation, dyspnea or anginal pain). Scores range from I-IV, with decreasing scores indicating improvement.
Medical Outcomes Study Short Form Health Survey with 36 items (SF-36): QOL measure with a range of scores from 0-100, with increasing scores indicating improvement.
Medical Outcomes Study Short Form with 12 items (SF-12): Shorter version of the SF-36 instrument. Also uses a range of scores from 0-100, with increasing scores indicating improvement.
European Quality of Life- 5 Dimensions (EuroQoL or EQ-5D): QOL measure with a range of scores from 0-100, with increasing scores indicating improvement.
Risk difference (RD): An absolute measure of how an intervention or exposure changes the risk or incidence of a dichotomous outcome, or an outcome with two potential values. Calculated as the difference in the incidence or risk of an event in an intervention or exposure group from the incidence or risk of the same event in a control or other intervention group.
Relative Risk (RR): The ratio of the incidence of a given outcome in an intervention or exposure group compared with the incidence of that same outcome in a control or other intervention group.
Standardized mean difference (SMD): Used in a meta-analysis when all of the analyzed studies evaluate the same continuous outcome but with different scales. Calculated as the ratio of the difference in mean outcome between groups to the standard deviation of the outcome among patients.4
Weighted mean difference (WMD): Mean difference calculated for continuous data from studies in a meta-analysis in which the results of some studies make a greater contribution to the total than others.5

## Glossary References

1 American Heart Association. About Heart Failure. http://www.heart.org/HEARTORG/Conditions/HeartFailure/AboutHeartFailure/About-Heart-Failure_UCM_002044_Article.jsp. September 23, 2013. Last updated on September 20, 2012.
2 World Health Organization Programme on Mental Health. Measuring quality of life: The World Health Organization quality of life instruments. Geneva, Switzerland. 1997.
3 American College of Rheumatology. Six Minute Walk Test (6MWT). September 23, 2013. Last updated on October 2011.
4 Higgins J, Green S, editors. The standardized mean difference Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 [updated March 2011]: The Cochrane Collaboration. 2011. Available from http://handbook.cochrane.org/chapter_9/9_2_3_2_the_standardized_mean_difference.htm.
5 Higgins J, Green S, editors. Principles of meta-analysis. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 [updated March 2011]: The Cochrane Collaboration. 2011. Available from http://handbook.cochrane.org/index.htm#front_page.htm.