# Peer Reviewers

Before publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Jalal Ghali, M.D.
  Division of Cardiology
  Mercer University School of Medicine
  Macon, GA
- Joseph Lau, M.D.
  Brown University Center for Evidence-based Medicine
  Providence, RI
- Christopher O. Phillips, M.D., M.P.H., FACP
  Director, Clinical Outcomes Research and Evaluation
  Associate Professor of Medicine and Epidemiology
  Department of General Internal Medicine
  Morehouse School of Medicine
  Atlanta, GA
- Ileana Piña, M.D., M.P.H.
  Albert Einstein College of Medicine of Yeshiva University
  Montefiore Medical Center
  Bronx, NY
- Michael W. Rich, M.D.
  Washington University in St. Louis School of Medicine
  St. Louis, MO
- Barbara Riegel, D.N.Sc., R.N., FAAN, FAHA
  University of Pennsylvania School of Nursing
  Philadelphia, PA